# Methods

Methodological practices followed in this review were derived from the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews22 (hereafter referred to as the “Methods Guide”) and its subsequent updates.

## Topic Development and Refinement

Key Questions were reviewed and refined as needed by the Evidence-based Practice Center (EPC) with input from Key Informants and the Technical Expert Panel (TEP) to ensure that the questions were specific and explicit about what information was being reviewed. In addition, for Comparative Effectiveness reviews, the Key Questions were posted for public comment and finalized by the EPC after review of the comments.

Key Informants are the end users of research, including patients and caregivers, practicing clinicians, relevant professional and consumer organizations, purchasers of health care, and others with experience in making health care decisions. Within the EPC program, the Key Informant role is to provide input into identifying the Key Questions for research that will guide health care decisions. The EPC solicits input from Key Informants when developing questions for systematic review or when identifying high priority research gaps and needed new research. Key Informants are not involved in analyzing the evidence or writing the report and have not reviewed the report, except as given the opportunity to do so through the peer or public review mechanism.

Key Informants had to disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals were invited to serve as Key Informants and those who presented without potential conflicts were retained. The AHRQ Task Order Officer and the EPC worked to balance, manage, or mitigate any potential conflicts of interest identified.

## Analytic Framework

Following is an analytic framework (see Figure 1) depicting the potential impact of using procalcitonin on both intermediate outcomes and health outcomes. Direct evidence of the impact of testing on health outcomes is shown by link A (morbidity, function, quality of life, and/or mortality) and link F (adverse events of therapy). Indirect evidence would have to be assembled in the absence of RCTs of the effects of testing on health outcomes. Link B addresses whether test results influence decisions about therapy, which may have an impact on health outcomes (link C) or intermediate outcomes (link D). Intermediate outcomes—such as antibiotic exposure, duration of antibiotic therapy, length of stay, and response to therapy—may have an association with health outcomes (link E).

Figure 1 Analytic framework for procalcitonin as a diagnostic indicator for infection and as an indicator of response to therapy

AECOPD = acute exacerbations of chronic obstructive pulmonary disease

Note: A–F show links between test results and outcomes. Please see the text above Figure 1 for more information

This figure depicts the potential impact of use of procalcitonin on both intermediate outcomes and health outcomes. Direct evidence of the impact of testing on health outcomes is shown by link A (morbidity, function, quality of life, and/or mortality) and link G (adverse events of testing). Indirect evidence would have to be assembled in the absence of randomized controlled trials (RCTs) of the effects of testing on health outcomes. An early link in an indirect chain of evidence concerns the diagnostic accuracy of testing (B). Link C addresses whether test results influence decisions regarding therapy, which may have an impact on health outcomes (link D) or intermediate outcomes (link E). Intermediate outcomes—such as antibiotic exposure, duration of antibiotic therapy, length of stay, and response to therapy—may have an association with health outcomes (link F). Links G and H focus on the adverse effects of testing and therapy.

## Literature Search Strategy

The databases listed below were searched for citations. The full search strings and strategies can be found in Appendix A. The search was limited to English-language references because our EPC's experience in past projects that included non-English references did not yield high-quality information that justified the resources required for translation. Furthermore, the search was limited to literature published after 1990, which is approximately 10 years before reports of the use of modern serum biomarkers began to appear in the medical literature in the late 1990s.

- MEDLINE^®^ (January 1, 1990, to December 16, 2011)
- Embase^®^ (January 1, 1990, to December 16, 2011)
- Cochrane Controlled Trials Register (through December 16, 2011)

To identify systematic reviews, we searched MEDLINE^®^, the Cochrane Database of Systematic Reviews, and the websites of the National Institute for Clinical Excellence (www.nice.org.uk), the National Guideline Clearinghouse (www.guidelines.gov), and the Health Technology Assessment Programme (www.hta.ac.uk) from January 1, 1990, to August 6, 2010. The MEDLINE^®^ search was updated in December 2011. We used results from previously conducted meta-analyses and systematic reviews when appropriate.

The TEP and individuals and organizations providing peer review were asked to inform the project team of any studies relevant to the Key Questions that were not included in the draft list of selected studies.

Search results were stored in EndNote9^®^ and ProCite^®^ databases. Using the study selection criteria for screening titles and abstracts, a single reviewer marked each citation as: (1) eligible for review as full-text articles; (2) ineligible for full-text review; or (3) uncertain. Citations marked as uncertain were reviewed by a second reviewer and inclusion and exclusion were decided by consensus opinion; a third reviewer was consulted if necessary. Using the final study selection criteria, full-text articles were reviewed in the same fashion to determine their inclusion in the systematic review. Records of the reason for exclusion for each paper retrieved in full-text, but excluded from the review, were kept in the EndNote9 and ProCite databases. A listing of excluded studies with reasons for exclusion can be found in Appendix B.

## Study Selection

Inclusion criteria: Studies were included if they fulfilled all of the following criteria:

- Study was a randomized controlled trial or a nonrandomized comparative study (observational, case-control, and cohort studies).
- Study included adult and/or pediatric patients with known or suspected local or systemic infection, including critically ill patients with sepsis syndromes or ventilator-associated pneumonia, adults with respiratory tract infections, neonates with sepsis, children with fever of unknown source, and postoperative patients at risk of infection.
- Study intervention included initiation, discontinuation, and/or intensification of antibiotic therapy guided by procalcitonin plus clinical criteria for infection.
- Study outcomes included antibiotic use, mortality, morbidity, and adverse events of antibiotic therapy.

Exclusion criteria: Studies were excluded if they fulfilled at least one of the following criteria:

- Published in non-English language
- Did not report primary data (i.e., did not report data from original research)
- Did not use a relevant design
- Did not study relevant disease
- Did not report relevant outcomes

A screening guide for titles and abstracts can be found in Appendix E; a guide for full text articles can be found in Appendix F.

## Search Strategies for Gray Literature

The EPC staff conducted a systematic search of the following gray literature sources to identify unpublished studies or studies published in journals that are not indexed in major bibliographic citation database in accordance with guidance from Effective Health Care Scientific Resource Center. The search strategies can be found in Appendix A.

1. Regulatory information
  a. Food and Drug Administration (FDA)
2. Clinical trial registries
  a. ClinicalTrials.gov
  b. Current controlled trials
  c. Clinical study results
  d. World Health Organization (WHO) clinical trials
3. Abstracts and conference papers
  a. Conference Papers Index
  b. Scopus
  c. Annual meeting of Interscience Conference on Antimicrobial Agents and Chemotherapy
  d. Annual meeting of Infectious Diseases Society of America (IDSA)
  e. Annual meeting of American College of Chest Physicians
  f. Annual meeting of Pediatric Academic Societies
4. Grants and federally funded research
  a. NIH RePORTER (a searchable database of federally funded biomedical research projects conducted at universities, hospitals, and other research institutions)
  b. HSRPROJ (a database providing access to ongoing grants and contracts in health services research)
  c. AHRQ GOLD (an online searchable database of AHRQ grants, working papers, and HHS recovery act projects)
5. Manufacturer database: Industry stakeholders were invited to submit the following types of information for possible inclusion as evidence:
  - A current product label;
  - Published RCTs and observational studies relevant to the clinical outcomes; and
  - Unpublished RCTs and observational studies relevant to the clinical outcomes

These sources were searched using sensitive searches similar to the searches in bibliographic databases, except for the following:

- Regulatory information: The FDA Web site was searched for only 510(k) decision summary documents related to procalcitonin assays.
- For clinical registries, NIH RePORTER, HSRPROJ, and AHRQ GOLD searches were limited to completed studies only.
- For abstracts and conferences, studies published prior to 2006 were excluded.

## Data Extraction and Data Management

### Data Elements

The following data elements from the intervention studies were abstracted, or recorded as not reported. The data elements to be abstracted were defined in consultation with the TEP and included the following: The data abstraction form can be found in Appendix G.

- Quality assessment
  ○ Number of participants and flow of participants through steps of study
  ○ Treatment-allocation methods (including concealment)
  ○ Use of blinding
  ○ Prospective versus retrospective
  ○ Use of an independent outcome assessor
  ○ Additional elements are described below under Assessment of Methodological Quality of Individual Studies
- Study funding sponsorship source acknowledgement
- Assessment of Applicability and Clinical Diversity
  ○ Patient characteristics, including:
    – Age
    – Sex
    – Race/ethnicity
    – Disease and type
    – Disease duration
    – Other prognostic characteristics (e.g., co-morbidities and other potential confounders and/or effect modifiers)
    – Setting
      ■ Outpatient
      ■ Inpatient
  ○ Diagnostic and treatment characteristics, including:
    – Procalcitonin assay type
    – Other measured indicators of sepsis or of response to treatment (e.g., fever, white blood cell count)
    – Decisionmaking for diagnosis and/or treatment (e.g., when to administer antibiotic therapy)
    – Antibiotic use during study period
    – Duration of observation
    – Other treatment modalities
- Outcome Assessment
  ○ Identified primary outcome
  ○ Identified secondary outcomes
  ○ Response criteria
  ○ Followup frequency and duration
  ○ Data analysis details, including:
    – Statistical analyses (statistical test/estimation results)
      ■ Test used
      ■ Summary measures
      ■ Sample variability measures
      ■ Precision of estimate
      ■ p values

### Evidence Tables

Templates for evidence tables were created in Microsoft Word^®^. One reviewer performed primary data abstraction of all data elements into the evidence tables, and a second reviewer reviewed the articles and evidence tables for accuracy. Disagreements were resolved by discussion, and if necessary, by consultation with a third reviewer. When small differences occurred in quantitative estimates of data from published figures, the values were calculated by averaging the estimates of the first two reviewers. Data abstraction tables can be found in Appendix C.

## Individual Study Quality Assessment

### Definition of Ratings Based on Criteria

In adherence with the Methods Guide,22 the general approach to grading individual comparative studies was performed by using a method used by the U.S. Preventive Services Task Force.23 The quality of the abstracted studies and the body of evidence were assessed by two independent reviewers. Discordant quality assessments were resolved with input from a third reviewer, if necessary.

- The quality of studies was assessed on the basis of the following criteria:
  ○ Initial assembly of comparable groups: adequate randomization, including concealment and whether potential confounders (e.g., other concomitant care) were distributed equally among groups.
  ○ Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination).
  ○ Important differential loss to followup or overall high loss to followup.
  ○ Measurements: equal, reliable, and valid (includes masking of outcome assessment).
  ○ Clear definition of interventions.
  ○ All important outcomes considered.
  ○ Analysis: adjustment for potential confounders and intention-to-treat analysis.
    – Intention-to-treat analysis was defined as no more than 5 percent loss in the analysis or use of a missing data handling procedure and all patients analyzed within the groups to which they were randomized.

The rating of intervention studies encompasses these three quality categories:

- Good. Meets all criteria; comparable groups were assembled initially and maintained throughout the study (followup at least 80 percent); reliable and valid measurement instruments were used and applied equally to the groups; interventions were spelled out clearly; all important outcomes were considered; and appropriate attention was given to confounders in analysis. In addition, intention-to-treat analysis was used for RCTs.
- Fair. Studies were graded “fair” if any or all of the following problems occurred, without the fatal flaws noted in the “poor” category below: In general, comparable groups were assembled initially, but some questions remained about whether some (although not major) differences occurred with followup; measurement instruments were acceptable (although not the best) and were generally applied equally; some but not all important outcomes were considered; and some but not all potential confounders were accounted for. Intention-to-treat analysis was done for RCTs.
- Poor. Studies were graded “poor” if any of the following fatal flaws existed: Groups assembled initially were not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments were used or not applied at all equally among groups; and key confounders were given little or no attention. Generally, lack of masked outcome assessment is considered a fatal flaw, but due to the nature of the interventions and comparators in this systematic review, it was not considered a fatal flaw. For RCTs, intention-to-treat analysis was lacking

## Data Synthesis

We anticipated that the decision to incorporate formal data synthesis into this evidence review would be made after completing the formal literature search. Similarly we also anticipated that the decision to pool studies would be based if there were sufficient number of studies available that were designed to ask similar questions and reported similarly defined outcomes. Specifically, meta-analysis was performed if a minimum of three studies selected a similar population and reported an outcome that was measured similarly and with sufficient detail. An example of similarly measured outcomes included combining in-hospital mortality, 28-day mortality or 6-week mortality. Several antibiotic outcomes were found not to be similar enough to be pooled, including duration of antibiotic therapy in days, rate of antibiotic prescription as a proportion, and total antibiotic exposure in number of days on antibiotics per total patient-days for an entire group as a rate. Sufficient detail for an outcome measured as a mean, such as length of stay, requires reporting of standard deviations. When meta-analysis could be performed, subgroup and sensitivity analyses would be based on assessment of study-level clinical diversity in a sufficient number of available studies. Degree of statistical heterogeneity is reported by the I^2^ statistic. The pooling method involves inverse variance weighting and a random effects model. Studies reporting zero events in one or both arm are excluded from pooling.

## Assessment of Applicability

Applicability of findings in this review was assessed within the EPICOT framework (Evidence, Population, Intervention, Comparison, Outcome, Timestamp).24 Selected studies were assessed for relevance against target populations, interventions of interest, and outcomes of interest.

## Grading the Body of Evidence for Each Key Question

The system used for rating the strength of the overall body of evidence is outlined in the Methods Guide22 and is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.25 This system explicitly addressed the following domains: risk of bias, consistency, directness, and precision. With respect to precision, studies could contribute to a rating of precise if confidence intervals did not overlap the null value or results were statistically significant, regardless of whether studies were powered to detect a particular effect for that outcome. The grade of evidence strength was classified into the following four categories:

- High. High confidence that the evidence reflected the true effect. Further research was very unlikely to change our confidence in the estimate of effect.
- Moderate. Moderate confidence that the evidence reflected the true effect. Further research may have changed our confidence in the estimate of effect and may have changed the estimate.
- Low. Low confidence that the evidence reflected the true effect. Further research was likely to change our confidence in the estimate of effect and was likely to change the estimate.
- Insufficient. Evidence was either unavailable or did not permit estimation of an effect.
- Additional domains including strength of association, publication bias, coherence, dose-response relationship, and residual confounding were addressed if appropriate.

Specific outcomes and comparisons were rated depending on the evidence found in the literature review. The grade rating was made by independent reviewers, and disagreements were resolved by consensus adjudication. In combining information from separate domains into an overall strength of evidence rating, we took into account the following considerations: whether the standard for comparison is superiority or noninferiority, the narrowness of a meta-analysis 95% confidence interval (CI), the consistency of narrow 95% CIs among individual studies, the consistency of statistically significant results, whether the direction of effect or both direction of effect and magnitude were consistent and whether similar outcomes measured differently had consistent findings.

## Peer Review and Public Commentary

Peer Reviewers were invited to provide written comments on the draft report based on their clinical, content, or methodological expertise. Peer review comments on the preliminary draft of the report were considered by the EPC in preparation of the final draft of the report. Peer Reviewers did not participate in writing or editing the final report or other products. The synthesis of the scientific literature presented in the final report does not necessarily represent the views of individual reviewers. The dispositions of the peer review comments will be documented and published three months after the publication of the evidence report.

Potential reviewers had to disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Invited Peer Reviewers could not have any financial conflict of interest greater than $10,000. Peer Reviewers who disclosed potential business or professional conflicts of interest were allowed to submit comments on the draft report through the public comment mechanism.