# Peer Reviewers

Derek Angus, M.D., M.P.H.

Professor and Chair, Critical Care Medicine

Professor, Medicine and Health Policy and Management

University of Pittsburgh School of Medicine

Pittsburgh, PA

Rongwei (Rochelle) Fu, Ph.D.

Associate Professor

Oregon Health & Science University

Portland, OR