# Technical Expert Panel

R. Phillip Dellinger, M.D.

Head, Critical Care Medicine

Cooper University Hospital

Camden, NJ

Jesse Hall, M.D.

Section Chief, Pulmonary and Critical Care Medicine

University of Chicago

Chicago, IL

Stephen Kahn, Ph.D.

Associate Director, Clinical Laboratories

Loyola University Chicago

Maywood, IL

Henry Masur, M.D.

Chief, Critical Care Medicine

National Institutes of Health

Bethesda, MD

Joshua Metlay, M.D., Ph.D.

Professor of Medicine, Epidemiology, and Emergency Medicine

Perelman School of Medicine

University of Pennsylvania

Philadelphia, PA

Emanuel Rivers, M.D., M.P.H.

Vice Chair and Director of Research for the Department of Emergency Medicine

Henry Ford Hospital

Detroit, MI

Gregory Schmidt, M.D.

Director, Critical Care Programs

University of Iowa

Iowa City, IA