# Data Abstraction Form

Table 1 Study Description

Study Description | Study design, interventions, presenting condition, setting, enrollment and follow-up numbers | Primary outcome, procalcitonin assay, decision-making processes, definitions of sepsis and related conditions | Inclusion/exclusion criteria | Participant characteristics | Participant characteristics
Author, year: Country, institution type: Enrollment period: Funding: Author industry relationship disclosures: | Design: Interventions: G1: G2: Presenting condition: Setting: N at enrollment: G1: G2: N at follow-up: G1: G2: Average follow-up, days: [mean (SD), median (range/IQR)] G1: G2: | Primary outcome: Assay type: Decision-making: G1: G2: Condition = definition: | Inclusion criteria: Exclusion criteria: | Age, years: [mean (SD), median (range/IQR)] G1: G2: [test, result (p-value, 95% CI)] G1/G2: Women, n (%): G1: G2: [test, result (p-value, 95% CI)] G1/G2: PCT: [mean (SD), median (range/IQR)] G1: G2: [test, result (p-value, 95% CI)] G1/G2: Infection site, n (%): G1: G2: | CHF (NYHA III/IV), n (%): [test, result (p-value, 95% CI)] G1: G2: G1/G2: Insulin-dependent diabetes, n (%): G1: G2: [test, result (p-value, 95% CI)] G1/G2: Cirrhosis, n (%): G1: G2: [test, result (p-value, 95% CI)] G1/G2: Home oxygen, n (%): G1: G2: [test, result (p-value, 95% CI)] G1/G2: CRF on hemodialysis, n (%): G1: G2: [test, result (p-value, 95% CI)] G1/G2: Metastatic cancer, n (%): G1: G2: [test, result (p-value, 95% CI)] G1/G2: Immunocompromised, n (%): G1: G2: [test, result (p-value, 95% CI)] G1/G2: SAPS II, mean (std dev): G1: G2: SOFA, mean (std dev): G1: G2: Septic shock, n (%): G1: G2:

Table 2 Intermediate Outcomes

Antibiotic treatment duration | Antibiotic prescription rate, number of courses of antibiotics | Antibiotic classes | Hospital length of stay | ICU admission, length of stay
Days without antibiotics at 28 days (superiority): [mean (SD), median (range/IQR)] G1: G2: [test, result (p-value, 95% CI)] G1/G2: Duration of first episode antibiotic treatment, mean (std dev): G1: G2: [test, result (p-value, 95% CI)] G1/G2: Days antibiotic exposure/1,000: (rate days exposed per #patient-days) G1: G2: [test, result (p-value, 95% CI)] G1/G2: | | | Days: [mean (SD), median (range/IQR)] G1: G2: [test, result (p-value, 95% CI)] G1/G2: | Days: [mean (SD), median (range/IQR)] G1: G2: [test, result (p-value, 95% CI)] G1/G2:

Table 3 Morbidity Outcomes

Morbidity | Morbidity | Recurrence | Sepsis/SIRS frequency | RTI symptoms, overall health, cure, success
SOFA day 28, mean (std dev): G1: G2: [test, result (p-value, 95% CI)] G1/G2: | Mechanical ventilation-free days: [mean (SD), median (range/IQR)] G1: G2: [test, result (p-value, 95% CI)] G1/G2: Nosocomial superinfection, n, (%): G1: G2: [test, result (p-value, 95% CI)] G1/G2: Multi drug resistant, n (%): G1: G2: [test, result (p-value, 95% CI)] G1/G2: | Relapse, n, (%): G1: G2: [test, result (p-value, 95% CI)] G1/G2:

Table 4 Mortality Outcomes

In-hospital mortality | 28-day mortality | 60-day mortality | Pneumonia-related death | Proportion surviving hospitalization
| Proportion (%): G1: G2: [test, result (p-value, 95% CI)] G1/G2: | Proportion (%): G1: G2: [test, result (p-value, 95% CI)] G1/G2:

Table 5 Function and Quality of Life Outcomes

Days ≤ 14 days of baseline with daily activities restricted by RTI | Days work missed | Visual analog functional scale | Quality of life score

Table 6 Adverse Effects and Adherence

Combined adverse outcome < 30 days | Antibiotic adverse effects, days with adverse effects from medication, antibiotic resistance | Pain, bleeding, local infection | Adherence

Table 7 Study Quality Ratings

Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results