# Screening Guide for Full-Text Articles

Population | Does the study include adults or children with suspected local or systemic infection?
Design | Was study designed to compare procalcitonin-guided treatment and comparator-guided treatment (RCT or QEX)?
Outcome | Does the study mention at least one of these outcomes:; - changes in patient management; - duration of antibiotic therapy; - length of stay; - antibiotic exposure; - morbidity; - mortality; - function; - quality of life; - adverse events (associated with testing, persistent/recurrent infection, antibiotic resistance)