# Screening Guide for Title and Abstract

Key Questions | Not relevant question Key question1
Study Design | administrative database animal study cost/cost-effectiveness analysis case-control study cohort study commentary case report (n<5) case series design unclear/possibly relevant diagnostic accuracy study editorial guideline in vitro letter meta-analysis no abstract not relevant design no primary data narrative review article phase I trial phase II trial physics study phantom study patient positioning study prognostic study prospective single-arm study quasi-experimental study (nonrandomized comparative) radiology/imaging study randomized controlled trial registry retrospective study systematic review disease staging study cross-sectional study
Study Setting | emergency department hospital wards medical intensive care unit primary care clinic surgical intensive care unit teaching hospital
Age | adult geriatrics neonate pediatrics
Disease | acute bronchitis autoimmune diseases acute lymphoblastic leukemia acute pyelonephritis aspiration syndromes bacteremia bacterial infection community-acquired pneumonia culture-negative sepsis chronic obstructive pulmonary disease chronic bronchitis diabetic foot infection empyema fever fungal infection fever of unknown origin hematological tumor H1N1 influenza intra-abdominal infection immunocompromised post-liver transplantation malnutrition meningitis not relevant disease neutropenia neonatal sepsis osteomyelitis peritonitis post-orthopedic surgery post-resuscitation disease parasitic infection sepsis (culture positive) systemic inflammatory response syndrome solid organ tumor septic shock skin/soft tissue infection severe sepsis urinary tract infection ventilator-associated pneumonia viral infection
Biomarker | atrial natriuretic peptide CD14 complement 3 complement 4 C-reactive protein C-terminal pro-atrial vasopressin cell-free plasma DNA interleukin-1b interleukin-4 interleukin-6 interleukin-8 interleukin-10 interleukin-12 lipopolysaccharide binding protein Mid-regional pro-atrial natriuretic peptide macrophage migration inhibitory factor neutrophilic CD64 neopterin procalcitonin (alveolar) procalcitonin (serum) procalcitonin (pleural fluid) soluble triggering receptor expressed on myeloid cells-1 thioredoxin tumor necrosis factor-α TNF receptor II TREM-1
Labs | bronchoalveolar lavage bone biopsy blood cultures erythrocyte sedimentation rate endotracheal aspirate ferritin Gram staining magnetic resonance imaging nuclear medicine scan real-time polymerase chain reaction pleural fluid culture swab culture serum sodium urine culture plain radiographs white blood cell count
Outcomes | antibiotic resistance antibiotic-free days antibiotic side effects prediction of bacterial infection detection of complications of infection diagnosis of bacterial infection diagnosis of sepsis duration of intravenous antibiotic total duration of antibiotic therapy initiation of antibiotic therapy length of stay in ICU length of stay in hospital mortality not relevant outcome (or no follow-up) persistent or recurrent fever response to antibiotic therapy septic shock development termination of antibiotic therapy
Assay type | Brahms PCT Kryptor rapid PCT test (semi-quantitative) Vidas Brahms PCT
Sample | n < 10 10 < n < 25 25 < n < 50 50 < n < 100 n > 100 n unclear
Scoring | APACHE II CRB Clinical Pulmonary Infection CURB-65 Sequential Organ Failure Assessment
Retrieval | do not retrieve full copy retrieve full copy uncertain; needs check by second reviewer