# Ongoing Procalcitonin Studies in ClinicalTrials.gov

| NCT ID | Title | Presenting condition(s) | n | Primary outcome | Secondary outcome | Date^†^
1 | NCT00914550 1 | Use Of Procalcitonin Level For Guidance of The Treatment of Suspected Community Acquired Pneumonia^*^ | - Pneumonia; - Radiographic Lung Infiltrates | 100 | - Differences in antibiotic discontinuation as an effect of the caregivers learning Procalcitonin levels for the therapy of new radiographic lung infiltrates | - | 1-Jun-10
2 | NCT01139489 2 | Safety and Efficacy of Procalcitonin Guided Antibiotic Therapy in Adult Intensive Care Units (ICU's)^*^ | - Sepsis; - Severe Sepsis; - Septic Shock | 2246 | - 28-day mortality; - Consumption of antibiotics (defined daily dosage and duration of antibiotic therapy) | - Length of ICU stay; - Acquisition costs of antibiotics; - Acquisition costs of procalcitonin | 1-Jul-11
3 | NCT01379547 3 | Procalcitonin to Shorten Antibiotics Duration in ICU Patients^*^ | - Sepsis | 1700 | - Average antibiotics duration; - 28-day mortality | - % of antibiotics use; - Length of ICU stay; - Recurrence of fever; - Re-infection; - APACHE-II score or SOFA score; - 90-day mortality; - 90-day infection related readmission rate | 1-Jun-13
4 | NCT00854932 4 | Neonatal Procalcitonin Intervention Study^*^ | - Sepsis | 1600 | - The absolute reduction of the duration of antibiotic therapy with unchanged outcome | - Duration of hospitalization | 1-Jul-12
5 | NCT00832039 5 | Placebo Controlled Trial of Sodium Selenite and Procalcitonin Guided Antimicrobial Therapy in Severe Sepsis^*^ | - Severe Sepsis; - Septic Shock | 1180 | - All cause mortality | - SOFA and SOFA subscores; - Frequency and duration of mechanical ventilation; - Frequency and duration of vasopressor support; - Frequency of adverse events and severe adverse events; - Clinical cure and microbiological cure; - Duration of antimicrobial therapy; - Costs of antimicrobial therapy; - Time to change of antibiotic therapy; - Days alive without antimicrobial therapy; - Frequency of resistance against antibiotics; - ICU length of stay; - Hospital length of stay; - Rate of surgical procedures for focus control; - Rate of procedures to diagnose infections; - Frequency of new infections | 1-Apr-14
6 | NCT01018199 6 | Procalcitonin Versus C-reactive Protein to Guide Therapy in Community Acquired Pneumonia^**^ | - Community-Acquired Pneumonia | 66 | - Duration of antibiotic therapy; - Total antibiotic exposure days per 1,000 days; - Days alive without antibiotics | - All cause 28-day mortality; - clinical cure rate; - Infection relapse; - Length of hospitalization stay; - In-hospital mortality; - Nosocomial infection rate; - Nosocomial superinfection; - Isolation of resistant bacteria; - All cause 90-day mortality; - Costs of hospitalization | 1-Dec-10
7 | NCT00987818 7 | Procalcitonin Guided Versus Conventional Antibiotic Therapy in Patients With Sepsis in the ICU^**^ | - Sepsis; - Intensive Care | 50 | - Duration of antibiotic therapy | - 28 day mortality | 1-Apr-10
8 | NCT01250574 8 | Neutrophil CD64 and Procalcitonin as Novel Biomarkers for Postoperative Infections^*^ | - Bacterial Infection; - Postoperative Infection; - Abdominal Infection | 150 | - | - | -
9 | NCT00870623 9 | Procalcitonin and Endotoxin Sequential Levels to Optimize the Treatment of Bloodstream Infections^*^ | - Infection of Bloodstream | 136 | - Length of treatment by observing the normalization of procalcitonin (PCT) and Endotoxin levels, compared with the length of treatment by standard of care. | - Treatment failure; - Complications; - Survival, cost; - Length of stay; - Progression to severe sepsis or superinfections | -
10 | NCT00934011 10 | Use of Inflammatory Biomarkers to Guide Antibiotic Therapy in Patients With Severe Infections^*^ | - Severe Sepsis; - Septic Shock | 124 | - Duration of antibiotic therapy; - Total antibiotic exposure days per 1,000 days; - Days alive without antibiotics | - 28-day mortality; - Clinical cure rate; - Infection relapse; - Length of ICU stay; - Nosocomial infection rate; - In-hospital mortality; - Sepsis-associated death; - Nosocomial superinfection; - Isolation of resistant bacteria Length of hospital stay | 1-Aug-11
11 | NCT01264549 11 | Stroke Adverse Outcome is Associated With Nosocomial Infections: PCTus- Guided Antibacterial Therapy in Severe Ischemic Stroke Patients (STRAWINSKI) * | - Ischemic Stroke | 200 | - Modified Rankin scale | - % of patients receiving any antibiotic therapy; - % of patients receiving any antibiotic therapy for any duration within 90 days; - Barthel Index score; - Days alive and out of hospital; - Time to first event of death, re-hospitalization or recurrent stroke; - Proportion of events of post stroke infections; - Median number of days with fever (≥ 37,5°C) per patient Stroke volume analysis | 1-Dec-12
12 | NCT01125098 12 | Comparison of a Serum PRO-CT Guided Treatment and the Recommended Antibiotic Treatment for COPD^*^ | - COPD | 200 | - Rate of severe ECOPD | - Costs; - Duration of antibiotic therapy Hospital re-admissions; - Any cause deaths; - FEV1; - Duration of hospitalization for severe ECOPD | 1-Dec-11
13 | NCT01091493 13 | Utility of Antibiotic Treatment in Non-purulent Exacerbations of Chronic Obstructive Pulmonary Disease: a Double Blinded, Randomized, Placebo-controlled Trial of Security and Efficacy^*^ | - COPD | 224 | - Efficacy of treatment WITHOUT antibiotics in non-purulent exacerbations of COPD | - Re-hospitalizations at six months.; - In-hospital stay (days); - All cause mortality; - Procalcitonin levels; - Quality of Life (QoL) (Saint George Respiratory Questionnaire); - CRP levels; - Cytokines levels (IL-1, IL-6, IL-8, IL-10); - TNF- alpha levels | 1-Mar-13
14 | NCT01311765 14 | Duration of Antibiotic Therapy in the Treatment of Severe Postoperative Peritonitis Admitted in ICU^*^ | - Postoperative Peritonitis | 620 | - Number of antibiotic-free days at D28 after inclusion; - Mortality at D45 after inclusion | - Duration of ICU and hospital stay; - Changes in SOFA score; - Number of days alive without organ failure; - Failure rate for clinically evaluable patients; - Failure rate for microbiologically evaluable patients; - Rate of relapse within 45 days; - Emergence of multidrug resistant microorganisms in clinical isolates and hygiene samples; - Total cost of antibiotic agents; - Evolution of procalcitonin plasma concentration; - Rate of death within 45 days; - Total cost of hospital stay and evaluation of costs and resources impact for the hospital administration | 1-Nov-14
15 | NCT01232140 15 | CRP-guided Antibiotic Treatment in COPD Exacerbations Admitted to the Hospital^**^ | - COPD; - ECOPD; - Bronchitis | 220 | - Number of patients treated with antibiotics during hospital stay | - Time to treatment failure within 30-days; - Length of stay; - Time to next exacerbation; - Symptom scores (VAS-LRTI, George's Respiratory Questionnaire); - Adverse events | 1-Jul-13

† Expected date of completion of the study,

* Study listed as recruiting,

** Study listed as not yet recruiting

1 Use Of Procalcitonin Level For Guidance of The Treatment of Suspected Community Acquired Pneumonia. Available from: http://clinicaltrials.gov/ct2/show/NCT00914550. 2011 August 18.
2 Safety and Efficacy of Procalcitonin Guided Antibiotic Therapy in Adult Intensive Care Units (ICU's) (SAPS). Available from: http://clinicaltrials.gov/ct2/show/NCT01139489. 2011 August 18.
3 Procalcitonin to Shorten Antibiotics Duration in ICU Patients (ProShort). Available from: http://clinicaltrials.gov/ct2/show/NCT01379547. 2011 August 18.
4 Neonatal Procalcitonin Intervention Study (NeoPInS). Available from: http://clinicaltrials.gov/ct2/show/NCT00854932. 2011 August 18.
5 Placebo Controlled Trial of Sodium Selenite and Procalcitonin Guided Antimicrobial Therapy in Severe Sepsis (SISPCT). Available from: http://clinicaltrials.gov/ct2/show/NCT00832039. 2011 August 18.
6 Procalcitonin Versus C-reactive Protein to Guide Therapy in Community Acquired Pneumonia (CAP-Marker). Available from: http://clinicaltrials.gov/ct2/show/NCT01018199. 2011 August 18.
7 Procalcitonin Guided Versus Conventional Antibiotic Therapy in Patients With Sepsis in the ICU. Available from: http://clinicaltrials.gov/ct2/show/NCT00987818. 2011 August 18.
8 Neutrophil CD64 and Procalcitonin as Novel Biomarkers for Postoperative Infections. Available from: http://clinicaltrials.gov/ct2/show/NCT01250574. 2011 August 18.
9 Procalcitonin and Endotoxin Sequential Levels to Optimize the Treatment of Bloodstream Infections. Available from: http://clinicaltrials.gov/ct2/show/NCT00870623. 2011 August 18.
10 Use of Inflammatory Biomarkers to Guide Antibiotic Therapy in Patients With Severe Infections. Available from: http://clinicaltrials.gov/ct2/show/NCT00934011. 2011 August 18.
11 Stroke Adverse Outcome is Associated With Nosocomial Infections: PCTus- Guided Antibacterial Therapy in Severe Ischemic Stroke Patients (STRAWINSKI). Available from: http://clinicaltrials.gov/ct2/show/NCT01264549. 2011 August 18.
12 Comparison of a Serum PRO-CT Guided Treatment and the Recommended Antibiotic Treatment for COPD. Available from: http://clinicaltrials.gov/ct2/show/NCT01125098. 2011 August 18.
13 Utility of Antibiotic Treatment in Non-purulent Exacerbations of Chronic Obstructive Pulmonary Disease: a Double Blinded, Randomized, Placebo-controlled Trial of Security and Efficacy (AEPOC-ATB). Available from: http://clinicaltrials.gov/ct2/show/NCT01091493. 2011 August 18.
14 Duration of Antibiotic Therapy in the Treatment of Severe Postoperative Peritonitis Admitted in ICU (DURAPOP). Available from: http://clinicaltrials.gov/ct2/show/NCT01311765. 2011 August 18.
15 CRP-guided Antibiotic Treatment in COPD Exacerbations Admitted to the Hospital (CATCH). Available from: http://clinicaltrials.gov/ct2/show/NCT01232140. 2011 August 18.