# Abstraction Tables

Evidence Table 1A Study Description Table for Bouadma et al., 2010^1^

Study Description | Study design, interventions, presenting condition, setting, enrollment and follow-up numbers | Primary outcome, procalcitonin assay, decision-making processes, definitions of sepsis and related conditions | Inclusion/exclusion criteria | Participant characteristics | | | Participant characteristics
Author, year: Bouadma et al., 2010. PRORATA (procalcitonin to reduce antibiotic treatments in acutely ill patients) Country, institution type: France, 5 university-affiliated hospitals Enrollment period: 06/07 – 05/08 Funding: Assistance Publique-Hôpitaux de Paris, France, and Brahms, Germany Author industry relationship disclosures: 4 authors disclosed conflicts | Design: RCT; 1:1, masked until randomization, stratified by center Superior for antibiotics free days Non-inferior with respect to mortality Interventions: G1: PCT-guided antibiotic therapy G2: Standard antibiotic therapy Presenting condition: Critically ill patients, , suspected bacterial infection on admission to ICU or during stay Setting: ICU (5 MICU, 2 SICU) N screened, reasons for exclusion N at enrollment: G1: 311 G2: 319 N at follow-up: G1: 307 G2: 314 Average follow-up, days: [mean (SD), median (range/IQR)] G1: NR G2: NR Follow-up to 60 days | Primary outcome: Mortality at days 28 and 60 (non-inferiority analysis), and number of days without antibiotics by day 28 (superiority analysis) 90 % power to detect a 3 day increase in days without antibiotics, 133 subjects per study group. To have 80 % chance of non-inferiority with respect to mortality (10 % alpha risk), 300 patients needed per study arm Secondary outcomes: ABT exposure, morbidity Assay type: Kryptor PCT, Brahms Decision-making: 2 interventions For antibiotic initiation G1: PCT < 0.25 antibiotics strongly discouraged; PCT ≥ 0.25, < 0.5 antibiotics discouraged; PCT ≥ 0.5 and < 1, antibiotics encouraged; PCT ≥ 1.0, antibiotics strongly encouraged G2: Standard therapy For antibiotic discontinuation G1: PCT < 0.25, stopping antibiotics strongly encouraged; PCT ≥ 80 % decrease from peak or < 0.5 ng/mL, stopping antibiotics encouraged; PCT < 80 % decrease from peak or ≥ 0.5, continuing antibiotics encouraged; PCT > baseline and ≥ 0.5, continuing antibiotics strongly encouraged G2: Standard therapy Condition = definition: Suspected bacterial infections Condition = definition: Sepsis | Inclusion criteria:; - Critically ill patients; - ICU; - Suspected bacterial infection; Exclusion criteria:; - Age < 18 years; - Antibiotics > 24 hours before enrollment; - Pregnancy; - Expected ICU stay < 3 days; - Stem cell transplantation; - ANC < 500; - Chronic infections; - SAPS II > 65 (unlikely to survive); - Do not resuscitate | Age, years: [mean (SD), median (range/IQR)] G1: 61.0 (15.2) G2: 62.1 (15.0) [test, result (p-value, 95% CI)] G1/G2: Women, n (%): G1: 100 (33 %) G2: 110 (35 %) [test, result (p-value, 95% CI)] G1/G2: PCT: [mean (SD), median (range/IQR)] G1: 12.0 (30.9) G2: 12.0 (32.6) [test, result (p-value, 95% CI)] G1/G2: Infection site, n (%): G1: | | | CHF (NYHA III/IV), n (%): [test, result (p-value, 95% CI)] G1: 16 (5 %) G2: 13 (4 %) G1/G2: Insulin-dependent diabetes, n (%): G1: 27 (9 %) G2: 22 (7 %) [test, result (p-value, 95% CI)] G1/G2: Cirrhosis, n (%): G1: 20 (7 %) G2: 13 (4 %) [test, result (p-value, 95% CI)] G1/G2: Home oxygen, n (%): G1: 23 (7 %) G2: 18 (6 %) [test, result (p-value, 95% CI)] G1/G2: CRF on hemodialysis, n (%): G1: 17 (6 %) G2: 11 (4 %) [test, result (p-value, 95% CI)] G1/G2: Metastatic cancer, n (%): G1: 8 (3 %) G2: 5 (2 %) [test, result (p-value, 95% CI)] G1/G2: Immunocompromised, n (%): G1: 47 (15 %) G2: 51 (16 %) [test, result (p-value, 95% CI)] G1/G2: SAPS II, mean (std dev): G1: 47.1 (17.9) G2: 46.9 (17.2) SOFA, mean (std dev): G1: 8.0 (4.7) G2: 7.7 (4.6) Septic shock, n (%): G1: 53 (17 %) G2: 55 (18 %)
| | | | Pulmonary | (183) | 71 %
| | | | UTI | (24) | 9 %
| | | | SSI | (5) | 2 %
| | | | Intra-abdominal | (14) | 5 %
| | | | CNS | (7) | 2 %
| | | | CVC | (5) | 3 %
| | | | Bacteremia | (9) | 4 %
| | | | Other | (11) | 4 %
| | | | G2:
| | | | Pulmonary | (211) | 71 %
| | | | UTI | (18) | 9 %
| | | | SSI | (6) | 2 %
| | | | Intra-abdominal | (20) | 5 %
| | | | CNS | (6) | 2 %
| | | | CVC | (3) | 3 %
| | | | Bacteremia | (11) | 4 %
| | | | Other | (9) | 4 %

Evidence Table 2A Intermediate Outcomes for Bouadma et al., 2010^1^

Antibiotic treatment duration | Antibiotic prescription rate, number of courses of antibiotics | Antibiotic classes | Hospital length of stay | ICU admission, length of stay
Days without antibiotics at 28 days (superiority): [mean (SD), median (range/IQR)] G1: 14.3 (9.1) G2: 11.6 (8.2) [test, result (p-value, 95% CI)] p < 0.0001 G1/G2: Duration of first episode antibiotic treatment, mean (std dev): G1: 6.1 (6.0) G2: 9.9 (7.1) [test, result (p-value, 95% CI)] p < 0.0001 G1/G2: Days antibiotic exposure/1,000: (rate days exposed per #patient-days) G1: 653 G2: 812 [test, result (p-value, 95% CI)] G1/G2: -159(-185 to -131) | NR | NR | Days: [mean (SD), median (range/IQR)] G1: 26.1 (19.3) G2: 26.4 (18.3) [test, result (p-value, 95% CI)] G1/G2: NSS | Days: [mean (SD), median (range/IQR)] G1: 15.9 (16.1) G2: 14.4 (14.1) [test, result (p-value, 95% CI)] G1/G2: NSS

Evidence Table 3A Morbidity Outcomes for Bouadma et al., 2010^1^

Morbidity | Morbidity | Recurrence | Sepsis/SIRS frequency | RTI symptoms, overall health, cure, success
SOFA day 28, mean (std dev): G1: 1.5 (3.0) G2: 0.9 (2.4) [test, result (p-value, 95% CI)] G1/G2: | Mechanical ventilation-free days: [mean (SD), median (range/IQR)] G1: 16.2 (11.1) G2: 16.9 (10.9) [test, result (p-value, 95% CI)] G1/G2: Nosocomial superinfection, n, (%): G1: 106 (34.5 %) G2: 97 (30.9 %) [test, result (p-value, 95% CI)] G1/G2: Multi drug resistant, n (%): G1: 55 (17.9 %) G2: 52 (16.6 %) [test, result (p-value, 95% CI)] G1/G2: | Relapse, n, (%): G1: 20 (6.5 %) G2: 16 (5.1 %) [test, result (p-value, 95% CI)] G1/G2: | NR | NR

Evidence Table 4A Mortality Outcomes for Bouadma et al., 2010^1^

In-hospital mortality | 28-day mortality | 60-day mortality | Pneumonia-related death | Proportion surviving hospitalization
NR | Proportion (%): G1: 21.2 % G2: 20.4 % [test, result (p-value, 95% CI)] G1/G2: Non-inferiority, 10 % margin | Proportion (%): G1: 30.0 % G2: 26.1 % [test, result (p-value, 95% CI)] G1/G2: Non-inferiority, 10 % margin | NR | NR

Evidence Table 5A Function and Quality of Life Outcomes for Bouadma et al., 2010^1^

Days ≤ 14 days of baseline with daily activities restricted by RTI | Days work missed | Visual analog functional scale | Quality of life score
NR | NR | NR | NR

Evidence Table 6A Adverse Effects, Adherence for Bouadma et al., 2010^1^

Combined adverse outcome < 30 days | Antibiotic adverse effects, days with adverse effects from medication, antibiotic resistance | Pain, bleeding, local infection | Adherence
NR | NR | NR | NR

Evidence Table 7A Randomized Trial Study Quality Ratings for Bouadma et al., 2010^1^

Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results
Y | Y | Y | Y | Y | Y | Y

Evidence Table 1B Study Description Table for Briel et al., 2008^2^

Study Description | Study design, interventions, presenting condition, setting, enrollment and follow-up numbers | Primary outcome, procalcitonin assay, decision-making processes, definitions of sepsis and related conditions | Inclusion/exclusion criteria | Participant characteristics | Participant characteristics
Author, year: Briel et al., 2008. Country, institution type: Switzerland Enrollment period: December 13, 2004-April 30, 2006 Funding: Swiss National Science Foundation; Assoc. for the Promotion of Science and Postgraduate Training of the University Hospital of Basel; Brahms Author industry relationship disclosures: 1 author consultant and recipient of funds from Brahms for travel, speaking | Design: RCT, open, multicenter, non-inferiority Interventions: G1: Procalcitonin-guided therapy G2: Standard therapy Presenting condition: Adults with acute respiratory tract infection in need of antibiotics Setting: 53 primary care physicians, multi-center, non-inferiority trial, monitored by independent monitoring board 8162 patients consulted for RTI 1480 assessed because of perceived need for antibiotics 1022 excluded 67 with symptoms> 28 days 21 given antibiotics within 28 days 180 not fluent 41 psych issues 35 needed immediate hospitalization 63 with severe immunosuppression 152 not available for follow-up 217 physician not able to follow 246 refused consent 458 randomized N at enrollment: G1: 232 G2: 226 N at follow-up: G1: 230 (2 LTFU) G2: 223 (2 LTFU) Average follow-up, days: [mean (SD), median (range/IQR)] G1: 28 days G2: 28 days | Primary outcome: Intent to treat and per protocol Primary outcomes Number of days in first 14 days after baseline with restricted activities due to RTI Intent to treat and per protocol Secondary outcomes: Only per protocol analysis Antibiotic prescription rate Duration of antibiotic Discomfort scale Days of work missed Days with adverse medication effects Ongoing or relapsed RTI SAEs within 28 days 275 needed to show hat at worst PCT-guided therapy increased antibiotic duration by 1 day, alpha error 5 % Response criteria, independent outcome assessor: Assay type: Kryptor, Brahms Results available within 2-4 hours Decision-making: G1: For PCT 0.01, antibiotics discouraged For PCT between 0.1-0.25, antibiotics not recommended For PCT > 0.25, antibiotics recommended Also if second PCT in 6-24 hours was increased by 50 % G2: Physicians encouraged to use evidence-based guidelines Decision-making: G1: If PCT < 0.25 at day 3, discontinuation recommended Condition = definition: Physician diagnosis | Inclusion criteria:; - Cold; - Sinusitis; - Pharyngitis; - Tonsillitis,; - Tracheobronchitis; - AECOPD,; - CAP; - Intention to prescribe antibiotics; Exclusion criteria:; - Antibiotics in previous 28 days; - Psych disorders; - Severe immunosuppression; - Cystic fibrosis; - TB; - Need for immediate hospitalization; - Not available for follow-up; - Not fluent in German | Age, years: [mean (SD), G1: 48 (18) G2: 48 (18) [test, result (p-value, 95% CI)] G1/G2: NSS Men, n (%): G1: 98 (42 %) G2: 87 (38 %) [test, result (p-value, 95% CI)] G1/G2: NSS Days with restricted activities, mean (SD): G1: 5.8 (4.7) G2: 6.5 (4.7) [test, result (p-value, 95% CI)] G1/G2: NSS Discomfort score, mean (SD): G1: 6.1 (2.6) G2: 6.2 (2.4) [test, result (p-value, 95% CI)] G1/G2: NSS Diagnosis Common cold, n, (%):] G1: 13 (5.6 %) G2: 18 (8.0 %) [test, result (p-value, 95% CI)] G1/G2: NSS Acute sinusitis, n, (%):] G1: 52 (22 %) G2: 52 (23 %) [test, result (p-value, 95% CI)] G1/G2: NSS Pharyngitis/tonsillitis, n, (%):] G1: 42 (18 %) G2: 33 (15 %) [test, result (p-value, 95% CI)] G1/G2: NSS Laryngitis/tracheitis, n, (%):] G1: 8 (3.5 %) G2: 4 (1.8 %) [test, result (p-value, 95% CI)] G1/G2: NSS Acute otitis media, n, (%):] G1: 0 G2: 5 (2.2 %) [test, result (p-value, 95% CI)] G1/G2: NSS Acute bronchitis, n, (%):] G1: 58 (25 %) G2: 70 (31 %) [test, result (p-value, 95% CI)] G1/G2: NSS Influenza, n, (%):] G1: 3 (1.3 %) G2: 1 (0.4 %) [test, result (p-value, 95% CI)] G1/G2: NSS AECOPD, n, (%):] G1: 12 (5.2 %) G2: 9 (4.0 %) [test, result (p-value, 95% CI)] G1/G2: NSS Acute asthma attack, n, (%):] G1: 6 (2.6 %) G2: 2 (1.3 %) [test, result (p-value, 95% CI)] G1/G2: NSS CAP, n, (%):] G1: 38 (16 %) G2: 31 (14 %) [test, result (p-value, 95% CI)] G1/G2: NSS | Any co-morbidities, n (%): [test, result (p-value, 95% CI)] G1: 33 (14 %) G2: 37 (16 %) G1/G2: NSS Chronic lung disease, n (%): [test, result (p-value, 95% CI)] G1: 12 (5.2 %) G2: 14 (6.2 %) G1/G2: NSS Diabetes mellitus, n (%): G1: 6 (2.6 %) G2: 7 (3.1 %) [test, result (p-value, 95% CI)] G1/G2: NSS Congestive heart failure, n (%): G1: 8 (3.4 %) G2: 6 (2.6 %) [test, result (p-value, 95% CI)] G1/G2: NSS Other, n (%): G1: 7 (3.0 %) G2: 10 (4.4 %) [test, result (p-value, 95% CI)] G1/G2: NSS PCT, mean (SD): G1: 0.39 (2.7) G2: 0.25 (1.3) [test, result (p-value, 95% CI)] G1/G2: NSS CRP, mean (SD): G1: 51 (65) G2: 51 (55) [test, result (p-value, 95% CI)] G1/G2: NSS

Evidence Table 2B Intermediate Outcomes for Briel et al., 2008^2^

Antibiotic treatment duration | Antibiotic prescription rate, number of courses of antibiotics | Antibiotic classes | Hospital length of stay | ICU admission, length of stay
Days with antibiotics: mean (SD) G1: 6.2 (2.5) G2: 7.1 (2.2) [test, result (p-value, 95% CI)] G1/G2: Adjusted difference in days (95 % CI) -1.0 (-1.7 to -0.4) | Any antibiotic use, antibiotic prescription rate (%): G1: 58 (25 %) G2: 219 (97 %) [test, result (p-value, 95% CI)] G1/G2: Difference -72 % (-78 to -66) Adjusted odds ratio (95 % CI) 0.01 (0.002 to 0.02) | NR | NR | NR

Evidence Table 3B Morbidity Outcomes for Briel et al., 2008^2^

Morbidity | Morbidity | Recurrence | Sepsis/SIRS frequency | RTI symptoms, overall health, cure, success
NR | Intent to treat Restricted activities, days: [mean (SD), median (range/IQR)] G1: 8.7 (3.9) G2: 8.6 (3.0) [test, result (p-value, 95% CI)] G1/G2: Adjusted difference (95 % CI) 0.2 (-0.4 to 0.9) Days of work missed within 14 days: [mean (SD), median (range/IQR)] G1: 4.9 (4.6) G2: 4.8 (4.2) [test, result (p-value, 95% CI)] G1/G2: Adjusted difference (95 % CI) 0.3 (-0.6 to 1.2) | NR | NR | RTI symptoms at 28 days (%): G1: 69 (30 %) G2: 67 (30 %) [test, result (p-value, 95% CI)] G1/G2: NSS Degree of discomfort score at 14 days: [mean (SD) G1: 1.9 (2.7) G2: 1.1 (1.9) [test, result (p-value, 95% CI)] G1/G2: Adjusted difference (95 % CI) 0.8 (0.4 to 1.2)

Evidence Table 4B Mortality Outcomes for Briel et al., 2008^2^

In-hospital mortality | 28-day mortality | Death | Pneumonia-related death | Proportion surviving hospitalization
NR | NR | NR | NR | NR

Evidence Table 5B Function and Quality of Life Outcomes for Briel et al., 2008^2^

Days ≤ 14 days of baseline with daily activities restricted by RTI | Days work missed | Visual analog functional scale | Quality of life score
NR | NR | NR | NR

Evidence Table 6B Adverse Effects and Adherence for Briel et al., 2008^2^

Combined adverse outcome < 30 days | Antibiotic adverse effects, days with adverse effects from medication, antibiotic resistance | Pain, bleeding, local infection | Adherence
Proportion (%): G1: G2: [test, result (p-value, 95% CI)] G1/G2: | Days of AEs within 14 days: [mean (SD), median (range/IQR)] G1: 2.3 (4.6) G2: 3.6 (6.1) [test, result (p-value, 95% CI)] G1/G2: Adjusted difference (95 % CI) -1.1 (-2.1 to -0.1) Mainly due to number with diarrhea (47/231 vs 76/224) | NR | NR

Evidence Table 7B Randomized Trial Study Quality Ratings for Briel et al., 2008^2^

Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results
Y- balanced Y-concealment | Y | Y | Y | Y | Y | Y

Evidence Table 1C Study Description Table for Burkhardt et al., 2010^3^

Study Description | Study design, interventions, presenting condition, setting, enrollment and follow-up numbers | Primary outcome, procalcitonin assay, decision-making processes, definitions of sepsis and related conditions | Inclusion/exclusion criteria | Participant characteristics | Participant characteristics
Author, year: Burkhardt et al., 2010. Country, institution type: Germany, Medical Hospital Hannover Enrollment period: Not given Funding: Not given Author industry relationship disclosures: Conflicts for 7 authors available at www.erj.ersjournals.com/misc/statements.dtl, 3 authors from Brahms Research Dept. | Design: RCT, intent to treat analysis Interventions: G1: PCT-guided antibiotic therapy G2: Standard care Presenting condition: Acute respiratory tract infection Setting: Primary care offices N at enrollment: G1: 275 G2: 275 N at follow-up: G1: NR G2: NR Average follow-up, days: [mean (SD), median (range/IQR)] G1: 14 day G2: 28 day | Primary outcome: Number of days with significant health impairment due to RTI at day 14 Non-inferior of the 95 % CI for the difference between groups in number of days with impairment was < 1 day 90 % chance to show that PCT-guided therapy does not lead to > 1 additional day of impairment with 275 patients per group Secondary outcomes: Prescription rate, duration of antibiotic, days with antibiotic-associated SEs, symptoms on day 14 and 28, revisit within 28 days, change of antibiotics within 28 days, hospitalization within 28 days, 28 day mortality Kruskal-Willis and Pearson's Chi-squared test Assay type: Brahms Kryptor PCT Decision-making: G1: PCT < 0.25, no antibiotics; PCT > 0.25, antibiotics recommended G2: Standard care | Inclusion criteria:; - > 18 years of age; - Symptoms of acute RTI, URTI or LRTI-no standardized clinical diagnosis; Exclusion criteria:; - Antibiotics in previous 2 weeks; - Major surgery in past 4 weeks; - Chronic liver disease; - Autoimmune or systemic disorders; - HD; - Medullary thyroid cancer; - Inflammatory diseases | Age, years: [mean (SD), median (range/IQR)] G1: 41.4 ±15.3 G2: 43.4 ±15.5 [test, result (p-value, 95% CI)] G1/G2: NSS Male, n (%): G1: 164 (59.6) G2: 161 (58.5) [test, result (p-value, 95% CI)] G1/G2: NSS PCT : [mean (SD), median (range/IQR)] G1: 0.054 ng/mL G2: 0.057 ng/mL [test, result (p-value, 95% CI)] G1/G2: NSS | Insulin-dependent diabetes, n (%): G1: 15/275 (5.5 %) G2: 9/275 (3.3 %) [test, result (p-value, 95% CI)] G1/G2: NSS Congestive heart failure, n (%): G1: 5/275 (1.8 %) G2: 5/275 (1.8 %) [test, result (p-value, 95% CI)] G1/G2: NSS COPD, n (%): G1: 4/275 (1.5 %) G2: 9/275 (3.3 %) [test, result (p-value, 95% CI)] G1/G2: NSS

Evidence Table 2C Intermediate Outcomes for Burkhardt et al., 2010^3^

Antibiotic treatment duration | Antibiotic prescription rate, number of courses of antibiotics | Antibiotic classes | Hospital length of stay | ICU admission, length of stay
Days: [mean (SD), median (range/IQR)] G1: 7.8 ± 2.8 G2: 7.7 ± 3.3 [test, result (p-value, 95% CI)] G1/G2: p = 0.68 | Any antibiotic use, antibiotic prescription rate (%): G1: 59/275 (21.5 %) G2: 101/275 (36.8 %) [test, result (p-value, 95% CI)] G1/G2: p = 0.0005 | NR | Hospitalization, n (%): [mean (SD), median (range/IQR)] G1: 0 (0.0 %) G2: 1/275 (0.4 %) [test, result (p-value, 95% CI)] G1/G2: | NR

Evidence Table 3C Morbidity Outcomes for Burkhardt et al., 2010^3^

Morbidity | Morbidity | Recurrence | Sepsis/SIRS frequency | RTI symptoms, overall health, cure, success
NR | NR | NR | NR | NR

Evidence Table 4C Mortality Outcomes for Burkhardt et al., 2010^3^

In-hospital mortality | 28-day mortality | Death | Pneumonia-related death | Proportion surviving hospitalization
NR | NR | NR | NR | NR

Evidence Table 5C Function and Quality of Life Outcomes for Burkhardt et al., 2010^3^

Days ≤ 14 days of baseline with daily activities restricted by RTI | Days work missed | Visual analog functional scale | Quality of life score
Modified intention to treat analysis Days: [mean (SD), median (range/IQR)] G1: 9.04 G2: 9.00 [test, result (p-value, 95% CI)] G1/G2: difference between G1 and G2 0.04 days, 95% CI -0.53 to 0.95) Worst case sensitivity analysis Days: [mean (SD), median (range/IQR)] G1: 9.06 G2: 8.80 [test, result (p-value, 95% CI)] G1/G2: difference between G1 and G2 0.25 days, 95% CI -0.52 to 1.03) | NR | NR | NR

Evidence Table 6C Adverse Effects and Adherence for Burkhardt et al., 2010^3^

Combined adverse outcome < 30 days | Antibiotic adverse effects, days with adverse effects from medication, antibiotic resistance | Pain, bleeding, local infection | Adherence
NR | Antibiotic adverse effects (%): G1: 11 G2: 16 [test, result (p-value, 95% CI)] G1/G2: p = 0.331 | NR | NR

Evidence Table 7C Randomized Trial Study Quality Ratings for Burkhardt et al., 2010^3^

Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results
Y balanced Y-concealment | Y | Y | Y | Y | Y | Y

Evidence Table 1D Study Description Table for Christ-Crain et al., 2004^4^

Study Description | Study design, interventions, presenting condition, setting, enrollment and follow-up numbers | Primary outcome, procalcitonin assay, decision-making processes, definitions of sepsis and related conditions | Inclusion/exclusion criteria | Participant characteristics | Participant characteristics
Author, year: Christ-Crain et al., 2004. Country, institution type: Switzerland, University Hospital Enrollment period: December 16, 2002, April 13, 2003 Funding: Brahms, Dept of Medicine, Freiwillige Akadmische Gesellschaft Basel Author industry relationship disclosures: 1 author consultant, recipient of payments from Brahms | Design: Prospective, cluster-randomized, single-blinded study Interventions: G1: Procalcitonin-based therapeutic strategy G2: Standard care Presenting condition: LRTI Setting: ED 4119 patients in ED 597 (14 %) with cough, dyspnea Screened Excluded N at enrollment: G1: 124 G2: 119 N at follow-up: G1: 112 (4 died, 8 LTFU) G2: 110 (4 died, 5 LTFU) Average follow-up, days: [mean (SD), median (range/IQR)] G1: NR G2: NR | Primary outcome: Use of antibiotics % prescription Patient-days RR antibiotic exposure for LRTI and AECOPD 95 % chance of detecting a 30 % reduction in antibiotic exposure Secondary outcomes: Clinical and laboratory outcome QOL Temp WBC count CRP PCT Admission rates LOS ICU Death for LRTIs Re-exacerbation, readmission for AECOPD Response criteria, independent outcome assessor: Assay type: Kryptor PCT, Brahms Decision-making: G1: For antibiotic initiation PCT < 0.1, antibiotics strongly discouraged PCT 0.1-0.25. antibiotics discouraged PCT 0.25-0.5, antibiotics encouraged PCT 0.5 or greater, antibiotics strongly encouraged G2: Standard therapy Decision-making: G1: For antibiotic discontinuation PCT < 0.25, d/c antibiotics G2: Standard therapy Condition = definition: | Inclusion criteria:; - Cough; - Dyspnea; - Both; - Lower RTI; Exclusion criteria:; - Severely immuno-compromised; - Neutropenic; - SCT; - Cystic fibrosis; - TB; - Nosocomial pneumonia; - HIV with CD4 < 200/mm^3^ | Age, years: mean (SD): G1: 62.8 (19.8) G2: 65.3 (17.3) [test, result (p-value, 95% CI)] G1/G2: NSS Men, n (%): G1: 67 (54 %) G2: 61 (51 %) [test, result (p-value, 95% CI)] G1/G2: NSS Current smoker, n, (%): G1: 27 (22 %) G2: 35 (29 %) [test, result (p-value, 95% CI)] G1/G2: NSS Pack- years: mean (SD): G1: 41.4 (25.0) G2: 40.0 (26.0) [test, result (p-value, 95% CI)] G1/G2: NSS Abnormal CXR, n, (%): G1: 48 (39 %) G2: 46 (39 %) [test, result (p-value, 95% CI)] G1/G2: NSS CAP, n, (%): G1: 42 (34 %) G2: 45 (38 %) [test, result (p-value, 95% CI)] G1/G2: NSS AECOPD, n, (%): G1: 29 (23 %) G2: 31 (26 %) [test, result (p-value, 95% CI)] G1/G2: NSS Acute bronchitis, n, (%): G1: 28 (23 %) G2: 31 (26 %) [test, result (p-value, 95% CI)] G1/G2: NSS Asthma attack, n, (%): G1: 10 (8 %) G2: 3 (3 %) [test, result (p-value, 95% CI)] G1/G2: NSS Other, n, (%): G1: 15 (12 %) G2: 9 (8 %) [test, result (p-value, 95% CI)] G1/G2: NSS PCT: mean (SD): G1: 1.6 (7.7) G2: 1.6 (4.2) [test, result (p-value, 95% CI)] G1/G2: NSS | Coronary artery disease, n (%): [test, result (p-value, 95% CI)] G1: 27 (22 %) G2: 32 (27 %) G1/G2: NSS Congestive heart failure, n (%): G1: 11 (9%) G2: 7 (6 %) [test, result (p-value, 95% CI)] G1/G2: NSS Peripheral vascular disease, n (%): G1: 10 (8 %) G2: 9 (8 %) [test, result (p-value, 95% CI)] G1/G2: NSS Cerebrovascular disease, n (%): G1: 4 (3 %) G2: 5 (4 5) [test, result (p-value, 95% CI)] G1/G2: NSS Renal dysfunction, n (%): 22 (18 %) G1: 18 (15 %) G2: [test, result (p-value, 95% CI)] G1/G2: NSS Liver dysfunction, n (%): 6 (5 %) G1: 6 (5 %) G2: [test, result (p-value, 95% CI)] G1/G2: NSS Diabetes mellitus, n (%): G1: 15 (12 %) G2: 17 (14 %) [test, result (p-value, 95% CI)] G1/G2: NSS Initial VAS: [mean (SD), median (range/IQR)] G1: 42.5 (20.4) G2: 43.1 (21.0) [test, result (p-value, 95% CI)] G1/G2: NSS Initial Quality of life: [mean (SD), median (range/IQR)] G1: 41.3 (14.3) G2: 39.3 (13.2) [test, result (p-value, 95% CI)] G1/G2: NSS

Evidence Table 2D Intermediate Outcomes for Christ-Crain et al., 2004^4^

Antibiotic treatment duration | Antibiotic prescription rate, number of courses of antibiotics | Antibiotic classes | Hospital length of stay | ICU admission, length of stay
Days: [mean (SD), median (range/IQR)] G1: 10.9 +/- 3.6 G2: 12.8 +/- 5.5 [test, result (p-value, 95% CI)] G1/G2: p =0.03 Incidence density antibiotic exposure: (rate days exposed per 1,000 patient-days) G1: 332 +/- 433 G2: 661 +/- 398 [test, result (p-value, 95% CI)] G1/G2: p < 0.0001 Antibiotic cost per patient, US $, mean(SD): G1: 96.3 (172.8) G2: 202.5 (250.6) [test, result (p-value, 95% CI)] G1/G2: p < 0.0001 | Any antibiotic use, antibiotic prescription rate (%): G1: 55/124 (44 %) G2: 99/119 (83 %) [test, result (p-value, 95% CI)] G1/G2: p < 0.001 G1-CAP: 38/42 G1-AECOPD: 11/29 G1-Bronchitis: 4/28 G1-Asthma: 0/10 G1-Others: 2/15 G2-CAP: 45/45, p = 0.003 G2-AECOPD: 27/31, p < 0.001 G2-Bronchitis: 16/31, p = 0.003 G2-Asthma: 2/3, p = 0.003 G2-Others: 9/9, p < 0.001 [test, result (p-value, 95% CI)] G1/G2: | NR | Admission rate (%): G1: 101 (81 %) G2: 88 (74 %) [test, result (p-value, 95% CI)] G1/G2: NSS Days: [mean (SD), median (range/IQR)] G1: 10.7 (8.9) G2: 11.2 (10.6) [test, result (p-value, 95% CI)] G1/G2: NSS | ICU admission (%): G1: 5 (4 %) G2: 6 (5 %) [test, result (p-value, 95% CI)] G1/G2: NSS

Evidence Table 3D Morbidity Outcomes for Christ-Crain et al., 2004^4^

Morbidity | Morbidity | Recurrence | Sepsis/SIRS frequency | RTI symptoms, overall health, cure, success
NR | NR | NR | NR | NR

Evidence Table 4D Mortality Outcomes for Christ-Crain et al., 2004^4^

In-hospital mortality | 28-day mortality | Death | Pneumonia-related death | Proportion surviving hospitalization
NR | NR | Proportion (%): G1: 4 (3 %) G2: 4 (3 %) [test, result (p-value, 95% CI)] G1/G2: NSS | NR | NR

Evidence Table 5D Function and Quality of Life Outcomes for Christ-Crain et al., 2004^4^

Days ≤ 14 days of baseline with daily activities restricted by RTI | Days work missed | Visual analog functional scale | Quality of life score
NR | NR | Final VAS: [mean (SD), median (range/IQR)] G1: 65.1 (21.8) G2: 64.1 (21.5) [test, result (p-value, 95% CI)] G1/G2: NSS | Final Quality of life: [mean (SD), median (range/IQR)] G1: 21.9 (14.7) G2: 22.9 (15.1) [test, result (p-value, 95% CI)] G1/G2: NSS

Evidence Table 6D Adverse Effects and Adherence for Christ-Crain et al., 2004^4^

Combined adverse outcome < 30 days | Antibiotic adverse effects, days with adverse effects from medication, antibiotic resistance | Pain, bleeding, local infection | Adherence
NR | NR | NR | NR

Evidence Table 7D Randomized Trial Study Quality Ratings for Christ-Crain et al., 2004^4^

Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results
Y-balanced N/A-concealment | Y | Y | Y | Y | Y | N

Evidence Table 1E Study Description Table for Christ-Crain et al., 2006^5^

Study Description | Study design, interventions, presenting condition, setting, enrollment and follow-up numbers | Primary outcome, procalcitonin assay, decision-making processes, definitions of sepsis and related conditions | Inclusion/exclusion criteria | Participant characteristics | Participant characteristics
Author, year: Christ-Crain et al., 2006. Country, institution type: Switzerland, University Hospital of Basel Enrollment period: November 2003-February 2005 Funding: Brahms, Pfizer, Mepha, University Hospital of Basel Author industry relationship disclosures: 1 author received grants and lecture fees from Brahms, 1 author was on the Brahms advisory board for lecture fees | Design: RCT, 1:1, intent-to-treat Interventions: G1: Procalcitonin guidance G2: Usual practice Presenting condition: CAP admitted to ED, single center Setting: ED 404 with CAP 102 excluded 37 immuno-compromised 3 TB 1 cystic fibrosis 17 HAP 17 no infiltrate 2 death before inclusion 25 no consent N at enrollment: G1: 151 G2: 151 N at follow-up: G1: 131 (20 died) G2: 131 (18 died, 2 LTFU) Average follow-up, days: [mean (SD), median (range/IQR)] G1: NR G2: NR 6 weeks | Primary outcome: Total antibiotic use (prescription) and duration Study powered to detect a 30 % reduction in antibiotic exposure (95 %). This also gave the study a 74 % chance to detect a 10 % increase in failure or complications Secondary outcomes: Laboratory, clinical outcomes Also cost assessment, direct (PCT, antibiotics) Indirect (adverse events, multidrug resistance, etc.) not considered Response criteria, independent outcome assessor: Assay type: Kryptor PCT, Brahms Decision-making: G1: 2 interventions For antibiotic initiation and discontinuation PCT < 0.1 antibiotics strongly discouraged PCT ≥ 0.1, < 0.25, antibiotics discouraged PCT ≥ 0.25, ≤ 0.5, antibiotics encouraged PCT > 0.5, antibiotics strongly encouraged I f baseline > 10, antibiotics discontinued if less than 10 % of initial value G2: Standard therapy | Inclusion criteria:; - > 18 years of age; - CAP principle diagnosis defined by new infiltrate on CXR and one of the following: cough, sputum production, dyspnea, fever > 38° C, abnormal breath sounds, white blood count > 10,000 or < 4,000; Exclusion criteria:; - Cystic fibrosis; - TB; - HAP; - severely immuno-compromised hosts | Age, years: mean (SD) G1: 70 (17) G2: 70 (17) [test, result (p-value, 95% CI)] G1/G2: NSS Men, n (%): G1: 94 (62 %) G2: 93 (62%) [test, result (p-value, 95% CI)] G1/G2: NSS Current smoker, n (%): G1: 34 (23 %) G2: 39 (26 %) [test, result (p-value, 95% CI)] G1/G2: NSS Pack- years: mean (SD) G1: 42 (27) G2: 38 (20) [test, result (p-value, 95% CI)] G1/G2: NSS Fever: [mean (SD) G1: 38.4 (1.1) G2: 38.4 (1.1) [test, result (p-value, 95% CI)] G1/G2: NSS PCT: median (range) G1: 0.57 (0.2-2.5) G2: 0.44 (0.2-1.9) [test, result (p-value, 95% CI)] G1/G2: NSS CRP: median (range) G1: 111 (57-204) G2: 152 (72-212) [test, result (p-value, 95% CI)] G1/G2: NSS WBC count: [mean (SD) G1: 13.7 (6.7) G2: 13.4 (6.6) [test, result (p-value, 95% CI)] G1/G2: NSS QOL score: mean (SD) G1: 40 (13) G2: 39 (13) [test, result (p-value, 95% CI)] G1/G2: NSS VAS, %: mean (SD) G1: 43 (20) G2: 39 (21) [test, result (p-value, 95% CI)] G1/G2: NSS PSI points: mean (SD) G1: 99.7 (36.1) G2: 99.2 (34.5) [test, result (p-value, 95% CI)] G1/G2: NSS PSI class I, II, III, n (%): G1: 54 (36 %) G2: 66 (44 %) [test, result (p-value, 95% CI)] G1/G2: NSS PSI class IV, n (%): G1: 68 (45 %) G2: 62 (41 %) [test, result (p-value, 95% CI)] G1/G2: NSS PSI class V, n (%): G1: 29 (19 %) G2: 23 (15 %) [test, result (p-value, 95% CI)] G1/G2: NSS | Coronary artery diseases, n (%):] G1: 49 (33 %) G2: 48 (32 %) G1/G2: NSS Hypertensive heart failure, n (%): G1: 42 (28 %) G2: 36 (24 %) [test, result (p-value, 95% CI)] G1/G2: NSS Congestive heart failure, n (%): G1: 7 (5 %) G2: 9 (6 %) [test, result (p-value, 95% CI)] G1/G2: NSS Peripheral vascular disease, n (%): G1: 11 (7 %) G2: 9 (6 %) [test, result (p-value, 95% CI)] G1/G2: NSS Cerebrovascular disease, n (%): G1: 8 (5 %) G2: 8 (5 %) [test, result (p-value, 95% CI)] G1/G2: NSS Renal dysfunction, n (%): G1: 36 (24 %) G2: 45 (30 %) [test, result (p-value, 95% CI)] G1/G2: Liver disease, n (%): G1: 12 (8 %) G2: 19 (13 %) [test, result (p-value, 95% CI)] G1/G2: NSS Diabetes mellitus, n (%): G1: 32 (21 %) G2: 29 (19 %) [test, result (p-value, 95% CI)] G1/G2: NSS COPD, n (%): G1: 44 (29 %) G2: 32 (21 %) [test, result (p-value, 95% CI)] G1/G2: NSS Cancer, n (%): G1: 25 (17 %) G2: 23 (15 %) [test, result (p-value, 95% CI)] G1/G2: NSS

Evidence Table 2E Intermediate Outcomes for Christ-Crain et al., 2006^5^

Antibiotic treatment duration | Antibiotic prescription rate, number of courses of antibiotics | Antibiotic classes | Hospital length of stay | ICU admission, length of stay
Days: [mean (SD), median (range/IQR)] G1: 5.8 (5.3) G2: 12.9 (6.5) [test, result (p-value, 95% CI)] G1/G2: p < 0.001 Days, if prescribed: [mean (SD), median (range/IQR)] G1: 6.8 (5.1) G2: 13.1 (6.4) [test, result (p-value, 95% CI)] G1/G2: p < 0.001 Days if bacteremic: [mean (SD), median (range/IQR)] G1: 13.0 (8.9) G2: 13.9 (4.9) [test, result (p-value, 95% CI)] G1/G2: NSS Incidence density antibiotic exposure: (rate days exposed per 1,000 patient-days) G1: 136 (95% CI 126 to 146) G2: 323 (95% CI 309 to 338) [test, result (p-value, 95% CI)] G1/G2: p < 0.001 Antibiotic cost, US $: G1: 29,248 G2: 59,535 [test, result (p-value, 95% CI)] G1/G2: p < 0.001 Antibiotic cost per patient, US $: G1: 100 (33-186) G2: 190 (133-337) [test, result (p-value, 95% CI)] G1/G2: p < 0.001 | Any antibiotic use, antibiotic prescription rate (%): G1: 128 (85 %) G2: 149 (99 %) [test, result (p-value, 95% CI)] G1/G2: p < 0.001 | NR | Hospitalization (%): G1: 146 (97 %) G2: 146 (97 %) [test, result (p-value, 95% CI)] G1/G2: NSS Days: [mean (SD), median (range/IQR)] G1: 12.0 (9.1) G2: 13.0 (9.0) [test, result (p-value, 95% CI)] G1/G2: NSS | ICU admission (%): G1: 20 (13 %) G2: 21 (14 %) [test, result (p-value, 95% CI)] G1/G2: NSS

Evidence Table 3E Morbidity Outcomes for Christ-Crain et al., 2006^5^

Morbidity | Morbidity | Recurrence | Sepsis/SIRS frequency | RTI symptoms, overall health, cure, success
NR | NR | Microbiological recurrence of infection (%): G1: 1 (1 %) G2: 0 [test, result (p-value, 95% CI)] G1/G2: NSS Clinical/radiological recurrence (%): G1: 4 (3 %) G2: 4 (3 %) [test, result (p-value, 95% CI)] G1/G2: Persistent of pneumonia: G1: 1 (1 %) G2: 3 (2 %) [test, result (p-value, 95% CI)] G1/G2: NSS Empyema, n (%): G1: 4 (3 %) G2: 7 (5 %) [test, result (p-value, 95% CI)] G1/G2: NSS ARDS, n (%): G1: 1 (1 %) G2: 1 (1 %) [test, result (p-value, 95% CI)] G1/G2: NSS | NR | Success at follow-up, n, (%): G1: 127/151 (84 %) G2: 124/151 (82 %) [test, result (p-value, 95% CI)] G1/G2: NSS Clinical cure, n, (%): G1: 108/127 (85 %) G2: 105/124 (85 %) [test, result (p-value, 95% CI)] G1/G2: NSS Improved, n, (%): G1: 19/127 (15 %) G2: 19/124 (15 %) [test, result (p-value, 95% CI)] G1/G2: NSS

Evidence Table 4E Mortality Outcomes for Christ-Crain et al., 2006^5^

In-hospital mortality | 28-day mortality | Death | Pneumonia-related death | Proportion surviving hospitalization
NR | NR | Proportion (%): G1: 18 (12 %) G2: 20 (13 %) [test, result (p-value, 95% CI)] G1/G2: NSS | Proportion (%): G1: 10 (56 %) G2: 10 (50 %) [test, result (p-value, 95% CI)] G1/G2: NSS | NR

Evidence Table 5E Function and Quality of Life Outcomes for Christ-Crain et al., 2006^5^

Days ≤ 14 days of baseline with daily activities restricted by RTI | Days work missed | Visual analog functional scale | Quality of life score
NR | NR | Function: [mean (SD), median (range/IQR)] G1: 79 (18) G2: 74 (20) [test, result (p-value, 95% CI)] G1/G2: NSS | Quality of life: [mean (SD) G1: 10 (10) G2: 11 (10) [test, result (p-value, 95% CI)] G1/G2: NSS

Evidence Table 6E Adverse Effects and Adherence for Christ-Crain et al., 2006^5^

Combined adverse outcome < 30 days | Antibiotic adverse effects, days with adverse effects from medication, antibiotic resistance | Pain, bleeding, local infection | Adherence
NR | NR | NR | NR

Evidence Table 7E Randomized Trial Study Quality Ratings for Christ-Crain et al., 2006^5^

Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results
Y- balanced Y-concealment | Y | Y | Y | Y | Y | Y

Evidence Table 1F Study Description Table for Chromik et al., 2005^6^

Study Description | Study design, interventions, presenting condition, setting, enrollment and follow-up numbers | Primary outcome, procalcitonin assay, decision-making processes, definitions of sepsis and related conditions | Inclusion/exclusion criteria | Participant characteristics | Participant characteristics
Author, year: Chromik et al., 2005. Country, institution type: Germany, University Hospital of Wurzburg Enrollment period: Not given Funding: Not given Author industry relationship disclosures: Not given | Design: RCT, 1:1, single arm with respect to PCT Interventions: G1: Preemptive treatment G2: Standard treatment Presenting condition: 250 consecutive colorectal surgery patients Setting: Inpatient hospital, surgical service N at enrollment: G1: 10 G2: 10 N at follow-up: G1: 10 G2: 10 | Primary outcome: Post-op complications; local wound or systemic infection Secondary outcomes: Mortality for post-op infections, complications, fever, WBC, duration of antibiotics, LOS No power calculation Response criteria, independent outcome assessor: Assay type: Kryptor, Brahms Decision-making: G1: PCT-guided pre-emptive antibiotics If PCT > 1.5 post-op, randomized 1 :1 to receive Ceftriaxone or placebo G2: No pre-emptive antibiotics, patients followed for signs of post-op infections Condition = definition: Colorectal surgery | Inclusion criteria:; - Elective colonic surgery; - Written consent; - Peri-operative antibiotic prophylaxis for < 24 hours; - PCT < 1.0 pre-op; - PCT > 1.5 post-op; - Age > 18 years; Exclusion criteria:; - > 24 hours of peri-operative antibiotic prophylaxis; - SZ; - pregnancy or lactation; - cephalosporin allergy; - renal failure; - HIV; - immune deficiency; - investigational treatment within last 30 days; - current cytostatic immunosuppressive medications | Age, years: [mean (SD), median (range/IQR)] G1: 62 (38-82) G2: 70 (62-89) [test, result (p-value, 95% CI)] G1/G2: | NR

Evidence Table 2F Intermediate Outcomes for Chromik et al., 2005^6^

Antibiotic treatment duration | Antibiotic prescription rate, number of courses of antibiotics | Antibiotic classes | Hospital length of stay | ICU admission, length of stay
Days: median (range): G1: 5.5 (4-20) G2: 9 (3-16) [test, result (p-value, 95% CI)] G1/G2: NSS | NR | NR | Days: median (range): G1: 18 (10-49) G2: 30 (9-82) [test, result (p-value, 95% CI)] G1/G2: NSS | NR

Evidence Table 3F Morbidity Outcomes for Chromik et al., 2005^6^

Morbidity | Morbidity | Recurrence | Sepsis/SIRS frequency | RTI symptoms, overall health, cure, success
NR | Wound infection (%): G1: 1/10 G2: 2/10 [test, result (p-value, 95% CI)] G1/G2: G1 + G2: 3/20 (15 %) G3: 16/230 (7.0 %) No antibiotics or further surgery Systemic infection (%): G1: 3/10 G2: 8/10 [test, result (p-value, 95% CI)] G1/G2: p = 0.001 G1 + G2: 11/20 (55 %) G3: 4/230 (1.7 %) No antibiotics or further surgery NPV for wound 93 % 98.3 % for systemic infection Multiple systemic infections (%): G1: 0/3 G2: 1/7 [test, result (p-value, 95% CI)] G1/G2: | NR | SIRS (C1), sepsis (C2), severe sepsis (C3), septic shock (C4), (%) G1-C1 1 G1-C2 0 G1-C3 1 G1-C4 0 G2-C1 1 G2-C2 4 G2-C3 2 G2-C4 1 Total G1: 2 Total G2: 8 [test, result (p-value, 95% CI)] G1/G2: p = 0.007 for total Requiring pressors (%): G1: 1 G2: 6 [test, result (p-value, 95% CI)] G1/G2: p = 0.019 | NR

Evidence Table 4F Mortality Outcomes for Chromik et al., 2005^6^

In-hospital mortality | 28-day mortality | Death | Pneumonia-related death | Proportion surviving hospitalization
Proportion (%): G1: 1/10 (10 %) G2: 3/10 (30 %) [test, result (p-value, 95% CI)] G1/G2: | NR | NR | NR | NR

Evidence Table 5F Function and Quality of Life Outcomes for Chromik et al., 2005^6^

Days ≤ 14 days of baseline with daily activities restricted by RTI | Days work missed | Visual analog functional scale | Quality of life score
NR | NR | NR | NR

Evidence Table 6F Adverse Effects and Adherence for Chromik et al., 2005^6^

Combined adverse outcome < 30 days | Antibiotic adverse effects, days with adverse effects from medication, antibiotic resistance | Pain, bleeding, local infection | Adherence
NR | NR | NR | NR

Evidence Table 7F Randomized Trial Study Quality Ratings for Chromik et al., 2005^6^

Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results
Y | Y | Y | Y | Y | Y | Y

Evidence Table 1G Study Description Table for Hochreiter et al., 2009^7^

Study Description | Study design, interventions, presenting condition, setting, enrollment and follow-up numbers | Primary outcome, procalcitonin assay, decision-making processes, definitions of sepsis and related conditions | Inclusion/exclusion criteria | Participant characteristics | Participant characteristics
Author, year: Hochreiter et al., 2009. Country, institution type: Germany, University affiliate Enrollment period: January 2006-March 2007 Funding: Not listed Author industry relationship disclosures: 1 author speaker's bureau, no other conflicts | Design: RCT, 1:1 randomization Interventions: G1: PCT-guided antibiotics therapy G2: Standard therapy Presenting condition: Proven or suspected post-op bacterial infection Setting: ICU N at enrollment: G1: 57 G2: 53 N at follow-up: G1: 57 G2: 53 Average follow-up, days: [mean (SD), median (range/IQR)] G1: NR G2: NR | Primary outcome: Response criteria, independent outcome assessor: No outcomes specified, no power calculation Assay type: Kryptor, Brahms Also CRP, IL-6, WBC Decision-making: G1: PCT Algorithm PCT < 1.0 and clinical signs resolved, stop antibiotics; PCT > 1.0 but dropped to 25-35 % of initial value over 3 days; stop antibiotics G2: Antibiotics standard regimen for 8 days Condition = definition: | Inclusion criteria:; - Proven or suspected bacterial infections needing antibiotics + 2 SIRS criteria; Exclusion criteria:; - Refused consent; - Antibiotics initiated before ICU admission | Age, years: Mean (SD) G1: 67.3 (14.4) G2: 66.6 (15.5) [test, result (p-value, 95% CI)] G1/G2: NSS Disease, n, (%): Pneumonia G1: 24/57 G2: 19/53 [test, result (p-value, 95% CI)] G1/G2: NSS Pneumonia G1: 24/57 G2: 19/53 [test, result (p-value, 95% CI)] G1/G2: NSS Peritonitis G1: 29/57 G2: 30/53 [test, result (p-value, 95% CI)] G1/G2: NSS Skin, soft tissue infection G1: 2/57 G2: 1/53 [test, result (p-value, 95% CI)] G1/G2: NSS UTI G1: 2/57 G2: 3/53 [test, result (p-value, 95% CI)] G1/G2: NSS | SAPS II, Mean (SD): [test, result (p-value, 95% CI)] G1: 40.1 ± 17.1 G2: 40.5 ± 15.1 G1/G2: NSS

Evidence Table 2G Intermediate Outcomes for Hochreiter et al., 2009^7^

Antibiotic treatment duration | Antibiotic prescription rate, number of courses of antibiotics | Antibiotic classes | Hospital length of stay | ICU admission, length of stay
Days: [mean (SD), median (range/IQR)] G1: 5.9 (1.7) G2: 7.9 (0.5) [test, result (p-value, 95% CI)] G1/G2: p < 0.001 | NR | No differences in antibiotics used | NR | ICU LOS, days, Mean (SD): G1: 15.5 (12.5) G2: 17.7 (10.1) [test, result (p-value, 95% CI)] G1/G2: p = 0.046

Evidence Table 3G Morbidity Outcomes for Hochreiter et al., 2009^7^

Morbidity | Morbidity | Recurrence | Sepsis/SIRS frequency | RTI symptoms, overall health, cure, success
NR | NR | NR | NR | NR

Evidence Table 4G Mortality Outcomes for Hochreiter et al., 2009^7^

In-hospital mortality | 28-day mortality | Death | Pneumonia-related death | Proportion surviving hospitalization
NR | NR | Proportion, (%): G1: 15/57 G2: 14/53 [test, result (p-value, 95% CI)] G1/G2: NSS | NR | NR

Evidence Table 5G Function and Quality of Life Outcomes for Hochreiter et al., 2009^7^

Days ≤ 14 days of baseline with daily activities restricted by RTI | Days work missed | Visual analog functional scale | Quality of life score
NR | NR | NR | NR

Evidence Table 6G Adverse Effects and Adherence for Hochreiter et al., 2009

Combined adverse outcome < 30 days | Antibiotic adverse effects, days with adverse effects from medication, antibiotic resistance | Pain, bleeding, local infection | Adherence
NR | NR | NR | NR

Evidence Table 7G Randomized Trial Study Quality Ratings for Hochreiter et al., 2009^7^

Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results
Y^*^ | Y | Y | Y | Y | Y | Y

* No details on allocation concealment but groups were comparable

Evidence Table 1H Study Description Table for Jensen et al., 2011^8^

Study Description | Study design, interventions, presenting condition, setting, enrollment and follow-up numbers | Primary outcome, procalcitonin assay, decision-making processes, definitions of sepsis and related conditions | Inclusion/exclusion criteria | Participant characteristics | Participant characteristics
Author, year: Jensen et al., 2011. Country, institution type: Denmark, Tertiary Care Public University Hospital Enrollment period: 2006-2009 Funding: Danish State, Lundbeck Foundation, Toyota Foundation, H.P. Moller Foundation, Hurbec Foundation, and Capitol Region of Denmark Author industry relationship disclosures: One author disclosed speaking and travel reimbursement from Brahms | Design: RCT; Open label Interventions: G1: expanded diagnostic radiology and expanded spectrum of antibiotic therapy for “alert procalcitonin”; de-escalation only after PCT < 1.0 for 3 days G2: Standard microbiologic sampling, radiology, and antibiotic therapy Presenting condition: Critically ill in ICU Setting: ICUs N at enrollment: G1: 604 G2: 596 N at follow-up: G1: 604 G2: 596 Average follow-up, days: [mean (SD), median (range/IQR)] G1: 28 days G2: 28 days | Primary outcome: 28 day mortality Secondary outcomes: Shorter ICU LOS; shorter duration of organ failure Response criteria, independent outcome assessor: Investigators, treating physicians, and coordinator were unaware of outcomes as well as procalcitonin measurements in the control group Assay type: Brahms Kryptor-PCT Decision-making: G1: Intervention algorithm based on “alert procalcitonin” (≥ 1.0 ng/mL that was not decreasing by at least 10 % from the previous day). At baseline a single measurement of > 1.0 ng/ml was also considered alert procalcitonin; G2: Standard of care algorithm | Inclusion criteria:; - ≥ 18 years of age; - Enrolled within 24 hours of admission to ICU; - Expected ICU stay ≥ 24 hours; Exclusion criteria:; - High bilirubin (> 40 mg/dL) or; - High triglycerides (> 1,000 mg/dL); - Patients judged to be at an increased risk from blood sampling | Age, years: median (range/IQR)] G1: 67 (58-76) G2: 67 (58-75) [test, result (p-value, 95% CI)] G1/G2: Women, n (%): G1: 274 (45.4 %) G2: 263 (44.1 %) [test, result (p-value, 95% CI)] G1/G2: NSS APACHE Score: median (range/IQR)] G1: 18 (13-25) G2: 18 (13-24) [test, result (p-value, 95% CI)] G1/G2: NSS Infection, Clinical Assessment No infection, n, (%): G1: 86 (14.2 %) G2: 118 (19.8 %) G1/G2: NSS Infection, n, (%): G1: 271 (44.9 %) G2: 266 (44.6 %) G1/G2: NSS Severe sepsis, septic shock, n, (%): G1: 247 (40.9 %) G2: 212 (35.6 %) G1/G2: NSS | Surgical patient, n (%): [test, result (p-value, 95% CI)] G1: 227 (37.6 %) G2: 260 (43.6 %) G1/G2: NSS 1 chronic co-morbidity, n (%): G1: 257 (42.6 %) G2: 279 (46.8 %) [test, result (p-value, 95% CI)] G1/G2: NSS 2 chronic co-morbidities, n (%): G1: 171 (28.3 %) G2: 173 (29.0 %) [test, result (p-value, 95% CI)] G1/G2: NSS 3 chronic co-morbidities, n (%) Congestive heart failure, n (%): G1: 53 (8.8 %) G2: 42 (7.1 %) [test, result (p-value, 95% CI)] G1/G2: NSS

Evidence Table 2H Intermediate Outcomes for Jensen et al., 2011^8^

Antibiotic treatment duration | Antibiotic prescription rate, number of courses of antibiotics | Antibiotic classes | Hospital length of stay | ICU admission, length of stay
Days: median (range/IQR)] G1: 6 (3-11) G2: 4 (3-10) [test, result (p-value, 95% CI)] G1/G2: Days spent in ICU with ≥ 3 antibiotics, n (%): G1: 3570 (65.5 %) G2: 2721 (57.7 %) G1/G2: 7.8, p = 0.002 | NR | NR | NR | Days: median (range/IQR)] G1: 6 (3-12) G2: 5 (3-11) [test, result (p-value, 95% CI)] G1/G2: p = 0.004

Evidence Table 3H Morbidity Outcomes Jensen et al., 2011^8^

Morbidity | Morbidity | Recurrence | Sepsis/SIRS frequency | RTI symptoms, overall health, cure, success
NR | ICU days on mechanical ventilation: [mean (SD), median (range/IQR)] G1: 3569 (65.5 %) G2: 2861 (60.7 %) [test, result (p-value, 95% CI)] G1/G2: 4.9 (3.0 to 6.7) ICU days with GFR < 60 mL/1.73 ml) on mechanical ventilation: [mean (SD), median (range/IQR)] G1: 2796 (51.3 %) G2: 2187 (46.4 %) [test, result (p-value, 95% CI)] G1/G2: 5.0 (3.0 to 6.9) | NR | NR | NR

Evidence Table 4H Mortality Outcomes for Jensen et al., 2011^8^

In-hospital mortality | 28-day mortality | Death | Pneumonia-related death | Proportion surviving hospitalization
NR | Proportion (%): G1: 190/604 (31.5 %) G2: 191/596 (32.0 %) [test, result (p-value, 95% CI)] G1/G2: -0.6 % (-4.7 to 5.9 %) | NR | NR | NR

Evidence Table 5A Function and Quality of Life Outcomes for Jensen et al., 2011^8^

Days ≤ 14 days of baseline with daily activities restricted by RTI | Days work missed | Visual analog functional scale | Quality of life score
NR | NR | NR | NR

Evidence Table 6H Adverse Effects and Adherence for Jensen et al., 2011^8^

Combined adverse outcome < 30 days | Antibiotic adverse effects, days with adverse effects from medication, antibiotic resistance | Pain, bleeding, local infection | Adherence
NR | NR | NR | Proportion of patients with baseline PCT alert who received antibiotics (G1) (%): G1: 256/312 (82.1 %) Proportion of patients at baseline who were judged to have severe sepsis or septic shock and who received antibiotics (G2) G2: 172/209 (82.4 %) [test, result (p-value, 95% CI)] G1/G2: | NR

Evidence Table 7H Randomized Trial Study Quality Ratings for Jensen et al., 2011^8^

Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results
Y | Y | Y | Y | Y | Y | Y

Evidence Table 1I Study Description Table for Kristoffersen et al., 2009^9^

Study Description | Study design, interventions, presenting condition, setting, enrollment and follow-up numbers | Primary outcome, procalcitonin assay, decision-making processes, definitions of sepsis and related conditions | Inclusion/exclusion criteria | Participant characteristics | Participant characteristics
Author, year: Kristoffersen et al., 2009. Country, institution type: Denmark Enrollment period: June 1, 2006 to April 30, 2007 Funding: Danish Medical Research Council, Danish Lung Association Author industry relationship disclosures: No conflicts | Design: RCT, multi-center Interventions: G1: Procalcitonin-guided treatment G2: Standard treatment Presenting condition: Hospitalized patients with LRTI, suspicion of pneumonia based on history (cough, sputum, dyspnea, and fever > 38o C) and physical (no CXR requirement) Setting: 223 enrolled 210 analyzed N at enrollment: G1: 103 G2: 107 N at follow-up: G1: 103 G2: 107 Average follow-up, days: [mean (SD), median (range/IQR)] G1: NR G2: NR | Primary outcome: Primary-intent to treat analysis Antibiotics use (days of antibiotics during hospitalization) LOS hospital Secondary outcome: Proportion of patients for whom physicians disregarded treatment guidelines 90 % power to detect a 20 % decrease in antibiotic exposure Response criteria, independent outcome assessor: Assay type: Kryptor, Brahms Decision-making: G1: PCT guided continuation or cessation of antibiotics If PCT < 0.25 ng/mL, antibiotics should be discouraged PCT 0.25-5.0, antibiotic encouraged PCT > 0.5, antibiotic strongly encouraged G2: | Inclusion criteria:; - ≥ 18 years of age; - Suspected pneumonia; - One or more symptoms of cough, expectoration, dsypnea, fever > 38° C; Exclusion criteria: • | Age, years: [mean (SD), median (range/IQR)] G1: 67.2 (17.6) G2: 67 (15.6) [test, result (p-value, 95% CI)] G1/G2: NSS Men, n (%): G1: 54 (52 %) G2: 58 (54 %) [test, result (p-value, 95% CI)] G1/G2: NSS Current/former smoker, n (%): G1: 68 (66 %) G2: 82 (77 %) [test, result (p-value, 95% CI)] G1/G2: NSS Antibiotics pre-treatment, n (%): G1: 48 (47 %) G2: 46 (43 %) [test, result (p-value, 95% CI)] G1/G2: NSS PSI, mean (SD): G1: 79.2 (27.8) G2: 75.8 (24.3) [test, result (p-value, 95% CI)] G1/G2: NSS PSI, I-III, n (%): G1: 65 (63 %) G2: 78 (73%) [test, result (p-value, 95% CI)] G1/G2: NSS PSI, IV, n (%): G1: 35 (34 %) G2: 27 (25 %) [test, result (p-value, 95% CI)] G1/G2: NSS PSI, V, n (%): G1: 3 (3 %) G2: 2 (2 %) [test, result (p-value, 95% CI)] G1/G2: NSS Abnormal CXR, n (%): G1: 40 (39 %) G2: 43 (40 %) [test, result (p-value, 95% CI)] G1/G2: NSS WBC, mean (SD): G1: 13.2 (7.5) G2: 12.1 (5.9) [test, result (p-value, 95% CI)] G1/G2: NSS CRP, mean (SD): G1: 1091 (1080) G2: 971 (1000) [test, result (p-value, 95% CI)] G1/G2: NSS PCT, median (range): G1: 0.14 (0.05-42.13) G2: 0.13 (0.02-30.12) [test, result (p-value, 95% CI)] G1/G2: NSS | Diabetes mellitus, n (%): G1: 13 (13 %) G2: 11 (10 %) [test, result (p-value, 95% CI)] G1/G2: NSS Cancer, n (%): G1: 7 (7 %) G2: 0 [test, result (p-value, 95% CI)] G1/G2: Congestive heart failure, n (%): G1: 15 (15 %) G2: 14 (13 %) [test, result (p-value, 95% CI)] G1/G2: NSS Cerebrovascular disease, n (%): G1: 4 (4 %) G2: 4 (4 %) [test, result (p-value, 95% CI)] G1/G2: NSS COPD, n (%): G1: 38 (37 %) G2: 51 (48 %) [test, result (p-value, 95% CI)] G1/G2: NSS Final Diagnosis CAP, n (%): G1: 47 (46 %) G2: 50 (47 %) [test, result (p-value, 95% CI)] G1/G2: NSS AECOPD, n (%): G1: 28 (37 %) G2: 32 (30 %) [test, result (p-value, 95% CI)] G1/G2: NSS Acute bronchitis, n (%): G1: 3 (3 %) G2: 5 (5 %) [test, result (p-value, 95% CI)] G1/G2: NSS Acute asthma, n (%): G1: 2 (2 %) G2: 3 (3 %) [test, result (p-value, 95% CI)] G1/G2: NSS Viral infection, n (%): G1: 2 (2 %) G2: 2 (2 %) [test, result (p-value, 95% CI)] G1/G2: NSS Other, n (%): G1: 21 (20 %) G2: 15 (14 %) [test, result (p-value, 95% CI)] G1/G2: NSS

Evidence Table 2I Intermediate Outcomes for Kristoffersen et al., 2009^9^

Antibiotic treatment duration | Antibiotic prescription rate, number of courses of antibiotics | Antibiotic classes | Hospital length of stay | ICU admission, length of stay
Days: [mean (SD), median (range/IQR)] G1: 5.1 (95 % CI 4.4-6.0) G2: 6.8 (95 % CI 5.9-7.7) [test, result (p-value, 95% CI)] G1/G2: p = 0.007 In 42/103 patients (41 %), treatment guidelines were ignored 47 % due to clinical presentation, 41 % due to late report 1.6 days to get report | Any antibiotic use, antibiotic prescription rate (%): G1: 88 (85 %) G2: 85 (79 %) [test, result (p-value, 95% CI)] G1/G2: NSS | NR | Days: [mean (SD), median (range/IQR)] G1: 5.9 (95 % CI 5.1-6.9) G2: 6.7 (95 % CI 5.9-7.7) [test, result (p-value, 95% CI)] G1/G2: NSS | ICU admission (%): G1: 7 (7 %) G2: 5 (5 %) [test, result (p-value, 95% CI)] G1/G2: NSS

Evidence Table 3I Morbidity Outcomes for Kristoffersen et al., 2009^9^

Morbidity | Morbidity | Recurrence | Sepsis/SIRS frequency | RTI symptoms, overall health, cure, success
NR | NR | NR | NR | NR

Evidence Table 4I Mortality Outcomes for Kristoffersen et al., 2009^9^

In-hospital mortality | 28-day mortality | Death | Pneumonia-related death | Proportion surviving hospitalization
Proportion (%): G1: 2 (2 %) G2: 1 (1 %) [test, result (p-value, 95% CI)] G1/G2: NSS | NR | NR | NR | NR

Evidence Table 5I Function and Quality of Life Outcomes for Kristoffersen et al., 2009^9^

Days ≤ 14 days of baseline with daily activities restricted by RTI | Days work missed | Visual analog functional scale | Quality of life score
NR | NR | NR | NR

Evidence Table 6I Adverse Effects and Adherence for Kristoffersen et al., 2009^9^

Combined adverse outcome < 30 days | Antibiotic adverse effects, days with adverse effects from medication, antibiotic resistance | Pain, bleeding, local infection | Adherence
NR | NR | NR | NR

Evidence Table 7I Randomized Trial Study Quality Ratings for Kristoffersen et al., 2009^9^

Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results
Y- balanced Y-concealment | Y | Y | Y | Y | Y | N

Evidence Table 1J Study Description Table for Long et al., 2011^10^

Study Description | Study design, interventions, presenting condition, setting, enrollment and follow-up numbers | Primary outcome, procalcitonin assay, decision-making processes, definitions of sepsis and related conditions | Inclusion/exclusion criteria | Participant characteristics | Participant characteristics
Author, year: Long et al., 2011. Country, institution type: Shanghai China, University hospital Enrollment period: February 2005 – December 2008 Funding: Grant Shanghai Fifth People's Hospital Science Foundation Author industry relationship disclosures: Not stated | Design: RCT, intention to treat Interventions: G1: PCT-guided antibiotic therapy G2: standard antimicrobial therapy Presenting condition: Suspected CAP outpatient Setting: ER 287 screened 172 enrolled N at enrollment: G1: 86 G2: 86 N at follow-up: G1: 77 4 lost to follow-up 4 withdrew 1 lung CA G2: 79 2 lost to follow-up 3 withdrew 2 TB Average follow-up, days: 28 day follow-up | Primary outcome: Total antibiotic use and duration of antibiotic treatment, antibiotic prescription rate Secondary outcomes: Treatment failure, treatment success, death, recurrence, relapse, patients lost to follow-up Response criteria, independent outcome assessor: Assay type: Kryptor-Brahms Decision-making: G1: PCT< 0.1 μg/L strongly discourage antibiotic use PCT 0.1-0.25 μg/L antibiotics discouraged PCT >0.25 antibiotics encouraged G2: Standard PCT levels tested at 6-12 hours then 3,6 and 8 days antibiotics were discontinued based on previous defined values | Inclusion criteria:; - > 18 years of age; - PSI class I-III; Exclusion criteria:; - Age 65 or older; - pregnancy; - Antibiotic 48-hour before enrollment; - systemic immune deficiency; - Withholding life-support; - Active TB | Age, years: [mean (SD), median (range/IQR)] G1: 44 +/- 16 G2: 47 +/- 19 [test, result (p-value, 95% CI)] G1/G2: Males, n (%): G1: 46 (59.7) G2: 49 (62.0) [test, result (p-value, 95% CI)] G1/G2: | Current Smokers, n (%): [test, result (p-value, 95% CI)] G1: 34 (44.2) G2: 33 (41.8) G1/G2: PSI class I-III n (%): I G1: 22 (28.6) I G2: 24 (30.4) II G1: 38 (49.3) II G2: 39 (49.4) III G1: 17 (22.1) III G2: 16 (20.2) [test, result (p-value, 95% CI)] G1/G2: Former Smokers, n (%): G1: 41 (53.2) G2: 45 (56.9) [test, result (p-value, 95% CI)] G1/G2: Body temperature n : [mean (SD), median (range/IQR)]: G1: 38.6 +/- 1.3 G2: 38.4 +/- 1.2 [test, result (p-value, 95% CI)] G1/G2: PCT n : [mean (SD), median (range/IQR)]: G1: 0.39 (0.26-1.12) G2: 0.42 (0.28-1.19) [test, result (p-value, 95% CI)]

Evidence Table 2J Intermediate Outcomes for Long et al., 2011^10^

Antibiotic treatment duration | Antibiotic prescription rate, number of courses of antibiotics | Antibiotic classes | Hospital length of stay | ICU admission, length of stay
Per protocol analysis median duration of therapy: Days: [mean (SD), median (range/IQR)] G1: 5 (3-6) G2: 7 (5-9) [test, result (p-value, 95% CI)] G1/G2: p<0.001 | Antibiotic use on initial assessment, antibiotic prescription rate (%): G1: 84.4% G2: 97.5% [test, result (p-value, 95% CI)] G1/G2: p=0.0004 Total rate antibiotics exposure decreased in G1 RR 0.55 95% CI: 0.51-0.60 p=0.003 | NR | NR | NR

Evidence Table 3J Morbidity Outcomes for Long et al., 2011^10^

Morbidity | Morbidity | Recurrence | Sepsis/SIRS frequency | RTI symptoms, overall health, cure, success
All patient survived | NR | NR | NR | Clinical success (%): ITT analysis G1: 69 (85.2) G2: 72 (88.9) [test, result (p-value, 95% CI)] G1/G2: absolute difference -3.7 (14.1-6.7)

Evidence Table 4J Mortality Outcomes for Long et al., 2011^10^

In-hospital mortality | 28-day mortality | Death | Pneumonia-related death | Proportion surviving hospitalization
NR | NR | NR | NR | NR

Evidence Table 5J Function and Quality of Life Outcomes for Long et al., 2011^10^

Days ≤ 14 days of baseline with daily activities restricted by RTI | Days work missed | Visual analog functional scale | Quality of life score
NR | NR | NR | NR

Evidence Table 6J Adverse Effects and Adherence for Long et al., 2011^10^

Combined adverse outcome < 30 days | Antibiotic adverse effects, days with adverse effects from medication, antibiotic resistance | Pain, bleeding, local infection | Adherence
NR | NR | NR | NR

Evidence Table 7J Randomized Trial Study Quality Ratings for Long et al., 2011^10^

Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results
Y- balanced U-concealment | Y | Y | Y | Y | Y | N

Evidence Table 1K Study Description Table for Manzano et al., 2010^11^

Study Description | Study design, interventions, presenting condition, setting, enrollment and follow-up numbers | Primary outcome, procalcitonin assay, decision-making processes, definitions of sepsis and related conditions | Inclusion/exclusion criteria | Participant characteristics | Participant characteristics
Author, year: Manzano et al., 2010. Country, institution type: Canada, CHU Ste-Justine, Montreal, Tertiary care center Enrollment period: Not given Funding: PCT-Q supplied by Brahms Author industry relationship disclosures: None disclosed | Design: RCT, 1:1 block randomization Interventions: G1: PCT result available, no recommendations PCT < 0.5, low risk of bacterial infection; PCT >/= 0.5 moderate risk; PCT >/= 2.0 high risk G2: Blinded to PCT result Presenting condition: Fever Setting: Pediatric ED N at enrollment: G1: 220 G2: 220 N at follow-up: G1: 192 G2: 192 Insufficient blood for 28 in each group | Primary outcome: Antibiotic prescription rate 80 % power to detect a difference in rate of Antibiotic prescriptions Needed 335-419 Secondary outcomes Hospitalization rate Additional studies, i.e., CXR, lumbar puncture; prescription rates without excluding patients treated for a bacterial infection Response criteria, independent outcome assessor: Assay type: PCT-Q, Brahms Decision-making: G1: PCT result revealed to treating physician G2: PCT result not revealed to treating physician | Inclusion criteria:; - Age 1-36 months; - T > 38°; - No identified source of infection; Exclusion criteria:; - Congenital immune deficiencies; - Known bacterial infection; - ANC < 500; - Children already treated with antibiotics | Age, years: [mean (SD), median (range/IQR)] G1: 12 +/- 8 mos G2: 12 +/- 8 mos [test, result (p-value, 95% CI)] G1/G2: NSS Triage level (5), n (%): G1-1: 0 (0) G1-2: 26 (14) G1-3: 77 (40) G1-4: 88 (46) G1-5: 1 (1) G2-1: 0 (0) G2-2: 34 (18) G2-3: 74 (39) G2-4: 83 (43) G2-5: 1 (1) [test, result (p-value, 95% CI)] G1/G2: NSS Tmax: [mean (SD), median (range/IQR)] G1: 39.6 +/- 0.7 G2: 39.6 +/- 0.6 [test, result (p-value, 95% CI)] G1/G2: NSS Fever duration, hours: [mean (SD), median (range/IQR)] G1: 62 +/-48 G2: 64 +/- 50 [test, result (p-value, 95% CI)] G1/G2: NSS VAS for serious bacterial infection, %: median (range/IQR)] G1: 19 (12-29) G2: 19 (11-31) [test, result (p-value, 95% CI)] G1/G2: NSS | NR

Evidence Table 2K Intermediate Outcomes for Manzano et al., 2010^11^

Antibiotic treatment duration | Antibiotic prescription rate, number of courses of antibiotics | Antibiotic classes | Hospital length of stay | ICU admission, length of stay
NR | All children Any antibiotic use, antibiotic prescription rate (%): G1: 48/192 (25) G2: 54/192 (28) [test, result (p-value, 95% CI)] G1/G2: -3 (-12 to 6) Children without SBI or neutropenia Any antibiotic use, antibiotic prescription rate (%): G1: 14/158 (9) G2: 16/154 (10) [test, result (p-value, 95% CI)] G1/G2: -2 (-8 to 5) | NR | All children Hospitalization rate, n (%): G1: 50/192 (26) G2: 48/192 (25) [test, result (p-value, 95% CI)] G1/G2: 1 (-8 to 10) Children without SBI or neutropenia Hospitalization rate, n (%): G1: 16/158 (10) G2: 11/154 (7) [test, result (p-value, 95% CI)] G1/G2: 3 (-3 to 10) | NR

Evidence Table 3K Morbidity Outcomes for Manzano et al., 2010^11^

Morbidity | Morbidity | Recurrence | Sepsis/SIRS frequency | RTI symptoms, overall health, cure, success
NR | NR | NR | NR | NR

Evidence Table 4K Mortality Outcomes for Manzano et al., 2010^11^

In-hospital mortality | 28-day mortality | Death | Pneumonia-related death | Proportion surviving hospitalization
NR | NR | NR | NR | NR

Evidence Table 5K Function and Quality of Life Outcomes for Manzano et al., 2010^11^

Days ≤ 14 days of baseline with daily activities restricted by RTI | Days work missed | Visual analog functional scale | Quality of life score
NR | NR | NR | NR

Evidence Table 6K Adverse Effects and Adherence for Manzano et al., 2010^11^

Combined adverse outcome < 30 days | Antibiotic adverse effects, days with adverse effects from medication, antibiotic resistance | Pain, bleeding, local infection | Adherence
NR | NR | NR | NR

Evidence Table 7K Randomized Trial Study Quality Ratings for Manzano et al., 2010^11^

Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results
Y | Y | Y | Y | Y | Y | N

Evidence Table 1L Study Description Table for Nobre et al., 2008^12^

Study Description | Study design, interventions, presenting condition, setting, enrollment and follow-up numbers | Primary outcome, procalcitonin assay, decision-making processes, definitions of sepsis and related conditions | Inclusion/exclusion criteria | Participant characteristics | Participant characteristics
Author, year: Nobre et al., 2008. Country, institution type: Switzerland, University Hospital, ICU Enrollment period: February 2006-April 2007 Funding: Not listed Author industry relationship disclosures: 2 authors with research funding from Brahms, and 1 author Brahms speaker's bureau | Design: RCT, 1:1 randomization Intent to treat Interventions: G1: PCT-guided antibiotics G2: Standard antibiotic therapy Presenting condition: Severe sepsis, septic shock Setting: ICU 282 assessed 203 excluded 42 > 48 hours antibiotics 35 severe immunosuppression 37 long-term antibiotics anticipated 20 DNR 32 with consent issues 8 PSAR 7 endocarditis 6 early ICU discharge 16 other N at enrollment: G1: 39 G2: 40 N at follow-up: G1: 31 G2: 37 G1 4 decreased or transferred early, 4 complicated infection G2 2 deceased of transferred, 1 complicated Average follow-up, days: [mean (SD), median (range/IQR)] G1: NR G2: NR Follow-up 28 days | Primary outcome: Systemic antibiotic exposure 90 % power to detect a 33 % (4 day) difference in antibiotic duration Secondary outcomes: 28 day mortality, IH mortality, ICU LOS. cure, recurrence, superinfection Response criteria, independent outcome assessor: Assay type: Kryptor, Brahms Decision-making: G1: PCT-guided antibiotic discontinuation Baseline PCT > 1.0, PCT decreased by 90 % from peak or < 0.25, stop antibiotic Baseline PCT < 1.0, PCT < 0.1, discontinue antibiotics G2: Standard antibiotic therapy Condition = definition: Sepsis, ATS, RCCM, 1992 Condition = definition: Septic shock, ATS, RCCM, 1992 | Inclusion criteria: • Exclusion criteria:; - Pseudomonas aeruginosa, Acinetobacter, Listeria, Legionella, PCP, TB, other chronic infections; - Solid organ transplantation; - AIDS; - ANC < 500; - Antibiotics > 48 hours before enrollment | Age, years: [mean (SD), median (range/IQR)] G1: 64.0 (12.3) G2: 66.9 (13.8) [test, result (p-value, 95% CI)] G1/G2: NSS Male, n (%): G1: 21 (67.7 %) G2: 25 (67.6 %) [test, result (p-value, 95% CI)] G1/G2: NSS Disease Pneumonia, n, (%): G1: 22 (71.0 %) G2: 25 (67.6 %) [test, result (p-value, 95% CI)] G1/G2: NSS Abdominal sepsis, n, (%): G1: 2 (6.5 %) G2: 6 (16.2 %) [test, result (p-value, 95% CI)] G1/G2: NSS Urosepsis, n, (%): G1: 5 (16.1 %) G2: 5 (13.5 %) [test, result (p-value, 95% CI)] G1/G2: NSS Other sepsis, n, (%): G1: 2 (6.5 %) G2: 1 (2.7 %) [test, result (p-value, 95% CI)] G1/G2: NSS Septic shock, n, (%): G1: 15 (48.4 %) G2: 16 (43.2 %) [test, result (p-value, 95% CI)] G1/G2: NSS SAPS III, mean (SD): G1: 68.5 (12.1) G2: 70.1 (13.1) [test, result (p-value, 95% CI)] G1/G2: NSS SOFA, Mean (SD): G1: 6.4 (3.3) G2: 6.6 (3.0) [test, result (p-value, 95% CI)] G1/G2: NSS Baseline PCT, Median (range): G1: 7.3 (0.1-93) G2: 5.4 (0.1-354) [test, result (p-value, 95% CI)] G1/G2: NSS Baseline PCT < 1.0, n, (%): G1: 7 (22.5 %) G2: 6 (16.2) [test, result (p-value, 95% CI)] G1/G2: NSS | Cancer, n (%): [test, result (p-value, 95% CI)] G1: 4 (12.9 %) G2: 5 (13.9 %) G1/G2: NSS Immunosuppression, n (%): G1: 1 (3.2 %) G2: 1 (2.7 %) [test, result (p-value, 95% CI)] G1/G2: NSS Cardiomyopathy, n (%): G1: 11 (35.5 %) G2: 17 (45.5 %) [test, result (p-value, 95% CI)] G1/G2: COPD, n (%): G1: 12 (38.7 %) G2: 7 (18.9 %) [test, result (p-value, 95% CI)] G1/G2: NSS Insulin-dependent diabetes, n (%): G1: 0 G2: 2 (5.4 %) [test, result (p-value, 95% CI)] G1/G2: Non-insulin-dependent diabetes, n (%): G1: 4 (12.9 %) G2: 6 (16.2 %) [test, result (p-value, 95% CI)] G1/G2: NSS Chronic renal failure, n (%): G1: 2 (6.5 %) G2: 6 (16.2 %) [test, result (p-value, 95% CI)] G1/G2: NSS Peripheral vascular disease, n (%): G1: 1 (3.2 %) G2: 1 (2.72 %) [test, result (p-value, 95% CI)] G1/G2: NSS Chronic liver disease, n (%): G1: 5 (16.1 %) G2: 5 (13.5 %) [test, result (p-value, 95% CI)] G1/G2: NSS

Evidence Table 2L Intermediate Outcomes for Nobre et al., 2008^12^

Antibiotic treatment duration | Antibiotic prescription rate, number of courses of antibiotics | Antibiotic classes | Hospital length of stay | ICU admission, length of stay
Intent to treat Duration antibiotics, Days: Median (range) G1: 6 (3-24) G2: 9.5 (2-33) [test, result (p-value, 95% CI)] G1/G2: Mean difference 2.6 (-0.3 to 5.5), p = 0.15 Incidence density antibiotic exposure: (rate days exposed per 1,000 patient-days) G1: 541 G2: 644 [test, result (p-value, 95% CI)] G1/G2: Mean difference 1.1 (0.9 to 1.3), p = 0.07 Days alive without antibiotics, mean (SD): G1: 15.3 (8.9) G2: 13 (8.2) [test, result (p-value, 95% CI)] G1/G2: Mean difference 2.3 (-5.9 to 1.8), p = 0.28 Per protocol Duration antibiotics, Days: Median (range) G1: 6 (4-16) G2: 10 (3-33) [test, result (p-value, 95% CI)] G1/G2: Mean difference 3.2 (1.1 to 5.4), p = 0.003 Incidence density antibiotic exposure: (rate days exposed per 1,000 patient-days) G1: 504 G2: 655 [test, result (p-value, 95% CI)] G1/G2: Mean difference 1.3 (1.1 to 1.5), p = 0.0002 Days alive without antibiotics, mean (SD): G1: 17.4 (7.6) G2: 13.6 (7.6) [test, result (p-value, 95% CI)] G1/G2: Mean difference 3.8 (0.1 to 7.5), p = 0.04 | NR | NR | Intent to treat Days: [mean (SD), median (range) G1: 17 (3-96) G2: 23.5 (5-44) [test, result (p-value, 95% CI)] G1/G2: NSS Per protocol Days: [mean (SD), median (range) G1: 14 (5-64) G2: 21 (5-89) [test, result (p-value, 95% CI)] G1/G2: NSS | Intent to treat ICU LOS, Days: [mean (SD), median (range) G1: 4 (1-21) G2: 7 (1-91) [test, result (p-value, 95% CI)] G1/G2: p = 0.02 Mean difference 4.6 (1.0 to 8.2) Per protocol ICU LOS, Days: [mean (SD), median (range) G1: 3 (1-8) G2: 5 (1-30) [test, result (p-value, 95% CI)] G1/G2: p = 0.03 Mean difference 4.3 (0.4 to 8.3)

Evidence Table 3L Morbidity Outcomes for Nobre et al., 2008^12^

Morbidity | Morbidity | Recurrence | Sepsis/SIRS frequency | RTI symptoms, overall health, cure, success
NR | NR | Intent to treat Relapse infection rate, n (%): G1: 1 (2.6 %) G2: 1 (2.5 %) [test, result (p-value, 95% CI)] G1/G2: NSS Per protocol Relapse infection rate, n (%): G1: 1 (3.2 %) G2: 1 (2.7 %) [test, result (p-value, 95% CI)] G1/G2: NSS | NR | Intent to treat Clinical cure (%): G1: 31 (79.4 %) G2: 32 (80 %) [test, result (p-value, 95% CI)] G1/G2: NSS Per protocol Clinical cure (%): G1: 28 (90.3 %) G2: 31 (83.8 %) [test, result (p-value, 95% CI)] G1/G2: NSS

Evidence Table 4L Mortality Outcomes for Nobre et al., 2008^12^

In-hospital mortality | 28-day mortality | Death | Sepsis--related death | Proportion surviving hospitalization
Intent to treat Proportion (%): G1: 9 (23.1 %) G2: 9 (22.5 %) [test, result (p-value, 95% CI)] G1/G2: NSS Per protocol Proportion (%): G1: 6 (19.4 %) G2: 7 (18.9 %) [test, result (p-value, 95% CI)] G1/G2: NSS | Intent to treat Proportion (%): G1: 8 (20.5 %) G2: 8 (20 %) [test, result (p-value, 95% CI)] G1/G2: NSS Per protocol Proportion (%): G1: 5 (16.1 %) G2: 6 (16.2 %) [test, result (p-value, 95% CI)] G1/G2: NSS | NR | Intent to treat Proportion (%): G1: 3 (37.5 %) G2: 2 (25 %) [test, result (p-value, 95% CI)] G1/G2: NSS Per protocol Proportion (%): G1: 3/5 (60 %) G2: 1/6 (16.6 %) [test, result (p-value, 95% CI)] G1/G2: NSS | NR

Evidence Table 5L Function and Quality of Life Outcomes for Nobre et al., 2008^12^

Days ≤ 14 days of baseline with daily activities restricted by RTI | Days work missed | Visual analog functional scale | Quality of life score
NR | NR | NR | NR

Evidence Table 6L Adverse Effects and Adherence for Nobre et al., 2008^12^

Combined adverse outcome < 30 days | Antibiotic adverse effects, days with adverse effects from medication, antibiotic resistance | Pain, bleeding, local infection | Adherence
NR | NR | NR | NR

Evidence Table 7L Randomized Trial Study Quality Ratings for Nobre et al., 2008^12^

Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results
Y | Y | Y | Y | Y | Y | Y

Evidence Table 1M Study Description Table for Schuetz et al., 2009^13^

Study Description | Study design, interventions, presenting condition, setting, enrollment and follow-up numbers | Primary outcome, procalcitonin assay, decision-making processes, definitions of sepsis and related conditions | Inclusion/exclusion criteria | Participant characteristics | Participant characteristics
Author, year: Schuetz et al., 2009. (ProHOSP) Country, institution type: Switzerland, multi-center, tertiary care hospitals (6 hospitals) Enrollment period: October 2006-March 2008 Funding: Swiss Nat'l Science Foundation; Gottried and Julia Bangerter-Rhyner Foundation, the University Hospital of Basel; the Medical University Clinic Liestal; the Medical Clinic Buergerspital Solothurn; the Cantonal Hospitals Muensterlingen; the Swiss Society for Internal Medicine; Brahms supplied the diagnostic kits Author industry relationship disclosures: 3 authors with support from Brahms; 1 author consultant for Brahms | Design: RCT, 1:1, non-inferiority Interventions: G1: PCT-guided initiation of antibiotics; PCT-guided discontinuation of antibiotics G2: Standard therapy Presenting condition: LRTI; CAP, AECOPD, acute bronchitis, other Setting: EDs 1825 with LRTI in Eds 1359 randomized N at enrollment: G1: 687 G2: 694 N at follow-up: G1: 671 G2: 688 G1: 34 died, 16 withdrew, 1 LTFU G2: 33 died, 6 withdrew, 0 LTFU Average follow-up, days: [mean (SD), median (range/IQR)] G1: G2: Duration of follow-up 30 days (phone interview) | Primary outcome: Overall adverse event rate within 30 days (death, ICU, disease-specific complications, recurrence), non-inferiority Both intent to treat and per protocol analysis performed for primary outcomes Study powered to detect a 7.5 % increase in combined endpoint; 90 % chance of detection, needed 1002 patients Secondary outcome: Antibiotic exposure Duration of antibiotics Adverse antibiotic effects LOS Superiority Response criteria, independent outcome assessor: Outcomes assessed by blinded investigators Assay type: Rapid Kryptor, Brahms Decision-making: G1: NR G2: NR Algorithm for PCT guided therapy For antibiotic initiation PCT < 0.1, antibiotics strongly discouraged; PCT ≤ 0.25, antibiotics discouraged; PCT > 0.25, antibiotics encouraged; PCT > 0.5, antibiotics strongly encouraged For antibiotic discontinuation PCT < 10 % of baseline, stopping antibiotics strongly encouraged; PCT < 20 % of baseline, stopping antibiotics discouraged Protocol could be overruled if ICU, hemodynamic instability, + Legionella Other interventions adequate antibiotic therapy Condition = definition: CAP = new infiltrate Condition = definition: COPD = GOLD criteria | Inclusion criteria:; - ED patients with LRTIs; - Age > 18 years; - Duration of illness < 28 days; - 1 respiratory symptom, 1 physical finding OR fever OR leukocytosis; Exclusion criteria:; - Intravenous drug use; - Severe immunosuppression (except corticosteroids); - HAP; - Chronic infection; - Imminent death | Age, years: [mean (SD), median (range/IQR)] G1: 73 (59-82) G2: 72 (59-82) [test, result (p-value, 95% CI)] G1/G2: NSS Male, n (%): G1: 402 (59.9 %) G2: 380 (55.2 %) [test, result (p-value, 95% CI)] G1/G2: NSS Disease CAP, n, (%): [mean (SD), median (range/IQR)] G1: 460 (68.6 %) G2: 465 (67.6 %) [test, result (p-value, 95% CI)] G1/G2: PSI for CAP, n, (%): [mean (SD), median (range/IQR)] G1: 91 (67-117) G2: 91 (66-114) [test, result (p-value, 95% CI)] G1/G2: NSS Over 50 % of patients with CAP were high-risk by PSI AECOPD, n, (%): [mean (SD), median (range/IQR)] G1: 115 (17.1 %) G2: 113 (16.4 %) [test, result (p-value, 95% CI)] G1/G2: NSS Acute bronchitis, n, (%): [mean (SD), median (range/IQR)] G1: 69 (10.3 %) G2: 82 (11.9 %) [test, result (p-value, 95% CI)] G1/G2:NSS Other, n, (%): [mean (SD), median (range/IQR)] G1: 27 (4.0 %) G2: 28 (4.0 %) [test, result (p-value, 95% CI)] G1/G2:NSS Hospitalized, n, (%): [mean (SD), median (range/IQR)] G1: 628 (93.7 %) G2: 629 (91.4 %) [test, result (p-value, 95% CI)] G1/G2:NSS | Coronary artery disease, n (%): [test, result (p-value, 95% CI)] G1: 146 (21.8 %) G2: 136 (19.8 %) G1/G2: Cerebrovascular disease, n (%): [test, result (p-value, 95% CI)] G1: 54 (8.1 %) G2: 56 (8.1 %) G1/G2: Renal dysfunction, n (%): [test, result (p-value, 95% CI)] G1: 156 (23.3 %) G2: 146 (21.2 %) G1/G2: COPD, n, (%): [test, result (p-value, 95% CI)] G1: 265 (39.5 %) G2: 268 (39.0 %) G1/G2: Cancer, n (%): G1: 69 (10.3 %) G2: 98 (14.2 %) [test, result (p-value, 95% CI)] G1/G2: Diabetes mellitus, n (%): G1: 118 (17.0 %) G2: 113 (16.4 %) [test, result (p-value, 95% CI)] G1/G2:

Evidence Table 2M Intermediate Outcomes for Schuetz et al., 2009^13^

Antibiotic treatment duration | Antibiotic prescription rate, number of courses of antibiotics | Antibiotic classes | Hospital length of stay | ICU admission, length of stay
Days: Mean,(median/IQR)] G1: 5.7 (5/1-8) G2: 8.7 (9/6-11) [test, result (p-value, 95% CI)] G1/G2: % difference 95 % CI, -34.8 (-40.3 to -28.7) | Any antibiotic use, antibiotic prescription rate, n, (%): G1: 506/671 (75.4 %) G2: 603/688 (87.7 %) [test, result (p-value, 95% CI)] G1/G2: CI -12.2 (-16.3 to -8.1) | NR | Days: Mean, (median/IQR) G1: 9.4 (8/4-12) G2: 9.2 (8/4-12) [test, result (p-value, 95% CI)] G1/G2: Relative mean change 1.8 (-6.9 to 11.0) | NR

Evidence Table 3M Morbidity Outcomes for Schuetz et al., 2009^13^

Morbidity | Morbidity | Recurrence | Sepsis/SIRS frequency | RTI symptoms, overall health, cure, success
Intent to Treat Overall adverse outcome, n, (%): G1: 103/671 (15.4 %) G2: 130/688 (18.9 %) [test, result (p-value, 95% CI)] G1/G2: CI for difference by Mantel-Haenszel weights stratified by site of infection. -3.5 (-7.6 to 0.4) Kaplan-Meier curves for time to first adverse event were calculated ICU, n, (%): G1: 43/671 (6.4 %) G2: 60/688 (8.7 %) [test, result (p-value, 95% CI)] G1/G2: CI -2.3 (-5.2 to 0.4) Disease-specific complications (%): G1: 17/671 (2.5 %) G2: 14/688 (2.0 %) [test, result (p-value, 95% CI)] G1/G2: Per protocol Overall adverse outcome, n, (%): G1: 95/633 (15.0 %) G2: 123/650 (18.9 %) [test, result (p-value, 95% CI)] G1/G2: -3.9 (-8.2 to 0.03) | Antibiotic adverse effects, n, (%): [mean (SD), median (range/IQR)] G1: 133/671 (19.8 %) G2: 193/688 (28.1 %) [test, result (p-value, 95% CI)] G1/G2: CI -8.2 (-12.7 to -3.7) | Intent to Treat Recurrence of infection (%): G1: 25/671 (3.7 %) G2: 45/688 (6.5 %) [test, result (p-value, 95% CI)] G1/G2: CI -2.8 (-5.1 to -0.4) | NR | NR

Evidence Table 4M Mortality Outcomes for Schuetz et al., 2009^13^

In-hospital mortality | 30-day mortality | Death | Pneumonia-related death | Proportion surviving hospitalization
NR | Intent to treat Proportion, n, (%): G1: 34/671 (5.1 %) G2: 33/688 (4.8 %) [test, result (p-value, 95% CI)] G1/G2: CI 0.3 (-2.1 to 2.5) Per protocol Proportion, n, (%): G1: 29/633 (4.6 %) G2: 31/650 (4.8 %) [test, result (p-value, 95% CI)] G1/G2: | NR | NR | NR

Evidence Table 5M Function and Quality of Life Outcomes for Schuetz et al., 2009^13^

Days ≤ 14 days of baseline with daily activities restricted by RTI | Days work missed | Visual analog functional scale | Quality of life score
NR | NR | NR | NR

Evidence Table 6M Adverse Effects and Adherence for Schuetz et al., 2009^13^

Combined adverse outcome < 30 days | Antibiotic adverse effects, days with adverse effects from medication, antibiotic resistance | Pain, bleeding, local infection | Adherence
NR | NR | NR | NR

Evidence Table 7M Randomized Trial Study Quality Ratings for Schuetz et al., 2009^13^

Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results
Y-balanced Y-concealment | Y | Y | Y | Y | Y | Y

Evidence Table 1N Study Description Table for Schroeder et al., 2009^14^

Study Description | Study design, interventions, presenting condition, setting, enrollment and follow-up numbers | Primary outcome, procalcitonin assay, decision-making processes, definitions of sepsis and related conditions | Inclusion/exclusion criteria | Participant characteristics | Participant characteristics
Author, year: Schroeder et al., 2009. Country, institution type: Germany, University hospital SICU Enrollment period: October 2006-April 2007 Funding: None listed Author industry relationship disclosures: 1 author Brahms speaker's bureau, no other conflicts | Design: RCT, 1:1 Interventions: G1: PCT-guided antibiotic therapy G2: Standard therapy Presenting condition: Status-post abdominal surgery Setting: SICU 125 screened 27 met inclusion criteria N at enrollment: G1: 14 G2: 13 N at follow-up: G1: 14 G2: 13 Average follow-up, days: [mean (SD), median (range/IQR)] G1: NR G2: NR | Primary outcome: Response criteria, independent outcome assessor: No power calculation Assay type: Kryptor, Brahms Also CRP, IL-6, WBC Decision-making: G1: PCT decreased to 1 or 25-35 % of baseline over 3 days G2: Standard Condition = definition: Severe sepsis, 1992 ATS, RCCM | Inclusion criteria:; - Status-post abdominal surgery; - Severe sepsis; Inclusion criteria:; - None listed | Age, years: [mean (SD), median (range/IQR)] G1: 69.3 (10.6) G2: 68.4 (13.7) [test, result (p-value, 95% CI)] G1/G2: NSS Male, n (%): G1: 8/14 G2: 7/13 [test, result (p-value, 95% CI)] G1/G2: NSS Disease Pneumonia, n, (%): [mean (SD), median (range/IQR)] G1: 4/14 G2: 4/13 [test, result (p-value, 95% CI)] G1/G2: NSS Disease Peritonitis, n, (%): [mean (SD), median (range/IQR)] G1: 10/14 G2: 9/13 [test, result (p-value, 95% CI)] G1/G2: NSS | SAPS II, Mean (SD): [test, result (p-value, 95% CI)] G1: 45.6± 18.5 G2: 53.7 ±14.7 G1/G2: NSS SOFA max, Mean (SD): G1: 7.3 (3.5) G2: 8.3 (4.2) [test, result (p-value, 95% CI)] G1/G2: NSS

Evidence Table 2N Intermediate Outcomes for Schroeder et al., 2009^14^

Antibiotic treatment duration | Antibiotic prescription rate, number of courses of antibiotics | Antibiotic classes | Hospital length of stay | ICU admission, length of stay
Days: [mean (SD), median (range/IQR)] G1: 6.6 (1.1) G2: 8.3 (0.7) [test, result (p-value, 95% CI)] G1/G2: p < 0.001 | NR | NR | NR | ICU admission, days: [mean (SD), median (range/IQR)] G1: 16.4 (8.3) G2: 16.7 (5.6) [test, result (p-value, 95% CI)] G1/G2: NSS

Evidence Table 3N Morbidity Outcomes for Schroeder et al., 2009^14^

Morbidity | Morbidity | Recurrence | Sepsis/SIRS frequency | RTI symptoms, overall health, cure, success
NR | NR | NR | NR | NR

Evidence Table 4N Mortality Outcomes for Schroeder et al., 2009^14^

In-hospital mortality | 28-day mortality | Death | Pneumonia-related death | Proportion surviving hospitalization
NR | NR | Proportion (%): G1: 3/14 G2: 3/13 [test, result (p-value, 95% CI)] G1/G2: NSS | NR | NR

Evidence Table 5N Function and Quality of Life Outcomes for Schroeder et al., 2009^14^

Days ≤ 14 days of baseline with daily activities restricted by RTI | Days work missed | Visual analog functional scale | Quality of life score
NR | NR | NR | NR

Evidence Table 6N Adverse Effects and Adherence14

Combined adverse outcome < 30 days | Antibiotic adverse effects, days with adverse effects from medication, antibiotic resistance | Pain, bleeding, local infection | Adherence
NR | NR | NR | NR

Evidence Table 7N Randomized Trial Study Quality Ratings for Schroeder et al., 2009^14^

Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results
Y^*^ | Y | Y | Y | Y | Y | Y

* No details on allocation concealment but groups were comparable

Evidence Table 1O Study Description Table for Stocker et al., 2010^15^

Study Description | Study design, interventions, presenting condition, setting, enrollment and follow-up numbers | Primary outcome, procalcitonin assay, decision-making processes, definitions of sepsis and related conditions | Inclusion/exclusion criteria | Participant characteristics | Participant characteristics
Author, year: Stocker et al., 2010. Country, institution type: Switzerland, single tertiary care institution Enrollment period: June 1, 2005-December 31, 2006 Funding: Brahms supplied test kits Author industry relationship disclosures: Not given | Design: RCT; 1:1, masked until randomization Interventions: G1: Procalcitonin-guided decision-making G2: Standard treatment Presenting condition: Suspected early-onset neonatal sepsis Setting: Neonatal and Pediatric ICU 126 screened, 5 excluded (2 no consent, 2 protocol errors, and 1 surgery in first 3 days) N at enrollment: G1: 60 G2: 61 N at follow-up: G1: 60 G2: 61 Average follow-up, days: [mean (SD), median (range/IQR)] G1: 3 days to 1 month G2: 3 days to 1 months | Primary outcome: Proportion of infants treated with antibiotics ≥ 72 hours Absolute reduction in duration of antibiotic therapy Trial 90 % powered to detect a 30 % difference in duration of antibiotic therapy Secondary outcome: Survival Recurrence of infection in first month (antibiotics given > 120 hours Assay type: Kryptor, Brahms Decision-making: G1: PCT age-adjusted for 0-120 hours of age, peak at 18-30 hours of 10 ng/mL G2: Standard therapy Condition = definition: Sepsis Diagnosis by risk factors, group B streptococcus, premature rupture of membranes, clinical status, including respiratory distress, tachycardia, bradycardia, hypotension, seizures, irritability, vomiting, feeding intolerance, ileus, WBC count, immature to total granulocytes, CRP | Inclusion criteria:; - Gestational age ≥ 34 weeks; - Early-onset sepsis (3 days); Exclusion criteria:; - Severe congenital malformations,; - Chromosomal abnormalities; - Surgery in first 3 days of life | Gestational age (weeks), mean (std dev): [test, result (p-value, 95% CI)] G1: 39.4 (34.4-42.0) G2: 39.7 (34.0-41.7) G1/G2: NSS Mann-Whitney U test, p < 0.05 significant Birth weight (grams), mean (std dev): G1: 3,200 (2,000-4.640) G2: 3,330 (1,800-4,900) [test, result (p-value, 95% CI)] G1/G2: NSS Male sex, n, (%): G1: 35 (58 %) G2: 40 (65 %) [test, result (p-value, 95% CI)] G1/G2: NSS Normal spontaneous vaginal delivery, n (%): G1: 36 (60 %) G2: 31 (51 %) [test, result (p-value, 95% CI)] G1/G2: NSS APGAR 1, median: G1: 8 G2: 8 [test, result (p-value, 95% CI)] G1/G2: NSS | APGAR 5, mean (std dev): G1: 9 G2: 9 [test, result (p-value, 95% CI)] G1/G2: NSS APGAR 10, mean (std dev): G1: 9 G2: 10 [test, result (p-value, 95% CI)] G1/G2: NSS Infection proven/probable, n, (%): G1: 9/0 (15 %) G2: 11/1 (20 %) [test, result (p-value, 95% CI)] G1/G2: NSS Infection possible, n, (%): G1: 21 (35 %) G2: 19/1(31 %) [test, result (p-value, 95% CI)] G1/G2: NSS Infection unlikely, n, (%): G1: 30 (50 %) G2: 30.1 (49 %) [test, result (p-value, 95% CI)] G1/G2: NSS

Evidence Table 2O Intermediate Outcomes for Stocker et al., 2010^15^

Antibiotic treatment duration | Antibiotic prescription rate, number of courses of antibiotics | Antibiotic classes | Hospital length of stay | ICU admission, length of stay
Reduction in duration of antibiotics (hours), mean (std dev): All newborns G1: 79.1 G2: 101.5 [test, result (p-value, 95% CI)] G1/G2: Abs reduction 22.4, Mann-Whitney U test, p = 0.012 Infection proven/probably G1: 177.8 G2: 170.8 [test, result (p-value, 95% CI)] G1/G2: Abs reduction 7, NSS Infection possible G1: 83.4 G2: 111.5 [test, result (p-value, 95% CI)] G1/G2: Abs reduction 28.1, p < 0.001 Infection unlikely G1: 46.5 G2: 67.4 [test, result (p-value, 95% CI)] G1/G2: Abs reduction 20.9, p = 0.001 | Proportion treated with antibiotics ≥ 72 hours, n, %: [mean (SD), median (range/IQR)] All newborns G1: 33/60 (55 %) G2: 50/61 (82 %) [test, result (p-value, 95% CI)] G1/G2: RR 27 %, Fisher's exact test, p = 0.002 Infection proven/probably G1: 9/9 (100 %) G2: 12/12 (100 %) [test, result (p-value, 95% CI)] G1/G2: RR 0 %, NSS Infection possible G1: 13/21 (61.9 %) G2: 19/19 (100 %) [test, result (p-value, 95% CI)] G1/G2: RR 38.1 %, p < 0.001 Infection unlikely G1: 11/30 (36.7 %) G2: 19/30 (63.3 %) [test, result (p-value, 95% CI)] G1/G2: RR, 26.6 %, p = 0.038 | NR | NR | NR

Evidence Table 3O Morbidity Outcomes for Stocker et al., 2010^15^

Morbidity | Morbidity | Recurrence | Sepsis/SIRS frequency | RTI symptoms, overall health, cure, success
NR | NR | Recurrence (%): G1: 32 % G2: 39 % [test, result (p-value, 95% CI)] G1/G2: OR 0.71, 95 % CI 0.34/1.51, Fisher's exact test, non-inferiority, NSS | NR | NR

Evidence Table 4O Mortality Outcomes for Stocker et al., 2010^15^

In-hospital mortality | 28-day mortality | Death | Pneumonia-related death | Proportion surviving hospitalization
Proportion (%): G1: 0 % G2: 0 % [test, result (p-value, 95% CI)] G1/G2: NSS | NR | NR | NR | NR

Evidence Table 5O Function and Quality of Life Outcomes for Stocker et al., 2010^15^

Days ≤ 14 days of baseline with daily activities restricted by RTI | Days work missed | Visual analog functional scale | Quality of life score
NR | NR | NR | NR

Evidence Table 6O Adverse Effects and Adherence for Stocker et al., 2010^15^

Combined adverse outcome < 30 days | Antibiotic adverse effects, days with adverse effects from medication, antibiotic resistance | Pain, bleeding, local infection | Adherence
NR | NR | NR | NR

Evidence Table 7O Randomized Trial Study Quality Ratings for Stocker et al., 2010^15^

Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results
Y | Y | Y | Y | Y | Y | Y

Evidence Table 1P Study Description Table for Stolz et al., 2007^16^

Study Description | Study design, interventions, presenting condition, setting, enrollment and follow-up numbers | Primary outcome, procalcitonin assay, decision-making processes, definitions of sepsis and related conditions | Inclusion/exclusion criteria | Participant characteristics | Participant characteristics
Author, year: Stolz et al., 2007. Country, institution type: Switzerland, University Hospital of Basel Enrollment period: November 2003-March 2005 Funding: Clinic of Pulmonary Medicine; Clinic of Endo, Diabetes, and Clinical Nutrition; ED of University Hospital of Basel; Brahms supplied the kits Author industry relationship disclosures: I author a consultant and recipient of payments for meetings, travel, speaking, and research; no other conflicts reported | Design: RCT; 1:1, masked until randomization, single center Interventions: G1: Procalcitonin-guidance G2: Standard therapy Presenting condition: AECOPD Setting: ED N at enrollment: G1: 102 G2: 106 N at 14 days follow-up: blinded G1: 99 (3 deaths) G2: 104 (2 deaths) N at 6 months follow-up: blinded G1: 97 (2 deaths) G2: 97 (7 deaths) | Primary outcome: Antibiotic use at index ECOPD Antibiotic use up to 6 months Secondary outcomes: Success, LOS, ICU need, CRP, PCT, PFTs on admission, short- and long-term follow-up, exacerbation rate, time to next exacerbation Time to clinic events by Kaplan-Meier and log-rank test 85 % chance of detecting a 30 % reduction in antibiotic use, alpha error of 0.05; needed 223 patients enrolled assuming a 20 % dropout rate Response criteria, independent outcome assessor: Assay type: Kryptor PCT, Brahms Decision-making: G1: For antibiotic initiation PCT < 0.1 antibiotics strongly discouraged; PCT ≥ 1.0 ≤ 0.25, antibiotics based on clinical condition; PCT > 0.25, antibiotics encouraged G2: Standard management | Inclusion criteria:; - ≥ 40 years of age; - Met post-bronchodilator therapy criteria for ECOPD within 48 hours of ED admission; Exclusion criteria:; - Other explanation for illness; - Psychiatric co-morbidities; - Immunosuppression; - Asthma; - Cystic fibrosis; - Infiltrate on CXR | Age, years: median (range/IQR)] G1: 69.5 (65-77) G2: 69.5 (64.8-79) [test, result (p-value, 95% CI)] G1/G2: NSS Men, n (%): G1: 50 (49 %) G2: 44 (41.5 %) [test, result (p-value, 95% CI)] G1/G2: NSS Current smoker, n (%): G1: 40 (39.2 %) G2: 54 (50.9 %) [test, result (p-value, 95% CI)] G1/G2: NSS Pack-years: median (range/IQR)]: G1: 43 (30-58.5) G2: 50 (30-60) [test, result (p-value, 95% CI)] G1/G2: NSS COPD duration, months: [mean (SD): G1: 128 (82) G2: 123 (85) [test, result (p-value, 95% CI)] G1/G2: NSS AECOPD previous year: [mean (SD): G1: 2.4 (2.1) G2: 1.9 (1.8) [test, result (p-value, 95% CI)] G1/G2: NSS Severity of COPD (GOLD staging), n, (%): G1- I: 6 (5.9 %) G1- II: 15 (14.7 %) G1- III: 47 (46.1 %) G1- IV: 34 (33.3 %) G2- I: 5 (4.7 %) G2- II: 25 (23.6 %) G2- III: 51 (48.1 %) G2- IV: 25 (23.6 %) [test, result (p-value, 95% CI)] G1/G2: NSS Home oxygen, n, (%): G1: 21 (20.6 %) G2: 13 (12.3 %) [test, result (p-value, 95% CI)] G1/G2: NSS Severity of AECOPD, n, (%): G1- 1: 51 (50 %) G1- 2: 24 (23.5 %) G1- 3: 27 (26.5 % G2- 1: 49 (46.2 %) G2- 2: 28 (26.4 %) G2- 3: 29 (27.4 %) [test, result (p-value, 95% CI)] G1/G2: NSS FEV1: [mean (SD): G1: 0.88 (0.41) G2: 0.98 (0.41) [test, result (p-value, 95% CI)] G1/G2: p = 0.02 Positive sputum culture, n, (%): G1: 37 (36 %) G2: 40 (38 %) [test, result (p-value, 95% CI)] G1/G2: NSS Mostly gram negative rods and Pneumococcus PCT: mean,(SD): G1: 0.274 (1.049) G2: 0.244 (0.516) [test, result (p-value, 95% CI)] G1/G2: NSS CRP, mean,(SD): G1: 32 (42) G2: 44 (55) [test, result (p-value, 95% CI)] G1/G2: NSS WBC count: mean,(SD): G1: 11.7 (8.4) G2: 11.5 (4.6) [test, result (p-value, 95% CI)] G1/G2: NSS | Diabetes mellitus, n (%): G1: 12 (11.8) G2: 11 (10.4) [test, result (p-value, 95% CI)] G1/G2: NSS Renal insufficiency, n (%): G1: 5 (4.9 %) G2: 12 (11.3 %) [test, result (p-value, 95% CI)] G1/G2: NSS Cardiomyopathy, n (%): G1: 42 (41.2) G2: 49 (46.2) [test, result (p-value, 95% CI)] G1/G2: NSS HTN, n (%): G1: 23 (22.5 %) G2: 27 (25.5 %) [test, result (p-value, 95% CI)] G1/G2: NSS Osteoporosis, n (%): G1: 17 (16.7 %) G2: 9 (8.5 %) [test, result (p-value, 95% CI)] G1/G2: NSS Cancer, n (%): G1: 12 (11.8 %) G2: 14 (13.2 %) [test, result (p-value, 95% CI)] G1/G2: NSS

Evidence Table 2P Intermediate Outcomes for Stolz et al., 2007^16^

Antibiotic treatment duration | Antibiotic prescription rate, number of courses of antibiotics | Antibiotic classes | Hospital length of stay | ICU admission, length of stay
Antibiotic exposure: (rate days exposed per #patient-days) G1: NR G2: NR [test, result (p-value, 95% CI)] G1/G2: Absolute risk reduction 31.5 (18.7 to 44.3), p < 0.0001 RR 0.56 (0.43 to 0.73), p<0.0001 RRR 44% (27 to 57%), p < 0.0001 At 6 months RR 0.76, (0.64 to 0.92), p = 0.004 Subsequent antibiotic use within 6 months (%): G1: 46 G2: 43 [test, result (p-value, 95% CI)] G1/G2: NSS Steroid use, n, (%): G1: 89 (87.3 %) G2: 93 (87.7 %) [test, result (p-value, 95% CI)] G1/G2: NSS Steroid dose, median, range: G1: 250 (119-400) G2: 280 (183-421) [test, result (p-value, 95% CI)] G1/G2: NSS | Any antibiotic use, antibiotic prescription rate (%): G1: 40 % G2: 72 % [test, result (p-value, 95% CI)] G1/G2: p < 0.0001 Number of courses of antibiotics: [mean (SD), median (range/IQR)] G1: NR G2: NR [test, result (p-value, 95% CI)] G1/G2: | Antibiotic classes, n (%): G1-1 antibiotic: 80 % G1-2 antibiotic: 15 % G1-3 antibiotic: 2 % G2-1 antibiotic: 68 % G2-2 antibiotic: 29 % G2-3 antibiotic: 3 % [test, result (p-value, 95% CI)] G1/G2: NSS Antibiotics prescribed were amino penicillin's (62 %), fluoroquinolones (16 %), cephalosporin's (11 %), macrolides (8 %), anti- Pseudomonas aeruginosa penicillin's (2 %), and other (1 %) | Days: [mean (SD), median (range/IQR)] G1: 9 (1-15) G2: 10 (1-15) [test, result (p-value, 95% CI)] G1/G2: NSS Hospital LOS < 24 hours, n, (%): G1: 22 (21.6 %) G2: 24 (22.6 %) [test, result (p-value, 95% CI)] G1/G2: NSS | ICU admission (%): G1: 8 (7.8 %) G2: 11 (10.4 %) [test, result (p-value, 95% CI)] G1/G2: NSS ICU LOS, days: mean (SD) G1: 3.3 (2.7) G2: 3.7 (2.1) [test, result (p-value, 95% CI)] G1/G2: NSS

Evidence Table 3P Morbidity Outcomes for Stolz et al., 2007^16^

Morbidity | Morbidity | Recurrence | Sepsis/SIRS frequency | RTI symptoms, overall health, cure, success
NR | FEV1 at 14 days, mean (SD): G1: 1.04 (0.48) G2: 1.01 (0.57) G1/G2: NSS FEV1 at 6 months, mean (SD): G1: 1.07 (0.55) G2: 1.11 (0.57) G1/G2: NSS | Recurrence of AECOPD 6 months, n, (%): G1: 44 (43.1 %) G2: 43 (40.1 %) [test, result (p-value, 95% CI)] G1/G2: NSS Hospitalization for recurrence of AECOPD 6 months, n, (%): G1: 18 (17.7 %) G2: 22 (20.8 %) [test, result (p-value, 95% CI)] G1/G2: NSS | NR | Clinical cure (%): G1: 84 (82.4 %) G2: 89 (83.9 %) [test, result (p-value, 95% CI)] G1/G2:

Evidence Table 4P Mortality Outcomes for Stolz et al., 2007^16^

In-hospital mortality | 28-day mortality | Death within 6 months | Pneumonia-related death | Proportion surviving hospitalization
NR | NR | Death of any cause, n (%): G1: 5 (4.9 %) G2: 9 (8.5 %) [test, result (p-value, 95% CI)] G1/G2: NSS | NR | NR

Evidence Table 5P Function and Quality of Life Outcomes for Stolz et al., 2007^16^

Days < 14 days of baseline with daily activities restricted by RTI | Days work missed | Visual analog functional scale | Quality of life score
NR | NR | NR | NR

Evidence Table 6P Adverse Effects and Adherence for Stolz et al., 2007^16^

Combined adverse outcome < 30 days | Antibiotic adverse effects, days with adverse effects from medication, antibiotic resistance | Pain, bleeding, local infection | Adherence
NR | NR | NR | NR

Evidence Table 7P Randomized Trial Study Quality Ratings for Stolz et al., 2007^16^

Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results
Y- balanced U-concealment | Y | Y | Y | Y | Y | N

Evidence Table 1Q Study Description Table for Stolz et al., 2009^17^

Study Description | Study design, interventions, presenting condition, setting, enrollment and follow-up numbers | Primary outcome, procalcitonin assay, decision-making processes, definitions of sepsis and related conditions | Inclusion/exclusion criteria | Participant characteristics | Participant characteristics
Author, year: Stolz et al., 2009. (ProVAP) Country, institution type: Switzerland, USA Enrollment period: Not given Funding: Swiss Nat'l Foundation; Margarete and Walter Liechtenstein Foundation; Friewillige Akademische Gesellschaft Basel; Will Rogers Foundation; Clinic of Pulmonary Medicine-University Hospital Basel; Brahms, Germany Author industry relationship disclosures: Statement at website | Design: Multi-national, RCT, 1:1, open interventional, 7 ICUs Interventions: G1: Procalitonin guidance G2: Treatment according to guidelines Presenting condition: VAP Setting: ICU N at enrollment: G1: 51 G2: 50 N at follow-up: G1: 51 G2: 50 Average follow-up, days: [mean (SD), median (range/IQR)] G1: NR G2: NR Patients re-evaluated daily up to 10 days after inclusion 164 patients screened 23 unable to consent 1 mental retardation 6 refused consent 3 physician refused 17 immunocompromised 5 CAP 4death before inclusion 4 other study | Primary outcome: Antibiotic-free days alive assessed at 28 days After enrollment Secondary outcomes Vent-free days, ICU-free days, clinical evidence of progression, and mortality Superiority trial for antibiotic free days. 84 patients needed to have a 90 % chance of detecting a 5 day difference 100 enrolled assuming 8 % lost to follow-up Response criteria, independent outcome assessor: Assay type: Kryptor, Brahms Decision-making: Measured at baseline, at 72 hours, and daily up to 10 days After 72 hours of empiric antibiotics, daily PCT reported to physician G1: PCT < 0.25, d/c antibiotics strongly encouraged, PCT 0.25-0.5 or decrease by 80 % from day 0, d/c antibiotics encouraged, PCT 0.5 or greater or decrease of less than 80 % from baseline, antibiotics encouraged, PCT > 1, antibiotics strongly encouraged G2: Standard antibiotic therapy based on respiratory secretions Condition = definition: VAP by ATS definition | Inclusion criteria:; - In ICU on vent > 48 hours; - Age > 18 years; - VAP by ATS criteria; Exclusion criteria:; - Pregnant; - Enrolled in another trial; - On immuno-suppressants or long-term corticosteroids (> 1 month); - Severely immunosuppressed (AIDS, etc.); - Extra-pulmonary infections | Age, years: [mean (SD), median (range/IQR)] G1: 53 (21-88) G2: 59 (18-83) [test, result (p-value, 95% CI)] G1/G2: Male, n (%): G1: 38 (75 %) G2: 37 (74 %) [test, result (p-value, 95% CI)] G1/G2: NSS Admission Medical, n (%): G1: 27 (53 %) G2: 26 (52 %) [test, result (p-value, 95% CI)] G1/G2: NSS Emergency surgery, n (%): G1: 23 (45 %) G2: 20 (40 %) [test, result (p-value, 95% CI)] G1/G2: NSS Elective surgery, n (%): G1: 1 (2 %) G2: 3 (6 %) [test, result (p-value, 95% CI)] G1/G2: NSS Duration of MV before VAP, days, mean (range): G1: 6 (3-7) G2: 6 (4-10) [test, result (p-value, 95% CI)] G1/G2: NSS Antibiotics before VAP, n (%): G1: 35 (69 %) G2: 41 (82 %) [test, result (p-value, 95% CI)] G1/G2: NSS Shock, n (%): G1: 11 (22 %) G2: 12 (24 %) [test, result (p-value, 95% CI)] G1/G2: NSS Bacteremia, n (%): G1: 14 (28 %) G2: 18 (36 %) [test, result (p-value, 95% CI)] G1/G2: NSS SAPS II, mean (SD): G1: 42 (13) G2: 45 (14) [test, result (p-value, 95% CI)] G1/G2: NSS PCT correlated with severity of disease, SAPSII (r2=0.358, p < 0.001) ODIN, mean (SD): G1: 1.9 (0.9) G2: 2.3 (1.0) [test, result (p-value, 95% CI)] G1/G2: NSS SOFA, mean (SD): G1: 7.3 (3.4) G2: 8.2 (3.4) [test, result (p-value, 95% CI)] G1/G2: NSS WBC, mean (SD): G1: 12.0 (6.6) G2: 13.3 (5.9) [test, result (p-value, 95% CI)] G1/G2: NSS PCT, mean (SD): G1: 0.66 (0.22-2.69) G2: 0.73 (0.21-2.36) [test, result (p-value, 95% CI)] G1/G2: NSS | Coronary artery disease, n (%): G1: 9 (18 %) G2: 4 (8 %) [test, result (p-value, 95% CI)] G1/G2: NSS Hypertensive heart failure, n (%): G1: 8 (16 %) G2: 8 (16 %) [test, result (p-value, 95% CI)] G1/G2: NSS Congestive heart failure, n (%): G1: 21 (41 %) G2: 27 (54 %) [test, result (p-value, 95% CI)] G1/G2: NSS Renal dysfunction, n (%): [test, result (p-value, 95% CI)] G1: 9 (18 %) G2: 7 (14 %) G1/G2: Liver disease, n (%): [test, result (p-value, 95% CI)] G1: 4 (8 %) G2: 3 (6 %) G1/G2: NSS Diabetes mellitus, n (%): G1: 10 (20 %) G2: 13 (26 %) [test, result (p-value, 95% CI)] G1/G2: NSS COPD, n (%): G1: 8 (16 %) G2: 11 (22 %) [test, result (p-value, 95% CI)] G1/G2: NSS Cancer, n (%): [test, result (p-value, 95% CI)] G1: 3 (6 %) G2: 5 (10 %) G1/G2: NSS Substance abuse, n (%): [test, result (p-value, 95% CI)] G1: 5 (10 %) G2: 8 (16 %) G1/G2: NSS

Evidence Table 2Q Intermediate Outcomes for Stolz et al., 2009^17^

Antibiotic treatment duration | Antibiotic prescription rate, number of courses of antibiotics | Antibiotic classes | Hospital length of stay | ICU admission, length of stay
Superiority Antibiotic-free days at day 28: [mean (SD), median (range/IQR)] G1: 13 (2-21) G2: 9.5 (1.5-17) [test, result (p-value, 95% CI)] G1/G2: p = 0.049 Incidence density antibiotic exposure: (rate days exposed per #patient-days) G1: 1,077 G2: 1,341 [test, result (p-value, 95% CI)] G1/G2: Antibiotic duration: G1: 10 (6-16) G2: 15 (10-23) Antibiotics > 7 days, n, %: G1: 65 % G2: 82 %, p = 0.044 Antibiotic discontinuation at day 10, HR: 2.235 (CI 1.077-4.64, p = 0.031) Duration of antibiotic longer for PSAR, Acinetobacter, Stenotrophomonas, and Klebsiella | Any antibiotic use, | NR | Days: [mean (SD), median (range/IQR)] G1: 26 (7-21) G2: 26 (17-22.3) [test, result (p-value, 95% CI)] G1/G2: NSS Did not depend on Micro | ICU free days alive: G1: 10 (0-18) G2: 8.5 (0-18) [test, result (p-value, 95% CI)] G1/G2: NSS Did not depend on Micro

Evidence Table 3Q Morbidity Outcomes for Stolz et al., 2009^17^

Morbidity | Morbidity | Recurrence | Sepsis/SIRS frequency | RTI symptoms, overall health, cure, success
Vent-free days, mean (std dev): G1: 21 (2-24) G2: 19(8.5-22.5) [test, result (p-value, 95% CI)] G1/G2: NSS ICU-free days, mean (std dev): G1: 10 (0-18) G2: 8.5 (0-18) [test, result (p-value, 95% CI)] G1/G2: VAP-related deterioration days 1-28, n, %: G1: 5 (10 %) G2: 7 (14 %) [test, result (p-value, 95% CI)] G1/G2: Discharge home days 1-28, n, (%): G1: 5 (10 %) G2: 3 (6 %) [test, result (p-value, 95% CI)] G1/G2: NSS Discharge elsewhere, n, (%): G1: 35 (69 %) G2: 32 (64 %) [test, result (p-value, 95% CI)] G1/G2: NSS | NR | NR | NR | NR

Evidence Table 4Q Mortality Outcomes for Stolz et al., 2009^17^

In-hospital mortality | 28-day mortality | Death | Pneumonia-related death | Proportion surviving hospitalization
Proportion (%): G1: 20 % G2: 28 % [test, result (p-value, 95% CI)] G1/G2: | NR | All causes days 1-28 (%): G1: 8 (16 %) G2: 12 (24 %) [test, result (p-value, 95% CI)] G1/G2: NSS | NR | NR

Evidence Table 5Q Function and Quality of Life Outcomes for Stolz et al., 2009^17^

Days ≤ 14 days of baseline with daily activities restricted by RTI | Days work missed | Visual analog functional scale | Quality of life score
NR | NR | NR | NR

Evidence Table 6Q Adverse Effects and Adherence for Stolz et al., 2009^17^

Combined adverse outcome < 30 days | Antibiotic adverse effects, days with adverse effects from medication, antibiotic resistance | Pain, bleeding, local infection | Adherence | Acquisition or persistence of pathogens up to day 28
NR | NR | NR | NR | NR

Evidence Table 7Q Randomized Trial Study Quality Ratings for Stolz et al., 2009^17^

Assembled comparable groups | Maintained comparable groups | Minimal follow-up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results
Y | Y | Y | Y | Y | Y | Y

Evidence Table 1R Study Description Table for Svoboda et al., 2007^18^

Study Description | Study design, interventions, presenting condition, setting, enrollment and follow-up numbers | Primary outcome, procalcitonin assay, decision-making processes, definitions of sepsis and related conditions | Inclusion/exclusion criteria | Participant characteristics | Participant characteristics
Author, year: Svoboda et al., 2007. Country, institution type: Czech, Academic medical center Enrollment period: May, 2003-September, 2005 Funding: Grant from IGA MZ CR ND 7676-3 Author industry relationship disclosures: Not given | Design: Single center, RCT Interventions: G1: Procalcitonin guidance G2: Standard therapy Presenting condition: Multiple trauma (289 ISS≥ 25)settings, 164 major abdominal surgeries (time > 120 minutes) admitted to ICU with severe sepsis Setting: ICU 453 screened 72 enrolled N at enrollment: G1: 38 G2: 34 N at follow-up: G1: G2: Average follow-up, days: [mean (SD), median (range/IQR)] G1: NR G2: NR | Primary outcome: No defined prospectively Response criteria, independent outcome assessor: No power calculation Assay type: PCT-Q, Brahms; good correlation with PCT LUMI Also WBC, CRP, IL-6, TNF, and AT III Decision-making: G1: PCT-guided treatment, PCT > 2, change antibiotics and IV catheters; PCT < 2 get US and/or CT with repeat surgical treatment G2: Standard treatment Condition = definition: Severe sepsis. ATS/RCCM definition, 1992. | Inclusion criteria:; - Age > 18 years; Inclusion criteria:; - Chemical trauma; - Burn trauma; - Moribund patients; - DNR | Age, years: median (range) G1: 43 (19-88) G2: 49 (20-86) [test, result (p-value, 95% CI)] G1/G2: NSS Male, n (%): G1: 23 (61 %) G2: 23 (68 %) [test, result (p-value, 95% CI)] G1/G2: NSS Septic shock, n, (SD): G1: 27 (71 %) G2: 23 (68 %) [test, result (p-value, 95% CI)] G1/G2: NSS APACHE II, mean (SD): G1: 15.7 (7.9) G2: 17.3 (9.3) [test, result (p-value, 95% CI)] G1/G2: NSS PCT > 2, n, (%): G1: 21 (55 %) G2: 16 (47 %) G1/G2: NSS | Multiple trauma, n (%): G1: 27 (71 %) G2: 22 (65 %) G1/G2: NSS Abdominal surgery, n (%): G1: 11 (29 %) G2: 12 (35 %) [test, result (p-value, 95% CI)] G1/G2: NSS

Evidence Table 2R Intermediate Outcomes for Svoboda et al., 2007^18^

Antibiotic treatment duration | Antibiotic prescription rate, number of courses of antibiotics | Antibiotic classes | Hospital length of stay | ICU admission, length of stay
NR | NR | NR | NR | ICU LOS, days, mean (SD): G1: 16.1 (6.9) G2: 19.4 (8.9) [test, result (p-value, 95% CI)] G1/G2: p = 0.09

Evidence Table 3R Morbidity Outcomes for Svoboda et al., 2007^18^

Morbidity | Morbidity | Recurrence | Sepsis/SIRS frequency | RTI symptoms, overall health, cure, success
SOFA, mean (DS): G1: 7.9 (2.8 G2: 9.3 (3.3) [test, result (p-value, 95% CI)] G1/G2: p = 0.06 | Days on ventilation, mean, (SD): G1: 10.3 (7.8) G2: 13.9 (9.4) [test, result (p-value, 95% CI)] G1/G2: p = 0.08 | NR | NR | NR

Evidence Table 4R Mortality Outcomes for Svoboda et al., 2007^18^

In-hospital mortality | 28-day mortality | Death | Pneumonia-related death | Proportion surviving hospitalization
NR | Proportion (%): G1: 10 (26 %) G2: 13 (38 %) [test, result (p-value, 95% CI)] G1/G2: NSS | NR | NR | NR

Evidence Table 5R Function and Quality of Life Outcomes for Svoboda et al., 2007^18^

Days ≤ 14 days of baseline with daily activities restricted by RTI | Days work missed | Visual analog functional scale | Quality of life score
NR | NR | NR | NR

Evidence Table 6R Adverse Effects and Adherence for Svoboda et al., 2007^18^

Combined adverse outcome < 30 days | Antibiotic adverse effects, days with adverse effects from medication, antibiotic resistance | Pain, bleeding, local infection | Adherence
NR | NR | NR | NR

Evidence Table 7R Randomized Trial Study Quality Ratings

Assembled comparable groups | Maintained comparable groups | Minimal follow- up loss | Measurements equal, valid, and reliable | Interventions clearly defined | Important outcomes considered | Appropriate analysis of results
Y | Y | Y | Y | N | Y | Y

## References

1 Bouadma L, Luyt CE, Tubach F, et al. Use of procalcitonin to reduce patients' exposure to antibiotics in intensive care units (PRORATA trial): a multicentre randomised controlled trial. Lancet. Feb. 6. 2010;375(9713):463-74. [pmid: 20097417].
2 Briel M, Schuetz P, Mueller B, et al. Procalcitonin-guided antibiotic use vs a standard approach for acute respiratory tract infections in primary care. Arch Intern Med. Oct. 13. 2008;168(18):2000-7. discussion 7-8. [pmid: 18852401].
3 Burkhardt O, Ewig S, Haagen U, et al. Procalcitonin guidance and reduction of antibiotic use in acute respiratory tract infection. Eur Respir J. Sep. 2010;36(3):601-7. [pmid: 20185423].
4 Christ-Crain M, Jaccard-Stolz D, Bingisser R, et al. Effect of procalcitonin-guided treatment on antibiotic use and outcome in lower respiratory tract infections: cluster-randomised, single-blinded intervention trial. Lancet. Feb. 21. 2004;363(9409):600-7. [pmid: 14987884].
5 Christ-Crain M, Stolz D, Bingisser R, et al. Procalcitonin guidance of antibiotic therapy in community-acquired pneumonia: a randomized trial. Am J Respir Crit Care Med. Jul. 1. 2006;174(1):84-93. [pmid: 16603606].
6 Chromik AM, Endter F, Uhl W, et al. Pre-emptive antibiotic treatment vs ‘standard’ treatment in patients with elevated serum procalcitonin levels after elective colorectal surgery: a prospective randomised pilot study. Langenbecks Arch Surg. Jun. 2006;391(3):187-94. [pmid: 16369855].
7 Hochreiter M, Kohler T, Schweiger AM, et al. Procalcitonin to guide duration of antibiotic therapy in intensive care patients: a randomized prospective controlled trial. Crit Care. 2009;13(3):R83. [pmid: 19493352].
8 Jensen JU, Hein L, Lundgren B, et al. Procalcitonin-guided interventions against infections to increase early appropriate antibiotics and improve survival in the intensive care unit: A randomized trial. Crit Care Med. 2011. May. 12. [pmid: 21572328].
9 Kristoffersen KB, Sogaard OS, Wejse C, et al. Antibiotic treatment interruption of suspected lower respiratory tract infections based on a single procalcitonin measurement at hospital admission--a randomized trial. Clin Microbiol Infect. May. 2009;15(5):481-7. [pmid: 19416298].
10 Long W, Deng X, Zhang Y, et al. Procalcitonin guidance for reduction of antibiotic use in low-risk outpatients with community-acquired pneumonia. Respirology. Jul. 2011;16(5):819-24. [pmid: 21507143].
11 Manzano S, Bailey B, Girodias JB, et al. Impact of procalcitonin on the management of children aged 1 to 36 months presenting with fever without source: a randomized controlled trial. Am J Emerg Med. Jul. 2010;28(6):647-53. [pmid: 20637377].
12 Nobre V, Harbarth S, Graf JD, et al. Use of procalcitonin to shorten antibiotic treatment duration in septic patients: a randomized trial. Am J Respir Crit Care Med. Mar. 1. 2008;177(5):498-505. [pmid: 18096708].
13 Schuetz P, Christ-Crain M, Thomann R, et al. Effect of procalcitonin-based guidelines vs standard guidelines on antibiotic use in lower respiratory tract infections: the ProHOSP randomized controlled trial. JAMA. Sep. 9. 2009;302(10):1059-66. [pmid: 19738090].
14 Schroeder S, Hochreiter M, Koehler T, et al. Procalcitonin (PCT)-guided algorithm reduces length of antibiotic treatment in surgical intensive care patients with severe sepsis: results of a prospective randomized study. Langenbecks Arch Surg. Mar. 2009;394(2):221-6. [pmid: 19034493].
15 Stocker M, Fontana M, El Helou S, et al. Use of procalcitonin-guided decision-making to shorten antibiotic therapy in suspected neonatal early-onset sepsis: prospective randomized intervention trial. Neonatology. 2010;97(2):165-74. [pmid: 19776651].
16 Stolz D, Christ-Crain M, Bingisser R, et al. Antibiotic treatment of exacerbations of COPD: a randomized, controlled trial comparing procalcitonin-guidance with standard therapy. Chest. Jan. 2007;131(1):9-19. [pmid: 17218551].
17 Stolz D, Smyrnios N, Eggimann P, et al. Procalcitonin for reduced antibiotic exposure in ventilator-associated pneumonia: a randomised study. Eur Respir J. Dec. 2009;34(6):1364-75. [pmid: 19797133].
18 Svoboda P, Kantorova I, Scheer P, et al. Can procalcitonin help us in timing of re-intervention in septic patients after multiple trauma or major surgery?. Hepatogastroenterology. Mar. 2007;54(74):359-63. [pmid: 17523274].