# Excluded Studies

EXC exclude

NRD not relevant disease (not relevant population)

NDE not relevant design

NRO not relevant outcome

SMN small n

Aalto H, Takala A, Kautiainen H, Repo H. Laboratory markers of systemic inflammation as predictors of bloodstream infection in acutely ill patients admitted to hospital in medical emergency. Eur J Clin Microbiol Infect Dis. 2004;23(9):699-704. Rec#: 4180. Exclusion Codes: SMN, EXC. [pmid: 15309668].
Adamik B, Kubler-Kielb J, Golebiowska B, Gamian A, Kubler A. Effect of sepsis and cardiac surgery with cardiopulmonary bypass on plasma level of nitric oxide metabolites, neopterin, and procalcitonin: correlation with mortality and postoperative complications. Intensive Care Med. 2000;26(9):1259-67. Rec#: 5940. Exclusion Codes: NDE, EXC. [pmid: 11089751].
Ahmadinejad Z, Dadsetan B, Jalili M, Soudbakhsh A, Rasolinejad M. Evaluation of serum procalcitonin in patients with systemic inflammatory response syndrome with and without infection. Acta Med. Iran. 2009;47(5):383-388. Rec#: 11910. Exclusion Codes: NDE, EXC.
Ahmadinejad Z, Soudbakhsh AR, Tayebi A. Serum procalcitonin level in infectious and non- infectious systemic inflammatory response syndrome: A three- year study. Tehran Uni. Med. J. 2010;67(10):724-730. Rec#: 11880. Exclusion Codes: NRD, EXC.
Ahn S, Kim WY, Yoon JY, Sohn CH, Seo DW, Kim SH, Hong SB, Lim CM, Koh YS, Kim W. Procalcitonin in 2009 H1N1 influenza pneumonia: Role in differentiating from bacterial pneumonia. Tuberc. Respir. Dis. 2010;68(4):205-211. Rec#: 15470. Exclusion Codes: NRD, EXC.
Aikawa N, Fujishima S, Endo S, Sekine I, Kogawa K, Yamamoto Y, Kushimoto S, Yukioka H, Kato N, Totsuka K, Kikuchi K, Ikeda T, Ikeda K, Harada K, Satomura S. Multicenter prospective study of procalcitonin as an indicator of sepsis. J Infect Chemother. 2005;11(3):152-9. Rec#: 3770. Exclusion Codes: NDE, EXC. [pmid: 15990980].
Ali AM, Moaz MA, Ghoniem E, Abd El Motaleb T, Sheri N. Reliability of serum procalcitonin concentrations for the diagnosis of sepsis in neonates. Egypt J Immunol. 2008;15(1):75-84. Rec#: 2210. Exclusion Codes: NDE, EXC. [pmid: 20306671].
Al-Nawas B, Krammer I, Shah PM. Procalcitonin in diagnosis of severe infections. Eur J Med Res. 1996;1(7):331-3. Rec#: 6910. Exclusion Codes: NDE, EXC. [pmid: 9364034].
Al-Nawas B, Shah P. Procalcitonin in acute malaria. Eur J Med Res. 1997;2(5):206-8. Rec#: 6840. Exclusion Codes: SMN, EXC. [pmid: 9153345].
al-Nawas B, Shah PM. Procalcitonin in patients with and without immunosuppression and sepsis. Infection. 1996;24(6):434-6. Rec#: 6890. Exclusion Codes: NDE, EXC. [pmid: 9007590].
Ames PR, Walker E, Aw D, Marshall D, de Villiers F, Staber M. Multi-organ failure in adult onset Still's disease: a septic disguise. Clin Rheumatol. Suppl 1. 2009;28:S3-6. Rec#: 1360. Exclusion Codes: NDE, EXC. [pmid: 18839267].
Amour J, Birenbaum A, Langeron O, Le Manach Y, Bertrand M, Coriat P, Riou B, Bernard M, Hausfater P. Influence of renal dysfunction on the accuracy of procalcitonin for the diagnosis of postoperative infection after vascular surgery. Crit Care Med. 2008;36(4):1147-54. Rec#: 1950. Exclusion Codes: NDE, EXC. [pmid: 18379240].
Andermahr J, Greb A, Hensler T, Helling HJ, Bouillon B, Sauerland S, Rehm KE, Neugebauer E. Pneumonia in multiple injured patients: a prospective controlled trial on early prediction using clinical and immunological parameters. Inflamm Res. 2002;51(5):265-72. Rec#: 5300. Exclusion Codes: NDE, EXC. [pmid: 12056515].
Anderson R, Schmidt R. Clinical biomarkers in sepsis. Front Biosci (Elite Ed). 2010;2:504-20. Rec#: 270. Exclusion Codes: NRD, EXC. [pmid: 20036897].
Andreola B, Bressan S, Callegaro S, Liverani A, Plebani M, Da Dalt L. Procalcitonin and C-reactive protein as diagnostic markers of severe bacterial infections in febrile infants and children in the emergency department. Pediatr Infect Dis J. 2007;26(8):672-7. Rec#: 8250. Exclusion Codes: NDE, EXC. [pmid: 17848876].
Aouifi A, Piriou V, Bastien O, Blanc P, Bouvier H, Evans R, Celard M, Vandenesch F, Rousson R, Lehot JJ. Usefulness of procalcitonin for diagnosis of infection in cardiac surgical patients. Crit Care Med. 2000;28(9):3171-6. Rec#: 6010. Exclusion Codes: NDE, EXC. [pmid: 11008977].
Aouifi A, Piriou V, Blanc P, Bouvier H, Bastien O, Chiari P, Rousson R, Evans R, Lehot JJ. Effect of cardiopulmonary bypass on serum procalcitonin and C-reactive protein concentrations. Br J Anaesth. 1999;83(4):602-7. Rec#: 6260. Exclusion Codes: NRO, EXC. [pmid: 10673877].
Apostolakis EE, Prokakis C, Dougenis D. Are procalcitonin levels sufficient for the follow up of patients undergoing lung decortication for pleural empyema?. Eur J Cardiothorac Surg. 2009;35(1):193. author reply 194. Rec#: 1220. Exclusion Codes: NDE, EXC. [pmid: 19046888].
Arkader R, Troster EJ, Lopes MR, Junior RR, Carcillo JA, Leone C, Okay TS. Procalcitonin does discriminate between sepsis and systemic inflammatory response syndrome. Arch Dis Child. 2006;91(2):117-20. Rec#: 3560. Exclusion Codes: SMN, EXC. [pmid: 16326799].
Assicot M, Gendrel D, Carsin H, Raymond J, Guilbaud J, Bohuon C. High serum procalcitonin concentrations in patients with sepsis and infection. Lancet. 1993;341(8844):515-8. Rec#: 6930. Exclusion Codes: NRO, EXC. [pmid: 8094770].
Atanasova V, Rosmanova R, Andreeva H. Procalcitonin: An innovative marker for bacterial infections. Biochemical, immunological and clinical aspects (chapter 2). Clin. Appl. Immunol. 2002;1(1):23-27. Rec#: 14680. Exclusion Codes: NDE, EXC.
Athhan F, Akagunduz B, Genel F, Bak M, Can D. Procalcitonin: a marker of neonatal sepsis. J Trop Pediatr. 2002;48(1):10-4. Rec#: 5490. Exclusion Codes: NDE, EXC. [pmid: 11866330].
Ayazi P, Mahyar A, Hashemi HJ, Daneshi MM, Karimzadeh T, Salimi F. Comparison of procalcitonin and C-reactive protein tests in children with urinary tract infection. Iran. J. Pediatr. 2009;19(4):381-386. Rec#: 15670. Exclusion Codes: NDE, EXC.
Aygun C, Oran O, Portakal O. Procalcitonin: Levels in newborns and as an indicator in the diagnosis of neonatal sepsis. Yenidoganlarda prokalsitonin duzeyleri ve sepsis tanisindaki yeri. Cocuk Sagligi Hast. Derg. 2003;46(2):83-89. Rec#: 14410. Exclusion Codes: NRD, EXC.
Azarpira N, Ramzi M, Aghdaie M, Daraie M. Procalcitonin and C-reactive protein serum levels after hematopoietic stem-cell transplant. Exp Clin Transplant. 2009;7(2):115-8. Rec#: 580. Exclusion Codes: NDE, EXC. [pmid: 19715516].
Aznar-Oroval E, Sanchez-Yepes M, Lorente-Alegre P, San Juan-Gadea MC, Ortiz-Munoz B, Prez-Ballestero P, Picn-Roig I, Maquez-Richart J. Diagnostic value of procalcitonin, interleukin 8, interleukin 6, and c-reactive protein for detecting bacteremia and fungemia in cancer patients. Valor diagnostico de la procalcitonina, la interleucina 8, la interleucina 6 y la proteina C reactiva en la deteccin de bacteriemia y fungemia en pacientes con cancer. Enferm. Infecc. Microbiol. Clin. 2010;28(5):273-277. Rec#: 11510. Exclusion Codes: NDE, EXC. [pmid: 20097454].
Balci C, Sivaci R, Akbulut G, Karabekir HS. Procalcitonin levels as an early marker in patients with multiple trauma under intensive care. J Int Med Res. 2009;37(6):1709-17. Rec#: 170. Exclusion Codes: NDE, EXC. [pmid: 20146868].
BalcI C, Sungurtekin H, Gurses E, Sungurtekin U, Kaptanoglu B. Usefulness of procalcitonin for diagnosis of sepsis in the intensive care unit. Crit Care. 2003;7(1):85-90. Rec#: 4970. Exclusion Codes: SMN, EXC. [pmid: 12617745].
Ballot DE, Perovic O, Galpin J, Cooper PA. Serum procalcitonin as an early marker of neonatal sepsis. S Afr Med J. 2004;94(10):851-4. Rec#: 4070. Exclusion Codes: NDE, EXC. [pmid: 15532763].
Barati M, Alinejad F, Bahar MA, Tabrisi MS, Shamshiri AR, Bodouhi NO, Karimi H. Comparison of WBC, ESR, CRP and PCT serum levels in septic and non-septic burn cases. Burns. 2008;34(6):770-4. Rec#: 1600. Exclusion Codes: SMN, EXC. [pmid: 18513877].
Bargues L, Chancerelle Y, Catineau J, Jault P, Carsin H. Evaluation of serum procalcitonin concentration in the ICU following severe burn. Burns. 2007;33(7):860-4. Rec#: 2710. Exclusion Codes: SMN, EXC. [pmid: 17532575].
Barnes C, Ignjatovic V, Newall F, Carlin J, Ng F, Hamilton S, Ashley D, Waters K, Monagle P. Change in serum procalcitonin (deltaPCT) predicts the clinical outcome of children admitted with febrile neutropenia. Br J Haematol. 2002;118(4):1197-8. Rec#: 5190. Exclusion Codes: SMN, EXC. [pmid: 12199815].
Baruti Gafurri Z, Pacarizi H, Zhubi B, Begolli L, Topciu V. The importance of determining procalcitonin and C reactive protein in different stages of sepsis. Bosn J Basic Med Sci. 2010;10(1):60-4. Rec#: 150. Exclusion Codes: NRO, EXC. [pmid: 20192933].
Basler T, Meier-Hellmann A, Bredle D, Reinhart K. Amino acid imbalance early in septic encephalopathy. Intensive Care Med. 2002;28(3):293-8. Rec#: 5460. Exclusion Codes: SMN, EXC. [pmid: 11904658].
Batard E, Asseray N, Kenzi A, Gueffet I, Orsonneau JL, Potel G. Role of C-reactive protein and procalcitonin in the management of sepsis: Meningitis. Interet de la proteine C-reactive et de la procalcitonine dans la prise en charge des sepsis: L'exemple de la meningite. Med. Ther. 2003;9(1-2):26-31. Rec#: 14500. Exclusion Codes: NRD, EXC.
Baumgarten R, Pequeriaux NCV, Van Puyenbroek MJE, Speelberg B. Diagnosis of sepsis by procalcitonin: Is procalcitonine van additionele waarde bij de diagnostiek van sepsis?. Ned. Tijdschr. Klin. Chem. 2002;27(1):32-35. Rec#: 14670. Exclusion Codes: NRD, EXC.
Baykut D, Schulte-Herbruggen J, Krian A. The value of procalcitonin as an infection marker in cardiac surgery. Eur J Med Res. 2000;5(12):530-6. Rec#: 5910. Exclusion Codes: NRO, EXC. [pmid: 11147997].
Baylan O, Balkan A, Inal A, Kisa O, Albay A, Doganci L, Acikel CH. The predictive value of serum procalcitonin levels in adult patients with active pulmonary tuberculosis. Jpn J Infect Dis. 2006;59(3):164-7. Rec#: 8770. Exclusion Codes: NDE, EXC. [pmid: 16785696].
Becker KL, Snider R, Nylen ES. Procalcitonin assay in systemic inflammation, infection, and sepsis: clinical utility and limitations. Crit Care Med. 2008;36(3):941-52. Rec#: 1870. Exclusion Codes: NRD, EXC. [pmid: 18431284].
Becker KL, Snider R, Nylen ES. Procalcitonin in sepsis and systemic inflammation: a harmful biomarker and a therapeutic target. Br J Pharmacol. 2010;159(2):253-64. Rec#: 300. Exclusion Codes: NDE, EXC. [pmid: 20002097].
Beghetti M, Rimensberger PC, Kalangos A, Habre W, Gervaix A. Kinetics of procalcitonin, interleukin 6 and C-reactive protein after cardiopulmonary-bypass in children. Cardiol Young. 2003;13(2):161-7. Rec#: 9870. Exclusion Codes: NRO, EXC. [pmid: 12887072].
Bell K, Wattie M, Byth K, Silvestrini R, Clark P, Stachowski E, Benson EM. Procalcitonin: a marker of bacteraemia in SIRS. Anaesth Intensive Care. 2003;31(6):629-36. Rec#: 4500. Exclusion Codes: NDE, EXC. [pmid: 14719423].
Bellmann-Weiler R, Ausserwinkler M, Kurz K, Theurl I, Weiss G. Clinical potential of C-reactive protein and procalcitonin serum concentrations to guide differential diagnosis and clinical management of pneumococcal and Legionella pneumonia. J. Clin. Microbiol. 2010;48(5):1915-1917. Rec#: 15440. Exclusion Codes: NDE, EXC. [pmid: 20220163].
Benador N, Siegrist CA, Gendrel D, Greder C, Benador D, Assicot M, Bohuon C, Girardin E. Procalcitonin is a marker of severity of renal lesions in pyelonephritis. Pediatrics. 1998;102(6):1422-5. Rec#: 10720. Exclusion Codes: SMN, EXC. [pmid: 9832579].
Bender L, Thaarup J, Varming K, Krarup H, Ellermann-Eriksen S, Ebbesen F. Early and late markers for the detection of early-onset neonatal sepsis. Dan Med Bull. 2008;55(4):219-23. Rec#: 1040. Exclusion Codes: NDE, EXC. [pmid: 19232162].
Benhamou D. Optimal duration of antibiotic therapy in community acquired pneumonia. Durees optimales de l'antibiotherapie dans les pneumonies communautaires. Rev. Mal. Respir. 2009;26(4):458-460. Rec#: 12380. Exclusion Codes: NDE, EXC. [pmid: 19421102].
Benitz WE. Adjunct laboratory tests in the diagnosis of early-onset neonatal sepsis. Clin. Perinatol. 2010;37(2):421-438. Rec#: 11410. Exclusion Codes: NDE, EXC. [pmid: 20569816].
Benoist JF, Mimoz O, Assicot M, Edouard A. Serum procalcitonin, but not C-reactive protein, identifies sepsis in trauma patients. Clin Chem. 1998;44(8 Pt 1):1778-9. Rec#: 6720. Exclusion Codes: NDE, EXC. [pmid: 9702980].
Beovic B, Kreft S, Osredkar J, Kese D, Bonac-Tuma B. Serum procalcitonin levels in patients with mild community-acquired pneumonia. Clin Microbiol Infect. 2005;11(12):1050-1. Rec#: 8990. Exclusion Codes: NRO, EXC. [pmid: 16307566].
Berger C, Schwarz S, Schaebitz WR, Aschoff A, Schwab S. Serum procalcitonin in cerebral ventriculitis. Crit Care Med. 2002;30(8):1778-81. Rec#: 5220. Exclusion Codes: SMN, EXC. [pmid: 12163792].
Bergmann A, Bohuon C. Decrease of serum dipeptidylpeptidase activity in severe sepsis patients: relationship to procalcitonin. Clin Chim Acta. 2002;321(1-2):123-6. Rec#: 5320. Exclusion Codes: NRO, EXC. [pmid: 12031601].
Bernard L, Ferriere F, Casassus P, Malas F, Leveque S, Guillevin L, Lortholary O. Procalcitonin as an early marker of bacterial infection in severely neutropenic febrile adults. Clin Infect Dis. 1998;27(4):914-5. Rec#: 6640. Exclusion Codes: NDE, EXC. [pmid: 9798066].
Bernstein LH, Devakonda A, Engelman E, Pancer G, Ferraraf J, Rucinski J, Raoof S, George L, Melniker L. The role of procalcitonin in the diagnosis of sepsis and patient assignment to medical intensive care. J. Clin. Ligand Assay. 2007;30(3-4):98-104. Rec#: 13240. Exclusion Codes: NDE, EXC.
Bewick T, Lim WS. Diagnosis of community-acquired pneumonia in adults. Expert Rev. Respir. Med. 2009;3(2):153-164. Rec#: 15790. Exclusion Codes: NDE, EXC. [pmid: 20477309].
Bhatia BD, Basu S. Newer diagnostic tests for bacterial diseases. Indian J Pediatr. 2007;74(7):673-7. Rec#: 8310. Exclusion Codes: NDE, EXC. [pmid: 17699977].
Bignardi GE, Dhar R, Heycock R, Bansal S, Majmudar N. Can procalcitonin testing reduce antibiotic prescribing for respiratory infections?. Age Ageing. 2006;35(6):625-6. Rec#: 8730. Exclusion Codes: NDE, EXC. [pmid: 16822805].
Billeter A, Turina M, Seifert B, Mica L, Stocker R, Keel M. Early serum procalcitonin, interleukin-6, and 24-hour lactate clearance: useful indicators of septic infections in severely traumatized patients. World J Surg. 2009;33(3):558-66. Rec#: 1080. Exclusion Codes: NDE, EXC. [pmid: 19148699].
Bistrian BR. Acute phase proteins and the systemic inflammatory response. Crit Care Med. 1999;27(3):452-3. Rec#: 6550. Exclusion Codes: NDE, EXC. [pmid: 10199509].
Bitkover CY, Hansson LO, Valen G, Vaage J. Effects of cardiac surgery on some clinically used inflammation markers and procalcitonin. Scand Cardiovasc J. 2000;34(3):307-14. Rec#: 6070. Exclusion Codes: NRO, EXC. [pmid: 10935779].
Blijlevens NM, Donnelly JP, Meis JF, De Keizer MH, De Pauw BE. Procalcitonin does not discriminate infection from inflammation after allogeneic bone marrow transplantation. Clin Diagn Lab Immunol. 2000;7(6):889-92. Rec#: 10480. Exclusion Codes: NDE, EXC. [pmid: 11063493].
Blommendahl J, Janas M, Laine S, Miettinen A, Ashorn P. Comparison of procalcitonin with CRP and differential white blood cell count for diagnosis of culture-proven neonatal sepsis. Scand J Infect Dis. 2002;34(8):620-2. Rec#: 5120. Exclusion Codes: NDE, EXC. [pmid: 12238581].
Boeken U, Feindt P, Micek M, Petzold T, Schulte HD, Gams E. Procalcitonin (PCT) in cardiac surgery: diagnostic value in systemic inflammatory response syndrome (SIRS), sepsis and after heart transplantation (HTX). Cardiovasc Surg. 2000;8(7):550-4. Rec#: 5980. Exclusion Codes: NDE, EXC. [pmid: 11068216].
Boeken U, Feindt P, Mohan E, Petzold Th, Micek M, Gams E. The influence of extracorporeal circulation and inflammatory responses such as SIRS and sepsis on secretion of procalcitonin (PCT). J. Clin. Basic Cardiol. 1999;2(2):225-227. Rec#: 15020. Exclusion Codes: SMN, EXC.
Boeken U, Feindt P, Petzold T, Klein M, Micek M, Seyfert UT, Mohan E, Schulte HD, Gams E. Diagnostic value of procalcitonin: the influence of cardiopulmonary bypass, aprotinin, SIRS, and sepsis. Thorac Cardiovasc Surg. 1998;46(6):348-51. Rec#: 6590. Exclusion Codes: NRO, EXC. [pmid: 9928856].
Bogar L, Molnar Z, Kenyeres P, Tarsoly P. Sedimentation characteristics of leucocytes can predict bacteraemia in critical care patients. J Clin Pathol. 2006;59(5):523-5. Rec#: 3410. Exclusion Codes: SMN, EXC. [pmid: 16533954].
Bogar L, Molnar Z, Tarsoly P, Kenyeres P, Marton S. Serum procalcitonin level and leukocyte antisedimentation rate as early predictors of respiratory dysfunction after oesophageal tumour resection. Crit Care. 2006;10(4):R110. Rec#: 3240. Exclusion Codes: SMN, EXC. [pmid: 16859526].
Bollu M, Marte-Grau AC, Bobba RK. Procalcitonin-guided antibiotic use in acute respiratory tract infections. Arch Intern Med. 2009;169(7):716. Rec#: 7450. Exclusion Codes: NDE, EXC. [pmid: 19365003].
Bonac B, Derganc M, Wraber B, Hojker S. Interleukin-8 and procalcitonin in early diagnosis of early severe bacterial infection in critically ill neonates. Pflugers Arch. 2000;440(5 Suppl):R72-4. Rec#: 6020. Exclusion Codes: NDE, EXC. [pmid: 11005618].
Boo NY, Nor Azlina AA, Rohana J. Usefulness of a semi-quantitative procalcitonin test kit for early diagnosis of neonatal sepsis. Singapore Med J. 2008;49(3):204-8. Rec#: 1990. Exclusion Codes: NDE, EXC. [pmid: 18363001].
Bossink AW, Groeneveld AB, Thijs LG. Prediction of microbial infection and mortality in medical patients with fever: plasma procalcitonin, neutrophilic elastase-alpha1-antitrypsin, and lactoferrin compared with clinical variables. Clin Infect Dis. 1999;29(2):398-407. Rec#: 6420. Exclusion Codes: NDE, EXC. [pmid: 10476749].
Bota DP, Van Nuffelen M, Zakariah AN, Vincent JL. Serum levels of C-reactive protein and procalcitonin in critically ill patients with cirrhosis of the liver. J Lab Clin Med. 2005;146(6):347-51. Rec#: 3570. Exclusion Codes: NDE, EXC. [pmid: 16310518].
Bottner F, Wegner A, Winkelmann W, Becker K, Erren M, Gotze C. Interleukin-6, procalcitonin and TNF-alpha: markers of peri-prosthetic infection following total joint replacement. J Bone Joint Surg Br. 2007;89(1):94-9. Rec#: 2970. Exclusion Codes: SMN, EXC. [pmid: 17259424].
Bouadma L, Luyt CE, Tubach F, Chastre J, Wolff M. Procalcitonin in intensive care units: the PRORATA trial - Authors' reply. Lancet. 2010;375(9726):1606-1607. Rec#: 11430. Exclusion Codes: NDE, EXC. [pmid: 20452516].
Bouros D, Anevlavis S. Scoring systems in community acquired pneumonia. Pneumon. 2009;22(4). Rec#: 12070. Exclusion Codes: NRD, EXC.
Boussekey N, Leroy O, Alfandari S, Devos P, Georges H, Guery B. Procalcitonin kinetics in the prognosis of severe community-acquired pneumonia. Intensive Care Med. 2006;32(3):469-72. Rec#: 3450. Exclusion Codes: NDE, EXC. [pmid: 16477418].
Boussekey N, Leroy O, Georges H, Devos P, d'Escrivan T, Guery B. Diagnostic and prognostic values of admission procalcitonin levels in community-acquired pneumonia in an intensive care unit. Infection. 2005;33(4):257-63. Rec#: 3690. Exclusion Codes: NDE, EXC. [pmid: 16091896].
Bressan S, Andreola B, Zucchetta P, Montini G, Burei M, Perilongo G, Da Dalt L. Procalcitonin as a predictor of renal scarring in infants and young children. Pediatr Nephrol. 2009;24(6):1199-204. Rec#: 7560. Exclusion Codes: SMN, EXC. [pmid: 19205751].
Briel M, Christ-Crain M, Young J, Schuetz P, Huber P, Periat P, Bucher HC, Muller B. Procalcitonin-guided antibiotic use versus a standard approach for acute respiratory tract infections in primary care: study protocol for a randomised controlled trial and baseline characteristics of participating general practitioners. BMC Fam Pract. 2005;6:34. Rec#: 9090. Exclusion Codes: NDE, EXC. [pmid: 16107222].
Brines R, Thorne M. Clinical consensus on COPD. Respir. Med. COPD Update. 2007;3(2):42-48. Rec#: 13340. Exclusion Codes: NDE, EXC.
Brodska H, Drabek T, Malickova K, Kazda A, Vitek A, Zima T, Markova M. Marked increase of procalcitonin after the administration of anti-thymocyte globulin in patients before hematopoietic stem cell transplantation does not indicate sepsis: a prospective study. Crit Care. 2009;13(2):R37. Rec#: 1010. Exclusion Codes: NDE, EXC. [pmid: 19291300].
Brown JS. Biomarkers and community-acquired pneumonia. Thorax. 2009;64(7):556-8. Rec#: 7320. Exclusion Codes: NDE, EXC. [pmid: 19561275].
Brown RO, Alexander E Jr, Hanes SD, Wood GC, Kudsk KA, Dickerson RN. Procalcitonin and enteral nutrition tolerance in critically ill patients. JPEN J Parenter Enteral Nutr. 2003;27(1):84-8. Rec#: 5010. Exclusion Codes: NRO, EXC. [pmid: 12549604].
Brunkhorst FM. Endotoxins in chronic heart failure. Lancet. 1999;354(9178):599-600. Rec#: 10670. Exclusion Codes: NRD, EXC. [pmid: 10470730].
Brunkhorst FM, Al-Nawas B, Krummenauer F, Forycki ZF, Shah PM. Procalcitonin, C-reactive protein and APACHE II score for risk evaluation in patients with severe pneumonia. Clin Microbiol Infect. 2002;8(2):93-100. Rec#: 5390. Exclusion Codes: NRO, EXC. [pmid: 11952722].
Brunkhorst FM, Clark AL, Forycki ZF, Anker SD. Pyrexia, procalcitonin, immune activation and survival in cardiogenic shock: the potential importance of bacterial translocation. Int J Cardiol. 1999;72(1):3-10. Rec#: 6320. Exclusion Codes: NRO, EXC. [pmid: 10636626].
Brunkhorst FM, Eberhard OK, Brunkhorst R. Discrimination of infectious and noninfectious causes of early acute respiratory distress syndrome by procalcitonin. Crit Care Med. 1999;27(10):2172-6. Rec#: 6360. Exclusion Codes: NRO, EXC. [pmid: 10548201].
Brunkhorst FM, Forycki ZF. Procalcitonin - An early and highly specific marker of bacterial or fungal induced sepsis. Clin. Chem. Lab. Med. 1998;36(4):A13. Rec#: 15170. Exclusion Codes: NRO, EXC.
Brunkhorst FM, Forycki ZF, Wagner J. Early identification of biliary acute pancreatitis with procalcitonin immunoreactivity-preliminary results. FRUHE IDENTIFIZIERUNG DER BILIAREN AKUTEN PANKREATITIS DURCH PROCALCITONIN-IMMUNREAKTIVITAT-VORLAUFIGE ERGEBNISSE. CHIR. GASTROENTEROL. INTERDISZIP. GESPR. 1995;11(SUPPL. 2):42-46. Rec#: 17170. Exclusion Codes: NRD, EXC.
Brunkhorst FM, Wegscheider K, Forycki ZF, Brunkhorst R. Procalcitonin for early diagnosis and differentiation of SIRS, sepsis, severe sepsis, and septic shock. Intensive Care Med. Suppl 2. 2000;26:S148-52. Rec#: 1770. Exclusion Codes: NDE, EXC. [pmid: 18470710].
Brunkhorst R, Eberhardt OK, Haubitz M, Brunkhorst FM. Procalcitonin for discrimination between activity of systemic autoimmune disease and systemic bacterial infection. Intensive Care Med. Suppl 2. 2000;26:S199-201. Rec#: 7910. Exclusion Codes: NDE, EXC. [pmid: 18470720].
Brusius AC, Zavascki AP, Costa S. How efficient is procalcitonin-guided antibiotic use in acute respiratory tract infections in primary care?. Arch Intern Med. 2009;169(13):1244. Rec#: 7300. Exclusion Codes: NDE, EXC. [pmid: 19597077].
Bugden SA, Coles C, Mills GD. The potential role of procalcitonin in the emergency department management of febrile young adults during a sustained meningococcal epidemic. Emerg Med Australas. 2004;16(2):114-9. Rec#: 9580. Exclusion Codes: NDE, EXC. [pmid: 15239725].
Bulbuller N, Dogru O, Ayten R, Akbulut H, Ilhan YS, Cetinkaya Z. Procalcitonin is a predictive marker for severe acute pancreatitis. Ulus Travma Acil Cerrahi Derg. 2006;12(2):115-20. Rec#: 8800. Exclusion Codes: SMN, EXC. [pmid: 16676250].
Bulut G, Yasmin D, Ak D, Yyldyz M. Value of procalcitonin in differentiating post-surgical systemic and infectious complications from inflammatory reaction caused by surgical trauma in fracture surgery: Preliminary report. Eur. J. Orthop. Surg. Traumatol. 2010;20(1):1-10. Rec#: 11900. Exclusion Codes: SMN, EXC.
Burgel PR. Applications and limitations of biological markers in lower respiratory tract infections. Apports et limites des marqueurs biologiques dans les infections respiratoires basses. Rev. Mal. Respir. 2009;26(4):456-457. Rec#: 15950. Exclusion Codes: NDE, EXC. [pmid: 19421101].
Butbul-Aviel Y, Koren A, Halevy R, Sakran W. Procalcitonin as a diagnostic aid in osteomyelitis and septic arthritis. Pediatr Emerg Care. 2005;21(12):828-32. Rec#: 3550. Exclusion Codes: NDE, EXC. [pmid: 16340758].
Cabioglu N, Bilgic S, Deniz G, Aktas E, Seyhun Y, Turna A, Gunay K, Esen F. Decreased cytokine expression in peripheral blood leukocytes of patients with severe sepsis. Arch Surg. 2002;137(9):1037-43. discussion 1043. Rec#: 5160. Exclusion Codes: NRO, EXC. [pmid: 12215155].
Cabre M. Pneumonia in the elderly. Curr. Opin. Pulm. Med. 2009;15(3):223-229. Rec#: 15890. Exclusion Codes: NDE, EXC. [pmid: 19276811].
Cakir E, Deniz O, Ozcan O, Tozkoparan E, Yaman H, Akgul EO, Bilgi C, Bilgic H, Ekiz K, Erbil MK. Pleural fluid and serum procalcitonin as diagnostic tools in tuberculous pleurisy. Clin Biochem. 2005;38(3):234-8. Rec#: 9350. Exclusion Codes: SMN, EXC. [pmid: 15708544].
Cals JW, Metlay JP. Procalcitonin-based guidelines and lower respiratory tract infections. JAMA. 2010;303(5):418. author reply 419-20. Rec#: 7000. Exclusion Codes: NDE, EXC. [pmid: 20124534].
Cardelli P, Ferraironi M, Amodeo R, Tabacco F, De Blasi RA, Nicoletti M, Sessa R, Petrucca A, Costante A, Cipriani P. Evaluation of neutrophil CD64 expression and procalcitonin as useful markers in early diagnosis of sepsis. Int J Immunopathol Pharmacol. 2008;21(1):43-9. Rec#: 2020. Exclusion Codes: NDE, EXC. [pmid: 18336730].
Carlet J. Rapid diagnostic methods in the detection of sepsis. Infect Dis Clin North Am. 1999;13(2):483-94. xi. Rec#: 6510. Exclusion Codes: NDE, EXC. [pmid: 10340179].
Carpenter CR, Keim SM, Upadhye S, Nguyen HB. Risk stratification of the potentially septic patient in the emergency department: the Mortality in the Emergency Department Sepsis (MEDS) score. J Emerg Med. 2009;37(3):319-27. Rec#: 890. Exclusion Codes: NDE, EXC. [pmid: 19427752].
Carrol ED, Mankhambo LA, Jeffers G, Parker D, Guiver M, Newland P, Banda DL, Molyneux EM, Heyderman RS, Molyneux ME, Hart CA. The diagnostic and prognostic accuracy of five markers of serious bacterial infection in Malawian children with signs of severe infection. PLoS One. 2009;4(8):e6621. Rec#: 7260. Exclusion Codes: NDE, EXC. [pmid: 19675669].
Carrol ED, Newland P, Riordan FA, Thomson AP, Curtis N, Hart CA. Procalcitonin as a diagnostic marker of meningococcal disease in children presenting with fever and a rash. Arch Dis Child. 2002;86(4):282-5. Rec#: 5440. Exclusion Codes: NDE, EXC. [pmid: 11919107].
Carrol ED, Newland P, Thomson AP, Hart CA. Prognostic value of procalcitonin in children with meningococcal sepsis. Crit Care Med. 2005;33(1):224-5. Rec#: 4020. Exclusion Codes: SMN, EXC. [pmid: 15644674].
Carrol ED, Thomson AP, Hart CA. Procalcitonin as a marker of sepsis. Int J Antimicrob Agents. 2002;20(1):1-9. Rec#: 5240. Exclusion Codes: NDE, EXC. [pmid: 12127705].
Casado-Flores J, Blanco-Quiros A, Asensio J, Arranz E, Garrote JA, Nieto M. Serum procalcitonin in children with suspected sepsis: a comparison with C-reactive protein and neutrophil count. Pediatr Crit Care Med. 2003;4(2):190-5. Rec#: 4820. Exclusion Codes: SMN, EXC. [pmid: 12749651].
Casado-Flores J, Blanco-Quiros A, Nieto M, Asensio J, Fernandez C. Prognostic utility of the semi-quantitative procalcitonin test, neutrophil count and C-reactive protein in meningococcal infection in children. Eur J Pediatr. 2006;165(1):26-9. Rec#: 3620. Exclusion Codes: SMN, EXC. [pmid: 16249930].
Castelli GP, Pognani C, Cita M, Paladini R. Procalcitonin as a prognostic and diagnostic tool for septic complications after major trauma. Crit Care Med. 2009;37(6):1845-9. Rec#: 920. Exclusion Codes: SMN, EXC. [pmid: 19384224].
Castelli GP, Pognani C, Cita M, Stuani A, Sgarbi L, Paladini R. Procalcitonin, C-reactive protein, white blood cells and SOFA score in ICU: diagnosis and monitoring of sepsis. Minerva Anestesiol. 2006;72(1-2):69-80. Rec#: 3490. Exclusion Codes: NDE, EXC. [pmid: 16407808].
Castelli GP, Pognani C, Meisner M, Stuani A, Bellomi D, Sgarbi L. Procalcitonin and C-reactive protein during systemic inflammatory response syndrome, sepsis and organ dysfunction. Crit Care. 2004;8(4):R234-42. Rec#: 4170. Exclusion Codes: NDE, EXC. [pmid: 15312223].
Caterino JM, Scheatzle MD, Forbes ML, D'Antonio JA. Bacteremic elder emergency department patients: procalcitonin and white count. Acad Emerg Med. 2004;11(4):393-6. Rec#: 4400. Exclusion Codes: NDE, EXC. [pmid: 15064215].
Celebi S, Koner O, Menda F, Balci H, Hatemi A, Korkut K, Esen F. Procalcitonin kinetics in pediatric patients with systemic inflammatory response after open heart surgery. Intensive Care Med. 2006;32(6):881-7. Rec#: 3310. Exclusion Codes: SMN, EXC. [pmid: 16715328].
Cetinkaya M, Ozkan H, Koksal N, Celebi S, Hacimustafaoglu M. Comparison of serum amyloid A concentrations with those of C-reactive protein and procalcitonin in diagnosis and follow-up of neonatal sepsis in premature infants. J Perinatol. 2009;29(3):225-31. Rec#: 1160. Exclusion Codes: NDE, EXC. [pmid: 19078972].
Chaker S, Gnat D, Ben-Ali N, Hansen V, Barlow P, Haumont D, Vertongen F. Measure of maternal procalcitonin in the pregnancy by an ultrasensitive immunoluminometric assay: Diagnostic and pronostic interests. Dosage de la procalcitonine maternelle au cours de la grossesse par une methode immunoluminometrique ultrasensible: Interets diagnostique et pronostique. Immuno-Anal. Biol. Spec. 2003;18(5):256-259. Rec#: 16800. Exclusion Codes: NDE, EXC.
Chakhunashvili L, Inasaridze A, Svanidze S, Samkharadze J, Chkhaidze I. Procalcitonin as the biomarker of inflammation in diagnostics of pediatric appendicular peritonitis and for the prognosis of early postoperative complications. Georgian Med News. 2005;(129):78-81. Rec#: 3470. Exclusion Codes: NRO, EXC. [pmid: 16444038].
Chan YL, Tseng CP, Tsay PK, Chang SS, Chiu TF, Chen JC. Procalcitonin as a marker of bacterial infection in the emergency department: an observational study. Crit Care. 2004;8(1):R12-20. Rec#: 4470. Exclusion Codes: NDE, EXC. [pmid: 14975050].
Charles PE, Castro C, Ruiz-Santana S, Leon C, Saavedra P, Martin E. Serum procalcitonin levels in critically ill patients colonized with Candida spp: new clues for the early recognition of invasive candidiasis?. Intensive Care Med. 2009;35(12):2146-50. Rec#: 480. Exclusion Codes: NDE, EXC. [pmid: 19760210].
Charles PE, Dalle F, Aho S, Quenot JP, Doise JM, Aube H, Olsson NO, Blettery B. Serum procalcitonin measurement contribution to the early diagnosis of candidemia in critically ill patients. Intensive Care Med. 2006;32(10):1577-83. Rec#: 3180. Exclusion Codes: NRO, EXC. [pmid: 16896850].
Charles PE, Kus E, Aho S, Prin S, Doise JM, Olsson NO, Blettery B, Quenot JP. Serum procalcitonin for the early recognition of nosocomial infection in the critically ill patients: a preliminary report. BMC Infect Dis. 2009;9:49. Rec#: 910. Exclusion Codes: SMN, EXC. [pmid: 19386110].
Charles PE, Ladoire S, Aho S, Quenot JP, Doise JM, Prin S, Olsson NO, Blettery B. Serum procalcitonin elevation in critically ill patients at the onset of bacteremia caused by either Gram negative or Gram positive bacteria. BMC Infect Dis. 2008;8:38. Rec#: 1980. Exclusion Codes: SMN, EXC. [pmid: 18366777].
Charles PE, Ladoire S, Snauwaert A, Prin S, Aho S, Pechinot A, Olsson NO, Blettery B, Doise JM, Quenot JP. Impact of previous sepsis on the accuracy of procalcitonin for the early diagnosis of blood stream infection in critically ill patients. BMC Infect Dis. 2008;8:163. Rec#: 1200. Exclusion Codes: NDE, EXC. [pmid: 19055740].
Charles PE, Tinel C, Barbar S, Aho S, Prin S, Doise JM, Olsson NO, Blettery B, Quenot JP. Procalcitonin kinetics within the first days of sepsis: relationship with the appropriateness of antibiotic therapy and the outcome. Crit Care. 2009;13(2):R38. Rec#: 1000. Exclusion Codes: NDE, EXC. [pmid: 19291325].
Chastre J, Luyt CE, Trouillet JL, Combes A. New diagnostic and prognostic markers of ventilator-associated pneumonia. Curr Opin Crit Care. 2006;12(5):446-51. Rec#: 3150. Exclusion Codes: NDE, EXC. [pmid: 16943724].
Chen DY, Chen YM, Ho WL, Chen HH, Shen GH, Lan JL. Diagnostic value of procalcitonin for differentiation between bacterial infection and non-infectious inflammation in febrile patients with active adult-onset Still's disease. Ann Rheum Dis. 2009;68(6):1074-5. Rec#: 7380. Exclusion Codes: SMN, EXC. [pmid: 19435724].
Chen N, Li H, Zhao LY, Liu JB, Huang Q, Wang TH, Hao XM. Therapy for clearing heat and resolving phlegm in treatment of systemic inflammatory response syndrome in acute deterioration stage of chronic obstructive pulmonary disease: A randomized controlled trial. J. Chin. Integr. Med. 2009;7(2):105-109. Rec#: 12430. Exclusion Codes: NRD, EXC.
Cheval C, Timsit JF, Garrouste-Orgeas M, Assicot M, De Jonghe B, Misset B, Bohuon C, Carlet J. Procalcitonin (PCT) is useful in predicting the bacterial origin of an acute circulatory failure in critically ill patients. Intensive Care Med. Suppl 2. 2000;26:S153-8. Rec#: 1760. Exclusion Codes: SMN, EXC. [pmid: 18470711].
Chiesa C, Pacifico L, Mancuso G, Panero A. Procalcitonin in pediatrics: overview and challenge. Infection. 1998;26(4):236-41. Rec#: 6700. Exclusion Codes: NDE, EXC. [pmid: 9717683].
Chiesa C, Pacifico L, Rossi N, Panero A, Matrunola M, Mancuso G. Procalcitonin as a marker of nosocomial infections in the neonatal intensive care unit. Intensive Care Med. Suppl 2. 2000;26:S175-7. Rec#: 1720. Exclusion Codes: NDE, EXC. [pmid: 18470715].
Chiesa C, Panero A, Rossi N, Stegagno M, De Giusti M, Osborn JF, Pacifico L. Reliability of procalcitonin concentrations for the diagnosis of sepsis in critically ill neonates. Clin Infect Dis. 1998;26(3):664-72. Rec#: 6790. Exclusion Codes: NDE, EXC. [pmid: 9524841].
Chiesa C, Pellegrini G, Panero A, Osborn JF, Signore F, Assumma M, Pacifico L. C-reactive protein, interleukin-6, and procalcitonin in the immediate postnatal period: influence of illness severity, risk status, antenatal and perinatal complications, and infection. Clin Chem. 2003;49(1):60-8. Rec#: 5020. Exclusion Codes: NDE, EXC. [pmid: 12507961].
Chirouze C, Schuhmacher H, Rabaud C, Gil H, Khayat N, Estavoyer JM, May T, Hoen B. Low serum procalcitonin level accurately predicts the absence of bacteremia in adult patients with acute fever. Clin Infect Dis. 2002;35(2):156-61. Rec#: 5260. Exclusion Codes: NDE, EXC. [pmid: 12087521].
Chiwakata CB, Manegold C, Bonicke L, Waase I, Julch C, Dietrich M. Procalcitonin as a parameter of disease severity and risk of mortality in patients with Plasmodium falciparum malaria. J Infect Dis. 2001;183(7):1161-4. Rec#: 10410. Exclusion Codes: SMN, EXC. [pmid: 11237849].
Chopin N, Floccard B, Sobas F, Illinger J, Boselli E, Benatir F, Levrat A, Guillaume C, Crozon J, Negrier C, Allaouchiche B. Activated partial thromboplastin time waveform analysis: a new tool to detect infection?. Crit Care Med. 2006;34(6):1654-60. Rec#: 3380. Exclusion Codes: NDE, EXC. [pmid: 16607236].
Christ-Crain M, Morgenthaler NG, Stolz D, Muller C, Bingisser R, Harbarth S, Tamm M, Struck J, Bergmann A, Muller B. Pro-adrenomedullin to predict severity and outcome in community-acquired pneumonia. Crit Care. 2006;10(3):R96. Rec#: 3270. Exclusion Codes: NDE, EXC. [pmid: 16805922].
Christ-Crain M, Muller B. Biomarkers in respiratory tract infections: diagnostic guides to antibiotic prescription, prognostic markers and mediators. Eur Respir J. 2007;30(3):556-73. Rec#: 2430. Exclusion Codes: NRD, EXC. [pmid: 17766633].
Christ-Crain M, Muller B. Procalcitonin and Pneumonia: Is it a useful marker?. Curr. Infect. Dis. Rep. 2007;9(3):233-240. Rec#: 16360. Exclusion Codes: NRD, EXC. [pmid: 17430706].
Christ-Crain M, Schuetz P, Huber AR, Muller B. Procalcitonin: Importance for the diagnosis of bacterial infections. Procalcitonin und seine bedeutung fur die diagnose bakterieller infektionen. LaboratoriumsMedizin. 2008;32(6):425-433. Rec#: 12630. Exclusion Codes: NDE, EXC.
Christ-Crain M, Stolz D, Jutla S, Couppis O, Muller C, Bingisser R, Schuetz P, Tamm M, Edwards R, Muller B, Grossman AB. Free and total cortisol levels as predictors of severity and outcome in community-acquired pneumonia. Am J Respir Crit Care Med. 2007;176(9):913-20. Rec#: 2490. Exclusion Codes: NDE, EXC. [pmid: 17702966].
Christofilopoulou S, Charvalos E, Petrikkos G. Could procalcitonin be a predictive biological marker in systemic fungal infections? Study of 14 cases. Eur. J. Intern. Med. 2002;13(8):493-495. Rec#: 16860. Exclusion Codes: SMN, EXC. [pmid: 12446193].
Chua AP, Lee KH. Procalcitonin in severe acute respiratory syndrome (SARS). J Infect. 2004;48(4):303-6. Rec#: 4390. Exclusion Codes: NRO, EXC. [pmid: 15066330].
Ciaccio M, Fugardi G, Titone L, Romano A, Giordano S, Bivona G, Scarlata F, Vocca L, Di Gangi M. Procalcitonin levels in plasma in oncohaematologic patients with and without bacterial infections. Clin Chim Acta. 2004;340(1-2):149-52. Rec#: 9710. Exclusion Codes: NRO, EXC. [pmid: 14734206].
Claessens YE, Mathevon T, Kierzek G, Grabar S, Jegou D, Batard E, Loyer C, Davido A, Hausfater P, Robert H, Lavagna-Perez L, Bernot B, Plaisance P, Leroy C, Renaud B. Accuracy of C-reactive protein, procalcitonin, and mid-regional pro-atrial natriuretic peptide to guide site of care of community-acquired pneumonia. Intensive Care Med. 2010;36(5):799-809. Rec#: 6960. Exclusion Codes: NDE, EXC. [pmid: 20232049].
Claessens YE, Schmidt J, Batard E, Grabar S, Jegou D, Hausfater P, Kierzek G, Guerin S, Pourriat JL, Dhainaut JF, Ginsburg C. Can C-reactive protein, procalcitonin and mid-regional pro-atrial natriuretic peptide measurements guide choice of in-patient or out-patient care in acute pyelonephritis? Biomarkers In Sepsis (BIS) multicentre study. Clin. Microbiol. Infect. 2010;16(6):753-760. Rec#: 15320. Exclusion Codes: NDE, EXC. [pmid: 19747215].
Claeys R, Vinken S, Spapen H, ver Elst K, Decochez K, Huyghens L, Gorus FK. Plasma procalcitonin and C-reactive protein in acute septic shock: clinical and biological correlates. Crit Care Med. 2002;30(4):757-62. Rec#: 5420. Exclusion Codes: SMN, EXC. [pmid: 11940741].
Clec'h C, Ferriere F, Karoubi P, Fosse JP, Cupa M, Hoang P, Cohen Y. Diagnostic and prognostic value of procalcitonin in patients with septic shock. Crit Care Med. 2004;32(5):1166-9. Rec#: 4300. Exclusion Codes: SMN, EXC. [pmid: 15190968].
Clec'h C, Fosse JP, Karoubi P, Vincent F, Chouahi I, Hamza L, Cupa M, Cohen Y. Differential diagnostic value of procalcitonin in surgical and medical patients with septic shock. Crit Care Med. 2006;34(1):102-7. Rec#: 3500. Exclusion Codes: NDE, EXC. [pmid: 16374163].
Cojocaru IM, Musuroi C, Iacob S, Cojocaru M. Investigation of TNF-alpha, IL-6, IL-8 and of procalcitonin in patients with neurologic complications in sepsis. Rom J Intern Med. 2003;41(1):83-93. Rec#: 4080. Exclusion Codes: NDE, EXC. [pmid: 15529589].
Connert S, Stremmel W, Elsing C. Procalcitonin is a valid marker of infection in decompensated cirrhosis. Z Gastroenterol. 2003;41(2):165-70. Rec#: 10000. Exclusion Codes: NDE, EXC. [pmid: 12592597].
Cooper D, Sharples L, Cornelissen J, Wallwork J, Alexander G, Trull A. Comparison between procalcitonin, serum amyloid A, and C-reactive protein as markers of serious bacterial and fungal infections after solid organ transplantation. Transplant Proc. 2001;33(1-2):1808-10. Rec#: 10370. Exclusion Codes: NDE, EXC. [pmid: 11267522].
Corona G, Artemisia A, Liotta C, Musolino A, Vita G, Quartarone G, Zirilli G, Barberi I. Comparison of procalcitonin with C reactive protein and absolute neutrophil count for the early diagnosis of neonatal infection. Ital. J. Pediat. 2004;30(4):240-244. Rec#: 16720. Exclusion Codes: NRO, EXC.
Cuculi F, Toggweiler S, Auer M, der Maur ChA, Zuber M, Erne P. Serum procalcitonin has the potential to identify Staphylococcus aureus endocarditis. Eur J Clin Microbiol Infect Dis. 2008;27(11):1145-9. Rec#: 1580. Exclusion Codes: SMN, EXC. [pmid: 18521635].
Cunha BA. Empiric antimicrobial therapy of community-acquired pneumonia: clinical diagnosis versus procalcitonin levels. Scand J Infect Dis. 2009;41(10):782-4. Rec#: 7250. Exclusion Codes: NDE, EXC. [pmid: 19681019].
Dahaba AA, Hagara B, Fall A, Rehak PH, List WF, Metzler H. Procalcitonin for early prediction of survival outcome in postoperative critically ill patients with severe sepsis. Br J Anaesth. 2006;97(4):503-8. Rec#: 3260. Exclusion Codes: NDE, EXC. [pmid: 16849384].
Dahaba AA, Metzler H. Procalcitonin's role in the sepsis cascade. Is procalcitonin a sepsis marker or mediator?. Minerva Anestesiol. 2009;75(7-8):447-52. Rec#: 1290. Exclusion Codes: NDE, EXC. [pmid: 18987569].
Dalton H. Procalcitonin: a predictor of lung injury attributable to sepsis?. Crit Care Med. 1999;27(10):2304-5. Rec#: 6350. Exclusion Codes: NDE, EXC. [pmid: 10548234].
Dambrauskas Z, Pundzius J, Barauskas G. Predicting development of infected necrosis in acute necrotizing pancreatitis. Medicina (Kaunas). 2006;42(6):441-9. Rec#: 8740. Exclusion Codes: NDE, EXC. [pmid: 16816537].
Damoiseaux RA. Procalcitonin-guided antibiotic use in primary care: the ultimate proof still ahead. Arch Intern Med. 2009;169(7):717-8. Rec#: 7440. Exclusion Codes: NDE, EXC. [pmid: 19365004].
Dandona P, Nix D, Wilson MF, Aljada A, Love J, Assicot M, Bohuon C. Procalcitonin increase after endotoxin injection in normal subjects. J Clin Endocrinol Metab. 1994;79(6):1605-8. Rec#: 11030. Exclusion Codes: NRO, EXC. [pmid: 7989463].
Dauber A, Weiss S, Maniaci V, Nylen E, Becker KL, Bachur R. Procalcitonin levels in febrile infants after recent immunization. Pediatrics. 2008;122(5):e1119-22. Rec#: 7700. Exclusion Codes: NDE, EXC. [pmid: 18977961].
Daubin C, Parienti JJ, Fradin S, Vabret A, Ramakers M, Terzi N, Freymuth F, Charbonneau P, du Cheyron D. Procalcitonin levels and bacterial aetiology among COPD patients admitted to the ICU with severe pneumonia: a prospective cohort study. BMC Infect Dis. 2009;9:157. Rec#: 460. Exclusion Codes: SMN, EXC. [pmid: 19772586].
Daubin C, Parienti JJ, Vabret A, Ramakers M, Fradin S, Terzi N, Freymuth F, Charbonneau P, du Cheyron D. Procalcitonin levels in acute exacerbation of COPD admitted in ICU: a prospective cohort study. BMC Infect Dis. 2008;8:145. Rec#: 1320. Exclusion Codes: SMN, EXC. [pmid: 18947382].
Davis BH. Improved diagnostic approaches to infection/sepsis detection. Expert Rev Mol Diagn. 2005;5(2):193-207. Rec#: 3840. Exclusion Codes: NDE, EXC. [pmid: 15833049].
Davis TM, Assicot M, Bohuon C, St John A, Li GQ, Anh TK. Serum procalcitonin concentrations in acute malaria. Trans R Soc Trop Med Hyg. 1994;88(6):670-1. Rec#: 11040. Exclusion Codes: NRO, EXC. [pmid: 7886767].
de Jager CP, de Wit NC, Weers-Pothoff G, van der Poll T, Wever PC. Procalcitonin kinetics in Legionella pneumophila pneumonia. Clin Microbiol Infect. 2009;15(11):1020-5. Rec#: 870. Exclusion Codes: NRO, EXC. [pmid: 19438643].
de Kruif MD, Limper M, Gerritsen H, Spek CA, Brandjes DP, ten Cate H, Bossuyt PM, Reitsma PH, van Gorp EC. Additional value of procalcitonin for diagnosis of infection in patients with fever at the emergency department. Crit Care Med. 2010;38(2):457-63. Rec#: 7030. Exclusion Codes: NDE, EXC. [pmid: 20083920].
De La Flor I Bru J. Procalcitonin and C-reactive protein as diagnostic markers of severe bacterial infections in febrile infants and children in the emergency department. Pediatr. Integr. 2007;11(8):729-730. Rec#: 16260. Exclusion Codes: FLA, EXC.
De La Rosa GD, Valencia ML, Arango CM, Gomez CI, Garcia A, Ospina S, Osorno S, Henao A, Jaimes FA. Toward an operative diagnosis in sepsis: a latent class approach. BMC Infect Dis. 2008;8:18. Rec#: 2100. Exclusion Codes: NDE, EXC. [pmid: 18284667].
de Mendonca-Filho HT, Gomes GS, Nogueira PM, Fernandes MA, Tura BR, Santos M, Castro-Faria-Neto HC. Macrophage migration inhibitory factor is associated with positive cultures in patients with sepsis after cardiac surgery. Shock. 2005;24(4):313-7. Rec#: 3640. Exclusion Codes: SMN, EXC. [pmid: 16205314].
De Talance N, Claudel C, Burlet C. Procalcitonin as a specific indication of septic shock?. La procalcitonine (PCT) est-elle le marqueur specifique du choc septique?. Immuno-Anal. Biol. Spec. 2003;18(2):120-122. Rec#: 14470. Exclusion Codes: NDE, EXC.
De Talance N, Schumacher H, Mertes PM, Burlet C. Interest of procalcitonin assay in case of infections diseases. Interets du dosage de procalcitonine en infectiologie. Immuno-Anal. Biol. Spec. 2001;16(1):18-21. Rec#: 16960. Exclusion Codes: NDE, EXC.
de Werra I, Jaccard C, Corradin SB, Chiolero R, Yersin B, Gallati H, Assicot M, Bohuon C, Baumgartner JD, Glauser MP, Heumann D. Cytokines, nitrite/nitrate, soluble tumor necrosis factor receptors, and procalcitonin concentrations: comparisons in patients with septic shock, cardiogenic shock, and bacterial pneumonia. Crit Care Med. 1997;25(4):607-13. Rec#: 6860. Exclusion Codes: SMN, EXC. [pmid: 9142024].
de Wit NC, de Jager CP, Meekelenkamp JC, Schoorl M, van Gageldonk-Lafeber AB, Leenders AC, Kusters R, Wever PC. Markers of infection in inpatients and outpatients with acute Q-fever. Clin Chem Lab Med. 2009;47(11):1407-9. Rec#: 7170. Exclusion Codes: NRO, EXC. [pmid: 19778289].
de Wolf HK, Gunnewiek JK, Berk Y, van den Ouweland J, de Metz M. Comparison of a new procalcitonin assay from roche with the established method on the brahms kryptor. Clin Chem. 2009;55(5):1043-4. Rec#: 7510. Exclusion Codes: NDE, EXC. [pmid: 19264851].
De Wolf HK, Klein Gunnewiek J, Berk Y, Van Den Ouweland J, De Metz M. Comparison of a new Roche Modular procalcitonin test with Brahms Kryptor method. Vergelijking van een nieuwe Roche Modular procalcitoninetest met de Brahms Kryptor methode. Ned. Tijdschr. Klin. Chem. Lab. Geneeskd. 2009;34(4):261-262. Rec#: 15820. Exclusion Codes: NDE, EXC.
Debard AL, Vautrin C, Pariset C, Bienvenu J, Monneret G. High serum procalcitonin levels do not predict bacteremia in adult patients with acute fever. Clin Infect Dis. 2003;36(6):825-6. author reply 826-7. Rec#: 4930. Exclusion Codes: NDE, EXC. [pmid: 12627373].
Decaluwe H, Harrison LM, Mariscalco MM, Gendrel D, Bohuon C, Tesh VL, Proulx F. Procalcitonin in children with Escherichia coli O157:H7 associated hemolytic uremic syndrome. Pediatr Res. 2006;59(4 Pt 1):579-83. Rec#: 8890. Exclusion Codes: NDE, EXC. [pmid: 16549533].
Deis JN, Creech CB, Estrada CM, Abramo TJ. Procalcitonin as a marker of severe bacterial infection in children in the emergency department. Pediatr Emerg Care. 2010;26(1):51-60. quiz 61-3. Rec#: 250. Exclusion Codes: NDE, EXC. [pmid: 20065834].
Dejmkova H, Pavelka K, Uhrova J. Procalcitonin in the diagnosis of bacterial infection in patients with autoimmune rheumatic diseases. Prokalcitonin v diagnoze bakterialni infekce u nemocnych s autoimunitnimi revmatickymi chorobami. Ceska Revmatol. 2007;15(4):186-189. Rec#: 13140. Exclusion Codes: NRD, EXC.
Dejmkova H, Sleglova O, Becvar R, Pavelka K, Uhrova J. Limited significance of procalcitonin in differentiation between sepsis and flare of a rheumatic disease. Omezeny vyznam prokalcitoninu v odliseni septickeho stavu od vzplanuti autoimunitniho onemocneni. Ceska Revmatol. 2009;17(2):79-82. Rec#: 12160. Exclusion Codes: NDE, EXC.
Del Castillo Martin F, Duque Alcorta M, Madero Jarabo R, Garcia Miguel MJ, De Jose Gomez MI, Baquero Artigao F, Aracil J, Buno Soto A. C-reactive protein and procalcitonin in community-adquired pneumococcal pneumonia. Proteina C reactiva y procalcitonina en la neumonia por neumococo adquirida en la comunidad. Pediatr. Integr. 2008;12(9):909-912. Rec#: 16020. Exclusion Codes: NDE, EXC.
Delevaux I, Andre M, Aumaitre O, Begue RJ, Colombier M, Piette JC. Procalcitonin measurement for differential diagnosis between pulmonary embolism and pneumonia. Crit Care Med. 2003;31(2):661. Rec#: 10020. Exclusion Codes: NDE, EXC. [pmid: 12576992].
Delevaux I, Andre M, Colombier M, Albuisson E, Meylheuc F, Begue RJ, Piette JC, Aumaitre O. Can procalcitonin measurement help in differentiating between bacterial infection and other kinds of inflammatory processes?. Ann Rheum Dis. 2003;62(4):337-40. Rec#: 9970. Exclusion Codes: NDE, EXC. [pmid: 12634233].
Denes E, Rogez JP, Weinbreck P. Procalcitonin level for the diagnosis of fever in non-neutropenic adults. Dosage de la procalcitonine pour le diagnostic d'une fievre chez l'adulte non neutropenique. Med. Mal. Infect. 2003;33(4):206-209. Rec#: 16810. Exclusion Codes: NDE, EXC.
Di Filippo A, Lombardi A, Ognibene A, Messeri G, Tonelli F. Procalcitonin as an early marker of postoperative infectious complications. Minerva Chir. 2002;57(1):59-62. Rec#: 5520. Exclusion Codes: NDE, EXC. [pmid: 11832860].
Distefano G, Curreri R, Betta P, Romeo MG, Amato M. Procalcitonin serum levels in perinatal bacterial and fungal infection of preterm infants. Acta Paediatr. 2004;93(2):216-9. Rec#: 4420. Exclusion Codes: NDE, EXC. [pmid: 15046277].
Don M, Valent F, Korppi M, Canciani M. Differentiation of bacterial and viral community-acquired pneumonia in children. Pediatr Int. 2009;51(1):91-6. Rec#: 7430. Exclusion Codes: NDE, EXC. [pmid: 19371285].
Don M, Valent F, Korppi M, Falleti E, De Candia A, Fasoli L, Tenore A, Canciani M. Efficacy of serum procalcitonin in evaluating severity of community-acquired pneumonia in childhood. Scand J Infect Dis. 2007;39(2):129-37. Rec#: 8510. Exclusion Codes: NDE, EXC. [pmid: 17366029].
Dorge H, Schondube FA, Dorge P, Seipelt R, Voss M, Messmer BJ. Procalcitonin is a valuable prognostic marker in cardiac surgery but not specific for infection. Thorac Cardiovasc Surg. 2003;51(6):322-6. Rec#: 4520. Exclusion Codes: NDE, EXC. [pmid: 14669128].
Dorizzi RM, Polati E, Sette P, Ferrari A, Rizzotti P, Luzzani A. Procalcitonin in the diagnosis of inflammation in intensive care units. Clin Biochem. 2006;39(12):1138-43. Rec#: 3090. Exclusion Codes: NDE, EXC. [pmid: 17052702].
Dornbusch HJ, Strenger V, Kerbl R, Lackner H, Schwinger W, Sovinz P, Urban C. Procalcitonin and C-reactive protein do not discriminate between febrile reaction to anti-T-lymphocyte antibodies and Gram-negative sepsis. Bone Marrow Transplant. 2003;32(9):941-5. Rec#: 4600. Exclusion Codes: SMN, EXC. [pmid: 14561996].
Dornbusch HJ, Strenger V, Sovinz P, Lackner H, Schwinger W, Kerbl R, Urban C. Non-infectious causes of elevated procalcitonin and C-reactive protein serum levels in pediatric patients with hematologic and oncologic disorders. Support Care Cancer. 2008;16(9):1035-40. Rec#: 2160. Exclusion Codes: NRO, EXC. [pmid: 18196287].
Drage SM, Barber VS, Young JD. Statins and sepsis: panacea or Pandora's box?. Lancet Infect. Dis. 2007;7(2):80. Rec#: 13530. Exclusion Codes: NRD, EXC. [pmid: 17251076].
Du B, Chen D, Pan J, Li Y. Procalcitonin may be a better predictor of interleukin-6 than conventional inflammatory markers. Crit. Care Shock. 2002;5(3):177-182. Rec#: 14590. Exclusion Codes: SMN, EXC.
Du B, Pan J, Chen D, Li Y. Serum procalcitonin and interleukin-6 levels may help to differentiate systemic inflammatory response of infectious and non-infectious origin. Chin Med J (Engl). 2003;116(4):538-42. Rec#: 4720. Exclusion Codes: SMN, EXC. [pmid: 12875718].
Dubos F, Korczowski B, Aygun DA, Martinot A, Prat C, Galetto-Lacour A, Casado-Flores J, Taskin E, Leclerc F, Rodrigo C, Gervaix A, Leroy S, Gendrel D, Breart G, Chalumeau M. Serum procalcitonin level and other biological markers to distinguish between bacterial and aseptic meningitis in children: a European multicenter case cohort study. Arch Pediatr Adolesc Med. 2008;162(12):1157-63. Rec#: 7660. Exclusion Codes: NDE, EXC. [pmid: 19047543].
Dubos F, Martinot A, Gendrel D, Breart G, Chalumeau M. Clinical decision rules for evaluating meningitis in children. Curr Opin Neurol. 2009;22(3):288-93. Rec#: 7420. Exclusion Codes: NDE, EXC. [pmid: 19381086].
Dubos F, Moulin F, Gajdos V, De Suremain N, Biscardi S, Lebon P, Raymond J, Breart G, Gendrel D, Chalumeau M. Serum procalcitonin and other biologic markers to distinguish between bacterial and aseptic meningitis. J Pediatr. 2006;149(1):72-6. Rec#: 8710. Exclusion Codes: NDE, EXC. [pmid: 16860131].
Dubska L, Bacikova L, Vyskocilova M, Jelinek P, Valik D. Monitoring of infection and sepsis in patients with solid tumors. Monitorovani infekcnich a septickych stavu u nemocnych se solidni malignitou. Alergie. 2009;11(4):264-268. Rec#: 11960. Exclusion Codes: NDE, EXC.
Duflo F, Debon R, Monneret G, Bienvenu J, Chassard D, Allaouchiche B. Alveolar and serum procalcitonin: diagnostic and prognostic value in ventilator-associated pneumonia. Anesthesiology. 2002;96(1):74-9. Rec#: 10210. Exclusion Codes: SMN, EXC. [pmid: 11753005].
Eberhard OK, Haubitz M, Brunkhorst FM, Kliem V, Koch KM, Brunkhorst R. Usefulness of procalcitonin for differentiation between activity of systemic autoimmune disease (systemic lupus erythematosus/systemic antineutrophil cytoplasmic antibody-associated vasculitis) and invasive bacterial infection. Arthritis Rheum. 1997;40(7):1250-6. Rec#: 10900. Exclusion Codes: NDE, EXC. [pmid: 9214425].
Eberhard OK, Langefeld I, Kuse ER, Brunkhorst FM, Kliem V, Schlitt HJ, Pichlmayr R, Koch KM, Brunkhorst R. Procalcitonin in the early phase after renal transplantation--will it add to diagnostic accuracy?. Clin Transplant. 1998;12(3):206-11. Rec#: 10800. Exclusion Codes: NDE, EXC. [pmid: 9642511].
Ecker-Schlipf B. Infections in the intensive care unit: Orientation to the procalcitonin level minimizes the use of antibiotics. Infektionen auf der intensivstation: Orientierung am procalcitonin-spiegel verringert den antibiotikaeinsatz. Arzneimitteltherapie. 2010;28(5):176-177. Rec#: 15430. Exclusion Codes: NRD, EXC.
Economou MS, Bau B, Steinbach G, Gansauge F, Mayer JM, Gnucrt A, Beger HG. The potential role of procalcitonin and interleukin-8 in the prediction of infected necrosis in acute pancreatitis. Hell. J. Gastroenterol. 1997;10(3):248-249. Rec#: 15210. Exclusion Codes: NDE, EXC.
Egger G, Aigner R, Glasner A, Hofer HP, Mitterhammer H, Zelzer S. Blood polymorphonuclear leukocyte migration as a predictive marker for infections in severe trauma: comparison with various inflammation parameters. Intensive Care Med. 2004;30(2):331-4. Rec#: 4480. Exclusion Codes: SMN, EXC. [pmid: 14727016].
Eisenhut M. Procalcitonin measurement to reduce antibiotic use in influenza. Biosecur Bioterror. 2009;7(4):453-4. Rec#: 7060. Exclusion Codes: NDE, EXC. [pmid: 20028254].
Elefsiniotis IS, Petrocheilou A, Scarmeas N, Ketikoglou I, Pantazis KD, Toutouza M, Tsianos EV. Serum procalcitonin levels in chronic hepatitis C patients under pegylated interferon-alpha plus ribavirin treatment. J Clin Virol. 2006;37(4):329-31. Rec#: 8640. Exclusion Codes: NRO, EXC. [pmid: 16996792].
Elefsiniotis IS, Skounakis M, Vezali E, Pantazis KD, Petrocheilou A, Pirounaki M, Papatsibas G, Kontou-Kastellanou C, Moulakakis A. Clinical significance of serum procalcitonin levels in patients with acute or chronic liver disease. Eur J Gastroenterol Hepatol. 2006;18(5):525-30. Rec#: 8820. Exclusion Codes: NDE, EXC. [pmid: 16607149].
Elsammak M, Hanna H, Ghazal A, Edeen FB, Kandil M. Diagnostic value of serum procalcitonin and C-reactive protein in Egyptian children with streptococcal tonsillopharyngitis. Pediatr Infect Dis J. 2006;25(2):174-6. Rec#: 8940. Exclusion Codes: SMN, EXC. [pmid: 16462299].
Endo S, Aikawa N, Fujishima S, Sekine I, Kogawa K, Yamamoto Y, Kushimoto S, Yukioka H, Kato N, Totsuka K, Kikuchi K, Ikeda T, Ikeda K, Yamada H, Harada K, Satomura S. Usefulness of procalcitonin serum level for the discrimination of severe sepsis from sepsis: a multicenter prospective study. J Infect Chemother. 2008;14(3):244-9. Rec#: 1530. Exclusion Codes: SMN, EXC. [pmid: 18574663].
Endter F, Reith HB, Thiede A. Strategies for the prevention and early detection of peri- and postoperative secondary infection and impaired wound healing. Chir. Prax. 2001;59(1):13-28. Rec#: 14710. Exclusion Codes: NDE, EXC.
Engel A, Steinbach G, Kern P, Kern WV. Diagnostic value of procalcitonin serum levels in neutropenic patients with fever: comparison with interleukin-8. Scand J Infect Dis. 1999;31(2):185-9. Rec#: 6430. Exclusion Codes: NDE, EXC. [pmid: 10447330].
Engel C, Brunkhorst FM, Loffler M, Reinhart K. Diagnosis and epidemiology of sepsis. Diagnose und epidemiologie der sepsis. Med. Welt. 2007;58(7-8):307-310. Rec#: 13320. Exclusion Codes: NRD, EXC.
Engelmann L, Petros S, Gundelach K, Wegscheider K. The importance of ‘second hit’ for the course of sepsis. Die bedeutung des “second hit” fur den sepsisverlauf. Intensivmed. Notf.med. 2006;43(3):189-201. Rec#: 13890. Exclusion Codes: NDE, EXC.
Engle WD, Jackson GL, Sendelbach DM, Stehel EK, Ford DM, McHugh KM, Norris MR, Vedro DA, Velaphi S, Michelow IC, Olsen KD. Pneumonia in term neonates: laboratory studies and duration of antibiotic therapy. J Perinatol. 2003;23(5):372-7. Rec#: 4730. Exclusion Codes: NDE, EXC. [pmid: 12847531].
Enguix A, Rey C, Concha A, Medina A, Coto D, Dieguez MA. Comparison of procalcitonin with C-reactive protein and serum amyloid for the early diagnosis of bacterial sepsis in critically ill neonates and children. Intensive Care Med. 2001;27(1):211-5. Rec#: 5820. Exclusion Codes: NDE, EXC. [pmid: 11280637].
Erickson YO, Samia NI, Bedell B, Friedman KD, Atkinson BS, Raife TJ. Elevated procalcitonin and C-reactive protein as potential biomarkers of sepsis in a subpopulation of thrombotic microangiopathy patients. J Clin Apher. 2009;24(4):150-4. Rec#: 710. Exclusion Codes: NRO, EXC. [pmid: 19591197].
Ernst A, Morgenthaler NG, Buerger K, Dodel R, Noelker C, Sommer N, Schwarz M, Koehrle J, Bergmann A, Hampel H. Procalcitonin is elevated in the cerebrospinal fluid of patients with dementia and acute neuroinflammation. J Neuroimmunol. 2007;189(1-2):169-74. Rec#: 2500. Exclusion Codes: SMN, EXC. [pmid: 17698209].
Erten N, Genc S, Besisik SK, Saka B, Karan MA, Tascioglu C. The predictive and diagnostic values of procalcitonin and C-reactive protein for clinical outcome in febrile neutropenic patients. J Chin Med Assoc. 2004;67(5):217-21. Rec#: 4130. Exclusion Codes: NDE, EXC. [pmid: 15357107].
Ertugrul BM, Yilmabasar A, Ertugrul O, Ayabakan HB, Kizilirmak S, Turkmen S. Do C-reactive protein and procalcitonin predict hospital-acquired infection in patients with trauma?. Saudi Med J. 2006;27(4):560-2. Rec#: 8850. Exclusion Codes: NDE, EXC. [pmid: 16598344].
Escobar GJ. Effect of the systemic inflammatory response on biochemical markers of neonatal bacterial infection: a fresh look at old confounders. Clin Chem. 2003;49(1):21-2. Rec#: 5030. Exclusion Codes: NDE, EXC. [pmid: 12507956].
Espinosa-Morales R, Escalante A. Use of procalcitonin as a diagnostic test: comment on the article by Eberhard et al. Arthritis Rheum. 1998;41(3):567-8. Rec#: 10840. Exclusion Codes: NRD, EXC. [pmid: 9506591].
Ewig S. Pneumonia alerts: Highlights pneumonie. Pneumologie. 2007;61(9):610-612. Rec#: 13250. Exclusion Codes: NDE, EXC.
Faesch S, Cojocaru B, Hennequin C, Pannier S, Glorion C, Lacour B, Cheron G. Can procalcitonin measurement help the diagnosis of osteomyelitis and septic arthritis? A prospective trial. Ital. J. Pediat. 2009;35(33). Rec#: 12000. Exclusion Codes: NDE, EXC.
Falcoz PE, Laluc F, Toubin MM, Puyraveau M, Clement F, Mercier M, Chocron S, Etievent JP. Usefulness of procalcitonin in the early detection of infection after thoracic surgery. Eur J Cardiothorac Surg. 2005;27(6):1074-8. Rec#: 3820. Exclusion Codes: NDE, EXC. [pmid: 15896620].
Fallaha D, Cuthbertson B. The application of biomarkers in critical illness. Care Crit. Ill. 2007;23(6):167-172. Rec#: 13130. Exclusion Codes: NRD, EXC.
Feezor RJ, Oberholzer C, Baker HV, Novick D, Rubinstein M, Moldawer LL, Pribble J, Souza S, Dinarello CA, Ertel W, Oberholzer A. Molecular characterization of the acute inflammatory response to infections with gram-negative versus gram-positive bacteria. Infect Immun. 2003;71(10):5803-13. Rec#: 4640. Exclusion Codes: NDE, EXC. [pmid: 14500502].
Feld R. Bloodstream infections in cancer patients with febrile neutropenia. Int J Antimicrob Agents. Suppl 1. 2008;32:S30-3. Rec#: 1410. Exclusion Codes: NDE, EXC. [pmid: 18778919].
Fendler WM, Piotrowski AJ. Procalcitonin in the early diagnosis of nosocomial sepsis in preterm neonates. J Paediatr Child Health. 2008;44(3):114-8. Rec#: 2350. Exclusion Codes: NDE, EXC. [pmid: 17927729].
Fernandez Lopez A, Luaces Cubells C, Garcia Garcia JJ, Fernandez Pou J. Procalcitonin in pediatric emergency departments for the early diagnosis of invasive bacterial infections in febrile infants: results of a multicenter study and utility of a rapid qualitative test for this marker. Pediatr Infect Dis J. 2003;22(10):895-903. Rec#: 4620. Exclusion Codes: NDE, EXC. [pmid: 14551491].
Fioretto JR, Borin FC, Bonatto RC, Ricchetti SM, Kurokawa CS, de Moraes M, Carpi MF, Padovani CR, Martin JG. Procalcitonin in children with sepsis and septic shock. J Pediatr (Rio J). 2007;83(4):323-8. Rec#: 2620. Exclusion Codes: SMN, EXC. [pmid: 17632669].
Fioretto JR, Martin JG, Kurokawa CS, Carpi MF, Bonatto RC, Ricchetti SM, de Moraes MA, Padovani CR. Interleukin-6 and procalcitonin in children with sepsis and septic shock. Cytokine. 2008;43(2):160-4. Rec#: 1540. Exclusion Codes: NDE, EXC. [pmid: 18565757].
Fiumefreddo R, Zaborsky R, Haeuptle J, Christ-Crain M, Trampuz A, Steffen I, Frei R, Muller B, Schuetz P. Clinical predictors for Legionella in patients presenting with community-acquired pneumonia to the emergency department. BMC Pulm. Med. 2009;9. Rec#: 16000. Exclusion Codes: NDE, EXC.
Flatley M. Procalcitonin-guided antibiotic use for respiratory tract infections. Thorax. 2009;64(4):367. Rec#: 12360. Exclusion Codes: NRD, EXC.
Fleischhack G, Cipic D, Juettner J, Hasan C, Bode U. Procalcitonin-a sensitive inflammation marker of febrile episodes in neutropenic children with cancer. Intensive Care Med. Suppl 2. 2000;26:S202-11. Rec#: 1680. Exclusion Codes: NDE, EXC. [pmid: 18470721].
Fleischhack G, Kambeck I, Cipic D, Hasan C, Bode U. Procalcitonin in paediatric cancer patients: its diagnostic relevance is superior to that of C-reactive protein, interleukin 6, interleukin 8, soluble interleukin 2 receptor and soluble tumour necrosis factor receptor II. Br J Haematol. 2000;111(4):1093-102. Rec#: 5900. Exclusion Codes: NDE, EXC. [pmid: 11167745].
Florianczyk B. Structure and diagnostic value of procalcitonin. Ann Univ Mariae Curie Sklodowska Med. 2003;58(1):338-42. Rec#: 4150. Exclusion Codes: NRO, EXC. [pmid: 15315011].
Fottner A, Birkenmaier C, von Schulze Pellengahr C, Wegener B, Jansson V. Can serum procalcitonin help to differentiate between septic and nonseptic arthritis?. Arthroscopy. 2008;24(2):229-33. Rec#: 2130. Exclusion Codes: SMN, EXC. [pmid: 18237709].
Franz AR, Kron M, Pohlandt F, Steinbach G. Comparison of procalcitonin with interleukin 8, C-reactive protein and differential white blood cell count for the early diagnosis of bacterial infections in newborn infants. Pediatr Infect Dis J. 1999;18(8):666-71. Rec#: 10680. Exclusion Codes: NDE, EXC. [pmid: 10462333].
Frasquet J, Saez J, Trigo C, Martinez J, Such J, Perez-Mateo M. Early measurement of procalcitonin does not predict severity in patients with acute pancreatitis. Br J Surg. 2003;90(9):1129-30. Rec#: 9850. Exclusion Codes: SMN, EXC. [pmid: 12945081].
Fraunberger P, Holler E, Parhofer KG, Walli AK, Seidel D. Interleukin 6, procalcitonin and CRP levels during first increase of fever in intensive care patients. Haben die konzentrationen von interleukin 6, procalcitonin und CRP bei intensivpatienten wahrend des ersten fieberanstieges eine prognostische bedeutung?. LaboratoriumsMedizin. 2008;32(6):434-437. Rec#: 12620. Exclusion Codes: NDE, EXC.
Fraunberger P, Walli AK. Biomarkers in sepsis and inflammation. Biomarker bei sepsis und entzundung. LaboratoriumsMedizin. 2007;31(6):294-309. Rec#: 13110. Exclusion Codes: NDE, EXC.
Fraunberger P, Wang Y, Holler E, Parhofer KG, Nagel D, Walli AK, Seidel D. Prognostic value of interleukin 6, procalcitonin, and C-reactive protein levels in intensive care unit patients during first increase of fever. Shock. 2006;26(1):10-2. Rec#: 3280. Exclusion Codes: SMN, EXC. [pmid: 16783191].
Gaini S, Koldkjaer OG, Moller HJ, Pedersen C, Pedersen SS. A comparison of high-mobility group-box 1 protein, lipopolysaccharide-binding protein and procalcitonin in severe community-acquired infections and bacteraemia: a prospective study. Crit Care. 2007;11(4):R76. Rec#: 2640. Exclusion Codes: NDE, EXC. [pmid: 17625012].
Gaini S, Koldkjaer OG, Pedersen C, Pedersen SS. Procalcitonin, lipopolysaccharide-binding protein, interleukin-6 and C-reactive protein in community-acquired infections and sepsis: a prospective study. Crit Care. 2006;10(2):R53. Rec#: 3390. Exclusion Codes: NDE, EXC. [pmid: 16569262].
Gaini S, Pedersen SS, Koldkaer OG, Pedersen C, Moestrup SK, Moller HJ. New immunological serum markers in bacteraemia: anti-inflammatory soluble CD163, but not proinflammatory high mobility group-box 1 protein, is related to prognosis. Clin Exp Immunol. 2008;151(3):423-31. Rec#: 2170. Exclusion Codes: NDE, EXC. [pmid: 18190604].
Gaini S, Pedersen SS, Koldkjaer OG, Pedersen C, Moller HJ. High mobility group box-1 protein in patients with suspected community-acquired infections and sepsis: a prospective study. Crit Care. 2007;11(2):R32. Rec#: 2900. Exclusion Codes: NDE, EXC. [pmid: 17346334].
Galetto-Lacour A, Zamora SA, Gervaix A. Bedside procalcitonin and C-reactive protein tests in children with fever without localizing signs of infection seen in a referral center. Pediatrics. 2003;112(5):1054-60. Rec#: 9800. Exclusion Codes: SMN, EXC. [pmid: 14595045].
Gattas DJ, Cook DJ. Procalcitonin as a diagnostic test for sepsis: health technology assessment in the ICU. J Crit Care. 2003;18(1):52-8. Rec#: 4910. Exclusion Codes: NDE, EXC. [pmid: 12640615].
Gavazzi G. Procalcitonin in elderly patients: State of the Art. Procalcitonine chez le sujet age : etat des lieux. Antibiotiques. 2010;12(2):82-89. Rec#: 11370. Exclusion Codes: NDE, EXC.
Gendrel D, Assicot M, Raymond J, Moulin F, Francoual C, Badoual J, Bohuon C. Procalcitonin as a marker for the early diagnosis of neonatal infection. J Pediatr. 1996;128(4):570-3. Rec#: 6920. Exclusion Codes: NRO, EXC. [pmid: 8618197].
Gendrel D, Bohuon C. Procalcitonin, a marker of bacterial infection. Infection. 1997;25(3):133-4. Rec#: 6850. Exclusion Codes: NDE, EXC. [pmid: 9181377].
Gendrel D, Bohuon C. Procalcitonin as a marker of bacterial infection. Pediatr Infect Dis J. 2000;19(8):679-87. quiz 688. Rec#: 10520. Exclusion Codes: NDE, EXC. [pmid: 10959733].
Gendrel D, Moulin F, Lorrot M, Marc E, Guerin S, Soulier N, Lebon P, Coste J, Iniguez JL, Kalifa G, Brunet F, Raymond J. Procalcitonin and markers of infection in community-acquired pneumonia of children. Procalcitonine et marqueurs de l'infection dans les pneumonies communautaires de l'enfant. Med. Mal. Infect. 2002;32(2):88-97. Rec#: 16950. Exclusion Codes: NDE, EXC.
Gendrel D, Moulin F, Raymond J, Bohuon C. Serum markers in lower respiratory tract infections in children. Marqueurs seriques dans les infections respiratoires basses de l'enfant. Med. Ther. Pediatr. 1999;2(SPEC. ISS. MAR):46-50. Rec#: 17080. Exclusion Codes: FLA, EXC.
Gendrel D, Raymond J, Assicot M, Avenel S, Lefevre H, Ravilly S, Moulin F, Lacombe C, Palmer P, Lebon P, Bohuon C. ProCalcitonin, C-reactive protein and interleukin-6 in children with bacterial and viral meningitis. Procalcitonine, proteine C-reactive et interleukine 6 dans les meningites bacteriennes et virales de l'enfant. Presse Med. 1998;27(23):1135-1139. Rec#: 17130. Exclusion Codes: NDE, EXC. [pmid: 9767794].
Gendrel D, Raymond J, Assicot M, Moulin F, Iniguez JL, Lebon P, Bohuon C. Measurement of procalcitonin levels in children with bacterial or viral meningitis. Clin Infect Dis. 1997;24(6):1240-2. Rec#: 10910. Exclusion Codes: SMN, EXC. [pmid: 9195090].
Gendrel D, Raymond J, Coste J, Moulin F, Lorrot M, Guerin S, Ravilly S, Lefevre H, Royer C, Lacombe C, Palmer P, Bohuon C. Comparison of procalcitonin with C-reactive protein, interleukin 6 and interferon-alpha for differentiation of bacterial vs. viral infections. Pediatr Infect Dis J. 1999;18(10):875-81. Rec#: 10640. Exclusion Codes: NDE, EXC. [pmid: 10530583].
Gendrel D, Vallet C, Gelmetti C, Moulin F, Brasme JF, Chalumeau M, Cohen R, Raymond J. Pneumococcal pneumonia highly probable in immunized children cared for in-group settings. Pneumonies a pneumocoque hautement probables chez les enfants vaccines gardes en collectivite. Arch. Pediatr. 2010;17(4):373-377. Rec#: 15480. Exclusion Codes: NRD, EXC. [pmid: 20189361].
George A, Coulson C, De R. Procalcitonin: a bacterial specific marker of infection. Clin Otolaryngol. 2007;32(4):310. Rec#: 2570. Exclusion Codes: NRD, EXC. [pmid: 17651293].
Geppert A, Steiner A, Delle-Karth G, Heinz G, Huber K. Usefulness of procalcitonin for diagnosing complicating sepsis in patients with cardiogenic shock. Intensive Care Med. 2003;29(8):1384-9. Rec#: 4740. Exclusion Codes: SMN, EXC. [pmid: 12827235].
Gerard Y, Hober D, Assicot M, Alfandari S, Ajana F, Bourez JM, Chidiac C, Mouton Y, Bohuon C, Wattre P. Procalcitonin as a marker of bacterial sepsis in patients infected with HIV-1. J Infect. 1997;35(1):41-6. Rec#: 6830. Exclusion Codes: NRO, EXC. [pmid: 9279723].
Gerard Y, Hober D, Petitjean S, Assicot M, Bohuon C, Mouton Y, Wattre P. High serum procalcitonin level in a 4-year-old liver transplant recipient with a disseminated candidiasis. Infection. 1995;23(5):310-1. Rec#: 10950. Exclusion Codes: NRO, EXC. [pmid: 8557394].
Gervaix A, Galetto-Lacour A, Gueron T, Vadas L, Zamora S, Suter S, Girardin E. Usefulness of procalcitonin and C-reactive protein rapid tests for the management of children with urinary tract infection. Pediatr Infect Dis J. 2001;20(5):507-11. Rec#: 10330. Exclusion Codes: SMN, EXC. [pmid: 11368108].
Ghorbani G. Procalcitonin role in differential diagnosis of infection stages and non infection inflammation. Pak J Biol Sci. 2009;12(4):393-6. Rec#: 730. Exclusion Codes: NRO, EXC. [pmid: 19579976].
Giamarellos-Bourboulis EJ, Giannopoulou P, Grecka P, Voros D, Mandragos K, Giamarellou H. Should procalcitonin be introduced in the diagnostic criteria for the systemic inflammatory response syndrome and sepsis?. J Crit Care. 2004;19(3):152-7. Rec#: 4090. Exclusion Codes: NDE, EXC. [pmid: 15484175].
Giamarellos-Bourboulis EJ, Grecka P, Poulakou G, Anargyrou K, Katsilambros N, Giamarellou H. Assessment of procalcitonin as a diagnostic marker of underlying infection in patients with febrile neutropenia. Clin Infect Dis. 2001;32(12):1718-25. Rec#: 5770. Exclusion Codes: NDE, EXC. [pmid: 11360214].
Giamarellos-Bourboulis EJ, Mega A, Grecka P, Scarpa N, Koratzanis G, Thomopoulos G, Giamarellou H. Procalcitonin: a marker to clearly differentiate systemic inflammatory response syndrome and sepsis in the critically ill patient?. Intensive Care Med. 2002;28(9):1351-6. Rec#: 5170. Exclusion Codes: NDE, EXC. [pmid: 12209289].
Giamarellou H, Giamarellos-Bourboulis EJ, Repoussis P, Galani L, Anagnostopoulos N, Grecka P, Lubos D, Aoun M, Athanassiou K, Bouza E, Devigili E, Krcmery V, Menichetti F, Panaretou E, Papageorgiou E, Plachouras D. Potential use of procalcitonin as a diagnostic criterion in febrile neutropenia: experience from a multicentre study. Clin Microbiol Infect. 2004;10(7):628-33. Rec#: 4290. Exclusion Codes: NDE, EXC. [pmid: 15214875].
Gibot S. Procalcitonin in intensive care units: the PRORATA trial. Lancet. 2010;375(9726):1605-6. author reply 1606-7. Rec#: 60. Exclusion Codes: NDE, EXC. [pmid: 20452514].
Gibot S, Cravoisy A. Soluble form of the triggering receptor expressed on myeloid cells-1 as a marker of microbial infection. Clin Med Res. 2004;2(3):181-7. Rec#: 3800. Exclusion Codes: SMN, EXC. [pmid: 15931355].
Gibot S, Cravoisy A, Dupays R, Barraud D, Nace L, Levy B, Bollaert PE. Combined measurement of procalcitonin and soluble TREM-1 in the diagnosis of nosocomial sepsis. Scand J Infect Dis. 2007;39(6-7):604-8. Rec#: 2650. Exclusion Codes: SMN, EXC. [pmid: 17577825].
Gibot S, Cravoisy A, Kolopp-Sarda MN, Bene MC, Faure G, Bollaert PE, Levy B. Time-course of sTREM (soluble triggering receptor expressed on myeloid cells)-1, procalcitonin, and C-reactive protein plasma concentrations during sepsis. Crit Care Med. 2005;33(4):792-6. Rec#: 3860. Exclusion Codes: SMN, EXC. [pmid: 15818107].
Gilbert DN. Use of plasma procalcitonin levels as an adjunct to clinical microbiology. J. Clin. Microbiol. 2010;48(7):2325-2329. Rec#: 11320. Exclusion Codes: NDE, EXC. [pmid: 20421436].
Girault C. Management of pneumonia acquired from mechanical ventilation. Prise en charge des pneumopathies acquises sous ventilation mecanique. Rev. Mal. Respir. 2003;20(5 II):6S151-6S154. Rec#: 14330. Exclusion Codes: NDE, EXC.
Girault C. Updates in intensive care unit. Actualites en reanimation. Rev. Mal. Respir. Actual. 2009;1(5):613-616. Rec#: 12040. Exclusion Codes: NDE, EXC.
Gomez Gerique JA, Ortiz Espejo M, Torrealba Rodriguez MI, Gordillo Alvarez J, Castellanos-Ortega A, Suberviola B, Teja JL. Evaluation of the diagnostic and prognostic capacity of procalcitonin, C reactive protein, interleukin-6 and lipopolysaccharide binding protein in patients suspected of having sepsis. Evaluacion de la capacidad diagnostica y pronostica de procalcitonina, proteina C reactiva, interleucina-6 y proteina ligadora del lipopolisacarido en pacientes con sospecha de sepsis. Rev. Lab. Clin. 2010;3(1):12-19. Rec#: 11860. Exclusion Codes: NDE, EXC.
Gorisek B, Miksic NG, Krajnc P, Pakiz M, Turk Z. The role of procalcitonin in gynaecological surgery. J Int Med Res. 2009;37(3):918-26. Rec#: 720. Exclusion Codes: NRO, EXC. [pmid: 19589278].
Gramm HJ, Dollinger P, Beier W. Procalcin - A new marker for inflammatory host response Serial studies in patients with sepsis and peritonitis. PROCALCITONIN - EIN NEUER MARKER DER INFLAMMATORISCHEN WIRTSANTWORT LONGITUDINALSTUDIEN BEI PATIENTEN MIT SEPSIS UND PERITONITIS. CHIR. GASTROENTEROL. INTERDISZIP. GESPR. 1995;11(SUPPL. 2):51-54. Rec#: 15240. Exclusion Codes: NRD, EXC.
Gregor H, Helmer H, Witt A, Reisenberger K, Kiss H. Amniotic fluid levels of procalcitonin, interleukin-6, tumor necrosis factor (alpha), glucose and leukocytes for detecting intraamniotic infection. Die wertigkeit von procalcitonin, interleukin-6, tumor-nekrose-faktor- alpha, glukose und leukozytenzahl im fruchtwasser als diagnostische parameter fur intrauterine infektionen - Erste ergebnisse. Geburtshilfe Frauenheilkd. 2000;60(7):362-365. Rec#: 17020. Exclusion Codes: NRD, EXC.
Greksova K, Parrak V, Chovancova D, Stencl P, Oravec J, Marsik L, Sysak R, Fuchs D, Peskova Z, Borovsky M. Procalcitonin, neopterin and C-reactive protein in diagnostics of intrauterine infection and preterm delivery. Bratisl Lek Listy. 2009;110(10):623-6. Rec#: 7070. Exclusion Codes: NDE, EXC. [pmid: 20017453].
Grieb G, Simons D, Piatkowski A, Bernhagen J, Steffens G, Pallua N. Macrophage migration inhibitory factor-A potential diagnostic tool in severe burn injuries?. Burns. 2010;36(3):335-342. Rec#: 11500. Exclusion Codes: SMN, EXC. [pmid: 19540674].
Groeneveld AB, Hack CE. The role of the innate immune response in hospital- versus community-acquired infection in febrile medical patients. Int J Infect Dis. 2008;12(6):660-70. Rec#: 1590. Exclusion Codes: NDE, EXC. [pmid: 18514561].
Groselj-Grenc M, Ihan A, Pavcnik-Arnol M, Kopitar AN, Gmeiner-Stopar T, Derganc M. Neutrophil and monocyte CD64 indexes, lipopolysaccharide-binding protein, procalcitonin and C-reactive protein in sepsis of critically ill neonates and children. Intensive Care Med. 2009;35(11):1950-8. Rec#: 500. Exclusion Codes: NDE, EXC. [pmid: 19756501].
Guen CG, Delmas C, Launay E, Caillon J, Loubersac V, Picherot G, Roze JC. Contribution of procalcitonin to occult bacteraemia detection in children. Scand J Infect Dis. 2007;39(2):157-9. Rec#: 2870. Exclusion Codes: NDE, EXC. [pmid: 17366034].
Guibourdenche J, Bedu A, Petzold L, Marchand M, Mariani-Kurdjian P, Hurtaud-Roux MF, Aujard Y, Porquet D. Biochemical markers of neonatal sepsis: value of procalcitonin in the emergency setting. Ann Clin Biochem. 2002;39(Pt 2):130-5. Rec#: 5430. Exclusion Codes: NDE, EXC. [pmid: 11928760].
Gurda-Duda A, Kusnierz-Cabala B, Nowak W, Naskalski JW, Kulig J. Assessment of the prognostic value of certain acute-phase proteins and procalcitonin in the prognosis of acute pancreatitis. Pancreas. 2008;37(4):449-53. Rec#: 7720. Exclusion Codes: NDE, EXC. [pmid: 18953261].
Gurgoze MK, Akarsu S, Yilmaz E, Godekmerdan A, Akca Z, Ciftci I, Aygun AD. Proinflammatory cytokines and procalcitonin in children with acute pyelonephritis. Pediatr Nephrol. 2005;20(10):1445-8. Rec#: 9110. Exclusion Codes: NDE, EXC. [pmid: 16079986].
Guven AG, Kazdal HZ, Koyun M, Aydn F, Gungor F, Akman S, Baysal YE. Accurate diagnosis of acute pyelonephritis: How helpful is procalcitonin?. Nucl Med Commun. 2006;27(9):715-21. Rec#: 8670. Exclusion Codes: SMN, EXC. [pmid: 16894326].
Guven H, Altintop L, Baydin A, Esen S, Aygun D, Hokelek M, Doganay Z, Bek Y. Diagnostic value of procalcitonin levels as an early indicator of sepsis. Am J Emerg Med. 2002;20(3):202-6. Rec#: 5350. Exclusion Codes: SMN, EXC. [pmid: 11992340].
Guz G, Colak B, Hizel K, Reis KA, Erten Y, Bali M, Sindel S. Procalcitonin and conventional markers of inflammation in peritoneal dialysis patients and peritonitis. Perit Dial Int. 2006;26(2):240-8. Rec#: 8810. Exclusion Codes: SMN, EXC. [pmid: 16623432].
Haeuptle J, Zaborsky R, Fiumefreddo R, Trampuz A, Steffen I, Frei R, Christ-Crain M, Muller B, Schuetz P. Prognostic value of procalcitonin in Legionella pneumonia. Eur J Clin Microbiol Infect Dis. 2009;28(1):55-60. Rec#: 1460. Exclusion Codes: SMN, EXC. [pmid: 18677519].
Hambach L, Eder M, Dammann E, Schrauder A, Sykora KW, Dieterich C, Kirschner P, Novotny J, Ganser A, Hertenstein B. Diagnostic value of procalcitonin serum levels in comparison with C-reactive protein in allogeneic stem cell transplantation. Haematologica. 2002;87(6):643-51. Rec#: 5310. Exclusion Codes: NDE, EXC. [pmid: 12031922].
Hammer C, Fraunberger P, Meiser B, Hammer S. Procalcitonin: a new marker for diagnosis of acute rejection and nonviral infection of heart and lung transplant patients. Transplant Proc. 2001;33(3):2204-6. Rec#: 5760. Exclusion Codes: NRO, EXC. [pmid: 11377503].
Hammer S, Fraunberger P, Meiser B, Stangl M, Seidel D, Hammer C. Procalcitonin, a new indicator for non-viral infections in heart, lung or liver transplant patients. Ann Transplant. 1999;4(2):5-9. Rec#: 6130. Exclusion Codes: NDE, EXC. [pmid: 10850584].
Hammer S, Fuchs AT, Rinker C, Daebritz S, Kozlik-Feldmann R, Netz H. Interleukin-6 and procalcitonin in serum of children undergoing cardiac surgery with cardiopulmonary bypass. Acta Cardiol. 2004;59(6):624-9. Rec#: 9390. Exclusion Codes: NRO, EXC. [pmid: 15636446].
Hammer S, Meisner E, Fraunberger P, Meiser B, Stangl M, Hammer C, Seidel D. Procalcitonin - Differential diagnosis of rejections and non viral infections in transplant patients. Procalcitonin - Differentialdiagnose von abstossungsreaktionen und nicht-viralen infektionen bei transplantationspatienten. Transplantationsmed. Organ Dtsch. Transplantationsges. 1999;11(1):54-58. Rec#: 15080. Exclusion Codes: NDE, EXC.
Hammer S, Meisner F, Dirschedl P, Fraunberger P, Meiser B, Reichart B, Hammer C. Procalcitonin for differential diagnosis of graft rejection and infection in patients with heart and/or lung grafts. Intensive Care Med. Suppl 2. 2000;26:S182-6. Rec#: 1710. Exclusion Codes: SMN, EXC. [pmid: 18470717].
Hammer S, Meisner F, Dirschedl P, Hobel G, Fraunberger P, Meiser B, Reichardt B, Hammer C. Procalcitonin: a new marker for diagnosis of acute rejection and bacterial infection in patients after heart and lung transplantation. Transpl Immunol. 1998;6(4):235-41. Rec#: 6500. Exclusion Codes: NDE, EXC. [pmid: 10342737].
Han YY, Doughty LA, Kofos D, Sasser H, Carcillo JA. Procalcitonin is persistently increased among children with poor outcome from bacterial sepsis. Pediatr Crit Care Med. 2003;4(1):21-5. Rec#: 4890. Exclusion Codes: NRO, EXC. [pmid: 12656537].
Hanes SD, Wood GC, Ritter B, Boucher BA. Serum and alveolar procalcitonin concentrations during ventilator-associated pneumonia. J. Infect. Dis. Pharmacother. 2003;6(2):59-72. Rec#: 14380. Exclusion Codes: NRO, EXC.
Harbarth S, Albrich WC, Muller B. When once is not enough--further evidence of procalcitonin-guided antibiotic stewardship. Crit Care. 2009;13(4):165. Rec#: 650. Exclusion Codes: NDE, EXC. [pmid: 19664168].
Harbarth S, Holeckova K, Froidevaux C, Pittet D, Ricou B, Grau GE, Vadas L, Pugin J. Diagnostic value of procalcitonin, interleukin-6, and interleukin-8 in critically ill patients admitted with suspected sepsis. Am J Respir Crit Care Med. 2001;164(3):396-402. Rec#: 5700. Exclusion Codes: SMN, EXC. [pmid: 11500339].
Hatherill M, Jones G, Lim E, Tibby SM, Murdoch IA. Procalcitonin aids diagnosis of adrenocortical failure. Lancet. 1997;350(9093):1749-50. Rec#: 6820. Exclusion Codes: NRO, EXC. [pmid: 9413471].
Hatherill M, Tibby SM, Sykes K, Turner C, Murdoch IA. Diagnostic markers of infection: comparison of procalcitonin with C reactive protein and leucocyte count. Arch Dis Child. 1999;81(5):417-21. Rec#: 6390. Exclusion Codes: NDE, EXC. [pmid: 10519716].
Hatherill M, Tibby SM, Turner C, Ratnavel N, Murdoch IA. Procalcitonin and cytokine levels: relationship to organ failure and mortality in pediatric septic shock. Crit Care Med. 2000;28(7):2591-4. Rec#: 6080. Exclusion Codes: SMN, EXC. [pmid: 10921600].
Hatzistilianou M, Hitoglou S, Gougoustamou D, Rekliti A, Tzouvelekis G, Nanas Ch, Catriu D, Kotsis A. Serum procalcitonin, adenosine deaminase and its isoenzymes in the aetiological diagnosis of pneumonia in children. Int. J. Immunopathol. Pharmacol. 2002;15(2):119-127. Rec#: 16910. Exclusion Codes: SMN, EXC. [pmid: 12590874].
Hatzistilianou M, Rekleity A, Athanassiadou F, DeLutiis MA, Conti P, Catriu D. Serial procalcitonin responses in infection of children with secondary immunodeficiency. Clin Invest Med. 2007;30(2):E75-85. Rec#: 8280. Exclusion Codes: NDE, EXC. [pmid: 17716545].
Hatzistilianou M, Rekliti A, Athanassiadou F, Catriu D. Procalcitonin as an early marker of bacterial infection in neutropenic febrile children with acute lymphoblastic leukemia. Inflamm Res. 2010;59(5):339-47. Rec#: 420. Exclusion Codes: NDE, EXC. [pmid: 19806318].
Hausfater P. Procalcitonin measurement in adult clinical practice. Le dosage de la procalcitonine en pratique clinique chez l'adulte. Rev. Med. Interne. 2007;28(5):296-305. Rec#: 13360. Exclusion Codes: NDE, EXC. [pmid: 17145122].
Hausfater P, Brochet C, Freund Y, Charles V, Bernard M. Procalcitonin measurement in routine emergency medicine practice: comparison between two immunoassays. Clin Chem Lab Med. 2010;48(4):501-4. Rec#: 6990. Exclusion Codes: NDE, EXC. [pmid: 20148728].
Hausfater P, Garric S, Ayed SB, Rosenheim M, Bernard M, Riou B. Usefulness of procalcitonin as a marker of systemic infection in emergency department patients: a prospective study. Clin Infect Dis. 2002;34(7):895-901. Rec#: 5480. Exclusion Codes: NDE, EXC. [pmid: 11880953].
Hausfater P, Juillien G, Madonna-Py B, Haroche J, Bernard M, Riou B. Serum procalcitonin measurement as diagnostic and prognostic marker in febrile adult patients presenting to the emergency department. Crit Care. 2007;11(3):R60. Rec#: 2750. Exclusion Codes: NDE, EXC. [pmid: 17521430].
Hayashi Y, Davis L, Paterson DL. Editorial: Why can't I prescribe that antibiotic? The role of antimicrobial stewardship programmes in modern medicine. Intern. Med. J. 2009;39(10):636-638. Rec#: 15800. Exclusion Codes: NDE, EXC. [pmid: 19849755].
Heath V. Procalcitonin assay shows promise. Nat. Rev. Endocrionol. 2009;5(4):184. Rec#: 15930. Exclusion Codes: NDE, EXC.
Hedlund J, Hansson LO. Procalcitonin and C-reactive protein levels in community-acquired pneumonia: correlation with etiology and prognosis. Infection. 2000;28(2):68-73. Rec#: 10580. Exclusion Codes: SMN, EXC. [pmid: 10782390].
Heffner JE. Empyema as an orphan disease: So many approaches and so few data. J. Infect. Public Health. 2009;2(1):1-3. Rec#: 15960. Exclusion Codes: NDE, EXC. [pmid: 20701854].
Hellerstein S. Acute urinary tract infection--evaluation and treatment. Curr Opin Pediatr. 2006;18(2):134-8. Rec#: 8840. Exclusion Codes: NDE, EXC. [pmid: 16601492].
Hellwig B. Respiratory tract infection: Procalcitonin as biomarker in practice guidelines. Atemwegsinfekte: Biomarker procalcitonin in leitlinien aufgenommen. Dtsch. Apoth. Ztg. 2009;149(45):50. Rec#: 11970. Exclusion Codes: NDE, EXC.
Hemmer CJ, Reisinger EC. Procalcitonin levels in severe Plasmodium falciparum malaria: predictor of outcome or reflection of pathomechanisms?. J Infect Dis. 2001;184(8):1091-2. Rec#: 10260. Exclusion Codes: NDE, EXC. [pmid: 11574929].
Hensler T, Sauerland S, Lefering R, Nagelschmidt M, Bouillon B, Andermahr J, Neugebauer EA. The clinical value of procalcitonin and neopterin in predicting sepsis and organ failure after major trauma. Shock. 2003;20(5):420-6. Rec#: 4610. Exclusion Codes: NDE, EXC. [pmid: 14560105].
Heper Y, Akalin EH, Mistik R, Akgoz S, Tore O, Goral G, Oral B, Budak F, Helvaci S. Evaluation of serum C-reactive protein, procalcitonin, tumor necrosis factor alpha, and interleukin-10 levels as diagnostic and prognostic parameters in patients with community-acquired sepsis, severe sepsis, and septic shock. Eur J Clin Microbiol Infect Dis. 2006;25(8):481-91. Rec#: 3190. Exclusion Codes: SMN, EXC. [pmid: 16896829].
Heppner HJ, Bertsch T, Alber B, Esslinger AS, Dragonas C, Bauer JM, Sieber CC. Procalcitonin: Inflammatory biomarker for assessing the severity of community-acquired pneumonia - A clinical observation in geriatric patients. Gerontology. 2010;56(4):385-389. Rec#: 15340. Exclusion Codes: NRO, EXC. [pmid: 19940454].
Herd D. In children under age three does procalcitonin help exclude serious bacterial infection in fever without focus?. Arch Dis Child. 2007;92(4):362-4. Rec#: 8500. Exclusion Codes: NDE, EXC. [pmid: 17376946].
Hergert M, Lestin HG, Scherkus M, Brinker K, Klett I, Stranz G, Lestin F. Procalcitonin in patients with sepsis and polytrauma. Procalcitonin bei Sepsis und Polytrauma. Clin. Lab. 1998;44(9):659-670. Rec#: 15150. Exclusion Codes: NRD, EXC.
Herget-Rosenthal S, Marggraf G, Pietruck F, Husing J, Strupat M, Philipp T, Kribben A. Procalcitonin for accurate detection of infection in haemodialysis. Nephrol Dial Transplant. 2001;16(5):975-9. Rec#: 5800. Exclusion Codes: SMN, EXC. [pmid: 11328903].
Herrlinger KR, Dittmann R, Weitz G, Wehkamp J, Ludwig D, Schwab M, Stange EF, Fellermann K. Serum procalcitonin differentiates inflammatory bowel disease and self-limited colitis. Inflamm Bowel Dis. 2004;10(3):229-33. Rec#: 9550. Exclusion Codes: NDE, EXC. [pmid: 15290916].
Herrmann W, Ecker D, Quast S, Klieden M, Rose S, Marzi I. Comparison of procalcitonin, sCD14 and interleukin-6 values in septic patients. Clin Chem Lab Med. 2000;38(1):41-6. Rec#: 6220. Exclusion Codes: NRO, EXC. [pmid: 10774960].
Hesselink DA, Burgerhart JS, Bosmans-Timmerarends H, Petit P, van Genderen PJ. Procalcitonin as a biomarker for severe Plasmodium falciparum disease: a critical appraisal of a semi-quantitative point-of-care test in a cohort of travellers with imported malaria. Malar J. 2009;8:206. Rec#: 7230. Exclusion Codes: NDE, EXC. [pmid: 19723338].
Hesselink DA, Burgerhart JS, Bosmans-Timmerarends H, Petit P, Van Genderen PJJ. Procalcitonin as a biomarker for severe Plasmodium falciparum disease: A critical appraisal of a semi-quantitative point-of-care test in a cohort of travellers with imported malaria. Malaria J. 2009;8(1). Rec#: 15780. Exclusion Codes: NDE, EXC.
Hillas G, Vassilakopoulos T, Plantza P, Rasidakis A, Bakakos P. C-reactive protein and procalcitonin as predictors of survival and septic shock in ventilator-associated pneumonia. Eur Respir J. 2010;35(4):805-11. Rec#: 570. Exclusion Codes: SMN, EXC. [pmid: 19717486].
Hirakata Y, Yanagihara K, Kurihara S, Izumikawa K, Seki M, Miyazaki Y, Kohno S. Comparison of usefulness of plasma procalcitonin and C-reactive protein measurements for estimation of severity in adults with community-acquired pneumonia. Diagn Microbiol Infect Dis. 2008;61(2):170-4. Rec#: 2050. Exclusion Codes: SMN, EXC. [pmid: 18329217].
Hitoglou-Hatzi S, Hatzistilianou M, Gougoustamou D, Rekliti A, Agguridaki Ch, Athanassiadou F, Frydas S, Kotsis A, Catriu D. Serum adenosine deaminase and procalcitonin concentrations in neutropenic febrile children with acute lymphoblastic leukaemia. Clin Exp Med. 2005;5(2):60-5. Rec#: 3680. Exclusion Codes: NDE, EXC. [pmid: 16096855].
Hladik M, Olosova A, Neiser J, Zaoral T. Procalcitonin--a marker and mediator of inflammation. Acta Chir Plast. 2005;47(2):51-4. Rec#: 3750. Exclusion Codes: NDE, EXC. [pmid: 16033153].
Hoffken G. Does procalcitonin (PCT) determination help for therapeutic decision in ambulant and nosocomial infections?. Ist die bestimmung von procalcitonin (PCT) hilfreich zum therapieentscheid bei ambulant und nosokomial erworbenen infektionen?. Atemwegs- Lungenkr. 2007;33(10):433-434. Rec#: 16250. Exclusion Codes: NRD, EXC.
Hoffmann G, Schobersberger W. Anti-inflammatory procalcitonin (PTC) in a human whole blood model septic shock. Cytokine. 2001;14(2):127-8. Rec#: 5780. Exclusion Codes: NDE, EXC. [pmid: 11356014].
Hoffmann G, Schobersberger W. Procalcitonin as a marker. Acta Anaesthesiol Scand. 2003;47(2):237. Rec#: 4920. Exclusion Codes: NDE, EXC. [pmid: 12631059].
Hoffmann O, Reuter U, Masuhr F, Holtkamp M, Kassim N, Weber JR. Low sensitivity of serum procalcitonin in bacterial meningitis in adults. Scand J Infect Dis. 2001;33(3):215-8. Rec#: 10360. Exclusion Codes: SMN, EXC. [pmid: 11303813].
Hoksch B, Fahrner R, Alexander Schmid R. Procalcitonin and brain natriuretic peptide as parameters in the postoperative course of patients with major pulmonary resection. Interact Cardiovasc Thorac Surg. 2007;6(2):155-9. Rec#: 2540. Exclusion Codes: SMN, EXC. [pmid: 17669797].
Hoksch B, Schmid RA. Reply to Apostolakis et al. Eur. J. Cardio-thorac. Surg. 2009;35(1):194. Rec#: 12450. Exclusion Codes: NDE, EXC.
Hollenstein U, Looareesuwan S, Aichelburg A, Thalhammer F, Stoiser B, Amradee S, Chullawichit S, El Menyawi I, Burgmann H. Serum procalcitonin levels in severe Plasmodium falciparum malaria. Am J Trop Med Hyg. 1998;59(6):860-3. Rec#: 6610. Exclusion Codes: NRO, EXC. [pmid: 9886189].
Holm A, Pedersen SS, Nexoe J, Obel N, Nielsen LP, Koldkjaer O, Pedersen C. Procalcitonin versus C-reactive protein for predicting pneumonia in adults with lower respiratory tract infection in primary care. Br J Gen Pract. 2007;57(540):555-60. Rec#: 8270. Exclusion Codes: NDE, EXC. [pmid: 17727748].
Huang DT, Weissfeld LA, Kellum JA, Yealy DM, Kong L, Martino M, Angus DC. Risk prediction with procalcitonin and clinical rules in community-acquired pneumonia. Ann Emerg Med. 2008;52(1):48-58.e2. Rec#: 8010. Exclusion Codes: NDE, EXC. [pmid: 18342993].
Huber W, Reichenberger J, Salmhofer H, Neu B, Ermler R, Schweigart U, Rothmeier L, Bottermann P, Classen M. Procalcitonin - A routine parameter in intensive medicine?. Procalcitonin - Ein routineparameter in der intensivmedizin?. Intensivmed. Notf.med. 1998;35(2):124-131. Rec#: 15200. Exclusion Codes: NDE, EXC.
Huber W, Schweigart U, Bottermann P. Failure of PCT to indicate severe fungal infection in two immunodeficient patients. Infection. 1997;25(6):377-8. Rec#: 10860. Exclusion Codes: NDE, EXC. [pmid: 9427059].
Hubl W, Krassler J, Zingler C, Pertschy A, Hentschel J, Gerhards-Reich C, Mack M, Demant T. Evaluation of a fully automated procalcitonin chemiluminescence immunoassay. Clin Lab. 2003;49(7-8):319-27. Rec#: 4690. Exclusion Codes: SMN, EXC. [pmid: 12908732].
Hugle T, Schuetz P, Mueller B, Laifer G, Tyndall A, Regenass S, Daikeler T. Serum procalcitonin for discrimination between septic and non-septic arthritis. Clin Exp Rheumatol. 2008;26(3):453-6. Rec#: 1520. Exclusion Codes: SMN, EXC. [pmid: 18578968].
Hunziker S, Hugle T, Schuchardt K, Groeschl I, Schuetz P, Mueller B, Dick W, Eriksson U, Trampuz A. The value of serum procalcitonin level for differentiation of infectious from noninfectious causes of fever after orthopaedic surgery. J Bone Joint Surg Am. 2010;92(1):138-48. Rec#: 260. Exclusion Codes: NDE, EXC. [pmid: 20048106].
Indino P, Lemarchand P, Bady P, de Torrente A, Genne L, Genne D. Prospective study on procalcitonin and other systemic infection markers in patients with leukocytosis. Int J Infect Dis. 2008;12(3):319-24. Rec#: 8170. Exclusion Codes: NDE, EXC. [pmid: 18077201].
Ingram PR, Inglis T, Moxon D, Speers D. Procalcitonin and C-reactive protein in severe 2009 H1N1 influenza infection. Intensive Care Med. 2010;36(3):528-32. Rec#: 240. Exclusion Codes: SMN, EXC. [pmid: 20069274].
Ip M, Rainer TH, Lee N, Chan C, Chau SS, Leung W, Leung MF, Tam TK, Antonio GE, Lui G, Lau TK, Hui DS, Fuchs D, Renneberg R, Chan PK. Value of serum procalcitonin, neopterin, and C-reactive protein in differentiating bacterial from viral etiologies in patients presenting with lower respiratory tract infections. Diagn Microbiol Infect Dis. 2007;59(2):131-6. Rec#: 8340. Exclusion Codes: NDE, EXC. [pmid: 17662560].
Isidor B, Caillaux G, Gilquin V, Loubersac V, Caillon J, Roze JC, Gras-le Guen C. The use of procalcitonin in the diagnosis of late-onset infection in neonatal intensive care unit patients. Scand J Infect Dis. 2007;39(11-12):1063-6. Rec#: 2420. Exclusion Codes: NDE, EXC. [pmid: 17852930].
Ito S, Sato N, Kojika M, Yaegashi Y, Suzuki Y, Suzuki K, Endo S. Serum procalcitonin levels are elevated in esophageal cancer patients with postoperative infectious complications. Eur Surg Res. 2005;37(1):22-8. Rec#: 3870. Exclusion Codes: SMN, EXC. [pmid: 15818038].
Ittner L, Born W, Rau B, Steinbach G, Fischer JA. Circulating procalcitonin and cleavage products in septicaemia compared with medullary thyroid carcinoma. Eur J Endocrinol. 2002;147(6):727-31. Rec#: 5050. Exclusion Codes: NRO, EXC. [pmid: 12457446].
Ivancevic N, Radenkovic D, Bumbasirevic V, Karamarkovic A, Jeremic V, Kalezic N, Vodnik T, Beleslin B, Milic N, Gregoric P, Zarkovic M. Procalcitonin in preoperative diagnosis of abdominal sepsis. Langenbecks Arch Surg. 2008;393(3):397-403. Rec#: 2300. Exclusion Codes: SMN, EXC. [pmid: 17968584].
Jacquot A, Labaune JM, Baum TP, Putet G, Picaud JC. Rapid quantitative procalcitonin measurement to diagnose nosocomial infections in newborn infants. Arch Dis Child Fetal Neonatal Ed. 2009;94(5):F345-8. Rec#: 860. Exclusion Codes: NDE, EXC. [pmid: 19439432].
Janota J, Stranak Z, Belohlavkova S, Mudra K, Simak J. Postnatal increase of procalcitonin in premature newborns is enhanced by chorioamnionitis and neonatal sepsis. Eur J Clin Invest. 2001;31(11):978-83. Rec#: 5600. Exclusion Codes: NDE, EXC. [pmid: 11737240].
Jaoude PA, Knight PR, Ohtake P, El-Solh AA. Biomarkers in the diagnosis of aspiration syndromes. Expert Rev Mol Diagn. 2010;10(3):309-19. Rec#: 110. Exclusion Codes: NDE, EXC. [pmid: 20370588].
Jaresova M, Striz I, Cermakova J, Lacha J, Sedlacek J, Mudra K, Hana I, Vitko S. Serum procalcitonin concentrations in transplant patients with acute rejection and bacterial infections. Immunol Lett. 1999;69(3):355-8. Rec#: 6380. Exclusion Codes: NDE, EXC. [pmid: 10528801].
Jeandrot A, Richard JL, Combescure C, Jourdan N, Finge S, Rodier M, Corbeau P, Sotto A, Lavigne JP. Serum procalcitonin and C-reactive protein concentrations to distinguish mildly infected from non-infected diabetic foot ulcers: a pilot study. Diabetologia. 2008;51(2):347-52. Rec#: 8230. Exclusion Codes: SMN, EXC. [pmid: 17934713].
Jebali MA, Hausfater P, Abbes Z, Aouni Z, Riou B, Ferjani M. Assessment of the accuracy of procalcitonin to diagnose postoperative infection after cardiac surgery. Anesthesiology. 2007;107(2):232-8. Rec#: 2550. Exclusion Codes: NDE, EXC. [pmid: 17667566].
Jensen JU, Heslet L, Jensen TH, Espersen K, Steffensen P, Tvede M. Procalcitonin increase in early identification of critically ill patients at high risk of mortality. Crit Care Med. 2006;34(10):2596-602. Rec#: 3160. Exclusion Codes: NDE, EXC. [pmid: 16915118].
Jensen JU, Lundgren B, Hein L, Mohr T, Petersen PL, Andersen LH, Lauritsen AO, Hougaard S, Mantoni T, Bomler B, Thornberg KJ, Thormar K, Loken J, Steensen M, Carl P, Petersen JA, Tousi H, Soe-Jensen P, Bestle M, Hestad S, Andersen MH, Fjeldborg P, Larsen KM, Rossau C, Thomsen CB, Ostergaard C, Kjaer J, Grarup J, Lundgren JD. The Procalcitonin And Survival Study (PASS) - a randomised multi-center investigator-initiated trial to investigate whether daily measurements biomarker Procalcitonin and pro-active diagnostic and therapeutic responses to abnormal Procalcitonin levels, can improve survival in intensive care unit patients. Calculated sample size (target population): 1000 patients. BMC Infect Dis. 2008;8:91. Rec#: 1490. Exclusion Codes: NRO, EXC. [pmid: 18620598].
Jensen JU, Lundgren B, Lundgren JD. Meta-analysis of procalcitonin for sepsis detection. Lancet Infect Dis. 2007;7(8):499-500. author reply 502-3. Rec#: 2590. Exclusion Codes: NRD, EXC. [pmid: 17646020].
Jensen JU, Lundgren J. Procalcitonin monitoring in trauma intensive care patients: how helpful is it?. Crit Care Med. 2009;37(6):2093-4. Rec#: 840. Exclusion Codes: NDE, EXC. [pmid: 19448450].
Jereb M, Kotar T. Usefulness of procalcitonin to differentiate typical from atypical community-acquired pneumonia. Wien Klin Wochenschr. 2006;118(5-6):170-4. Rec#: 8780. Exclusion Codes: SMN, EXC. [pmid: 16773483].
Jereb M, Kotar T, Jurca T, Lejko Zupanc T. Usefulness of procalcitonin for diagnosis of infective endocarditis. Intern Emerg Med. 2009;4(3):221-6. Rec#: 940. Exclusion Codes: SMN, EXC. [pmid: 19357824].
Jereb M, Muzlovic I, Hojker S, Strle F. Predictive value of serum and cerebrospinal fluid procalcitonin levels for the diagnosis of bacterial meningitis. Infection. 2001;29(4):209-12. Rec#: 10290. Exclusion Codes: SMN, EXC. [pmid: 11545482].
Jimeno A, Garcia-Velasco A, del Val O, Gonzalez-Billalabeitia E, Hernando S, Hernandez R, Sanchez-Munoz A, Lopez-Martin A, Duran I, Robles L, Cortes-Funes H, Paz-Ares L. Assessment of procalcitonin as a diagnostic and prognostic marker in patients with solid tumors and febrile neutropenia. Cancer. 2004;100(11):2462-9. Rec#: 4320. Exclusion Codes: NDE, EXC. [pmid: 15160353].
Jin M, Khan AI. Procalcitonin: Uses in the clinical laboratory for the diagnosis of sepsis. Lab. Med. 2010;41(3):173-177. Rec#: 11740. Exclusion Codes: NDE, EXC.
Johnston IG. Procalcitonin - An exciting prospect as a marker in sepsis. Care Crit. Ill. 2001;17(3):81-82. Rec#: 14750. Exclusion Codes: NDE, EXC.
Jones AE, Fiechtl JF, Brown MD, Ballew JJ, Kline JA. Procalcitonin test in the diagnosis of bacteremia: a meta-analysis. Ann Emerg Med. 2007;50(1):34-41. Rec#: 3030. Exclusion Codes: NDE, EXC. [pmid: 17161501].
Jongwutiwes U, Suitharak K, Tiengrim S, Thamlikitkul V. Serum procalcitonin in diagnosis of bacteremia. J Med Assoc Thai. Suppl 2. 2009;92:S79-87. Rec#: 760. Exclusion Codes: SMN, EXC. [pmid: 19562990].
Joram N, Boscher C, Denizot S, Loubersac V, Winer N, Roze JC, Gras-Le Guen C. Umbilical cord blood procalcitonin and C reactive protein concentrations as markers for early diagnosis of very early onset neonatal infection. Arch Dis Child Fetal Neonatal Ed. 2006;91(1):F65-6. Rec#: 3510. Exclusion Codes: NDE, EXC. [pmid: 16371391].
Jung B, Embriaco N, Roux F, Forel JM, Demory D, Allardet-Servent J, Jaber S, La Scola B, Papazian L. Microbiogical data, but not procalcitonin improve the accuracy of the clinical pulmonary infection score. Intensive Care Med. 2010;36(5):790-8. Rec#: 120. Exclusion Codes: SMN, EXC. [pmid: 20217042].
Kabir K, Keller H, Grass G, Minor T, Stueber F, Schroeder S, Putensen C, Paul C, Burger C, Rangger C, Neville LF, Mathiak G. Cytokines and chemokines in serum and urine as early predictors to identify septic patients on intensive care unit. Int J Mol Med. 2003;12(4):565-70. Rec#: 4660. Exclusion Codes: NRO, EXC. [pmid: 12964035].
Kafetzis DA, Tigani GS, Costalos C. Immunologic markers in the neonatal period: diagnostic value and accuracy in infection. Expert Rev Mol Diagn. 2005;5(2):231-9. Rec#: 9260. Exclusion Codes: NDE, EXC. [pmid: 15833052].
Kahn RE. Procalcitonin to guide duration of antibiotic therapy in intensive care patients: some research questions. Crit Care. 2009;13(4):414. author reply 414. Rec#: 640. Exclusion Codes: NDE, EXC. [pmid: 19664199].
Kallio R, Surcel HM, Bloigu A, Syrjala H. C-reactive protein, procalcitonin and interleukin-8 in the primary diagnosis of infections in cancer patients. Eur J Cancer. 2000;36(7):889-94. Rec#: 6210. Exclusion Codes: SMN, EXC. [pmid: 10785594].
Kandemir O, Uluba B, Polat G, Sezer C, Camdeviren H, Kaya A. Elevation of procalcitonin level in patients with pulmonary tuberculosis and in medical staff with close patient contact. Arch Med Res. 2003;34(4):311-4. Rec#: 9840. Exclusion Codes: NRO, EXC. [pmid: 12957529].
Kang YA, Kwon SY, Yoon HI, Lee JH, Lee CT. Role of C-reactive protein and procalcitonin in differentiation of tuberculosis from bacterial community acquired pneumonia. Korean J Intern Med. 2009;24(4):337-42. Rec#: 7100. Exclusion Codes: SMN, EXC. [pmid: 19949732].
Kapoor S. Procalcitonin and its utility as a diagnostic and prognostic assay in patients with renal dysfunction and immunosuppressive conditions. J Infect Chemother. 2009;15(1):58. author reply 59. Rec#: 1020. Exclusion Codes: NDE, EXC. [pmid: 19280304].
Kapoor S. The rapidly expanding role of procalcitonin as a diagnostic and prognostic assay besides in UTIs. Int Urol Nephrol. 2009;41(2):435-6. Rec#: 7610. Exclusion Codes: NDE, EXC. [pmid: 19130286].
Karavanaki K, Angelos Haliotis F, Sourani M, Kariyiannis C, Hantzi E, Zachariadou L, Avlonitis S, Papassotiriou I, Stefanidis CJ. DMSA scintigraphy in febrile urinary tract infections could be omitted in children with low procalcitonin levels. Infect. Dis. Clin. Pract. 2007;15(6):377-381. Rec#: 16240. Exclusion Codes: SMN, EXC.
Karzai W, Oberhoffer M, Meier-Hellmann A, Reinhart K. Procalcitonin--a new indicator of the systemic response to severe infections. Infection. 1997;25(6):329-34. Rec#: 10870. Exclusion Codes: NDE, EXC. [pmid: 9427049].
Karzai W, Reinhart K. Sepsis: definitions and diagnosis. Int J Clin Pract Suppl. 1998;95:44-8. Rec#: 6650. Exclusion Codes: NDE, EXC. [pmid: 9796555].
Keel M, Harter L, Reding T, Sun LK, Hersberger M, Seifert B, Bimmler D, Graf R. Pancreatic stone protein is highly increased during posttraumatic sepsis and activates neutrophil granulocytes. Crit Care Med. 2009;37(5):1642-8. Rec#: 970. Exclusion Codes: NRO, EXC. [pmid: 19325491].
Keenan J. The European Respiratory Society Congress Munich, Germany September 2-6, 2006. Ann. Long-Term Care. 2007;15(1):28-32. Rec#: 13570. Exclusion Codes: NRD, EXC.
Khan DA, Rahman A, Khan FA. Is procalcitonin better than C-reactive protein for early diagnosis of bacterial pneumonia in children?. J Clin Lab Anal. 2010;24(1):1-5. Rec#: 7020. Exclusion Codes: SMN, EXC. [pmid: 20087955].
Kim HC, Kim KM, Lee SM, Lee SJ, Ham HS, Cho YJ, Jeong YY, Lee JD, Hwang YS. Measuring serum procalcitonin in patients with fever in the ICU to differentiate infectious causes from non-infectious causes. Tuberc. Respir. Dis. 2006;61(1):20-25. Rec#: 13790. Exclusion Codes: NRD, EXC.
Kim JY, Kim CH, Park S, Lee CY, Yong IH, Choi JH, Shin T, Park YB, Jang SH, Jae YL, Sang MP, Kim DG, Lee MG, Hyun IG, Jung KS. Semi-quantitative procalcitonin assay in critically ill patients with respiratory infections. Tuberc. Respir. Dis. 2009;67(3):205-211. Rec#: 12120. Exclusion Codes: NRD, EXC.
Kim SH, Joo YP, Hyun SP, Hee SS, Shin TK, Chong WK, Bu GL, Seok JL, Shun NL, Jin KN, Min SL, Won YL, Suk JY, Kye CS. Diagnostic value of procalcitonin and C-reactive protein in differentiation of pleural effusions. Tuberc. Respir. Dis. 2007;63(4):353-361. Rec#: 16270. Exclusion Codes: NRD, EXC.
Kindberg Boysen A, Madsen JS, Jorgensen PE. Procalcitonin as a marker of postoperative complications. Scand J Clin Lab Invest. 2005;65(5):387-94. Rec#: 3700. Exclusion Codes: NDE, EXC. [pmid: 16081361].
Kisacik B, Kalyoncu U, Erol MF, Karadag O, Yildiz M, Akdogan A, Kaptanoglu B, Hayran M, Ureten K, Ertenli I, Kiraz S, Calguneri M. Accurate diagnosis of acute abdomen in FMF and acute appendicitis patients: how can we use procalcitonin?. Clin Rheumatol. 2007;26(12):2059-62. Rec#: 8490. Exclusion Codes: SMN, EXC. [pmid: 17415505].
Kitanovski L, Jazbec J, Hojker S, Gubina M, Derganc M. Diagnostic accuracy of procalcitonin and interleukin-6 values for predicting bacteremia and clinical sepsis in febrile neutropenic children with cancer. Eur J Clin Microbiol Infect Dis. 2006;25(6):413-5. Rec#: 3290. Exclusion Codes: NDE, EXC. [pmid: 16767494].
Knudsen TB, Kristiansen TB. Issues pertaining to data extraction and classification and publication bias in meta-analysis of the diagnostic accuracy of markers for bacterial infection. Clin Infect Dis. 2005;40(9):1372-3. author reply 1373-4. Rec#: 9270. Exclusion Codes: NDE, EXC. [pmid: 15825043].
Knudsen TB, Larsen K, Kristiansen TB, Moller HJ, Tvede M, Eugen-Olsen J, Kronborg G. Diagnostic value of soluble CD163 serum levels in patients suspected of meningitis: comparison with CRP and procalcitonin. Scand J Infect Dis. 2007;39(6-7):542-53. Rec#: 8390. Exclusion Codes: SMN, EXC. [pmid: 17577816].
Kocabas E, Sarikcioglu A, Aksaray N, Seydaoglu G, Seyhun Y, Yaman A. Role of procalcitonin, C-reactive protein, interleukin-6, interleukin-8 and tumor necrosis factor-alpha in the diagnosis of neonatal sepsis. Turk J Pediatr. 2007;49(1):7-20. Rec#: 2770. Exclusion Codes: NDE, EXC. [pmid: 17479639].
Kocazeybek B, Kucukoglu S, Oner YA. Procalcitonin and C-reactive protein in infective endocarditis: correlation with etiology and prognosis. Chemotherapy. 2003;49(1-2):76-84. Rec#: 4830. Exclusion Codes: SMN, EXC. [pmid: 12714816].
Kofoed K, Andersen O, Kronborg G, Tvede M, Petersen J, Eugen-Olsen J, Larsen K. Use of plasma C-reactive protein, procalcitonin, neutrophils, macrophage migration inhibitory factor, soluble urokinase-type plasminogen activator receptor, and soluble triggering receptor expressed on myeloid cells-1 in combination to diagnose infections: a prospective study. Crit Care. 2007;11(2):R38. Rec#: 2880. Exclusion Codes: NDE, EXC. [pmid: 17362525].
Kofteridis DP, Samonis G, Karatzanis AD, Fragiadakis GM, Bourolias CA, Maraki S, Papadakis JA, Velegrakis GA. C-reactive protein and serum procalcitonin levels as markers of bacterial upper respiratory tract infections. Am. J. Infect. Dis. 2009;5(4):289-294. Rec#: 15730. Exclusion Codes: NRO, EXC.
Koksal N, Harmanci R, Cetinkaya M, Hacimustafaoglu M. Role of procalcitonin and CRP in diagnosis and follow-up of neonatal sepsis. Turk J Pediatr. 2007;49(1):21-9. Rec#: 2760. Exclusion Codes: NDE, EXC. [pmid: 17479640].
Korczowski B. Serum concentration of procalcitonin in various childhood diseases. Med. Sci. Monit. 1999;5(5):996-1000. Rec#: 15040. Exclusion Codes: NDE, EXC.
Korczowski B. Diagnostic usefulness of procalcitonin in acute pancreatitis. Diagnostyczna przydatnosc prokalcytoniny w ostrym zapaleniu trzustki. Gastroenterol. Pol. 2006;13(1):63-65. Rec#: 13870. Exclusion Codes: NDE, EXC.
Korczowski B. Serum procalcitonin concentration in children with liver disease. Pediatr Infect Dis J. 2006;25(3):268-9. Rec#: 8920. Exclusion Codes: NRO, EXC. [pmid: 16511394].
Korczowski B, Mroczkowska-Juchkiewicz A, Papierkowski A. High serum procalcitonin concentration in Kawasaki disease. Med. Sci. Monit. 1998;4(6):1072-1074. Rec#: 17100. Exclusion Codes: NDE, EXC.
Korczowski B, Szybist W. Serum procalcitonin and C-reactive protein in children with diarrhoea of various aetiologies. Acta Paediatr. 2004;93(2):169-73. Rec#: 4430. Exclusion Codes: NDE, EXC. [pmid: 15046268].
Korczowski B, Szybist W, Romanczuk W, Sieklucki J, Rusin J. Diagnostic usefulness of procalcitonin and C-reactive protein in the diarrhea of different etiology. Pediatr. Wspolczesna. 2002;4(3):289-292. Rec#: 14560. Exclusion Codes: NDE, EXC.
Kordek A, Giedrys-Kalemba S, Pawlus B, Loniewska B, Bartkowiak E, Rudnicki J, Szych Z, Czajka R. Comparison of quantitative (LUMItest) and semi-quantitative (Brahms PCT-Q) Tests for PCT concentration measurements in the newborn infants' blood. Porownanie ilosciowej (LUMItest) i pol ilosciowej (Brahms PCT-Q) medody oznaczania stezenia prokalcytoniny w surowicy krwi noworodkow. Adv. Clin. Exp. Med. 2004;13(6):945-948. Rec#: 16690. Exclusion Codes: NRD, EXC.
Kordek A, Giedrys-Kalemba S, Pawlus B, Podraza W, Czajka R. Umbilical cord blood serum procalcitonin concentration in the diagnosis of early neonatal infection. J Perinatol. 2003;23(2):148-53. Rec#: 9950. Exclusion Codes: NDE, EXC. [pmid: 12673266].
Kordek A, Halasa M, Podraza W. Early detection of an early onset infection in the neonate based on measurements of procalcitonin and C-reactive protein concentrations in cord blood. Clin Chem Lab Med. 2008;46(8):1143-8. Rec#: 7850. Exclusion Codes: NDE, EXC. [pmid: 18590465].
Kordek A, Podraza W, Czajka R. Reliability of semiquantitative determination of procalcitonin serum concentrations in neonates. Diagn Microbiol Infect Dis. 2006;56(1):31-4. Rec#: 8700. Exclusion Codes: NDE, EXC. [pmid: 16860512].
Kordek A, Torbe A, Czajka R. Maternal venous procalcitonin levels do not correlate with umbilical cord blood and venous blood concentrations in the neonate. J Perinat Med. 2006;34(6):462-5. Rec#: 8610. Exclusion Codes: NRO, EXC. [pmid: 17140295].
Korppi M, Don M, Valent F, Canciani M. The value of clinical features in differentiating between viral, pneumococcal and atypical bacterial pneumonia in children. Acta Paediatr. 2008;97(7):943-7. Rec#: 7950. Exclusion Codes: NDE, EXC. [pmid: 18422803].
Korppi M, Remes S. Serum procalcitonin in pneumococcal pneumonia in children. Eur Respir J. 2001;17(4):623-7. Rec#: 10310. Exclusion Codes: NDE, EXC. [pmid: 11401055].
Korppi M, Remes S, Heiskanen-Kosma T. Serum procalcitonin concentrations in bacterial pneumonia in children: a negative result in primary healthcare settings. Pediatr Pulmonol. 2003;35(1):56-61. Rec#: 10060. Exclusion Codes: NDE, EXC. [pmid: 12461740].
Koskenvuo MM, Irjala K, Kinnala A, Ruuskanen O, Kero P. Value of monitoring serum procalcitonin in neonates at risk of infection. Eur J Clin Microbiol Infect Dis. 2003;22(6):377-8. Rec#: 9910. Exclusion Codes: NDE, EXC. [pmid: 12750960].
Kotoula A, Gardikis S, Tsalkidis A, Mantadakis E, Zissimopoulos A, Deftereos S, Tripsianis G, Manolas K, Chatzimichael A, Vaos G. Comparative efficacies of procalcitonin and conventional inflammatory markers for prediction of renal parenchymal inflammation in pediatric first urinary tract infection. Urology. 2009;73(4):782-6. Rec#: 7590. Exclusion Codes: SMN, EXC. [pmid: 19152962].
Kotoula A, Gardikis S, Tsalkidis A, Mantadakis E, Zissimopoulos A, Deftereos S, Tripsianis G, Manolas K, Chatzimichael A, Vaos G. Comparative Efficacies of Procalcitonin and Conventional Inflammatory Markers for Prediction of Renal Parenchymal Inflammation in Pediatric First Urinary Tract Infection. Urology. 2009;73(4):782-786. Rec#: 15940. Exclusion Codes: NDE, EXC. [pmid: 19152962].
Kotoula A, Gardikis S, Tsalkidis A, Mantadakis E, Zissimopoulos A, Kambouri K, Deftereos S, Tripsianis G, Manolas K, Chatzimichael A, Vaos G. Procalcitonin for the early prediction of renal parenchymal involvement in children with UTI: preliminary results. Int Urol Nephrol. 2009;41(2):393-9. Rec#: 7770. Exclusion Codes: SMN, EXC. [pmid: 18836845].
Kruger S, Ewig S, Kunde J, Hartmann O, Suttorp N, Welte T. Pro-atrial natriuretic peptide and pro-vasopressin for predicting short-term and long-term survival in community-acquired pneumonia: results from the German Competence Network CAPNETZ. Thorax. 2010;65(3):208-14. Rec#: 6940. Exclusion Codes: NDE, EXC. [pmid: 20335288].
Kruger S, Ewig S, Marre R, Papassotiriou J, Richter K, von Baum H, Suttorp N, Welte T. Procalcitonin predicts patients at low risk of death from community-acquired pneumonia across all CRB-65 classes. Eur Respir J. 2008;31(2):349-55. Rec#: 8210. Exclusion Codes: NDE, EXC. [pmid: 17959641].
Kruger S, Ewig S, Papassotiriou J, Kunde J, Marre R, von Baum H, Suttor N, Welte T. Inflammatory parameters predict etiologic patterns but do not allow for individual prediction of etiology in patients with CAP: results from the German competence network CAPNETZ. Respir Res. 2009;10:65. Rec#: 7310. Exclusion Codes: NDE, EXC. [pmid: 19594893].
Kruseova J, Prucha M, Dostal M, Pindurova E, Liskova I, Nyc O, Sumerauer D, Nemcova J, Stary J. The role of plasma procalcitonin and other inflammatory markers as identifiers of bacterial infections in children with solid tumor. Diagnosticky vyznam prokalcitoninu a dalsich markeru zanetu u deti se solidnimi nadory. Cesko-Slov. Pediatr. 2005;60(4):206-212. Rec#: 14110. Exclusion Codes: NRD, EXC.
Krysan D. Serum procalcitonin levels aid in distinguishing bacterial from aseptic meningitis in children. J. Pediatr. 2009;154(5):773. Rec#: 12310. Exclusion Codes: NDE, EXC. [pmid: 19364565].
Kunz D, Kohse KP. Diagnostic of inflammation in pediatric patients. Entzundungsdiagnostik in der padiatrie. LaboratoriumsMedizin. 2002;26(5-6):335-340. Rec#: 16900. Exclusion Codes: NDE, EXC.
Kupeli S, Turul T, Cuzdanci H, Uckan D, Cetin M, Tuncer M, Tezcan I. Procalcitonin, C-reactive protein and erythrocyte sedimentation rate values in bone marrow transplanted children. Kemik iligi transplantasyonu yapilan cocuklarda prokalsitonin, kantitatif C-reaktif protein ve eritrosit sedimentasyon hizi degerleri. Cocuk Sagligi Hast. Derg. 2007;50(1):1-5. Rec#: 13500. Exclusion Codes: NRD, EXC.
Kuse ER, Jaeger K. Procalcitonin increase after anti-CD3 monoclonal antibody therapy does not indicate infectious disease. Transpl Int. 2001;14(1):55. Rec#: 10380. Exclusion Codes: NDE, EXC. [pmid: 11263558].
Kuse ER, Langefeld I, Jaeger K, Kulpmann WR. Procalcitonin in fever of unknown origin after liver transplantation: a variable to differentiate acute rejection from infection. Crit Care Med. 2000;28(2):555-9. Rec#: 6240. Exclusion Codes: NDE, EXC. [pmid: 10708199].
Kuse ER, Langefeld I, Jaeger K, Kulpmann WR. Procalcitonin-a new diagnostic tool in complications following liver transplantation. Intensive Care Med. Suppl 2. 2000;26:S187-92. Rec#: 1700. Exclusion Codes: NDE, EXC. [pmid: 18470718].
Kushimoto S, Shibata Y, Koido Y, Kawai M, Yokota H, Yamamoto Y. The clinical usefulness of procalcitonin measurement for assessing the severity of bacterial infection in patients requiring corticosteroid therapy. J. Nippon Med. Sch. 2006;73(6):354-356. Rec#: 16380. Exclusion Codes: SMN, EXC.
Kushimoto S, Shibata Y, Koido Y, Kawai M, Yokota H, Yamamoto Y. The clinical usefulness of procalcitonin measurement for assessing the severity of bacterial infection in critically ill patients requiring corticosteroid therapy. J Nippon Med Sch. 2007;74(3):236-40. Rec#: 2630. Exclusion Codes: NDE, EXC. [pmid: 17625373].
Kylanpaa-Back ML, Takala A, Kemppainen E, Puolakkainen P, Haapiainen R, Repo H. Procalcitonin strip test in the early detection of severe acute pancreatitis. Br J Surg. 2001;88(2):222-7. Rec#: 10430. Exclusion Codes: NDE, EXC. [pmid: 11167871].
Lacoma A, Prat C, Andreo F, Dominguez J. Biomarkers in the management of COPD. Eur. Respir. Rev. 2009;18(112):96-104. Rec#: 12260. Exclusion Codes: NDE, EXC. [pmid: 20956129].
Lacour AG, Gervaix A, Zamora SA, Vadas L, Lombard PR, Dayer JM, Suter S. Procalcitonin, IL-6, IL-8, IL-1 receptor antagonist and C-reactive protein as identificators of serious bacterial infections in children with fever without localising signs. Eur J Pediatr. 2001;160(2):95-100. Rec#: 5830. Exclusion Codes: NDE, EXC. [pmid: 11271398].
Lacour AG, Zamora SA, Gervaix A. A score identifying serious bacterial infections in children with fever without source. Pediatr Infect Dis J. 2008;27(7):654-6. Rec#: 7890. Exclusion Codes: NDE, EXC. [pmid: 18536624].
Lacroix J. What tests can help diagnose and estimate the severity of sepsis?. J Pediatr (Rio J). 2007;83(4):297-8. Rec#: 2530. Exclusion Codes: NRD, EXC. [pmid: 17676234].
Lagabrielle JF, Tachet A, Boin V. Evaluation of two automated immunoassays for procalcitonin measurement: Kryptor(registered trademark) (Brahms) and Vidas(registered trademark) (BioMerieux). Dosage de la procalcitonine : comparaison des resultats obtenus sur Kryptor(registered trademark) (Brahms) et Vidas(registered trademark) (BioMerieux). Immuno-Anal. Biol. Spec. 2008;23(4):245-250. Rec#: 12790. Exclusion Codes: NDE, EXC.
Lai CC, Chen SY, Wang CY, Wang JY, Su CP, Liao CH, Tan CK, Huang YT, Lin HI, Hsueh PR. Diagnostic value of procalcitonin for bacterial infection in elderly patients in the emergency department. J Am Geriatr Soc. 2010;58(3):518-22. Rec#: 160. Exclusion Codes: NDE, EXC. [pmid: 20163483].
Lam HS, Ng PC. Diagnostic markers in neonatal sepsis. Fetal Matern. Med. Rev. 2007;18(1):53-65. Rec#: 13550. Exclusion Codes: NDE, EXC.
Lam MF, Leung JC, Lam CW, Tse KC, Lo WK, Lui SL, Chan TM, Tam S, Lai KN. Procalcitonin fails to differentiate inflammatory status or predict long-term outcomes in peritoneal dialysis-associated peritonitis. Perit Dial Int. 2008;28(4):377-84. Rec#: 7870. Exclusion Codes: SMN, EXC. [pmid: 18556380].
Landman GW, Kleefstra N. Procalcitonin in intensive care units: the PRORATA trial. Lancet. 2010;375(9726):1606. author reply 1606-7. Rec#: 40. Exclusion Codes: NDE, EXC. [pmid: 20452516].
Lanuti M, Fahrner, Van Schil, End A, Szoke T, Turna A. Conference discussion. Interact. Cardiovasc. Thorac. Surg. 2007;6(2):158-159. Rec#: 13420. Exclusion Codes: SMN, EXC.
Lapillonne A, Basson E, Monneret G, Bienvenu J, Salle BL. Lack of specificity of procalcitonin for sepsis diagnosis in premature infants. Lancet. 1998;351(9110):1211-2. Rec#: 6760. Exclusion Codes: NDE, EXC. [pmid: 9643726].
Lavrentieva A, Kontakiotis T, Lazaridis L, Tsotsolis N, Koumis J, Kyriazis G, Bitzani M. Inflammatory markers in patients with severe burn injury. What is the best indicator of sepsis?. Burns. 2007;33(2):189-94. Rec#: 3020. Exclusion Codes: SMN, EXC. [pmid: 17215085].
Lawn SD, Obeng J, Acheampong JW, Griffin GE. Serum procalcitonin concentrations in patients with pulmonary tuberculosis. Trans R Soc Trop Med Hyg. 1998;92(5):540-1. Rec#: 10710. Exclusion Codes: NRO, EXC. [pmid: 9861374].
Le Roux P. Laboratory investigations in acute lower respiratory tract infections in children. Les examens a visee etiologique dans les pneumopathies communautaires de l'enfant (hors imagerie). Arch. Pediatr. 1998;5(SUPPL. 1):28s-32s. Rec#: 17140. Exclusion Codes: NRD, EXC. [pmid: 10223159].
Leaver SK, MacCallum NS, Pingle V, Hacking MB, Quinlan GJ, Evans TW, Burke-Gaffney A. Increased plasma thioredoxin levels in patients with sepsis: positive association with macrophage migration inhibitory factor. Intensive Care Med. 2010;36(2):336-41. Rec#: 510. Exclusion Codes: NDE, EXC. [pmid: 19756498].
Leclerc F, Cremer R, Noizet O. Procalcitonin as a diagnostic and prognostic biomarker of sepsis in critically ill children. Pediatr Crit Care Med. 2003;4(2):264-6. Rec#: 4810. Exclusion Codes: SMN, EXC. [pmid: 12749670].
Leclerc F, Leteurtre S, Noizet O, Dorkenoo A, Sadik A, Cremer R, Fourier C. Procalcitonin as a prognostic marker in children with meningococcal septic shock. Arch Dis Child. 2002;87(5):450. Rec#: 5100. Exclusion Codes: SMN, EXC. [pmid: 12390935].
Lee BE, Davies HD. Aseptic meningitis. Curr Opin Infect Dis. 2007;20(3):272-7. Rec#: 8470. Exclusion Codes: NDE, EXC. [pmid: 17471037].
Lee CC, Chen SY, Tsai CL, Wu SC, Chiang WC, Wang JL, Sun HY, Chen SC, Chen WJ, Hsueh PR. Prognostic value of mortality in emergency department sepsis score, procalcitonin, and C-reactive protein in patients with sepsis at the emergency department. Shock. 2008;29(3):322-7. Rec#: 2460. Exclusion Codes: NDE, EXC. [pmid: 17724429].
Lemiale V, Renaud B, Moutereau S, N'Gako A, Salloum M, Calmettes MJ, Herve J, Boraud C, Santin A, Grego JC, Braconnier F, Roupie E. A single procalcitonin level does not predict adverse outcomes of women with pyelonephritis. Eur Urol. 2007;51(5):1394-401. Rec#: 8570. Exclusion Codes: SMN, EXC. [pmid: 17207908].
Leroy S, Romanello C, Galetto-Lacour A, Smolkin V, Korczowski B, Rodrigo C, Tuerlinckx D, Gajdos V, Moulin F, Contardo M, Gervaix A, Halevy R, Duhl B, Prat C, Borght TV, Foix-l'Helias L, Dubos F, Gendrel D, Breart G, Chalumeau M. Procalcitonin to reduce the number of unnecessary cystographies in children with a urinary tract infection: a European validation study. J Pediatr. 2007;150(1):89-95. Rec#: 8590. Exclusion Codes: NDE, EXC. [pmid: 17188622].
Lestin F, Lestin HG, Burstein C, Anders O, Freund M. Provisional experience with procalcitonin, C-reactive protein, neopterin, selected cytokines, and hemostatic parameters in patients with malignant hematological diseases and febrile neutropenia induced by cytostatic treatment. Vorlaufige Erfahrungen mit Procalcitonin, C-reaktivem Protein, Neopterin, ausgewahlten Zytokinen und Hamostaseparametern an Patienten mit malignen hamatologischen Erkrankungen, bei Zytostatika-induzierter Neutropenie und Fieber. Clin. Lab. 1998;44(6):451-461. Rec#: 17120. Exclusion Codes: NRD, EXC.
Li MX, Liu BY, Jin ML, Song Y. Diagnostic value of procalcitonin in inflammation and sepsis. Chin. J. Infect. Chemother. 2008;8(3):216-218. Rec#: 12910. Exclusion Codes: NDE, EXC.
Liao XL, Jin XD, Kang Y, Deng YY, Zhang ZW, Zhou Y, Zhang ZW, Liu C, Yin WH. Role of procalcitonin in the diagnosis of ventilator-associated pneumonia. Chin. Crit. Care Med. 2010;22(3):142-145. Rec#: 11690. Exclusion Codes: NRD, EXC.
Liaudat S, Dayer E, Praz G, Bille J, Troillet N. Usefulness of procalcitonin serum level for the diagnosis of bacteremia. Eur J Clin Microbiol Infect Dis. 2001;20(8):524-7. Rec#: 5630. Exclusion Codes: NDE, EXC. [pmid: 11681430].
Linssen CF, Bekers O, Drent M, Jacobs JA. C-reactive protein and procalcitonin concentrations in bronchoalveolar lavage fluid as a predictor of ventilator-associated pneumonia. Ann Clin Biochem. 2008;45(Pt 3):293-8. Rec#: 1660. Exclusion Codes: NDE, EXC. [pmid: 18482918].
Lisboa T, Rello J. De-escalation in lower respiratory tract infections. Curr Opin Pulm Med. 2006;12(5):364-8. Rec#: 8660. Exclusion Codes: NDE, EXC. [pmid: 16926653].
Liu L, Zhen YQ, Jing CM, Xie W, Li CL. Dynamic monitoring the levels of endotoxin, IL-6, IL-10, TNF-(alpha) and procalcitonin (PCT) in serum of pediatric patients with systemic inflammatory response syndrome. Chin. J. Antibiot. 2008;33(5):297-299. Rec#: 12730. Exclusion Codes: NRD, EXC.
Livaditi O, Kotanidou A, Psarra A, Dimopoulou I, Sotiropoulou C, Augustatou K, Papasteriades C, Armaganidis A, Roussos C, Orfanos SE, Douzinas EE. Neutrophil CD64 expression and serum IL-8: sensitive early markers of severity and outcome in sepsis. Cytokine. 2006;36(5-6):283-90. Rec#: 2860. Exclusion Codes: SMN, EXC. [pmid: 17368039].
Llorente E, Prieto B, Cardo L, Avello N, Alvarez FV. Umbilical cord blood serum procalcitonin by Time-Resolved Amplified Cryptate Emission (TRACE) technology: reference values of a potential marker of vertically transmitted neonatal sepsis. Clin Chem Lab Med. 2007;45(11):1531-5. Rec#: 2380. Exclusion Codes: NDE, EXC. [pmid: 17892436].
Lode H. MRSA infections: Competent and safe treatment is the standard, but that is no reason for giving the all clear signal: An interview. MRSA-infektionen: Kompetente und sichere therapie ist standard, doch das ist kein grund zur entwarnung!. Klinikartz. 2007;36(6):350-351. Rec#: 16310. Exclusion Codes: NDE, EXC.
Loebe M, Lodziewski S, Qedra N, Brunkhorst F, Wagner F, Hetzer R. Procalcitonin, a marker of infection in cardiac surgery. Der infektionsmarker procalcitonin in der herzchirurgie. Z. Herz- Thorax- Gefasschir. 1999;13(5):215-220. Rec#: 15000. Exclusion Codes: NDE, EXC.
Lommatzsch M, Niewerth A, Klotz J, Schulte-Herbruggen O, Zingler C, Schuff-Werner P, Virchow JC. Platelet and plasma BDNF in lower respiratory tract infections of the adult. Respir Med. 2007;101(7):1493-9. Rec#: 8540. Exclusion Codes: NRO, EXC. [pmid: 17317133].
Lopez Sastre JB, Perez Solis D, Roques Serradilla V, Fernandez Colomer B, Coto Cotallo GD, Krauel Vidal X, Narbona Lopez E, Garcia del Rio M, Sanchez Luna M, Belaustegui Cueto A, Moro Serrano M, Urbon Artero A, Alvaro Iglesias E, Cotero Lavin A, Martinez Vilalta E, Jimenez Cobos B. Procalcitonin is not sufficiently reliable to be the sole marker of neonatal sepsis of nosocomial origin. BMC Pediatr. 2006;6:16. Rec#: 3330. Exclusion Codes: NDE, EXC. [pmid: 16709255].
Lopez Sastre JB, Solis DP, Serradilla VR, Colomer BF, Cotallo GD. Evaluation of procalcitonin for diagnosis of neonatal sepsis of vertical transmission. BMC Pediatr. 2007;7:9. Rec#: 2910. Exclusion Codes: NDE, EXC. [pmid: 17324267].
Lorrot M, Moulin F, Coste J, Ravilly S, Guerin S, Lebon P, Lacombe C, Raymond J, Bohuon C, Gendrel D. Procalcitonin in pediatric emergency situations: Comparison with C- reactive protein, interleukin-6, and alpha-interferon for differentiating bacterial and viral infections. Procalcitonine aux urgences pediatriques: Comparaison avec la proteine c-reactive, l'interleukine-6 et l'interferon-alpha pour la differenciation des infections bacteriennes et virales. Presse Med. 2000;29(3):128-134. Rec#: 17040. Exclusion Codes: NDE, EXC. [pmid: 10686961].
Lorton F, Veinberg F, Ielsch D, Deschenes G, Bensman A, Ulinski T. Procalcitonin serum levels in children undergoing chronic haemodialysis. Pediatr Nephrol. 2007;22(3):430-5. Rec#: 8620. Exclusion Codes: NRO, EXC. [pmid: 17043886].
Lotric-Furlan S, Rojko T, Strle F. Concentration of procalcitonin and C-reactive protein in patients with human granulocytic anaplasmosis and the initial phase of tick-borne encephalitis. Ann N Y Acad Sci. 2005;1063:439-41. Rec#: 8930. Exclusion Codes: SMN, EXC. [pmid: 16481557].
Lukaszewski M, Durek G, Mierzchala M. Severe sepsis or clinical view of autoaggressive disease. Wegener's granulomatosis - Case report. Ciezka sepsa czy obraz kliniczny choroby z autoagresji. Ziarniniak wegenera - Opis przypadku. Pol. Merkuriusz Lek. 2006;21(124):351-353. Rec#: 13640. Exclusion Codes: NDE, EXC.
Luyt CE, Combes A, Reynaud C, Hekimian G, Nieszkowska A, Tonnellier M, Aubry A, Trouillet JL, Bernard M, Chastre J. Usefulness of procalcitonin for the diagnosis of ventilator-associated pneumonia. Intensive Care Med. 2008;34(8):1434-40. Rec#: 1890. Exclusion Codes: NDE, EXC. [pmid: 18421435].
Luyt CE, Guerin V, Combes A, Trouillet JL, Ayed SB, Bernard M, Gibert C, Chastre J. Procalcitonin kinetics as a prognostic marker of ventilator-associated pneumonia. Am J Respir Crit Care Med. 2005;171(1):48-53. Rec#: 4120. Exclusion Codes: SMN, EXC. [pmid: 15447947].
Luzzani A, Polati E, Dorizzi R, Rungatscher A, Pavan R, Merlini A. Comparison of procalcitonin and C-reactive protein as markers of sepsis. Crit Care Med. 2003;31(6):1737-41. Rec#: 4780. Exclusion Codes: SMN, EXC. [pmid: 12794413].
Macrina F, Tritapepe L, Pompei F, Sciangula A, Evangelista E, Toscano F, Criniti A, Brancaccio G, Puddu PE. Procalcitonin is useful whereas C-reactive protein is not, to predict complications following coronary artery bypass surgery. Perfusion. 2005;20(3):169-75. Rec#: 3730. Exclusion Codes: SMN, EXC. [pmid: 16038389].
Madhi SA, Kohler M, Kuwanda L, Cutland C, Klugman KP. Usefulness of C-reactive protein to define pneumococcal conjugate vaccine efficacy in the prevention of pneumonia. Pediatr Infect Dis J. 2006;25(1):30-6. Rec#: 8970. Exclusion Codes: NDE, EXC. [pmid: 16395099].
Magadle R, Mohammedi I, Martin O, Argaud L, Robert D. Fever in a medical intensive care unit. Clin. Intensive Care. 2003;14(1-2):31-35. Rec#: 14490. Exclusion Codes: NRO, EXC.
Maire F, Heraud MC, Loriette Y, Normand B, Begue RJ, Labbe A. Value of procalcitonin measurement in neonatal infections. Interet de la procalcitonine dans les infections neonatales. Arch. Pediatr. 1999;6(5):503-509. Rec#: 15100. Exclusion Codes: NRD, EXC. [pmid: 10370804].
Makhoul IR, Yacoub A, Smolkin T, Sujov P, Kassis I, Sprecher H. Values of C-reactive protein, procalcitonin, and Staphylococcus-specific PCR in neonatal late-onset sepsis. Acta Paediatr. 2006;95(10):1218-23. Rec#: 3130. Exclusion Codes: NDE, EXC. [pmid: 16982493].
Malaska J, Kratochvil M, Kyr M, Jabandziev P, Otevrel F, Muriova K, Fedora M, Sramek V, Michalek J, Sevcik P. Cytokine response in severe sepsis - Predicting and modelling the course of illness. Int. J. Infect. Dis. 2010;14:e367. Rec#: 11720. Exclusion Codes: NRO, EXC. [pmid: 20561807].
Malickova K, Brodska H, Lachmanova J, Dusilova Sulkova S, Janatkova I, Mareckova H, Tesar V, Zima T. Plasma calprotectin in chronically dialyzed end-stage renal disease patients. Inflamm Res. 2010;59(4):299-305. Rec#: 7130. Exclusion Codes: SMN, EXC. [pmid: 19856199].
Mandi Y, Farkas G, Takacs T, Boda K, Lonovics J. Diagnostic relevance of procalcitonin, IL-6, and sICAM-1 in the prediction of infected necrosis in acute pancreatitis. Int J Pancreatol. 2000;28(1):41-9. Rec#: 5890. Exclusion Codes: SMN, EXC. [pmid: 11185709].
Manegold C, Schmiedel S, Chiwakata CB, Dietrich M. Procalcitonin serum levels in tertian malaria. Malaria J. 2003;2:1-3. Rec#: 16790. Exclusion Codes: NDE, EXC.
Manegold C, Schmiedel S, Chiwakata CB, Dietrich M. Procalcitonin serum levels in tertian malaria. Malar J. 2003;2:34. Rec#: 9790. Exclusion Codes: NRO, EXC. [pmid: 14613513].
Manekeller S, Lauschke H, Hirner A, Putensen C, Hoeft A, Stuber F, Schroeder S. Severe falciparum malaria infection associated with sepsis and peritonitis - Case report of an intensive care patient. Schwere sepsis bei peritonitis im rahmen einer malaria-tropica-infektion: Ein fallbericht aus der operativen intensivmedizin. Anasthesiol. Intensivmed. 2002;43(12):765-769. Rec#: 14530. Exclusion Codes: NRD, EXC.
Maniaci V, Dauber A, Weiss S, Nylen E, Becker KL, Bachur R. Procalcitonin in young febrile infants for the detection of serious bacterial infections. Pediatrics. 2008;122(4):701-10. Rec#: 7780. Exclusion Codes: NDE, EXC. [pmid: 18829791].
Mantadakis E, Plessa E, Vouloumanou EK, Karageorgopoulos DE, Chatzimichael A, Falagas ME. Serum procalcitonin for prediction of renal parenchymal involvement in children with urinary tract infections: a meta-analysis of prospective clinical studies. J Pediatr. 2009;155(6):875-881.e1. Rec#: 7140. Exclusion Codes: NDE, EXC. [pmid: 19850301].
Marik PE. Monitoring therapeutic interventions in critically III septic patients. Nutr. Clin. Prac. 2004;19(5):423-432. Rec#: 14190. Exclusion Codes: NDE, EXC.
Mariscalco MM. Is plasma procalcitonin ready for prime time in the pediatric intensive care unit?. Pediatr Crit Care Med. 2003;4(1):118-9. Rec#: 4880. Exclusion Codes: NDE, EXC. [pmid: 12656558].
Marshall JC. Measurements in the intensive care unit: what do they mean?. Crit Care. 2003;7(6):415-6. Rec#: 4570. Exclusion Codes: SMN, EXC. [pmid: 14624678].
Martin-Denavit T, Monneret G, Labaune JM, Isaac C, Bienvenu F, Putet G, Bienvenu J. Usefulness of procalcitonin in neonates at risk for infection. Clin Chem. 1999;45(3):440-1. Rec#: 10700. Exclusion Codes: NRO, EXC. [pmid: 10053059].
Martinez FJ, Curtis JL. Procalcitonin-guided antibiotic therapy in COPD exacerbations: closer but not quite there. Chest. 2007;131(1):1-2. Rec#: 3000. Exclusion Codes: NDE, EXC. [pmid: 17218546].
Martinez R, Gaul C, Buchfelder M, Erbguth F, Tschaikowsky K. Serum procalcitonin monitoring for differential diagnosis of ventriculitis in adult intensive care patients. Intensive Care Med. 2002;28(2):208-10. Rec#: 5450. Exclusion Codes: SMN, EXC. [pmid: 11907666].
Martinez-Albarran M, Perez-Molina Jde J, Gallegos-Castorena S, Sanchez-Zubieta F, Del Toro-Arreola S, Troyo-Sanroman R, Gonzalez-Ramella O. Procalcitonin and C-reactive protein serum levels as markers of infection in a pediatric population with febrile neutropenia and cancer. Pediatr Hematol Oncol. 2009;26(6):414-25. Rec#: 670. Exclusion Codes: NDE, EXC. [pmid: 19657991].
Martini A, Gottin L, Menestrina N, Schweiger V, Simion D, Vincent JL. Procalcitonin levels in surgical patients at risk of candidemia. J. Infect. 2010;60(6):425-430. Rec#: 11350. Exclusion Codes: SMN, EXC. [pmid: 20226210].
Martinot M, Sordet C, Soubrier M, Puechal X, Saraux A, Liote F, Guggenbuhl P, Legre V, Jaulhac B, Maillefert JF, Zeisel M, Coumaros G, Sibilia J. Diagnostic value of serum and synovial procalcitonin in acute arthritis: a prospective study of 42 patients. Clin Exp Rheumatol. 2005;23(3):303-10. Rec#: 3790. Exclusion Codes: SMN, EXC. [pmid: 15971417].
Maruna P, Frasko R, Gurlich R. Plasma procalcitonin in patients with ileus. Relations to other inflammatory parameters. Physiol Res. 2008;57(3):481-6. Rec#: 2690. Exclusion Codes: SMN, EXC. [pmid: 17552872].
Masia M, Gutierrez F, Padilla S, Soldan B, Mirete C, Shum C, Hernandez I, Royo G, Martin-Hidalgo A. Clinical characterisation of pneumonia caused by atypical pathogens combining classic and novel predictors. Clin Microbiol Infect. 2007;13(2):153-61. Rec#: 8530. Exclusion Codes: NDE, EXC. [pmid: 17328727].
Masia M, Gutierrez F, Shum C, Padilla S, Navarro JC, Flores E, Hernandez I. Usefulness of procalcitonin levels in community-acquired pneumonia according to the patients outcome research team pneumonia severity index. Chest. 2005;128(4):2223-9. Rec#: 9010. Exclusion Codes: NDE, EXC. [pmid: 16236878].
Masia M, Papassotiriou J, Morgenthaler NG, Hernandez I, Shum C, Gutierrez F. Midregional pro-A-type natriuretic peptide and carboxy-terminal provasopressin may predict prognosis in community-acquired pneumonia. Clin Chem. 2007;53(12):2193-201. Rec#: 2320. Exclusion Codes: NDE, EXC. [pmid: 17951293].
Massaro KS, Costa SF, Leone C, Chamone DA. Procalcitonin (PCT) and C-reactive protein (CRP) as severe systemic infection markers in febrile neutropenic adults. BMC Infect Dis. 2007;7:137. Rec#: 2270. Exclusion Codes: SMN, EXC. [pmid: 18034890].
Matesanz JL, Fernandez E, Fernandez JM, Viejo G. Plasma procalcitonin and C-reactive protein concentrations in pediatric patients with Epstein-Barr virus infection. Clin Chem. 2003;49(12):2103-4. Rec#: 9750. Exclusion Codes: NDE, EXC. [pmid: 14633891].
Matull WR, Pereira SP, O'Donohue JW. Biochemical markers of acute pancreatitis. J Clin Pathol. 2006;59(4):340-4. Rec#: 8860. Exclusion Codes: NDE, EXC. [pmid: 16567468].
Mayaud C, Fartoukh M, Prigent H, Parrot A, Cadranel J. Critical evaluation and predictive value of clinical presentation in out-patients with acute community-acquired pneumonia. 07 - Analyse critique et valeurs predictives des signes de pneumonies aigues communautaires en medecine ambulatoire. Med. Mal. Infect. 2006;36(11-12):625-635. Rec#: 16400. Exclusion Codes: NDE, EXC. [pmid: 17084571].
McLean A. Procalcitonin: seeking a niche. Crit Care. 2009;13(3):149. Rec#: 810. Exclusion Codes: NDE, EXC. [pmid: 19519928].
McMaster P, Park DY, Shann F, Cochrane A, Morris K, Gray J, Cottrell S, Belcher J. Procalcitonin versus C-reactive protein and immature-to-total neutrophil ratio as markers of infection after cardiopulmonary bypass in children. Pediatr Crit Care Med. 2009;10(2):217-21. Rec#: 1190. Exclusion Codes: NDE, EXC. [pmid: 19057447].
Meisner M. Procalcitonin: Experience with a new diagnostic tool for bacterial infection and systemic inflammation. Procalcitonin: Erfahrungen mit einer neuen Messgrosse fur bakterielle Infektionen und systemische Inflammation. LaboratoriumsMedizin. 1999;23(5):263-272. Rec#: 15070. Exclusion Codes: NDE, EXC.
Meisner M. Pathobiochemistry and clinical use of procalcitonin. Clin Chim Acta. 2002;323(1-2):17-29. Rec#: 5230. Exclusion Codes: NDE, EXC. [pmid: 12135804].
Meisner M. Biomarkers of sepsis: clinically useful?. Curr Opin Crit Care. 2005;11(5):473-80. Rec#: 3660. Exclusion Codes: NDE, EXC. [pmid: 16175035].
Meisner M. Evidence-based diagnosis and treatment monitoring of septic patients. Evidenzbasierte diagnostik und therapiekontrolle septischer patienten. J. Anasth. Intensivbehandl. 2005;12(2):213-214. Rec#: 13970. Exclusion Codes: NDE, EXC.
Meisner M. Diagnosis and treatment of shock types. Recommendations of the interdisciplinary working group shock of the DIVI - Part V: Septic shock [3]. Zur diagnostik und therapie der schockformen. Empfehlungen der interdisziplinaren arbeitsgruppe schock der DIVI - Teil V: Septischer schock. Anasthesiol. Intensivmed. 2006;47(3):173-175. Rec#: 13910. Exclusion Codes: NRD, EXC.
Meisner M, Adina H, Schmidt J. Correlation of procalcitonin and C-reactive protein to inflammation, complications, and outcome during the intensive care unit course of multiple-trauma patients. Crit Care. 2006;10(1):R1. Rec#: 3540. Exclusion Codes: SMN, EXC. [pmid: 16356205].
Meisner M, Huttemann E, Lohs T, Kasakov L, Reinhart K. Elimination of procalcitonin and plasma concentrations during continuous veno-venous haemodiafiltration in septic patients. Eur J Anaesthesiol. 2000;17(11):665-71. Rec#: 5990. Exclusion Codes: NRO, EXC. [pmid: 11029564].
Meisner M, Lohs T, Huettemann E, Schmidt J, Hueller M, Reinhart K. The plasma elimination rate and urinary secretion of procalcitonin in patients with normal and impaired renal function. Eur J Anaesthesiol. 2001;18(2):79-87. Rec#: 5850. Exclusion Codes: NRO, EXC. [pmid: 11270029].
Meisner M, Rauschmayer C, Schmidt J, Feyrer R, Cesnjevar R, Bredle D, Tschaikowsky K. Early increase of procalcitonin after cardiovascular surgery in patients with postoperative complications. Intensive Care Med. 2002;28(8):1094-102. Rec#: 5210. Exclusion Codes: NDE, EXC. [pmid: 12185431].
Meisner M, Reinhart K. Is procalcitonin really a marker of sepsis?. Int. J. Intensive Care. 2001;8(1):15-25. Rec#: 14770. Exclusion Codes: NDE, EXC.
Meisner M, Tschaikowsky K, Hutzler A, Schick C, Schuttler J. Postoperative plasma concentrations of procalcitonin after different types of surgery. Intensive Care Med. 1998;24(7):680-4. Rec#: 6690. Exclusion Codes: NDE, EXC. [pmid: 9722037].
Meisner M, Tschaikowsky K, Palmaers T, Schmidt J. Comparison of procalcitonin (PCT) and C-reactive protein (CRP) plasma concentrations at different SOFA scores during the course of sepsis and MODS. Crit. Care. 1999;3(1):45-50. Rec#: 15050. Exclusion Codes: SMN, EXC. [pmid: 11056723].
Mejjad O, Vittecoq O, Tamion F, Girault C, Lecot S, Cailleux N, Le Loet X. A shock associated with adult-onset Still's disease. Joint Bone Spine. 2001;68(1):76-8. Rec#: 5870. Exclusion Codes: NDE, EXC. [pmid: 11235787].
Mendes AV, Sapolnik R, Mendonca N. New guidelines for the clinical management of febrile neutropenia and sepsis in pediatric oncology patients. J Pediatr (Rio J). 2007;83(2 Suppl):S54-63. Rec#: 2720. Exclusion Codes: NDE, EXC. [pmid: 17530138].
Mendonca Coelho MC, Tannuri U, Aoun Tannuri AC, Reingenheim C, Troster EJ. Is procalcitonin useful to differentiate rejection from bacterial infection in the early post-operative period of liver transplantation in children?. Pediatr. Transplant. 2009;13(8):1004-1006. Rec#: 11980. Exclusion Codes: NDE, EXC. [pmid: 19032409].
Menendez R, Cavalcanti M, Reyes S, Mensa J, Martinez R, Marcos MA, Filella X, Niederman M, Torres A. Markers of treatment failure in hospitalised community acquired pneumonia. Thorax. 2008;63(5):447-52. Rec#: 8090. Exclusion Codes: NDE, EXC. [pmid: 18245147].
Menendez R, Martinez R, Reyes S, Mensa J, Filella X, Marcos MA, Martinez A, Esquinas C, Ramirez P, Torres A. Biomarkers improve mortality prediction by prognostic scales in community-acquired pneumonia. Thorax. 2009;64(7):587-91. Rec#: 7600. Exclusion Codes: NDE, EXC. [pmid: 19131448].
Menendez R, Martinez R, Reyes S, Mensa J, Polverino E, Filella X, Esquinas C, Martinez A, Ramirez P, Torres A. Stability in community-acquired pneumonia: one step forward with markers?. Thorax. 2009;64(11):987-92. Rec#: 470. Exclusion Codes: NDE, EXC. [pmid: 19762338].
Meng FS, Su L, Tang YQ, Wen Q, Liu YS, Liu ZF. Serum procalcitonin at the time of admission to the ICU as a predictor of short-term mortality. Clin Biochem. 2009;42(10-11):1025-31. Rec#: 980. Exclusion Codes: SMN, EXC. [pmid: 19324026].
Messer J, Kuhn P. Biological markers of maternofetal infection. Marqueurs biologiques de l'infection materno-foetale. Med. Ther. Pediatr. 1999;2(1):41-45. Rec#: 17090. Exclusion Codes: NRD, EXC.
Micek M, Feindt P, Petzold T, Boeken U, Zimmermann N, Gams E. A clinically reliable and fast differentiation between infection and rejection in heart transplantation: Results of procalcitonin (PCT) measurement. Z. Kardiovask. Med. 2000;4(4):143-148. Rec#: 14790. Exclusion Codes: NDE, EXC.
Michalik DE, Duncan BW, Mee RB, Worley S, Goldfarb J, Danziger-Isakov LA, Davis SJ, Harrison AM, Appachi E, Sabella C. Quantitative analysis of procalcitonin after pediatric cardiothoracic surgery. Cardiol Young. 2006;16(1):48-53. Rec#: 3460. Exclusion Codes: NRO, EXC. [pmid: 16454877].
Michelow IC, Katz K, McCracken GH, Hardy RD. Systemic cytokine profile in children with community-acquired pneumonia. Pediatr Pulmonol. 2007;42(7):640-5. Rec#: 8440. Exclusion Codes: NRO, EXC. [pmid: 17534977].
Mierzchala M, Lipinska-Gediga M, Durek G. The role of LBP in transduction of signal induced by LPS and in modulation of immune system response. Rola LBP w transdukcji sygnalu indukowanego LPS i w modulacji odpowiedzi ukladu immunologicznego. Adv. Clin. Exp. Med. 2006;15(1):127-134. Rec#: 13880. Exclusion Codes: NRD, EXC.
Mikic D, Vasilijic S, Maravic V, Colic M. Relationship between plasma levels of procalcitonin, tumor necrosis factor-(alpha) and C-reactive protein and clinical characteristic of septic patients. Clin. Appl. Immunol. 2006;5(1):556-562. Rec#: 13700. Exclusion Codes: SMN, EXC.
Mills GD, Lala HM, Oehley MR, Craig AB, Barratt K, Hood D, Thornley CN, Nesdale A, Manikkam NE, Reeve P. Elevated procalcitonin as a diagnostic marker in meningococcal disease. Eur J Clin Microbiol Infect Dis. 2006;25(8):501-9. Rec#: 3200. Exclusion Codes: NDE, EXC. [pmid: 16896823].
Mimoz O, Benoist JF, Edouard AR, Assicot M, Bohuon C, Samii K. Procalcitonin and C-reactive protein during the early posttraumatic systemic inflammatory response syndrome. Intensive Care Med. 1998;24(2):185-8. Rec#: 6780. Exclusion Codes: NDE, EXC. [pmid: 9539079].
Mira JP, Max A, Burgel PR. The role of biomarkers in community-acquired pneumonia: predicting mortality and response to adjunctive therapy. Crit Care. Suppl 6. 2008;12:S5. Rec#: 1120. Exclusion Codes: NDE, EXC. [pmid: 19105798].
Mitaka C. Clinical laboratory differentiation of infectious versus non-infectious systemic inflammatory response syndrome. Clin Chim Acta. 2005;351(1-2):17-29. Rec#: 4050. Exclusion Codes: NDE, EXC. [pmid: 15563869].
Mittelkotter U. Procalcitonin in the early treatment to prevent postoperative septic complications. Procalcitonin-gesteuerte fruhtherapie zur pravention postoperativer septischer komplikationen. J. Anasth. Intensivbehandl. 2003;10(1):186-187. Rec#: 14350. Exclusion Codes: NDE, EXC.
Modrau IS, Floyd AK, Thorlacius-Ussing O. The clinical value of procalcitonin in early assessment of acute pancreatitis. Am J Gastroenterol. 2005;100(7):1593-7. Rec#: 9200. Exclusion Codes: SMN, EXC. [pmid: 15984987].
Mofidi R, Suttie SA, Patil PV, Ogston S, Parks RW. The value of procalcitonin at predicting the severity of acute pancreatitis and development of infected pancreatic necrosis: systematic review. Surgery. 2009;146(1):72-81. Rec#: 7350. Exclusion Codes: NDE, EXC. [pmid: 19541012].
Mokart D, Leone M. Procalcitonin in intensive care units: the PRORATA trial. Lancet. 2010;375(9726):1605. author reply 1606-7. Rec#: 50. Exclusion Codes: NPD, EXC. [pmid: 20452515].
Mokart D, Merlin M, Sannini A, Brun JP, Delpero JR, Houvenaeghel G, Moutardier V, Blache JL. Procalcitonin, interleukin 6 and systemic inflammatory response syndrome (SIRS): early markers of postoperative sepsis after major surgery. Br J Anaesth. 2005;94(6):767-73. Rec#: 3830. Exclusion Codes: SMN, EXC. [pmid: 15849208].
Molnar Z, Szakmany T, Heigl P. Microalbuminuria does not reflect increased systemic capillary permeability in septic shock. Intensive Care Med. 2003;29(3):391-5. Rec#: 5000. Exclusion Codes: NRO, EXC. [pmid: 12560870].
Mongardon N, Lemiale V, Perbet S, Dumas F, Legriel S, Guerin S, Charpentier J, Chiche JD, Mira JP, Cariou A. Value of procalcitonin for diagnosis of early onset pneumonia in hypothermia-treated cardiac arrest patients. Intensive Care Med. 2010;36(1):92-9. Rec#: 390. Exclusion Codes: NDE, EXC. [pmid: 19844695].
Monneret G. Dear PCT, you are not a specific marker of bacterial infection. Intensive Care Med. 2002;28(3):377-8. Rec#: 10180. Exclusion Codes: NRD, EXC. [pmid: 11904672].
Monneret G, Doche C, Durand DV, Lepape A, Bienvenu J. Procalcitonin as a specific marker of bacterial infection in adults. Clin Chem Lab Med. 1998;36(1):67-8. Rec#: 10830. Exclusion Codes: NRD, EXC. [pmid: 9594089].
Monneret G, Labaune JM, Isaac C, Bienvenu F, Putet G, Bienvenu J. Procalcitonin and C-reactive protein levels in neonatal infections. Acta Paediatr. 1997;86(2):209-12. Rec#: 6880. Exclusion Codes: NRO, EXC. [pmid: 9055895].
Monneret G, Labaune JM, Isaac C, Bienvenu F, Putet G, Bienvenu J. Increased serum procalcitonin levels are not specific to sepsis in neonates. Clin Infect Dis. 1998;27(6):1559-61. Rec#: 6620. Exclusion Codes: NDE, EXC. [pmid: 9868696].
Montagnana M, Minicozzi AM, Salvagno GL, Danese E, Cordiano C, De Manzoni G, Guidi GC, Lippi G. Postoperative variation of C-reactive protein and procalcitonin in patients with gastrointestinal cancer. Clin Lab. 2009;55(5-6):187-92. Rec#: 550. Exclusion Codes: NRO, EXC. [pmid: 19728551].
Moosig F, Csernok E, Reinhold-Keller E, Schmitt W, Gross WL. Elevated procalcitonin levels in active Wegener's granulomatosis. J Rheumatol. 1998;25(8):1531-3. Rec#: 10760. Exclusion Codes: NRO, EXC. [pmid: 9712096].
Morath C, Sis J, Haensch GM, Zeier M, Andrassy K, Schwenger V. Procalcitonin as marker of infection in patients with Goodpasture's syndrome is misleading. Nephrol Dial Transplant. 2007;22(9):2701-4. Rec#: 8420. Exclusion Codes: NRO, EXC. [pmid: 17556410].
Moreira VG, Prieto B, Rodriguez JS, Alvarez FV. Usefulness of cell-free plasma DNA, procalcitonin and C-reactive protein as markers of infection in febrile patients. Ann Clin Biochem. 2010;47(Pt 3):253-8. Rec#: 90. Exclusion Codes: NDE, EXC. [pmid: 20421309].
Morgenthaler NG, Struck J, Fischer-Schulz C, Bergmann A. Sensitive immunoluminometric assay for the detection of procalcitonin. Clin Chem. 2002;48(5):788-90. Rec#: 10170. Exclusion Codes: NRD, EXC. [pmid: 11978614].
Morgenthaler NG, Struck J, Fischer-Schulz C, Seidel-Mueller E, Beier W, Bergmann A. Detection of procalcitonin (PCT) in healthy controls and patients with local infection by a sensitive ILMA. Clin Lab. 2002;48(5-6):263-70. Rec#: 5290. Exclusion Codes: NDE, EXC. [pmid: 12071576].
Moulin F, Raymond J, Lorrot M, Marc E, Coste J, Iniguez JL, Kalifa G, Bohuon C, Gendrel D. Procalcitonin in children admitted to hospital with community acquired pneumonia. Arch Dis Child. 2001;84(4):332-6. Rec#: 10390. Exclusion Codes: SMN, EXC. [pmid: 11259234].
Mueller C, Christ-Crain M, Muller B. What cardiologists do need to know about procalcitonin. Clin Lab. 2005;51(1-2):1-4. Rec#: 9340. Exclusion Codes: NDE, EXC. [pmid: 15719698].
Mueller C, Huber P, Laifer G, Mueller B, Perruchoud AP. Procalcitonin and the early diagnosis of infective endocarditis. Circulation. 2004;109(14):1707-10. Rec#: 9660. Exclusion Codes: SMN, EXC. [pmid: 15066945].
Muller B. Endocrine aspects of critical illness. Ann Endocrinol (Paris). 2007;68(4):290-8. Rec#: 2560. Exclusion Codes: NRD, EXC. [pmid: 17662955].
Muller B, Becker KL, Schachinger H, Rickenbacher PR, Huber PR, Zimmerli W, Ritz R. Calcitonin precursors are reliable markers of sepsis in a medical intensive care unit. Crit Care Med. 2000;28(4):977-83. Rec#: 6170. Exclusion Codes: NDE, EXC. [pmid: 10809269].
Muller B, Christ-Crain M, Nylen ES, Snider R, Becker KL. Limits to the use of the procalcitonin level as a diagnostic marker. Clin Infect Dis. 2004;39(12):1867-8. Rec#: 9420. Exclusion Codes: NDE, EXC. [pmid: 15578415].
Muller B, Christ-Crain M, Schuetz P. Meta-analysis of procalcitonin for sepsis detection. Lancet Infect Dis. 2007;7(8):498-9. author reply 502-3. Rec#: 2600. Exclusion Codes: NRD, EXC. [pmid: 17646019].
Muller B, Harbarth S, Stolz D, Bingisser R, Mueller C, Leuppi J, Nusbaumer C, Tamm M, Christ-Crain M. Diagnostic and prognostic accuracy of clinical and laboratory parameters in community-acquired pneumonia. BMC Infect Dis. 2007;7:10. Rec#: 8520. Exclusion Codes: NDE, EXC. [pmid: 17335562].
Muller B, Prat C. Markers of acute inflammation in assessing and managing lower respiratory tract infections: Focus on procalcitonin. Clin. Microbiol. Infect. 2006;12(SUPPL. 9):8-16. Rec#: 13590. Exclusion Codes: NDE, EXC. [pmid: 16827814].
Muller B, Schuetz P, Trampuz A. Circulating biomarkers as surrogates for bloodstream infections. Int J Antimicrob Agents. Suppl 1. 2007;30:S16-23. Rec#: 2390. Exclusion Codes: NRD, EXC. [pmid: 17884358].
Muller B, Suess E, Schuetz P, Muller C, Bingisser R, Bergmann A, Stolz D, Tamm M, Morgenthaler NG, Christ-Crain M. Circulating levels of pro-atrial natriuretic peptide in lower respiratory tract infections. J Intern Med. 2006;260(6):568-76. Rec#: 3070. Exclusion Codes: NDE, EXC. [pmid: 17116008].
Muller CA, Uhl W, Printzen G, Gloor B, Bischofberger H, Tcholakov O, Buchler MW. Role of procalcitonin and granulocyte colony stimulating factor in the early prediction of infected necrosis in severe acute pancreatitis. Gut. 2000;46(2):233-8. Rec#: 10630. Exclusion Codes: SMN, EXC. [pmid: 10644318].
Muller F, Christ-Crain M, Bregenzer T, Krause M, Zimmerli W, Mueller B, Schuetz P. Procalcitonin levels predict bacteremia in patients with community-acquired pneumonia: A prospective cohort trial. Chest. 2010;138(1):121-129. Rec#: 11310. Exclusion Codes: NDE, EXC. [pmid: 20299634].
Muller-Werdan U, Werdan K, Schuster HP. Monitoring of critically ill patients with sepsis, multiple organ dysfunction syndrome and cardiovascular disease. Monitoring von kritisch kranken mit sepsis, multiorgandysfunktionssyndrom und herz-kreislauf-erkrankungen. Intensiv- Notfallbehandl. 1999;24(1):10-24. Rec#: 15090. Exclusion Codes: NDE, EXC.
Munoz P, Simarro N, Rivera M, Alonso R, Alcala L, Bouza E. Evaluation of procalcitonin as a marker of infection in a nonselected sample of febrile hospitalized patients. Diagn Microbiol Infect Dis. 2004;49(4):237-41. Rec#: 4160. Exclusion Codes: NDE, EXC. [pmid: 15313527].
Mussap M, Degrandi R, Cataldi L, Fanos V, Plebani M. Biochemical markers for the early assessment of neonatal sepsis: the role of procalcitonin. J Chemother. Suppl 2. 2007;19:35-8. Rec#: 1920. Exclusion Codes: NRD, EXC. [pmid: 18073178].
Muthiah KA, Rachakonda KS, Davis MJ, Simmons EG, Schier G, Gil FS. Prospective evaluation of procalcitonin in sepsis in the Illawarra area of Australia: PEPSIA study. Crit Care Resusc. 2007;9(2):137-42. Rec#: 2700. Exclusion Codes: NDE, EXC. [pmid: 17536980].
Naderi M, Hashemi M, Kouhpayeh H, Ahmadi R. The status of serum procalcitonin in pulmonary tuberculosis and nontuberculosis pulmonary disease. J Pak Med Assoc. 2009;59(9):647-8. Rec#: 7190. Exclusion Codes: NDE, EXC. [pmid: 19750868].
Naeini AE, Montazerolghaem S. Procalcitonin marker for sepsis diagnosis. Evaluating a rapid immuno-chromatografic test. Saudi Med J. 2006;27(3):422-4. Rec#: 3420. Exclusion Codes: NRD, EXC. [pmid: 16532118].
Nakamura A, Wada H, Ikejiri M, Hatada T, Sakurai H, Matsushima Y, Nishioka J, Maruyama K, Isaji S, Takeda T, Nobori T. Efficacy of procalcitonin in the early diagnosis of bacterial infections in a critical care unit. Shock. 2009;31(6):586-91. Rec#: 1180. Exclusion Codes: NDE, EXC. [pmid: 19060784].
Nathan BR, Scheld WM. The potential roles of C-reactive protein and procalcitonin concentrations in the serum and cerebrospinal fluid in the diagnosis of bacterial meningitis. Curr Clin Top Infect Dis. 2002;22:155-65. Rec#: 10040. Exclusion Codes: NDE, EXC. [pmid: 12520652].
Neely AN, Fowler LA, Kagan RJ, Warden GD. Procalcitonin in pediatric burn patients: an early indicator of sepsis?. J Burn Care Rehabil. 2004;25(1):76-80. Rec#: 4490. Exclusion Codes: SMN, EXC. [pmid: 14726743].
Nicolau-Raducu RE, Eleborg L, Kristiansson M, Hansson LO. Systemic concentrations of procalcitonin, amyloid-A, C-reactive protein and cytokines during and after liver transplantation. Rom. J. Gastroenterol. 2001;10(4):305-310. Rec#: 14700. Exclusion Codes: NDE, EXC.
Niederman MS. Biological markers to determine eligibility in trials for community-acquired pneumonia: a focus on procalcitonin. Clin Infect Dis. Suppl 3. 2008;47:S127-32. Rec#: 7680. Exclusion Codes: NDE, EXC. [pmid: 18986278].
Nikfar R, Khotaee G, Ataee N, Shams S. Usefulness of procalcitonin rapid test for the diagnosis of acute pyelonephritis in children in the emergency department. Pediatr. Int. 2010;52(2):196-198. Rec#: 15460. Exclusion Codes: NDE, EXC. [pmid: 20500474].
Nonnenmacher L. Informations about reagents: Brain natriuretic peptide (BNP), procalcitonin (PCT) and protein S-100 (beta). Informations reactifs: Brain Natriuretic Peptide (BNP), procalcitonine (PCT) et proteine S-100 (beta). Immuno-Anal. Biol. Spec. 2003;18(6):365-368. Rec#: 16770. Exclusion Codes: NDE, EXC.
Novotny A, Emmanuel K, Matevossian E, Kriner M, Ulm K, Bartels H, Holzmann B, Weighardt H, Siewert JR. Use of procalcitonin for early prediction of lethal outcome of postoperative sepsis. Am J Surg. 2007;194(1):35-9. Rec#: 2670. Exclusion Codes: NDE, EXC. [pmid: 17560906].
Novotny AR, Emmanuel K, Hueser N, Knebel C, Kriner M, Ulm K, Bartels H, Siewert JR, Holzmann B. Procalcitonin ratio indicates successful surgical treatment of abdominal sepsis. Surgery. 2009;145(1):20-6. Rec#: 1150. Exclusion Codes: NDE, EXC. [pmid: 19081471].
Novotny AR, Luppa P, Rosenberg R, Schneider H, Maak M, Bartels H, Holzmann B, Friess H. Procalcitonin can be used for monitoring sepsis in patients with medullary thyroid carcinoma. Thyroid. 2009;19(11):1287-9. Rec#: 440. Exclusion Codes: NDE, EXC. [pmid: 19785521].
Nseir S, Cavestri B, Di Pompeo C, Diarra M, Brisson H, Lemyze M, Roussel-Delvallez M, Durocher A. Factors predicting bacterial involvement in severe acute exacerbations of chronic obstructive pulmonary disease. Respiration. 2008;76(3):253-60. Rec#: 1560. Exclusion Codes: SMN, EXC. [pmid: 18547944].
Nunez AA. To convert the low risk in zero risk in patients with febrile neutropenia. Neutropenia febril: Convertir el bajo riesgo en cero riesgo. Rev. Cuba. Hematol. Imunol. Hemoterapia. 2009;25(2):29-33. Rec#: 12300. Exclusion Codes: NRD, EXC.
Nyamande K, Lalloo UG. Serum procalcitonin distinguishes CAP due to bacteria, Mycobacterium tuberculosis and PJP. Int J Tuberc Lung Dis. 2006;10(5):510-5. Rec#: 3340. Exclusion Codes: NDE, EXC. [pmid: 16704032].
Nylen E, Muller B, Becker KL, Snider R. The future diagnostic role of procalcitonin levels: the need for improved sensitivity. Clin Infect Dis. 2003;36(6):823-4. author reply 826-7. Rec#: 4950. Exclusion Codes: NDE, EXC. [pmid: 12627371].
Nylen ES, Snider RH Jr, Thompson KA, Rohatgi P, Becker KL. Pneumonitis-associated hyperprocalcitoninemia. Am J Med Sci. 1996;312(1):12-8. Rec#: 6900. Exclusion Codes: NRO, EXC. [pmid: 8686724].
Oberhoffer M, Karzai W, Meier-Hellmann A, Bogel D, Fassbinder J, Reinhart K. Sensitivity and specificity of various markers of inflammation for the prediction of tumor necrosis factor-alpha and interleukin-6 in patients with sepsis. Crit Care Med. 1999;27(9):1814-8. Rec#: 6400. Exclusion Codes: NDE, EXC. [pmid: 10507603].
Oberhoffer M, Karzai W, Meier-Hellmann A, Reinhart K. Procalcitonin. A new diagnostic parameter for severe infection and sepsis. Procalcitonin. Ein neur diagnostischer parameter bei schweren infektionen und sepsis. Anaesthesist. 1998;47(7):581-587. Rec#: 15160. Exclusion Codes: NRD, EXC. [pmid: 9740932].
Oberhoffer M, Russwurm S, Bredle D, Chatzinicolaou K, Reinhart K. Discriminative power of inflammatory markers for prediction of tumor necrosis factor-alpha and interleukin-6 in ICU patients with systemic inflammatory response syndrome (SIRS) or sepsis at arbitrary time points. Intensive Care Med. Suppl 2. 2000;26:S170-4. Rec#: 1730. Exclusion Codes: NDE, EXC. [pmid: 18470714].
Oberhoffer M, Vogelsang H, Russwurm S, Hartung T, Reinhart K. Outcome prediction by traditional and new markers of inflammation in patients with sepsis. Clin Chem Lab Med. 1999;37(3):363-8. Rec#: 6480. Exclusion Codes: NDE, EXC. [pmid: 10353484].
Oberholzer A, Souza SM, Tschoeke SK, Oberholzer C, Abouhamze A, Pribble JP, Moldawer LL. Plasma cytokine measurements augment prognostic scores as indicators of outcome in patients with severe sepsis. Shock. 2005;23(6):488-93. Rec#: 3810. Exclusion Codes: NRO, EXC. [pmid: 15897799].
Obladen M. Infection parameters: What helps me further? Interleukins, TNF-alpha, CRP, PCT in the evaluation of neonates. Infektionsparameter: Was hilft mir weiter? Interleukine, TNF-(alpha), CRP, PCT in evaluation bei neonaten. J. Anasth. Intensivbehandl. 2002;9(2):114-115. Rec#: 16870. Exclusion Codes: NDE, EXC.
Oconnor E, Venkatesh B, Mashongonyika C, Lipman J, Hall J, Thomas P. Serum procalcitonin and C-reactive protein as markers of sepsis and outcome in patients with neurotrauma and subarachnoid haemorrhage. Anaesth Intensive Care. 2004;32(4):465-70. Rec#: 3980. Exclusion Codes: SMN, EXC. [pmid: 15675205].
Oczenski W, Fitzgerald RD, Schwarz S. Procalcitonin: a new parameter for the diagnosis of bacterial infection in the peri-operative period. Eur J Anaesthesiol. 1998;15(2):202-9. Rec#: 6770. Exclusion Codes: NDE, EXC. [pmid: 9587727].
Oezcueruemez-Porsch M, Kunz D, Hardt PD, Fadgyas T, Kress O, Schulz HU, Schnell-Kretschmer H, Temme H, Westphal S, Luley C, Kloer HU. Diagnostic relevance of interleukin pattern, acute-phase proteins, and procalcitonin in early phase of post-ERCP pancreatitis. Dig Dis Sci. 1998;43(8):1763-9. Rec#: 10740. Exclusion Codes: SMN, EXC. [pmid: 9724166].
Oh JS, Kim SU, Oh YM, Choe SM, Choe GH, Choe SP, Kim YM, Hong TY, Park KN. The usefulness of the semiquantitative procalcitonin test kit as a guideline for starting antibiotic administration. Am J Emerg Med. 2009;27(7):859-63. Rec#: 620. Exclusion Codes: SMN, EXC. [pmid: 19683118].
Okada Y, Minakami H, Tomomasa T, Kato M, Inoue Y, Kozawa K, Kimura H, Morikawa A. Serum procalcitonin concentration in patients with Kawasaki disease. J Infect. 2004;48(2):199-205. Rec#: 9720. Exclusion Codes: SMN, EXC. [pmid: 14720497].
Okimoto N, Hayashi Y, Ishiga M, Nanba F, Kishimoto M, Yagi S, Kurihara T, Asaoka N, Tamada S. Procalcitonin and severity of community-acquired pneumonia. J Infect Chemother. 2009;15(6):426-7. Rec#: 7080. Exclusion Codes: NRO, EXC. [pmid: 20012738].
Olaciregui I, Hernandez U, Munoz JA, Emparanza JI, Landa JJ. Markers that predict serious bacterial infection in infants under 3 months of age presenting with fever of unknown origin. Arch Dis Child. 2009;94(7):501-5. Rec#: 1060. Exclusion Codes: NDE, EXC. [pmid: 19158133].
Olah A, Belagyi T, Issekutz A, Makay R, Zaborszky A. Value of procalcitonin quick test in the differentiation between sterile and infected forms of acute pancreatitis. Hepatogastroenterology. 2005;52(61):243-5. Rec#: 3890. Exclusion Codes: SMN, EXC. [pmid: 15783040].
Oppert M, Reinicke A, Muller C, Barckow D, Frei U, Eckardt KU. Elevations in procalcitonin but not C-reactive protein are associated with pneumonia after cardiopulmonary resuscitation. Resuscitation. 2002;53(2):167-70. Rec#: 10150. Exclusion Codes: SMN, EXC. [pmid: 12009220].
Orlowska H, Roszkowska-Blaim M. Procalcitonin - A new inflammatory marker in children with urinary tract infection - A preliminary study. Prokalcytonina - Nowy marker stanu zapalnego u dzieci z zakazeniem ukladu moczowego - Doniesienie wstepne. Pediatr. Pol. 2004;79(2):111-114. Rec#: 16750. Exclusion Codes: NDE, EXC.
Ortega M, Rovira M, Filella X, Almela M, Puig de la Bellacasa J, Carreras E, Mensa J. Prospective evaluation of procalcitonin in adults with febrile neutropenia after haematopoietic stem cell transplantation. Br J Haematol. 2004;126(3):372-6. Rec#: 4230. Exclusion Codes: NDE, EXC. [pmid: 15257709].
Ortega M, Rovira M, Filella X, Martinez JA, Almela M, Puig J, Carreras E, Mensa J. Prospective evaluation of procalcitonin in adults with non-neutropenic fever after allogeneic hematopoietic stem cell transplantation. Bone Marrow Transplant. 2006;37(5):499-502. Rec#: 8950. Exclusion Codes: NDE, EXC. [pmid: 16415895].
Oshita H, Sakurai J, Kamitsuna M. Semi-quantitative Procalcitonin Test for the Diagnosis of Bacterial Infection: Clinical Use and Experience in Japan. J. Microbiol. Immunol. Infect. 2010;43(3):222-227. Rec#: 11420. Exclusion Codes: NDE, EXC. [pmid: 21291850].
Ozdemir O, Baytan B, Demirkaya M, Celebi S. The value of C-reactive protein and procalcitonin in febrile neutropenia. Febril notropenide C-reaktif protein ve prokalsitoninin yeri. Guncel Pediatr. 2009;7(1):7-12. Rec#: 11990. Exclusion Codes: NRD, EXC.
Ozturk R, Yilmaz GR, Bulut C, Parpucu H, Kinikli S, Duranay M, Demiroz AP. Assessment of procalcitonin and other inflammatory markers in peritoneal dialysis-related peritonitis. Peritoneal diyalizle iliskili peritonitte prokalsitonin ve diger inflamatuar parametrelerin degerlendirilmesi. Turk. J. Med. Sci. 2010;40(2):199-206. Rec#: 15290. Exclusion Codes: NDE, EXC.
Park HP, Lee JS, Jang YS, Kim MS. Usefulness of procalcitonin in the assessing the severity of community-acquired pneumonia patient. Tuberc. Respir. Dis. 2009;67(5):430-435. Rec#: 15760. Exclusion Codes: NRD, EXC.
Paugam-Burtz C, Mantz J, Dupont H, Dehoux M. Procalcitonin levels and sequential organ failure assessment scores in secondary peritonitis. Arch Surg. 2007;142(8):803. author reply 803-4. Rec#: 8300. Exclusion Codes: NDE, EXC. [pmid: 17709736].
Pavcnik-Arnol M, Hojker S, Derganc M. Lipopolysaccharide-binding protein in critically ill neonates and children with suspected infection: comparison with procalcitonin, interleukin-6, and C-reactive protein. Intensive Care Med. 2004;30(7):1454-60. Rec#: 4340. Exclusion Codes: NDE, EXC. [pmid: 15127192].
Pavcnik-Arnol M, Hojker S, Derganc M. Lipopolysaccharide-binding protein, lipopolysaccharide, and soluble CD14 in sepsis of critically ill neonates and children. Intensive Care Med. 2007;33(6):1025-32. Rec#: 2820. Exclusion Codes: NDE, EXC. [pmid: 17410342].
Pavic M, Bronic A, Kopcinovic LM. Procalcitonin in systemic and localized bacterial infection. Biochem Med. 2010;20(2):236-241. Rec#: 11380. Exclusion Codes: SMN, EXC.
Pecile P, Miorin E, Romanello C, Falleti E, Valent F, Giacomuzzi F, Tenore A. Procalcitonin: a marker of severity of acute pyelonephritis among children. Pediatrics. 2004;114(2):e249-54. Rec#: 9560. Exclusion Codes: NDE, EXC. [pmid: 15286264].
Pecile P, Romanello C. Procalcitonin and pyelonephritis in children. Curr Opin Infect Dis. 2007;20(1):83-7. Rec#: 8580. Exclusion Codes: NDE, EXC. [pmid: 17197887].
Pelinka LE, Petto H, Kroepfl A, Schmidhammer R, Redl H. Serum Procalcitonin and S100B Are Associated with Mortality after Traumatic Brain Injury. Eur. J. Trauma. 2003;29(5):316-323. Rec#: 14360. Exclusion Codes: SMN, EXC.
Pelinka LE, Sendova K, Mauritz W, Redl H. Quantitative versus semiquantitative procalcitonin measurement: Experience in a trauma intensive care unit. Eur. J. Trauma. 2003;29(2):81-84. Rec#: 14480. Exclusion Codes: SMN, EXC.
Pelosi P, Barassi A, Severgnini P, Gomiero B, Finazzi S, Merlini G, d'Eril GM, Chiaranda M, Niederman MS. Prognostic role of clinical and laboratory criteria to identify early ventilator-associated pneumonia in brain injury. Chest. 2008;134(1):101-8. Rec#: 1930. Exclusion Codes: SMN, EXC. [pmid: 18403669].
Penel N, Fournier C, Clisant S, N'Guyen M. Causes of fever and value of C-reactive protein and procalcitonin in differentiating infections from paraneoplastic fever. Support Care Cancer. 2004;12(8):593-8. Rec#: 9690. Exclusion Codes: NRO, EXC. [pmid: 14770304].
Perren A, Cerutti B, Lepori M, Senn V, Capelli B, Duchini F, Domenighetti G. Influence of steroids on procalcitonin and C-reactive protein in patients with COPD and community-acquired pneumonia. Infection. 2008;36(2):163-6. Rec#: 2040. Exclusion Codes: NRO, EXC. [pmid: 18330505].
Persson L, Engervall P, Magnuson A, Vikerfors T, Soderquist B, Hansson LO, Tidefelt U. Use of inflammatory markers for early detection of bacteraemia in patients with febrile neutropenia. Scand J Infect Dis. 2004;36(5):365-71. Rec#: 4190. Exclusion Codes: NDE, EXC. [pmid: 15287382].
Persson L, Soderquist B, Engervall P, Vikerfors T, Hansson LO, Tidefelt U. Assessment of systemic inflammation markers to differentiate a stable from a deteriorating clinical course in patients with febrile neutropenia. Eur J Haematol. 2005;74(4):297-303. Rec#: 3900. Exclusion Codes: NDE, EXC. [pmid: 15777341].
Peters RP, Twisk JW, van Agtmael MA, Groeneveld AB. The role of procalcitonin in a decision tree for prediction of bloodstream infection in febrile patients. Clin Microbiol Infect. 2006;12(12):1207-13. Rec#: 3060. Exclusion Codes: NDE, EXC. [pmid: 17121627].
Petrikkos GL, Christofilopoulou SA, Tentolouris NK, Charvalos EA, Kosmidis CJ, Daikos GL. Value of measuring serum procalcitonin, C-reactive protein, and mannan antigens to distinguish fungal from bacterial infections. Eur J Clin Microbiol Infect Dis. 2005;24(4):272-5. Rec#: 9210. Exclusion Codes: SMN, EXC. [pmid: 15902534].
Pettila V, Hynninen M, Takkunen O, Kuusela P, Valtonen M. Predictive value of procalcitonin and interleukin 6 in critically ill patients with suspected sepsis. Intensive Care Med. 2002;28(9):1220-5. Rec#: 5180. Exclusion Codes: SMN, EXC. [pmid: 12209268].
Pezzilli R, Morselli-Labate AM, Romboli E, Dibenedetti F, Massa M, Migliori M, Barakat B, Merlini G, Corinaldesi R, Melzi d'Eril GV. Pancreatic involvement during the early phase of shock. JOP. 2002;3(5):139-43. Rec#: 10120. Exclusion Codes: NDE, EXC. [pmid: 12221328].
Pfafflin A, Schleicher E. Inflammation markers in point-of-care testing (POCT). Anal Bioanal Chem. 2009;393(5):1473-80. Rec#: 1130. Exclusion Codes: NDE, EXC. [pmid: 19104782].
Phua J, Koay ES, Lee KH. Lactate, procalcitonin, and amino-terminal pro-B-type natriuretic peptide versus cytokine measurements and clinical severity scores for prognostication in septic shock. Shock. 2008;29(3):328-33. Rec#: 2110. Exclusion Codes: SMN, EXC. [pmid: 18277855].
Phua J, Koay ES, Zhang D, Lee KH. How well do serum sTREM-1 measurements prognosticate in septic shock?. Anaesth Intensive Care. 2008;36(5):654-8. Rec#: 1330. Exclusion Codes: SMN, EXC. [pmid: 18853582].
Piechota M, Banach M, Irzmanski R, Barylski M, Piechota-Urbanska M, Kowalski J, Pawlicki L. Plasma endothelin-1 levels in septic patients. J Intensive Care Med. 2007;22(4):232-9. Rec#: 2470. Exclusion Codes: NRO, EXC. [pmid: 17722367].
Piechota M, Banach M, Irzmanski R, Misztal M, Rysz J, Barylski M, Piechota-Urbanska M, Kowalski J, Pawlicki L. N-terminal brain natriuretic propeptide levels correlate with procalcitonin and C-reactive protein levels in septic patients. Cell Mol Biol Lett. 2007;12(2):162-75. Rec#: 3040. Exclusion Codes: NRO, EXC. [pmid: 17149558].
Pihusch M, Pihusch R, Fraunberger P, Pihusch V, Andreesen R, Kolb HJ, Holler E. Evaluation of C-reactive protein, interleukin-6, and procalcitonin levels in allogeneic hematopoietic stem cell recipients. Eur J Haematol. 2006;76(2):93-101. Rec#: 8960. Exclusion Codes: NDE, EXC. [pmid: 16405429].
Pindak D, Parrak V, Pechan J, Vavrecka A, Kuzela L, Fuchs D, Irsakova J. The clinical value of the procalcitonin in prediction of severity and outcome in acute pancreatitis. Hepatogastroenterology. Suppl 2. 2003;50:ccviii-ccix. Rec#: 4240. Exclusion Codes: NDE, EXC. [pmid: 15244180].
Ploder M, Pelinka L, Schmuckenschlager C, Wessner B, Ankersmit HJ, Fuerst W, Redl H, Roth E, Spittler A. Lipopolysaccharide-induced tumor necrosis factor alpha production and not monocyte human leukocyte antigen-DR expression is correlated with survival in septic trauma patients. Shock. 2006;25(2):129-34. Rec#: 3430. Exclusion Codes: NRO, EXC. [pmid: 16525350].
Polzin A, Pletz M, Erbes R, Raffenberg M, Mauch H, Wagner S, Arndt G, Lode H. Procalcitonin as a diagnostic tool in lower respiratory tract infections and tuberculosis. Eur Respir J. 2003;21(6):939-43. Rec#: 4750. Exclusion Codes: NDE, EXC. [pmid: 12797485].
Pontier S. Nosocomial pneumonia. Les pneumonies nosocomiales. Rev. Mal. Respir. 2007;24(ATS):166-172. Rec#: 16280. Exclusion Codes: NDE, EXC.
Porcel JM. Pleural fluid tests to identify complicated parapneumonic effusions. Curr. Opin. Pulm. Med. 2010;16(4):357-361. Rec#: 15270. Exclusion Codes: NDE, EXC. [pmid: 20224408].
Porcel JM, Vives M, Cao G, Bielsa S, Ruiz-Gonzalez A, Martinez-Iribarren A, Esquerda A. Biomarkers of infection for the differential diagnosis of pleural effusions. Eur Respir J. 2009;34(6):1383-9. Rec#: 7340. Exclusion Codes: NDE, EXC. [pmid: 19541708].
Povoa P. Serum markers in community-acquired pneumonia and ventilator-associated pneumonia. Curr Opin Infect Dis. 2008;21(2):157-62. Rec#: 2060. Exclusion Codes: NDE, EXC. [pmid: 18317039].
Poyrazoglu MH, Per H, Ozturk M, Bingol N, Uzums K. Serum procalcitonin concentrations in pneumonia in children. Cocukluk cagi pnomonilerinde serum prokalsitonin duzeyleri. Cocuk Sagligi Hast. Derg. 2003;46(3):169-176. Rec#: 16780. Exclusion Codes: NDE, EXC.
Prat C, Dominguez J, Andreo F, Blanco S, Pallares A, Cuchillo F, Ramil C, Ruiz-Manzano J, Ausina V. Procalcitonin and neopterin correlation with aetiology and severity of pneumonia. J Infect. 2006;52(3):169-77. Rec#: 9130. Exclusion Codes: NRO, EXC. [pmid: 16026842].
Prat C, Dominguez J, Rodrigo C, Gimenez M, Azuara M, Blanco S, Ausina V. Use of quantitative and semiquantitative procalcitonin measurements to identify children with sepsis and meningitis. Eur J Clin Microbiol Infect Dis. 2004;23(2):136-8. Rec#: 4510. Exclusion Codes: SMN, EXC. [pmid: 14689316].
Prat C, Dominguez J, Rodrigo C, Gimenez M, Azuara M, Jimenez O, Gali N, Ausina V. Elevated serum procalcitonin values correlate with renal scarring in children with urinary tract infection. Pediatr Infect Dis J. 2003;22(5):438-42. Rec#: 9890. Exclusion Codes: SMN, EXC. [pmid: 12792386].
Prat C, Dominguez J, Rodrigo C, Gimenez M, Azuara M, Jimenez O, Gali N, Ausina V. Procalcitonin, C-reactive protein and leukocyte count in children with lower respiratory tract infection. Pediatr Infect Dis J. 2003;22(11):963-8. Rec#: 9780. Exclusion Codes: NDE, EXC. [pmid: 14614368].
Prat C, Ricart P, Ruyra X, Dominguez J, Morillas J, Blanco S, Tomasa T, Torres T, Camara L, Molinos S, Ausina V. Serum concentrations of procalcitonin after cardiac surgery. J Card Surg. 2008;23(6):627-32. Rec#: 1270. Exclusion Codes: NDE, EXC. [pmid: 19016986].
Prat C, Sancho JM, Dominguez J, Xicoy B, Gimenez M, Ferra C, Blanco S, Lacoma A, Ribera JM, Ausina V. Evaluation of procalcitonin, neopterin, C-reactive protein, IL-6 and IL-8 as a diagnostic marker of infection in patients with febrile neutropenia. Leuk Lymphoma. 2008;49(9):1752-61. Rec#: 1470. Exclusion Codes: NDE, EXC. [pmid: 18661397].
Price S, Evans T. Bacterial translocation in cardiopenic shock: the gastrointestinal tract as the motor of sepsis?. Int J Cardiol. 1999;72(1):11-2. Rec#: 6310. Exclusion Codes: NDE, EXC. [pmid: 10636627].
Prieto B, Alvarez FV. Lack of transferability of results between procalcitonin assays. Clin Chem. 2009;55(12):2226-7. author reply 2227-8. Rec#: 7150. Exclusion Codes: NDE, EXC. [pmid: 19797714].
Prieto B, Llorente E, Gonzalez-Pinto I, Alvarez FV. Plasma procalcitonin measured by time-resolved amplified cryptate emission (TRACE) in liver transplant patients. A prognosis marker of early infectious and non-infectious postoperative complications. Clin Chem Lab Med. 2008;46(5):660-6. Rec#: 1350. Exclusion Codes: NDE, EXC. [pmid: 18839468].
Prucha M, Zazula R, Hyanek J. Procalcitonin - The sensitive and specific marker of severe bacterial inflammation. Prokalcitonin - Senzitivni a specificky parametr tezkeho bakterialniho zanetu. Anesteziol. Neodkladna Pece. 2002;13(2):83-85. Rec#: 14650. Exclusion Codes: NRD, EXC.
Pugin J. Biomarkers of sepsis: is procalcitonin ready for prime time?. Intensive Care Med. 2002;28(9):1203-4. Rec#: 5090. Exclusion Codes: NDE, EXC. [pmid: 12400563].
Puhan M. Procalcitonin guidance of antibiotic therapy in pneumonia in the future?. Comment: In zukunft procalcitonin-geleitete antibiotikatherapie bei pneumonie?. Kommentar. Schweiz. Rundsch. Med. Prax. 2007;96(12):479-480. Rec#: 16370. Exclusion Codes: FLA, EXC.
Purkayastha S, Chow A, Athanasiou T, Cambaroudis A, Panesar S, Kinross J, Tekkis P, Darzi A. Does serum procalcitonin have a role in evaluating the severity of acute pancreatitis? A question revisited. World J Surg. 2006;30(9):1713-21. Rec#: 8650. Exclusion Codes: NDE, EXC. [pmid: 16927057].
Qu JM, Summah H. Biomarkers: A definite plus in pneumonia. Mediators Inflamm. 2009;2009. Rec#: 15640. Exclusion Codes: NDE, EXC.
Quintana G, Medina YF, Rojas C, Fernandez A, Restrepo JF, Rondon F, Iglesias A. The use of procalcitonin determinations in evaluation of systemic lupus erythematosus. J Clin Rheumatol. 2008;14(3):138-42. Rec#: 1570. Exclusion Codes: SMN, EXC. [pmid: 18525431].
Quintilla JM, Luaces C. Update in emergency care. Novetats a urgencies. Pediatr. Catalana. 2003;63(6):339-346. Rec#: 14340. Exclusion Codes: NDE, EXC.
Ramirez P, Garcia MA, Ferrer M, Aznar J, Valencia M, Sahuquillo JM, Menendez R, Asenjo MA, Torres A. Sequential measurements of procalcitonin levels in diagnosing ventilator-associated pneumonia. Eur Respir J. 2008;31(2):356-62. Rec#: 2310. Exclusion Codes: SMN, EXC. [pmid: 17959634].
Ramirez P, Menendez R, Torres A. New biological markers of ventilator-associated pneumonia. Clin. Pulm. Med. 2007;14(2):93-98. Rec#: 13510. Exclusion Codes: NDE, EXC.
Rammaert B, Verdier N, Cavestri B, Nseir S. Procalcitonin as a prognostic factor in severe acute exacerbation of chronic obstructive pulmonary disease. Respirology. 2009;14(7):969-74. Rec#: 660. Exclusion Codes: NDE, EXC. [pmid: 19659517].
Ramos Amador JT, Sanchez Granados JM, Gonzalez Tome MI, Carreno Guerra MP. Infection markers in pediatrics. Marcadores de infeccion en pediatria. Acta Pediatr. Esp. 2003;61(2):58-64. Rec#: 16830. Exclusion Codes: NRD, EXC.
Ramsthaler F, Kettner M, Mall G, Bratzke H. The use of rapid diagnostic test of procalcitonin serum levels for the postmortem diagnosis of sepsis. Forensic Sci Int. 2008;178(2-3):139-45. Rec#: 1810. Exclusion Codes: NDE, EXC. [pmid: 18450398].
Rau B, Schilling MK, Beger HG. Laboratory markers of severe acute pancreatitis. Dig Dis. 2004;22(3):247-57. Rec#: 9290. Exclusion Codes: NDE, EXC. [pmid: 15753607].
Rau B, Steinbach G, Baumgart K, Gansauge F, Grunert A, Beger HG. The clinical value of procalcitonin in the prediction of infected necrosis in acute pancreatitis. Intensive Care Med. Suppl 2. 2000;26:S159-64. Rec#: 1750. Exclusion Codes: NDE, EXC. [pmid: 18470712].
Rau B, Steinbach G, Gansauge F, Mayer JM, Grunert A, Beger HG. The potential role of procalcitonin and interleukin 8 in the prediction of infected necrosis in acute pancreatitis. Gut. 1997;41(6):832-40. Rec#: 6800. Exclusion Codes: SMN, EXC. [pmid: 9462219].
Rau BM, Frigerio I, Buchler MW, Wegscheider K, Bassi C, Puolakkainen PA, Beger HG, Schilling MK. Evaluation of procalcitonin for predicting septic multiorgan failure and overall prognosis in secondary peritonitis: a prospective, international multicenter study. Arch Surg. 2007;142(2):134-42. Rec#: 2930. Exclusion Codes: SMN, EXC. [pmid: 17309964].
Rau BM, Kemppainen EA, Gumbs AA, Buchler MW, Wegscheider K, Bassi C, Puolakkainen PA, Beger HG. Early assessment of pancreatic infections and overall prognosis in severe acute pancreatitis by procalcitonin (PCT): a prospective international multicenter study. Ann Surg. 2007;245(5):745-54. Rec#: 2790. Exclusion Codes: NDE, EXC. [pmid: 17457167].
Ravishankar K. Laboratory diagnosis of neonatal sepsis. J. Neonatal. 2009;23(1):48-52. Rec#: 12480. Exclusion Codes: NDE, EXC.
Ray P, Badarou-Acossi G, Viallon A, Boutoille D, Arthaud M, Trystram D, Riou B. Accuracy of the cerebrospinal fluid results to differentiate bacterial from non bacterial meningitis, in case of negative gram-stained smear. Am J Emerg Med. 2007;25(2):179-84. Rec#: 8550. Exclusion Codes: NDE, EXC. [pmid: 17276808].
Rea-Neto A, Youssef NC, Tuche F, Brunkhorst F, Ranieri VM, Reinhart K, Sakr Y. Diagnosis of ventilator-associated pneumonia: a systematic review of the literature. Crit Care. 2008;12(2):R56. Rec#: 1880. Exclusion Codes: NRD, EXC. [pmid: 18426596].
Reina PM, Alcantara IR, Mico SV, Lucea JLLP, Alapont VMI. Accuracy of the procalcitonin test in the diagnosis of occult bacteremia in paediatrics: A systematic review and meta-analysis. Exactitud del test de procalcitonina en el diagnostico de bacteriemia oculta en pediatria: revision sistematica y metanalisis. An. Pediatr. 2010;72(6):403-412. Rec#: 11390. Exclusion Codes: NDE, EXC.
Reinhart K, Bayer O, Brunkhorst F, Meisner M. Markers of endothelial damage in organ dysfunction and sepsis. Crit Care Med. 2002;30(5 Suppl):S302-12. Rec#: 5340. Exclusion Codes: NDE, EXC. [pmid: 12004252].
Reinhart K, Brunkhorst FM. Meta-analysis of procalcitonin for sepsis detection. Lancet Infect Dis. 2007;7(8):500-2. author reply 502-3. Rec#: 2580. Exclusion Codes: NRD, EXC. [pmid: 17646021].
Reinhart K, Karzai W. Re: Procalcitonin: a new parameter for the diagnosis of bacterial infection in the perioperative period. Oczenski et al., Eur J Anaesthesiol 1998; 15: 129-132. Eur J Anaesthesiol. 1998;15(5):618-9. Rec#: 6660. Exclusion Codes: NDE, EXC. [pmid: 9785086].
Reinhart K, Meisner M, Brunkhorst FM. Markers for sepsis diagnosis: what is useful?. Crit Care Clin. 2006;22(3):503-19. ix. x. Rec#: 3210. Exclusion Codes: NDE, EXC. [pmid: 16893736].
Reith HB. Patients with abdominal sepsis - Options for using adjuvant intravenous immunoglobulins. Przydatnosc dozylnych preparatow immunoglobulin w leczeniu chorych z objawami posocznicy w przebiegu zakazen wewnatrzbrzusznych. Pol. Prz. Chir. 2007;79(2):234-247. Rec#: 13440. Exclusion Codes: NRO, EXC.
Reith HB, Lehmkuhl P, Beier W, Hogy B. Procalcitonin - A prognostic parameter of infection in peritonitis. PROCALCITONIN-EIN PROGNOSTISCHER INFEKTIONS-PARAMETER BEI DER PERITONITIS. CHIR. GASTROENTEROL. INTERDISZIP. GESPR. 1995;11(SUPPL. 2):47-50. Rec#: 15230. Exclusion Codes: NRD, EXC.
Reith HB, Mittelkotter U, Debus ES, Kussner C, Thiede A. Procalcitonin in early detection of postoperative complications. Dig Surg. 1998;15(3):260-5. Rec#: 6630. Exclusion Codes: SMN, EXC. [pmid: 9845596].
Reith HB, Mittelkotter U, Maseizik T, Hager S, Beutner U, Ulrichs K, Thiede A. Peritonitis monitoring with procalcitonin and diagnostic of immune function disorder with HLA-DR expression on monocytes. Peritonitis-monitoring mit procalcitonin und diagnostik von immunfunktionsstorungen durch HLA-DR-expression auf monozyten. Chir. Gastroenterol. Interdiszip. 1999;15(SUPPL. 1):8-14. Rec#: 15030. Exclusion Codes: NRD, EXC.
Reith HB, Mittelkotter U, Wagner R, Thiede A. Procalcitonin (PCT) in patients with abdominal sepsis. Intensive Care Med. Suppl 2. 2000;26:S165-9. Rec#: 1740. Exclusion Codes: NDE, EXC. [pmid: 18470713].
Reith HB, Rauchschwalbe SK. Pro-atrial natriuretic peptide (proANP) a new prognostic marker in clinical outcome of critically ill patients. Prekursor przedsionkowego peptydu natriuretycznego - Nowy marker o znaczeniu rokowniczym odnosnie do wyniku klinicznego leczenia chorych w stanie ciezkim. Pol. Prz. Chir. 2007;79(3):293-302. Rec#: 13430. Exclusion Codes: NRO, EXC.
Reith HB, Rauchschwalbe SK, Mittelkotter U. Nosocomial pneumonia: third-group chinolone versus clindamycin/ceftriaxone in modulation of the acute phase reaction and outcome and cost efficacy. Int Surg. 2006;91(5):272-5. Rec#: 3080. Exclusion Codes: NRO, EXC. [pmid: 17061673].
Repetto HA, Alarcon PA, Pellegrini M. Procalcitonin as a marker of acute pyelonephritis. Pediatr Nephrol. 2003;18(7):726. Rec#: 9940. Exclusion Codes: NDE, EXC. [pmid: 12721819].
Resch B, Gusenleitner W, Muller W. Procalcitonin, interleukin-6, C-reactive protein and leukocyte counts in infants with bronchiolitis. Pediatr Infect Dis J. 2003;22(5):475-6. Rec#: 9880. Exclusion Codes: NDE, EXC. [pmid: 12792393].
Resch B, Gusenleitner W, Muller WD. Procalcitonin and interleukin-6 in the diagnosis of early-onset sepsis of the neonate. Acta Paediatr. 2003;92(2):243-5. Rec#: 4850. Exclusion Codes: NDE, EXC. [pmid: 12710654].
Rey C, Los Arcos M, Concha A, Medina A, Prieto S, Martinez P, Prieto B. Procalcitonin and C-reactive protein as markers of systemic inflammatory response syndrome severity in critically ill children. Intensive Care Med. 2007;33(3):477-84. Rec#: 2960. Exclusion Codes: SMN, EXC. [pmid: 17260130].
Rhodes A, Wort SJ, Thomas H, Collinson P, Bennett ED. Plasma DNA concentration as a predictor of mortality and sepsis in critically ill patients. Crit Care. 2006;10(2):R60. Rec#: 3370. Exclusion Codes: NRO, EXC. [pmid: 16613611].
Richard-Lenoble D, Duong TH, Ferrer A, Lacombe C, Assicot M, Gendrel D, Bohuon C, Kombila M. Changes in procalcitonin and interleukin 6 levels among treated African patients with different clinical forms of malaria. Trans R Soc Trop Med Hyg. 1997;91(3):305-6. Rec#: 10930. Exclusion Codes: NRO, EXC. [pmid: 9231203].
Richards GA, Schleicher GK. Targeted interventions to decrease sepsis in the ICU. South. Afr. J. Crit. Care. 2003;19(2):49-52. Rec#: 14280. Exclusion Codes: NDE, EXC.
Riche FC, Cholley BP, Laisne MJ, Vicaut E, Panis YH, Lajeunie EJ, Boudiaf M, Valleur PD. Inflammatory cytokines, C reactive protein, and procalcitonin as early predictors of necrosis infection in acute necrotizing pancreatitis. Surgery. 2003;133(3):257-62. Rec#: 4870. Exclusion Codes: SMN, EXC. [pmid: 12660636].
Rinaldi S, Adembri C, Grechi S, De Gaudio AR. Low-dose hydrocortisone during severe sepsis: effects on microalbuminuria. Crit Care Med. 2006;34(9):2334-9. Rec#: 3250. Exclusion Codes: NRO, EXC. [pmid: 16850006].
Rintala EM, Aittoniemi J, Laine S, Nevalainen TJ, Nikoskelainen J. Early identification of bacteremia by biochemical markers of systemic inflammation. Scand J Clin Lab Invest. 2001;61(7):523-30. Rec#: 5570. Exclusion Codes: SMN, EXC. [pmid: 11763410].
Rizza A, Rodak R, Zimmerli L. Increased inflammatory signs: Role of BSR, CRP, PCT in practice. Erhohte entzundungszeichen: Rolle von BSR, CRP, PCT in der praxis. Schweiz. Rundsch. Med. Prax. 2009;98(12):625-633. Rec#: 15830. Exclusion Codes: FLA, EXC.
Rosmarakis ES, Prapas SN, Rellos K, Michalopoulos A, Samonis G, Falagas ME. Nosocomial infections after off-pump coronary artery bypass surgery: frequency, characteristics, and risk factors. Interact Cardiovasc Thorac Surg. 2007;6(6):759-67. Rec#: 2370. Exclusion Codes: NDE, EXC. [pmid: 17905781].
Rothenburger M, Markewitz A, Lenz T, Kaulbach HG, Marohl K, Kuhlmann WD, Weinhold C. Detection of acute phase response and infection. The role of procalcitonin and C-reactive protein. Clin Chem Lab Med. 1999;37(3):275-9. Rec#: 6490. Exclusion Codes: NDE, EXC. [pmid: 10353472].
Rowther FB, Rodrigues CS, Deshmukh MS, Kapadia FN, Hegde A, Mehta AP, Joshi VR. Prospective comparison of eubacterial PCR and measurement of procalcitonin levels with blood culture for diagnosing septicemia in intensive care unit patients. J Clin Microbiol. 2009;47(9):2964-9. Rec#: 690. Exclusion Codes: SMN, EXC. [pmid: 19641068].
Ruiz-Alvarez MJ, Garcia-Valdecasas S, De Pablo R, Sanchez Garcia M, Coca C, Groeneveld TW, Roos A, Daha MR, Arribas I. Diagnostic efficacy and prognostic value of serum procalcitonin concentration in patients with suspected sepsis. J Intensive Care Med. 2009;24(1):63-71. Rec#: 1210. Exclusion Codes: NDE, EXC. [pmid: 19054806].
Ruokonen E, Ilkka L, Niskanen M, Takala J. Procalcitonin and neopterin as indicators of infection in critically ill patients. Acta Anaesthesiol Scand. 2002;46(4):398-404. Rec#: 5410. Exclusion Codes: NDE, EXC. [pmid: 11952440].
Ruokonen E, Nousiainen T, Pulkki K, Takala J. Procalcitonin concentrations in patients with neutropenic fever. Eur J Clin Microbiol Infect Dis. 1999;18(4):283-5. Rec#: 6450. Exclusion Codes: NDE, EXC. [pmid: 10385017].
Russwurm S, Oberhoffer M, Zipfel PF, Reinhart K. Procalcitonin--a novel biochemical marker for the mediator-directed therapy of sepsis. Mol Med Today. 1999;5(7):286-7. Rec#: 6460. Exclusion Codes: NDE, EXC. [pmid: 10377518].
Sabat R, Hoflich C, Docke WD, Oppert M, Kern F, Windrich B, Rosenberger C, Kaden J, Volk HD, Reinke P. Massive elevation of procalcitonin plasma levels in the absence of infection in kidney transplant patients treated with pan-T-cell antibodies. Intensive Care Med. 2001;27(6):987-91. Rec#: 5710. Exclusion Codes: NRO, EXC. [pmid: 11497157].
Sablotzki A, Borgermann J, Baulig W, Friedrich I, Spillner J, Silber RE, Czeslick E. Lipopolysaccharide-binding protein (LBP) and markers of acute-phase response in patients with multiple organ dysfunction syndrome (MODS) following open heart surgery. Thorac Cardiovasc Surg. 2001;49(5):273-8. Rec#: 5640. Exclusion Codes: NRO, EXC. [pmid: 11605136].
Sablotzki A, Dehne MG, Friedrich I, Grond S, Zickmann B, Muhling J, Silber RE, Czeslick EG. Different expression of cytokines in survivors and non-survivors from MODS following cardiovascular surgery. Eur J Med Res. 2003;8(2):71-6. Rec#: 4960. Exclusion Codes: NRO, EXC. [pmid: 12626284].
Sachse C, Dressler F, Henkel E. Increased serum procalcitonin in newborn infants without infection. Clin Chem. 1998;44(6 Pt 1):1343-4. Rec#: 10810. Exclusion Codes: NRO, EXC. [pmid: 9625064].
Sachse C, Machens HG, Felmerer G, Berger A, Henkel E. Procalcitonin as a marker for the early diagnosis of severe infection after thermal injury. J Burn Care Rehabil. 1999;20(5):354-60. Rec#: 6410. Exclusion Codes: NDE, EXC. [pmid: 10501320].
Sakha K, Husseini MB, Seyyedsadri N. The role of the procalcitonin in diagnosis of neonatal sepsis and correlation between procalcitonin and C-reactive protein in these patients. Pak J Biol Sci. 2008;11(14):1785-90. Rec#: 1380. Exclusion Codes: NDE, EXC. [pmid: 18817217].
Sakr Y, Burgett U, Nacul FE, Reinhart K, Brunkhorst F. Lipopolysaccharide binding protein in a surgical intensive care unit: a marker of sepsis?. Crit Care Med. 2008;36(7):2014-22. Rec#: 1550. Exclusion Codes: NDE, EXC. [pmid: 18552695].
Sakr Y, Sponholz C, Tuche F, Brunkhorst F, Reinhart K. The role of procalcitonin in febrile neutropenic patients: review of the literature. Infection. 2008;36(5):396-407. Rec#: 1420. Exclusion Codes: NDE, EXC. [pmid: 18759057].
Sanchez R, Gutierrez C, Angeles Cesar M, Pastor R, Vilanova A. Procalcitonin and C-reactive protein in the diagnosis of bacterial pneumonias in patients in the Emergency Department. Procalcitonina y proteina C reactiva en el diagnostico de neumonias bacterianas en pacientes de urgencias. Rev. Lab. Clin. 2008;1(2):59-63. Rec#: 16150. Exclusion Codes: NDE, EXC.
Sand M, Trullen XV, Bechara FG, Pala XF, Sand D, Landgrafe G, Mann B. A prospective bicenter study investigating the diagnostic value of procalcitonin in patients with acute appendicitis. Eur Surg Res. 2009;43(3):291-7. Rec#: 630. Exclusion Codes: NDE, EXC. [pmid: 19672084].
Sandek A, Springer J, Habedank D, Brunkhorst F, Anker SD. Procalcitonin-guided antibiotic treatment in heart failure. Lancet. 2004;363(9420):1555. author reply 1555-6. Rec#: 9610. Exclusion Codes: NDE, EXC. [pmid: 15135615].
Sandner F. The ProHOSP Study shows benefits of procalcitonin determination in deep respiratory tract infections. ProHOSP-Studie zeigt Nutzen der Procalcitonin-Bestimmung bei tiefen Atemwegsinfekten. J. Pharmakol. Ther. 2009;18(4):124-125. Rec#: 15810. Exclusion Codes: NDE, EXC.
Sandri MT, Passerini R, Leon ME, Peccatori FA, Zorzino L, Salvatici M, Riggio D, Cassatella C, Cinieri S, Martinelli G. Procalcitonin as a useful marker of infection in hemato-oncological patients with fever. Anticancer Res. 2008;28(5B):3061-5. Rec#: 1260. Exclusion Codes: NDE, EXC. [pmid: 19031957].
Santolaya ME, Alvarez AM, Aviles CL, Becker A, King A, Mosso C, O'Ryan M, Paya E, Salgado C, Silva P, Topelberg S, Tordecilla J, Varas M, Villarroel M, Viviani T, Zubieta M. Predictors of severe sepsis not clinically apparent during the first twenty-four hours of hospitalization in children with cancer, neutropenia, and fever: a prospective, multicenter trial. Pediatr Infect Dis J. 2008;27(6):538-43. Rec#: 1800. Exclusion Codes: NDE, EXC. [pmid: 18458649].
Santuz P, Soffiati M, Dorizzi RM, Benedetti M, Zaglia F, Biban P. Procalcitonin for the diagnosis of early-onset neonatal sepsis: a multilevel probabilistic approach. Clin Biochem. 2008;41(14-15):1150-5. Rec#: 1500. Exclusion Codes: NDE, EXC. [pmid: 18606160].
Saribas S, Kocazeybek B, Aslan M, Altun S, Seyhun Y, Oner YA, Memisoglu N. Do procalcitonin and C-reactive protein levels have a place in the diagnosis and follow-up of Helicobacter pylori infections?. J Med Microbiol. 2004;53(Pt 7):639-44. Rec#: 9590. Exclusion Codes: SMN, EXC. [pmid: 15184535].
Sarmati L, Beltrame A, Dori L, Maffongelli G, Cudillo L, De Angelis G, Picardi A, Ottaviani L, Cefalo MG, Venditti A, Amadori S, Arcese W, Andreoni M. Procalcitonin is a reliable marker of severe systemic infection in neutropenic haematological patients with mucositis. Am J Hematol. 2010;85(5):380-3. Rec#: 80. Exclusion Codes: NRD, EXC. [pmid: 20425801].
Sauer M, Tiede K, Fuchs D, Gruhn B, Berger D, Zintl F. Procalcitonin, C-reactive protein, and endotoxin after bone marrow transplantation: identification of children at high risk of morbidity and mortality from sepsis. Bone Marrow Transplant. 2003;31(12):1137-42. Rec#: 4770. Exclusion Codes: NDE, EXC. [pmid: 12796793].
Savagner C, Hoppe A, Montcho Y, Leboucher B, Le Bouedec S, Lemarie C, Boux de Casson F, Bouderlique C. Interest of Procalcitonin in neonatal intensive care unit for patients suspected of nosocomial sepsis: Retrospective study on 40 children. Interet de la procalcitonine pour le diagnostic d'infections nosocomiales bacteriennes en neonatalogie : etude retrospective sur 40 enfants. J. Pediatr. Pueric. 2008;21(7):292-298. Rec#: 12700. Exclusion Codes: NDE, EXC.
Schalinski S, Braun C, Tsokos M. High-grade decubitus ulcers and sepsis in the end-of-life phase. A prospective autopsy study. Hohergradige dekubitalulzera und sepsis im umfeld der sterbephase. Prospektive obduktionsstudie. Rechtsmedizin. 2007;17(6):376-379. Rec#: 13170. Exclusion Codes: NDE, EXC.
Schinella M, Lippi G, Curci V, Gualdi P, Collini L, Mattarei M. Procalcitonin concentrations in bacteremia. Riv. Ital. Med. Labor. 2009;5(1):38-43. Rec#: 12220. Exclusion Codes: NRO, EXC.
Schneider HG, Lam QT. Procalcitonin for the clinical laboratory: a review. Pathology. 2007;39(4):383-90. Rec#: 2520. Exclusion Codes: NRD, EXC. [pmid: 17676478].
Schroder J, Staubach KH, Zabel P, Stuber F, Kremer B. Procalcitonin as a marker of severity in septic shock. Langenbecks Arch Surg. 1999;384(1):33-8. Rec#: 6470. Exclusion Codes: NRO, EXC. [pmid: 10367627].
Schuetz P, Albrich W, Christ-Crain M, Chastre J, Mueller B. Procalcitonin for guidance of antibiotic therapy. Expert Rev Anti Infect Ther. 2010;8(5):575-87. Rec#: 30. Exclusion Codes: NDE, EXC. [pmid: 20455686].
Schuetz P, Batschwaroff M, Dusemund F, Albrich W, Burgi U, Maurer M, Brutsche M, Huber AR, Muller B. Effectiveness of a procalcitonin algorithm to guide antibiotic therapy in respiratory tract infections outside of study conditions: a post-study survey. Eur J Clin Microbiol Infect Dis. 2010;29(3):269-77. Rec#: 7050. Exclusion Codes: NDE, EXC. [pmid: 20039090].
Schuetz P, Briel M, Christ-Crain M, Wolbers M, Stolz D, Tamm M, Bucher H, Muller B. Procalcitonin to initiate or withhold antibiotics in acute respiratory tract infections. Cochrane Database Syst. Rev. 2008;(4). Rec#: 12570. Exclusion Codes: NDE, EXC.
Schuetz P, Christ-Crain M, Albrich W, Zimmerli W, Mueller B. Guidance of antibiotic therapy with procalcitonin in lower respiratory tract infections: Insights into the ProHOSP study. Virulence. 2010;1(2):88-92. Rec#: 11730. Exclusion Codes: NDE, EXC. [pmid: 21178422].
Schuetz P, Christ-Crain M, Morgenthaler NG, Struck J, Bergmann A, Muller B. Circulating precursor levels of endothelin-1 and adrenomedullin, two endothelium-derived, counteracting substances, in sepsis. Endothelium. 2007;14(6):345-51. Rec#: 2240. Exclusion Codes: NDE, EXC. [pmid: 18080871].
Schuetz P, Christ-Crain M, Muller B. Biomarkers to improve diagnostic and prognostic accuracy in systemic infections. Curr Opin Crit Care. 2007;13(5):578-85. Rec#: 2450. Exclusion Codes: NRD, EXC. [pmid: 17762239].
Schuetz P, Christ-Crain M, Muller B. Procalcitonin and other biomarkers to improve assessment and antibiotic stewardship in infections--hope for hype?. Swiss Med Wkly. 2009;139(23-24):318-26. Rec#: 800. Exclusion Codes: NDE, EXC. [pmid: 19529989].
Schuetz P, Christ-Crain M, Wolbers M, Schild U, Thomann R, Falconnier C, Widmer I, Neidert S, Blum CA, Schonenberger R, Henzen C, Bregenzer T, Hoess C, Krause M, Bucher HC, Zimmerli W, Muller B. Procalcitonin guided antibiotic therapy and hospitalization in patients with lower respiratory tract infections: a prospective, multicenter, randomized controlled trial. BMC Health Serv Res. 2007;7:102. Rec#: 8370. Exclusion Codes: NDE, EXC. [pmid: 17615073].
Schuetz P, Mueller B, Trampuz A. Serum procalcitonin for discrimination of blood contamination from bloodstream infection due to coagulase-negative staphylococci. Infection. 2007;35(5):352-5. Rec#: 2400. Exclusion Codes: SMN, EXC. [pmid: 17882355].
Schuetz P, Stolz D, Mueller B, Morgenthaler NG, Struck J, Mueller C, Bingisser R, Tamm M, Christ-Crain M. Endothelin-1 precursor peptides correlate with severity of disease and outcome in patients with community acquired pneumonia. BMC Infect Dis. 2008;8:22. Rec#: 2090. Exclusion Codes: NDE, EXC. [pmid: 18304365].
Schuttrumpf S, Binder L, Hagemann T, Berkovic D, Trumper L, Binder C. Procalcitonin: a useful discriminator between febrile conditions of different origin in hemato-oncological patients?. Ann Hematol. 2003;82(2):98-103. Rec#: 9990. Exclusion Codes: SMN, EXC. [pmid: 12601488].
Schuttrumpf S, Binder L, Hagemann T, Berkovic D, Trumper L, Binder C. Utility of procalcitonin concentration in the evaluation of patients with malignant diseases and elevated C-reactive protein plasma concentrations. Clin Infect Dis. 2006;43(4):468-73. Rec#: 8720. Exclusion Codes: NDE, EXC. [pmid: 16838236].
Schutzle H, Forster J, Superti-Furga A, Berner R. Is serum procalcitonin a reliable diagnostic marker in children with acute respiratory tract infections? A retrospective analysis. Eur J Pediatr. 2009;168(9):1117-24. Rec#: 7620. Exclusion Codes: NDE, EXC. [pmid: 19107517].
Schwarz S, Bertram M, Schwab S, Andrassy K, Hacke W. Serum procalcitonin levels in bacterial and abacterial meningitis. Crit Care Med. 2000;28(6):1828-32. Rec#: 6090. Exclusion Codes: SMN, EXC. [pmid: 10890628].
Schwenger V, Sis J, Breitbart A, Andrassy K. CRP levels in autoimmune disease can be specified by measurement of procalcitonin. Infection. 1998;26(5):274-6. Rec#: 10730. Exclusion Codes: NRO, EXC. [pmid: 9795783].
Scire CA, Cavagna L, Perotti C, Bruschi E, Caporali R, Montecucco C. Diagnostic value of procalcitonin measurement in febrile patients with systemic autoimmune diseases. Clin Exp Rheumatol. 2006;24(2):123-8. Rec#: 8790. Exclusion Codes: NDE, EXC. [pmid: 16762145].
Scott LK, Grier LR, Arnold TC, Conrad SA. Serum procalcitonin concentration as a negative predictor of serious bacterial infection in acute sickle cell pain crisis. Med Sci Monit. 2003;9(10):CR426-31. Rec#: 9830. Exclusion Codes: NDE, EXC. [pmid: 14523331].
Secmeer G, Devrim I, Kara A, Ceyhan M, Cengiz B, Kutluk T, Buyukpamukcu M, Yetgin S, Tuncer M, Uludag AK, Tezer H, Yildirim I. Role of procalcitonin and CRP in differentiating a stable from a deteriorating clinical course in pediatric febrile neutropenia. J Pediatr Hematol Oncol. 2007;29(2):107-11. Rec#: 2950. Exclusion Codes: NDE, EXC. [pmid: 17279007].
Selberg O, Hecker H, Martin M, Klos A, Bautsch W, Kohl J. Discrimination of sepsis and systemic inflammatory response syndrome by determination of circulating plasma concentrations of procalcitonin, protein complement 3a, and interleukin-6. Crit Care Med. 2000;28(8):2793-8. Rec#: 6050. Exclusion Codes: SMN, EXC. [pmid: 10966252].
Seligman R, Meisner M, Lisboa TC, Hertz FT, Filippin TB, Fachel JM, Teixeira PJ. Decreases in procalcitonin and C-reactive protein are strong predictors of survival in ventilator-associated pneumonia. Crit Care. 2006;10(5):R125. Rec#: 3140. Exclusion Codes: SMN, EXC. [pmid: 16956405].
Setvak D, Zahorec R, Misianik J. The use of procalcitonin as a marker of sepsis in postoperative and intensive care. Vyuzitie procalcitoninu ako zapaloveho markeru v pooperacnej a intenzivnej starostlivosti. Anesteziol. Neodkladna Pece. 2000;11(4):165-169. Rec#: 14820. Exclusion Codes: NRD, EXC.
Sfia M, Boeckler P, Lipsker D. High procalcitonin levels in patients with severe drug reactions. Arch Dermatol. 2007;143(12):1591. Rec#: 8150. Exclusion Codes: NDE, EXC. [pmid: 18087019].
Shafiq N, Malhotra S, Bhasin DK, Rana S, Siddhu S, Pandhi P. Estimating the diagnostic accuracy of procalcitonin as a marker of the severity of acute pancreatitis: a meta-analytic approach. JOP. 2005;6(3):231-7. Rec#: 9230. Exclusion Codes: NDE, EXC. [pmid: 15883473].
Sherlock R. Neonatal sepsis and septic shock: Current trends in epidemiology and management. J. Pediatr. Infect. Dis. 2009;4(2):153-159. Rec#: 12350. Exclusion Codes: NDE, EXC.
Sherwin C, Broadbent R, Young S, Worth J, McCaffrey F, Medlicott NJ, Reith D. Utility of interleukin-12 and interleukin-10 in comparison with other cytokines and acute-phase reactants in the diagnosis of neonatal sepsis. Am J Perinatol. 2008;25(10):629-36. Rec#: 1340. Exclusion Codes: NDE, EXC. [pmid: 18850512].
Shimetani N, Shimetani K, Mori M. Levels of three inflammation markers, C-reactive protein, serum amyloid A protein and procalcitonin, in the serum and cerebrospinal fluid of patients with meningitis. Scand J Clin Lab Invest. 2001;61(7):567-74. Rec#: 5560. Exclusion Codes: NRO, EXC. [pmid: 11763415].
Shimizu T, Hanasawa K, Sato K, Umeki M, Koga N, Naganuma T, Sato S, Shimonishi T, Ikeda T, Matsuno N, Ono S, Saitoh H, Satoh K, Otani Y, Endo Y, Eguchi Y, Tani T. The clinical significance of serum procalcitonin levels following direct hemoperfusion with polymyxin B-immobilized fiber column in septic patients with colorectal perforation. Eur Surg Res. 2009;42(2):109-17. Rec#: 1110. Exclusion Codes: NDE, EXC. [pmid: 19122457].
Shin KC, Lee YJ, Kang SW, Baek HJ, Lee EB, Kim HA, Song YW. Serum procalcitonin measurement for detection of intercurrent infection in febrile patients with SLE. Ann Rheum Dis. 2001;60(10):988-9. Rec#: 10230. Exclusion Codes: NRO, EXC. [pmid: 11589181].
Siassi M, Riese J, Steffensen R, Meisner M, Thiel S, Hohenberger W, Schmidt J. Mannan-binding lectin and procalcitonin measurement for prediction of postoperative infection. Crit Care. 2005;9(5):R483-9. Rec#: 3600. Exclusion Codes: NRO, EXC. [pmid: 16277709].
Siempos II, Michalopoulos A, Falagas ME. Treatment of acute bacterial exacerbations of chronic bronchitis. Expert Opin Pharmacother. 2009;10(7):1173-82. Rec#: 7400. Exclusion Codes: NDE, EXC. [pmid: 19405791].
Sierra R. C-reactive protein and procalcitonin as markers of infection, inflammatory response, and sepsis. Clin. Pulm. Med. 2007;14(3):127-139. Rec#: 13390. Exclusion Codes: NDE, EXC.
Simon L, Gauvin F, Amre DK, Saint-Louis P, Lacroix J. Serum procalcitonin and C-reactive protein levels as markers of bacterial infection: a systematic review and meta-analysis. Clin Infect Dis. 2004;39(2):206-17. Rec#: 9540. Exclusion Codes: NDE, EXC. [pmid: 15307030].
Simon L, Saint-Louis P, Amre DK, Lacroix J, Gauvin F. Procalcitonin and C-reactive protein as markers of bacterial infection in critically ill children at onset of systemic inflammatory response syndrome. Pediatr Crit Care Med. 2008;9(4):407-13. Rec#: 1620. Exclusion Codes: SMN, EXC. [pmid: 18496408].
Sitter T, Schmidt M, Schneider S, Schiffl H. Differential diagnosis of bacterial infection and inflammatory response in kidney diseases using procalcitonin. J Nephrol. 2002;15(3):297-301. Rec#: 10130. Exclusion Codes: NDE, EXC. [pmid: 12113602].
Sleglova O, Dejmkova H, Uhrova J. Can the determination of serum procalcitonin be helpful in the differential diagnosis of an infection and an acute exacerbation in patients with a systemic autoimmune disease?. Muze stanoveni seroveho prokalcitoninu pomoci v diferencialni diagnoze mezi infekci a akutnim zhorsenim u pacientu se syste movym autoimunitnim onemocnenim?. Ceska Revmatol. 2010;18(1):4-11. Rec#: 15390. Exclusion Codes: NRD, EXC.
Smith L. Management of bacterial meningitis: New guidelines from the IDSA. Am. Fam. Phys. 2005;71(10):2003-2008. Rec#: 16640. Exclusion Codes: NRD, EXC.
Smith MD, Suputtamongkol Y, Chaowagul W, Assicot M, Bohuon C, Petitjean S, White NJ. Elevated serum procalcitonin levels in patients with melioidosis. Clin Infect Dis. 1995;20(3):641-5. Rec#: 10970. Exclusion Codes: SMN, EXC. [pmid: 7756489].
Smolkin V, Koren A, Raz R, Colodner R, Sakran W, Halevy R. Procalcitonin as a marker of acute pyelonephritis in infants and children. Pediatr Nephrol. 2002;17(6):409-12. Rec#: 10140. Exclusion Codes: SMN, EXC. [pmid: 12107804].
Snider RH Jr, Nylen ES, Becker KL. Procalcitonin and its component peptides in systemic inflammation: immunochemical characterization. J Investig Med. 1997;45(9):552-60. Rec#: 6810. Exclusion Codes: NRO, EXC.
Soderquist B, Jones I, Fredlund H, Vikerfors T. Bacterial or crystal-associated arthritis? Discriminating ability of serum inflammatory markers. Scand J Infect Dis. 1998;30(6):591-6. Rec#: 6520. Exclusion Codes: NDE, EXC. [pmid: 10225388].
Sorbera LA. Procalcitonin as an effective biomarker for the diagnosis and prognosis of severe sepsis. Highlights from the 25th International Symposium on Intensive Care and Emergency Medicine. March 21-25, 2005, Brussels, Belgium. Drugs Today (Barc). 2005;41(4):253-6. Rec#: 3740. Exclusion Codes: NDE, EXC. [pmid: 16034489].
Soto GJ. Diagnostic strategies for nosocomial pneumonia. Curr Opin Pulm Med. 2007;13(3):186-91. Rec#: 2810. Exclusion Codes: NDE, EXC. [pmid: 17414125].
Spada S, Cuccu A, Mussap M, Testa M, Puddu M, Pisu C, Burrai P, Fanos V. Reliability of procalcitonin in neonatology. Experience in 59 preterm newborns. J Matern Fetal Neonatal Med. Suppl 3. 2009;22:96-101. Rec#: 330. Exclusion Codes: NDE, EXC. [pmid: 19925368].
Spahr L, Morard I, Hadengue A, Vadas L, Pugin J. Procalcitonin is not an accurate marker of spontaneous bacterial peritonitis in patients with cirrhosis. Hepatogastroenterology. 2001;48(38):502-5. Rec#: 10320. Exclusion Codes: NRO, EXC. [pmid: 11379342].
Spapen HD, Hachimi-Idrissi S, Corne L, Huyghens LP. Diagnostic markers of sepsis in the emergency department. Acta Clin Belg. 2006;61(3):138-42. Rec#: 3230. Exclusion Codes: NDE, EXC. [pmid: 16881563].
Spiegler P. Using procalcitonin to refine treatment of chronic obstructive pulmonary disease exacerbations. Clin. Pulm. Med. 2007;14(3):184-185. Rec#: 13380. Exclusion Codes: NRD, EXC.
Spiegler P. Do antibiotics for copd exacerbations improve outcomes?. Clin. Pulm. Med. 2009;16(4):226-227. Rec#: 12210. Exclusion Codes: NRD, EXC.
Sponholz C, Sakr Y, Reinhart K, Brunkhorst F. Diagnostic value and prognostic implications of serum procalcitonin after cardiac surgery: a systematic review of the literature. Crit Care. 2006;10(5):R145. Rec#: 3100. Exclusion Codes: NDE, EXC. [pmid: 17038199].
Staehler M, Hammer C, Meiser B, Reichart B. Procalcitonin: a new marker for differential diagnosis of acute rejection and bacterial infection in heart transplantation. Transplant Proc. 1997;29(1-2):584-5. Rec#: 6870. Exclusion Codes: NDE, EXC. [pmid: 9123140].
Steichen O, Bouvard E, Grateau G, Bailleul S, Capeau J, Lefevre G. Diagnostic value of procalcitonin in acutely hospitalized elderly patients. Eur J Clin Microbiol Infect Dis. 2009;28(12):1471-6. Rec#: 7220. Exclusion Codes: NDE, EXC. [pmid: 19727867].
Steinbach G, Bolke E, Grunert A, Storck M, Orth K. Procalcitonin in patients with acute and chronic renal insufficiency. Wien Klin Wochenschr. 2004;116(24):849-53. Rec#: 3960. Exclusion Codes: NDE, EXC. [pmid: 15690970].
Steinbach G, Grunert A. Procalcitonin--a new indicator for bacterial infections. Exp Clin Endocrinol Diabetes. 1998;106(3):164-7. Rec#: 10770. Exclusion Codes: NDE, EXC. [pmid: 9710354].
Steinbach G, Rau B, Debard AL, Javourez JF, Bienvenu J, Ponzio A, Bonfa A, Hubl W, Demant T, Kulpmann WR, Buchholz J, Schumann G. Multicenter evaluation of a new immunoassay for procalcitonin measurement on the Kryptor System. Clin Chem Lab Med. 2004;42(4):440-9. Rec#: 9600. Exclusion Codes: NDE, EXC. [pmid: 15147156].
Steurer J. Procalcitonin determination as decision support for antibiotic therapy in acute respiratory tract infections. Procalcitonin-bestimmungen als entscheidungshilfe fur antibiotikatherapie bei akuten infekten des respirationstraktes. Schweiz. Rundsch. Med. Prax. 2009;98(23):1383-1384. Rec#: 15690. Exclusion Codes: FLA, EXC.
Stijnis C, van Nieuwkoop C, van Dissel JT. Procalcitonin-based guidelines and lower respiratory tract infections. JAMA. 2010;303(5):418-9. author reply 419-20. Rec#: 7010. Exclusion Codes: NDE, EXC. [pmid: 20124533].
Stolz D, Christ-Crain M, Gencay MM, Bingisser R, Huber PR, Muller B, Tamm M. Diagnostic value of signs, symptoms and laboratory values in lower respiratory tract infection. Swiss Med Wkly. 2006;136(27-28):434-40. Rec#: 8690. Exclusion Codes: NDE, EXC. [pmid: 16862463].
Stolz D, Christ-Crain M, Morgenthaler NG, Leuppi J, Miedinger D, Bingisser R, Muller C, Struck J, Muller B, Tamm M. Copeptin, C-reactive protein, and procalcitonin as prognostic biomarkers in acute exacerbation of COPD. Chest. 2007;131(4):1058-67. Rec#: 2800. Exclusion Codes: NDE, EXC. [pmid: 17426210].
Stolz D, Stulz A, Muller B, Gratwohl A, Tamm M. BAL neutrophils, serum procalcitonin, and C-reactive protein to predict bacterial infection in the immunocompromised host. Chest. 2007;132(2):504-14. Rec#: 8400. Exclusion Codes: NDE, EXC. [pmid: 17573524].
Stolz D, Tamm M. Discriminate use of antibiotics for exacerbation of COPD. Curr Opin Pulm Med. 2009;15(2):126-32. Rec#: 790. Exclusion Codes: NDE, EXC. [pmid: 19532027].
Streit G, Alber D, Toubin MM, Toussirot E, Wendling D. Procalcitonin, C-reactive protein, and complement-3a assays in synovial fluid for diagnosing septic arthritis: preliminary results. Joint Bone Spine. 2008;75(2):238-9. Rec#: 2200. Exclusion Codes: NRO, EXC. [pmid: 18178503].
Striz I, Jaresova M, Lacha J, Sedlacek J, Vitko S. MRP 8/14 and procalcitonin serum levels in organ transplantations. Ann Transplant. 2001;6(2):6-9. Rec#: 10200. Exclusion Codes: NRO, EXC. [pmid: 11803621].
Struck J. Pathobiochemistry and clinical use of procalcitonin. Clin Chim Acta. 2003;328(1-2):199. author reply 201. Rec#: 10030. Exclusion Codes: NRD, EXC. [pmid: 12559620].
Stryjewski GR, Nylen ES, Bell MJ, Snider RH, Becker KL, Wu A, Lawlor C, Dalton H. Interleukin-6, interleukin-8, and a rapid and sensitive assay for calcitonin precursors for the determination of bacterial sepsis in febrile neutropenic children. Pediatr Crit Care Med. 2005;6(2):129-35. Rec#: 3930. Exclusion Codes: NDE, EXC. [pmid: 15730597].
Stucker F, Herrmann F, Graf JD, Michel JP, Krause KH, Gavazzi G. Procalcitonin and infection in elderly patients. J Am Geriatr Soc. 2005;53(8):1392-5. Rec#: 3710. Exclusion Codes: NDE, EXC. [pmid: 16078967].
Suberviola Canas B, Gonzalez Castro A, Fernandez Miret B, Rubio Lopez I, Garcia Astudillo LA. Procalcitonin: An ally in the management of patient subjected to abdominal surgery. Procalcitonina: Un aliado en el manejo del paciente sometido a cirugia abdominal. Rev. Esp. Enferm. Dig. 2009;101(7):513-514. Rec#: 12180. Exclusion Codes: NRO, EXC. [pmid: 19642849].
Summah H, Qu JM. Biomarkers: a definite plus in pneumonia. Mediators Inflamm. 2009;2009:675753. Rec#: 7090. Exclusion Codes: NDE, EXC. [pmid: 20011658].
Summerton N. Diagnostic testing: the importance of context. Br J Gen Pract. 2007;57(541):678-9. Rec#: 8320. Exclusion Codes: NDE, EXC. [pmid: 17688774].
Sun B, Xu F, Yu W. Sepsis and septic shock study in pediatric critical care: An overview of recent Chinese literature. J. Pediatr. Infect. Dis. 2009;4(2):147-152. Rec#: 12340. Exclusion Codes: NDE, EXC.
Suprin E, Camus C, Gacouin A, Le Tulzo Y, Lavoue S, Feuillu A, Thomas R. Procalcitonin: a valuable indicator of infection in a medical ICU?. Intensive Care Med. 2000;26(9):1232-8. Rec#: 5950. Exclusion Codes: NDE, EXC. [pmid: 11089747].
Suzuki N, Mizuno H, Nezu M, Takai Y, Misu T, Kuroda H, Aoki M, Nakashima I, Itoyama Y. Procalcitonin might help in discrimination between meningeal neuro-Behcet disease and bacterial meningitis. Neurology. 2009;72(8):762-3. Rec#: 7540. Exclusion Codes: NRO, EXC. [pmid: 19237707].
Svaldi M, Hirber J, Lanthaler AI, Mayr O, Faes S, Peer E, Mitterer M. Procalcitonin-reduced sensitivity and specificity in heavily leucopenic and immunosuppressed patients. Br J Haematol. 2001;115(1):53-7. Rec#: 5610. Exclusion Codes: NDE, EXC. [pmid: 11722409].
Szakmany T, Molnar Z. Procalcitonin levels do not predict mortality following major abdominal surgery. Can J Anaesth. 2003;50(10):1082-3. Rec#: 4540. Exclusion Codes: NDE, EXC. [pmid: 14656802].
Takubo T, Kumura T, Ohta K, Yamane T, Hino M, Kamitani T, Tatsumi N. Elevation of serum procalcitonin level in a patient with chronic myelocytic leukemia. Haematologia (Budap). 2001;31(2):177-9. Rec#: 10240. Exclusion Codes: NDE, EXC. [pmid: 11583031].
Tamaki K, Kogata Y, Sugiyama D, Nakazawa T, Hatachi S, Kageyama G, Nishimura K, Morinobu A, Kumagai S. Diagnostic accuracy of serum procalcitonin concentrations for detecting systemic bacterial infection in patients with systemic autoimmune diseases. J Rheumatol. 2008;35(1):114-9. Rec#: 8190. Exclusion Codes: SMN, EXC. [pmid: 18050369].
Tang BM, Eslick GD. Procalcitonin for sepsis: methodological issues in meta-analysis lead to further uncertainty. Crit Care Med. 2007;35(2):679. author reply 679-80. Rec#: 2980. Exclusion Codes: NDE, EXC. [pmid: 17251741].
Tang BM, Eslick GD, Craig JC, McLean AS. Accuracy of procalcitonin for sepsis diagnosis in critically ill patients: systematic review and meta-analysis. Lancet Infect Dis. 2007;7(3):210-7. Rec#: 2920. Exclusion Codes: NDE, EXC. [pmid: 17317602].
Tang H, Huang T, Jing J, Shen H, Cui W. Effect of procalcitonin-guided treatment in patients with infections: a systematic review and meta-analysis. Infection. 2009;37(6):497-507. Rec#: 400. Exclusion Codes: NDE, EXC. [pmid: 19826761].
Tasabehji WR, Al-Quobaili FA, Al-Daher NA. Usefulness of procalcitonin and some inflammatory parameters in septic patients. Saudi Med J. 2008;29(4):520-5. Rec#: 1940. Exclusion Codes: NRD, EXC. [pmid: 18382791].
Tasci C, Balkan A, Karadurmus N, Inal S, Kilic S, Ozkan M, Bigic H, Ekiz K. The importance of serum procalcitonin levels in patients with chronic obstructive pulmonary disease exacerbations. Turk. J. Med. Sci. 2008;38(2):139-144. Rec#: 12980. Exclusion Codes: SMN, EXC.
Tasdelen Fisgin N, Aliyazicioglu Y, Tanyel E, Coban AY, Ulger F, Zivalioglu M, Esen S, Leblebicioglu H. The value of neopterin and procalcitonin in patients with sepsis. South Med J. 2010;103(3):216-9. Rec#: 180. Exclusion Codes: SMN, EXC. [pmid: 20134373].
Taskin E, Turgut M, Kilic M, Akbulut H, Aygun AD. Serum procalcitonin and cerebrospinal fluid cytokines level in children with meningitis. Mediators Inflamm. 2004;13(4):269-73. Rec#: 9430. Exclusion Codes: SMN, EXC. [pmid: 15545058].
ten Boekel E, Vroonhof K, Huisman A, van Kampen C, de Kieviet W. Clinical laboratory findings associated with in-hospital mortality. Clin Chim Acta. 2006;372(1-2):1-13. Rec#: 3350. Exclusion Codes: NDE, EXC. [pmid: 16697361].
Tessmer M. Community-acquired lower respiratory tract infections/community-acquired pneumonias in adult patients - Diagnosis, antimicrobial therapy and management: Recommendations of the current S3 guideline. Ambulant erworbene untere atemwegs-infektionen/ambulant erworbene pneumonien bei erwachsenen patienten - Diagnostik, antimikrobielle therapie und management: Empfehlungen der aktuellen S3-leitlinie. Arzneimitteltherapie. 2010;28(2):60-67. Rec#: 11810. Exclusion Codes: NRD, EXC.
Thayyil S, Shenoy M, Hamaluba M, Gupta A, Frater J, Verber IG. Is procalcitonin useful in early diagnosis of serious bacterial infections in children?. Acta Paediatr. 2005;94(2):155-8. Rec#: 3780. Exclusion Codes: SMN, EXC. [pmid: 15981747].
Thia KT, Chan ES, Ling KL, Ng WY, Jacob E, Ooi CJ. Role of procalcitonin in infectious gastroenteritis and inflammatory bowel disease. Dig Dis Sci. 2008;53(11):2960-8. Rec#: 7960. Exclusion Codes: SMN, EXC. [pmid: 18415679].
Thiemermann C. What's new in SHOCK, October 2007?. Shock. 2007;28(4):371-374. Rec#: 13220. Exclusion Codes: NRD, EXC.
Toikka P, Irjala K, Juven T, Virkki R, Mertsola J, Leinonen M, Ruuskanen O. Serum procalcitonin, C-reactive protein and interleukin-6 for distinguishing bacterial and viral pneumonia in children. Pediatr Infect Dis J. 2000;19(7):598-602. Rec#: 10550. Exclusion Codes: NDE, EXC. [pmid: 10917215].
Tollens M, Westerholt S, Oberhoffer M, Klare B, Emmrich P, Oberhoffer R. Procalcitonin in children with hemolytic uremic syndrome (HUS) - First clinical experiences. Procalcitonin bei kindern mit hamolytisch-uramischem syndrom (HUS): Erste klinische erfahrungen. Monatsschr. Kinderheilkd. 1999;147(4):373-376. Rec#: 17070. Exclusion Codes: NDE, EXC.
Topolcan O, Bartunek L, Holubec L Jr., Polivkova V, Casova M, Hajek T, Wolfe OJ. Importance of procalcitonin in post-cardiosurgical patients. J. Clin. Ligand Assay. 2008;31(1-4):57-60. Rec#: 12590. Exclusion Codes: NDE, EXC.
Torbe A. Maternal plasma procalcitonin concentrations in pregnancy complicated by preterm premature rupture of membranes. Mediators Inflamm. 2007;2007:35782. Rec#: 8290. Exclusion Codes: NDE, EXC. [pmid: 17710246].
Torbe A, Czajka R. Maternal plasma procalcitonin concentrations in patients with preterm labor and intact membranes--prediction of preterm delivery and admission-to-delivery interval. J Perinat Med. 2004;32(4):332-6. Rec#: 9520. Exclusion Codes: SMN, EXC. [pmid: 15346819].
Trallero-Araguas E, Selva-O'Callaghan A, Vilardell-Tarres M. Serum procalcitonin levels in febrile patients with systemic autoimmune diseases. Curr. Rheumatol. Rev. 2007;3(2):103-111. Rec#: 13370. Exclusion Codes: NDE, EXC.
Trelinska J, Stolarska M, Zalewska-Szewczyk B, Wyka K, Pastorczak A, Mlynarski W. Hypophosphatemia correlates with high procalcitonin level in bacterial infections in children with cancer. Hipofosfatemia koreluje z wysokimi stezeniami prokalcytoniny w przebiegu zakazen bakteryjnych u dzieci leczonych z powodu choroby nowotoworowej. Acta Haematol. Pol. 2008;39(3):469-475. Rec#: 12580. Exclusion Codes: NRD, EXC.
Tsangaris I, Plachouras D, Kavatha D, Gourgoulis GM, Tsantes A, Kopterides P, Tsaknis G, Dimopoulou I, Orfanos S, Giamarellos-Bourboulis E, Giamarellou H, Armaganidis A. Diagnostic and prognostic value of procalcitonin among febrile critically ill patients with prolonged ICU stay. BMC Infect Dis. 2009;9:213. Rec#: 290. Exclusion Codes: SMN, EXC. [pmid: 20028533].
Tschaikowsky K, Hedwig-Geissing M, Schiele A, Bremer F, Schywalsky M, Schuttler J. Coincidence of pro- and anti-inflammatory responses in the early phase of severe sepsis: Longitudinal study of mononuclear histocompatibility leukocyte antigen-DR expression, procalcitonin, C-reactive protein, and changes in T-cell subsets in septic and postoperative patients. Crit Care Med. 2002;30(5):1015-23. Rec#: 5330. Exclusion Codes: NRO, EXC. [pmid: 12006796].
Tseng JS, Chan MC, Hsu JY, Kuo BI, Wu CL. Procalcitonin is a valuable prognostic marker in ARDS caused by community-acquired pneumonia. Respirology. 2008;13(4):505-9. Rec#: 7940. Exclusion Codes: SMN, EXC. [pmid: 18422867].
Tsokos M. Postmortem measurement of serum procalcitonin concentration in Waterhouse-Friderichsen syndrome. Virchows Arch. 2002;441(6):629-31. Rec#: 10010. Exclusion Codes: NDE, EXC. [pmid: 12587602].
Tsokos M. Fatal Waterhouse-Friderichsen syndrome due to Ewingella americana infection. Am J Forensic Med Pathol. 2003;24(1):41-4. Rec#: 4980. Exclusion Codes: NRO, EXC. [pmid: 12604997].
Tsokos M, Reichelt U, Nierhaus A, Puschel K. Serum procalcitonin (PCT): a valuable biochemical parameter for the post-mortem diagnosis of sepsis. Int J Legal Med. 2001;114(4-5):237-43. Rec#: 5790. Exclusion Codes: NRO, EXC. [pmid: 11355402].
Tugrul S, Esen F, Celebi S, Ozcan PE, Akinci O, Cakar N, Telci L. Reliability of procalcitonin as a severity marker in critically ill patients with inflammatory response. Anaesth Intensive Care. 2002;30(6):747-54. Rec#: 5040. Exclusion Codes: SMN, EXC. [pmid: 12500512].
Tugrul S, Ozcan PE, Akinci O, Seyhun Y, Cagatay A, Cakar N, Esen F. The effects of IgM-enriched immunoglobulin preparations in patients with severe sepsis. Crit Care. 2002;6(4):357-62. Rec#: 5140. Exclusion Codes: SMN, EXC. [pmid: 12225613].
Turner D, Hammerman C, Rudensky B, Schlesinger Y, Goia C, Schimmel MS. Procalcitonin in preterm infants during the first few days of life: introducing an age related nomogram. Arch Dis Child Fetal Neonatal Ed. 2006;91(4):F283-6. Rec#: 3400. Exclusion Codes: NRO, EXC. [pmid: 16547079].
Turner D, Hammerman C, Rudensky B, Schlesinger Y, Schimmel MS. The role of procalcitonin as a predictor of nosocomial sepsis in preterm infants. Acta Paediatr. 2006;95(12):1571-6. Rec#: 3050. Exclusion Codes: NDE, EXC. [pmid: 17129964].
Turner D, Hammerman C, Rudensky B, Schlesinger Y, Wine E, Muise A, Schimmel MS. Low levels of procalcitonin during episodes of necrotizing enterocolitis. Dig Dis Sci. 2007;52(11):2972-6. Rec#: 2830. Exclusion Codes: NDE, EXC. [pmid: 17393328].
Turton P. Ventilator-associated pneumonia in paediatric intensive care: a literature review. Nurs Crit Care. 2008;13(5):241-8. Rec#: 1390. Exclusion Codes: NDE, EXC. [pmid: 18816310].
Ucar B, Yildiz B, Aksit MA, Yarar C, Colak O, Akbay Y, Colak E. Serum amyloid A, procalcitonin, tumor necrosis factor-alpha, and interleukin-1beta levels in neonatal late-onset sepsis. Mediators Inflamm. 2008;2008:737141. Rec#: 1230. Exclusion Codes: NDE, EXC. [pmid: 19043563].
Uettwiller-Geiger DL. Clinical applications of procalcitonin (PCT). J. Clin. Ligand Assay. 2007;30(1-2):20-28. Rec#: 13490. Exclusion Codes: NDE, EXC.
Ugarte H, Silva E, Mercan D, De Mendonca A, Vincent JL. Procalcitonin used as a marker of infection in the intensive care unit. Crit Care Med. 1999;27(3):498-504. Rec#: 6540. Exclusion Codes: NDE, EXC. [pmid: 10199528].
Uys A, Rapoport BL, Fickl H, Meyer PW, Anderson R. Prediction of outcome in cancer patients with febrile neutropenia: comparison of the Multinational Association of Supportive Care in Cancer risk-index score with procalcitonin, C-reactive protein, serum amyloid A, and interleukins-1beta, -6, -8 and -10. Eur J Cancer Care (Engl). 2007;16(6):475-83. Rec#: 2330. Exclusion Codes: NDE, EXC. [pmid: 17944761].
Uzun G, Solmazgul E, Curuksulu H, Turhan V, Ardic N, Top C, Yildiz S, Cimsit M. Procalcitonin as a diagnostic aid in diabetic foot infections. Tohoku J Exp Med. 2007;213(4):305-12. Rec#: 2260. Exclusion Codes: SMN, EXC. [pmid: 18075234].
Uzzan B, Cohen R, Nicolas P, Cucherat M, Perret GY. Procalcitonin as a diagnostic test for sepsis in critically ill adults and after surgery or trauma: a systematic review and meta-analysis. Crit Care Med. 2006;34(7):1996-2003. Rec#: 3320. Exclusion Codes: NDE, EXC. [pmid: 16715031].
Uzzan B, Izri A, Durand R, Deniau M, Bouchaud O, Perret GY. Serum procalcitonin in uncomplicated falciparum malaria: a preliminary study. Travel Med Infect Dis. 2006;4(2):77-80. Rec#: 3220. Exclusion Codes: SMN, EXC. [pmid: 16887728].
Valencia M, Torres A. Ventilator-associated pneumonia. Curr. Opin. Crit. Care. 2009;15(1):30-35. Rec#: 15980. Exclusion Codes: NDE, EXC. [pmid: 19186407].
Valenta J, Jabor A, Brodska H, Stach Z, Kazda A, Stritesky M. Analysis of the specificity and sensitivity of procalcitonin in relation to other markers of inflammation in critically ill patients. Analyza specificity a senzitivity prokalcitoninu ve srovnani s dalsimi markery zanetu u kriticky nemocnych. Anesteziol. Intenzivni Med. 2006;17(3):164-170. Rec#: 13600. Exclusion Codes: NRD, EXC.
Vallianou N, Koutalas P. Procalcitonin and infections. Arch. Hell. Med. 2008;25(5):602-604. Rec#: 12760. Exclusion Codes: NDE, EXC.
van den Broek MA, Olde Damink SW, Winkens B, Broelsch CE, Malago M, Paul A, Saner FH. Procalcitonin as a prognostic marker for infectious complications in liver transplant recipients in an intensive care unit. Liver Transpl. 2010;16(3):402-10. Rec#: 140. Exclusion Codes: NDE, EXC. [pmid: 20209599].
Van der Kaay DC, De Kleijn ED, De Rijke YB, Hop WC, De Groot R, Hazelzet JA. Procalcitonin as a prognostic marker in meningococcal disease. Intensive Care Med. 2002;28(11):1606-12. Rec#: 5060. Exclusion Codes: SMN, EXC. [pmid: 12415448].
Van Der Kaay DCM, De Kleijn ED, De Groot R, Hazelzet JA, De Rijke YB. BRAHMS PCT (registered trademark)-Q semi-quantitative test method to determine procalcitonin in children with meningococcal disease. BRAHMS PCT(registered trademark)-Q semi-kwantitatieve test voor procalcitoninebepaling bij kinderen met meningokokkenziekte. Ned. Tijdschr. Klin. Chem. Lab. Geneeskd. 2004;29(6):308-313. Rec#: 14160. Exclusion Codes: NRD, EXC.
van Dissel JT. Procalcitonin and other markers of infection. What should be their role in clinical practice?. Clin Microbiol Infect. 2002;8(2):70-3. Rec#: 5400. Exclusion Codes: NDE, EXC. [pmid: 11952718].
van Dissel JT. Procalcitonin: what should be its role in the clinical management of febrile patients admitted to the hospital?. Clin Infect Dis. 2003;36(6):824-5. author reply 826-7. Rec#: 4940. Exclusion Codes: NDE, EXC. [pmid: 12627372].
van Langevelde P, Joop K, van Loon J, Frolich M, Groeneveld PH, Westendorp RG, van Dissel JT. Endotoxin, cytokines, and procalcitonin in febrile patients admitted to the hospital: identification of subjects at high risk of mortality. Clin Infect Dis. 2000;31(6):1343-8. Rec#: 5930. Exclusion Codes: NDE, EXC. [pmid: 11096000].
van Oers JA, Tulleken JE, Zijlstra JG. Does serum procalcitonin have a diagnostic value in febrile adult patients presenting to the emergency department?. Crit Care. 2007;11(6):422. author reply 422. Rec#: 8160. Exclusion Codes: NDE, EXC. [pmid: 18086319].
van Rossum AM, Wulkan RW, Oudesluys-Murphy AM. Procalcitonin as an early marker of infection in neonates and children. Lancet Infect Dis. 2004;4(10):620-30. Rec#: 4110. Exclusion Codes: NDE, EXC. [pmid: 15451490].
Vandewoude MFJ. Infections in older people. Aging Health. 2007;3(6):711-714. Rec#: 13150. Exclusion Codes: NRD, EXC.
Vandijck DM, Brusselaers N, Blot SI. Inflammatory markers in patients with severe burn injury: what is the best indicator of sepsis?. Burns. 2007;33(7):939-40. author reply 941-2. Rec#: 2610. Exclusion Codes: NRD, EXC. [pmid: 17644262].
Vassilopoulou S, Antonopoulou A, Giamarellos-Bourboulis EJ, Plachouras D, Raftogiannis M, Tsaganos T, Baziaka F, Syriopoulou V, Giamarellou H. Is there any role for innate immunity in the pathogenesis of bacterial and abacterial meningitis?. Infect. Dis. Clin. Pract. 2006;14(1):17-22. Rec#: 16540. Exclusion Codes: NRO, EXC.
Vazzalwar R, Pina-Rodrigues E, Puppala BL, Angst DB, Schweig L. Procalcitonin as a screening test for late-onset sepsis in preterm very low birth weight infants. J Perinatol. 2005;25(6):397-402. Rec#: 3850. Exclusion Codes: NDE, EXC. [pmid: 15830005].
Vega VL. A marker for posttraumatic-sepsis: Searching for the Holy Grail around intensive care units. Crit. Care Med. 2009;37(5):1806-1807. Rec#: 12270. Exclusion Codes: NDE, EXC. [pmid: 19373052].
Venkatesh B, Kennedy P, Kruger PS, Looke D, Jones M, Hall J, Barruel GR. Changes in serum procalcitonin and C-reactive protein following antimicrobial therapy as a guide to antibiotic duration in the critically ill: a prospective evaluation. Anaesth Intensive Care. 2009;37(1):20-6. Rec#: 1070. Exclusion Codes: SMN, EXC. [pmid: 19157341].
Verboon-Maciolek MA, Thijsen SF, Hemels MA, Menses M, van Loon AM, Krediet TG, Gerards LJ, Fleer A, Voorbij HA, Rijkers GT. Inflammatory mediators for the diagnosis and treatment of sepsis in early infancy. Pediatr Res. 2006;59(3):457-61. Rec#: 3440. Exclusion Codes: NDE, EXC. [pmid: 16492989].
Verheij T. Excessive use of antibiotics still a relevant problem in the Netherlands as well. Overmatig gebruik van antibiotica ook in Nederland nog een relevant probleem. Huisarts Wet. 2009;52(12):570-571. Rec#: 15770. Exclusion Codes: NDE, EXC.
Verner L, Czaja E, Szabo M, Maravic-Stojkovic V. Relation between pro-calcitonin levels with apache II-score in intensive care unit patients. Korelacija prokalcitonina sa apache-II klasifikacionim sistemom kod pacijenata na jedinici za intenzivnu negu. Jugosl. Med. Biokem. 1999;18(1):23-28. Rec#: 15110. Exclusion Codes: NDE, EXC.
Viallon A, Guyomarc'h P, Guyomarc'h S, Tardy B, Robert F, Marjollet O, Caricajo A, Lambert C, Zeni F, Bertrand JC. Decrease in serum procalcitonin levels over time during treatment of acute bacterial meningitis. Crit Care. 2005;9(4):R344-50. Rec#: 9050. Exclusion Codes: NRO, EXC. [pmid: 16137346].
Viallon A, Guyomarc'h S, Marjollet O, Berger C, Carricajo A, Robert F, Laporte S, Lambert C, Page Y, Zeni F, Bertrand JC. Can emergency physicians identify a high mortality subgroup of patients with sepsis: role of procalcitonin. Eur J Emerg Med. 2008;15(1):26-33. Rec#: 2190. Exclusion Codes: NDE, EXC. [pmid: 18180663].
Viallon A, Guyomarc'h S, Zeni F, Piteaud I, Lucht F, Levy M, Cotte L, Aubert G, Bertrand JC. Serum procalcitonin and cerebrospinal fluid lactate levels in emergency room differential diagnosis of acute meningitis with a negative Gram stain. Meningites aigues de l'adulte a examen direct negatif: Interet de la procalcitonine serique et de l'acide lactique cephalo-rachidien dans la prise en charge diagnostique en urgence. JEUR. 2003;16(1):4-12. Rec#: 16820. Exclusion Codes: NDE, EXC.
Viallon A, Zeni F, Lambert C, Pozzetto B, Tardy B, Venet C, Bertrand JC. High sensitivity and specificity of serum procalcitonin levels in adults with bacterial meningitis. Clin Infect Dis. 1999;28(6):1313-6. Rec#: 10690. Exclusion Codes: NDE, EXC. [pmid: 10451174].
Viallon A, Zeni F, Pouzet V, Lambert C, Quenet S, Aubert G, Guyomarch S, Tardy B, Bertrand JC. Serum and ascitic procalcitonin levels in cirrhotic patients with spontaneous bacterial peritonitis: diagnostic value and relationship to pro-inflammatory cytokines. Intensive Care Med. 2000;26(8):1082-8. Rec#: 10500. Exclusion Codes: SMN, EXC. [pmid: 11030164].
Villanueva JL, Cervin RJ. Serum procalcitonin levels and empirical antibiotic treatment of patients with community-acquired febrile syndromes. Clin Infect Dis. 2003;36(6):822. author reply 826-7. Rec#: 9980. Exclusion Codes: NDE, EXC. [pmid: 12627370].
Vincent JL, Vannuffelen M, Zakariah A. Sepsis: Current state of play. Crit. Care Shock. 2004;7(1):1-4. Rec#: 14270. Exclusion Codes: NDE, EXC.
Volante E, Moretti S, Pisani F, Bevilacqua G. Early diagnosis of bacterial infection in the neonate. J Matern Fetal Neonatal Med. Suppl 2. 2004;16:13-6. Rec#: 4040. Exclusion Codes: NDE, EXC. [pmid: 15590427].
Volk HD, Reinke P, Docke WD. Immunological monitoring of the inflammatory process: Which variables? When to assess?. Eur J Surg Suppl. 1999;(584):70-2. Rec#: 6100. Exclusion Codes: NDE, EXC. [pmid: 10890238].
von Heimburg D, Stieghorst W, Khorram-Sefat R, Pallua N. Procalcitonin--a sepsis parameter in severe burn injuries. Burns. 1998;24(8):745-50. Rec#: 6600. Exclusion Codes: NRO, EXC. [pmid: 9915676].
von Lilienfeld-Toal M, Dietrich MP, Glasmacher A, Lehmann L, Breig P, Hahn C, Schmidt-Wolf IG, Marklein G, Schroeder S, Stuber F. Markers of bacteremia in febrile neutropenic patients with hematological malignancies: procalcitonin and IL-6 are more reliable than C-reactive protein. Eur J Clin Microbiol Infect Dis. 2004;23(7):539-44. Rec#: 4280. Exclusion Codes: NDE, EXC. [pmid: 15221617].
von Lilienfeld-Toal M, Schneider A, Orlopp K, Hahn-Ast C, Glasmacher A, Stuber F. Change of procalcitonin predicts clinical outcome of febrile episodes in patients with hematological malignancies. Support Care Cancer. 2006;14(12):1241-5. Rec#: 3300. Exclusion Codes: SMN, EXC. [pmid: 16733657].
Wagner F. Immunomonitoring in sepsis: Immunmonitoring bei sepsis. Z. Herz- Thorax- Gefasschir. 2003;17(4):185-190. Rec#: 14400. Exclusion Codes: NDE, EXC.
Wanner GA, Keel M, Steckholzer U, Beier W, Stocker R, Ertel W. Relationship between procalcitonin plasma levels and severity of injury, sepsis, organ failure, and mortality in injured patients. Crit Care Med. 2000;28(4):950-7. Rec#: 6180. Exclusion Codes: NDE, EXC. [pmid: 10809265].
Watkin RW, Harper LV, Vernallis AB, Lang S, Lambert PA, Ranasinghe AM, Elliott TS. Pro-inflammatory cytokines IL6, TNF-alpha, IL1beta, procalcitonin, lipopolysaccharide binding protein and C-reactive protein in infective endocarditis. J Infect. 2007;55(3):220-5. Rec#: 8380. Exclusion Codes: NRO, EXC. [pmid: 17586049].
Weinberg GA, D'Angio CT. The search for new diagnostic tests for neonatal sepsis. J. Pediatr. 2009;155(5):763-764. Rec#: 12020. Exclusion Codes: NRD, EXC. [pmid: 19840628].
Werner J, Hartwig W, Uhl W, Muller C, Buchler MW. Useful markers for predicting severity and monitoring progression of acute pancreatitis. Pancreatology. 2003;3(2):115-27. Rec#: 9920. Exclusion Codes: NDE, EXC. [pmid: 12748420].
Werner M, Otto U, Schreiter D, Lamesch P, Kohlhaw K, Witzigmann H, Hauss J, Fiedler M, Thiery J. The Immunological Patient at Risk in Sepsis and Transplantation. Der Immunologische Risikopatient bei Sepsis und Transplantation. Transplantationsmed. Organ Dtsch. Transplantationsges. 2003;15(2):70-90. Rec#: 14300. Exclusion Codes: NDE, EXC.
Whang KT, Steinwald PM, White JC, Nylen ES, Snider RH, Simon GL, Goldberg RL, Becker KL. Serum calcitonin precursors in sepsis and systemic inflammation. J Clin Endocrinol Metab. 1998;83(9):3296-301. Rec#: 6680. Exclusion Codes: SMN, EXC. [pmid: 9745444].
Wolk DM, Fiorello AB. Code Sepsis: Rapid Methods To Diagnose Sepsis and Detect Hematopathogens. Part II: Challenges to the Laboratory Diagnosis of Sepsis. Clin. Microbiol. Newsl. 2010;32(6):41-49. Rec#: 11680. Exclusion Codes: NDE, EXC.
Worthington T, Dunlop D, Casey A, Lambert P, Luscombe J, Elliott T. Serum procalcitonin, interleukin-6, soluble intercellular adhesin molecule-1 and IgG to short-chain exocellular lipoteichoic acid as predictors of infection in total joint prosthesis revision. Br. J. Biomed. Sci. 2010;67(2):71-76. Rec#: 11290. Exclusion Codes: NDE, EXC. [pmid: 20669762].
Wroblewski T, Marcisz C. Procalcitonin as a biomarker of acute lower respiratory tract infections. Expert Opin. Med. Diagn. 2009;3(1):67-79. Rec#: 12460. Exclusion Codes: NDE, EXC.
Wunder C, Eichelbronner O, Roewer N. Are IL-6, IL-10 and PCT plasma concentrations reliable for outcome prediction in severe sepsis? A comparison with APACHE III and SAPS II. Inflamm Res. 2004;53(4):158-63. Rec#: 4410. Exclusion Codes: SMN, EXC. [pmid: 15060722].
Yaegashi Y, Shirakawa K, Sato N, Suzuki Y, Kojika M, Imai S, Takahashi G, Miyata M, Furusako S, Endo S. Evaluation of a newly identified soluble CD14 subtype as a marker for sepsis. J Infect Chemother. 2005;11(5):234-8. Rec#: 3610. Exclusion Codes: NDE, EXC. [pmid: 16258819].
Yamada H, Matsuda S, Ushio Y, Nakamura K, Kobatake S, Satomura S, Matsuura S. Determination of procalcitonin concentration using the SphereLight 180 clinical auto-analyzer. Clin Chim Acta. 2008;388(1-2):38-40. Rec#: 2280. Exclusion Codes: NRD, EXC. [pmid: 18021760].
Yan SY. Premonitor indexes for early diagnosis of sepsis. Chin. Crit. Care Med. 2009;21(3):185-188. Rec#: 12410. Exclusion Codes: NDE, EXC.
Yealy DM, Fine MJ. Measurement of serum procalcitonin: a step closer to tailored care for respiratory infections?. JAMA. 2009;302(10):1115-6. Rec#: 7210. Exclusion Codes: NDE, EXC. [pmid: 19738100].
Yildiz C, Yildiz H, Kavuncuoglu S, Siraneci R. Procalcitonin levels in the diagnosis of early neonatal sepsis. Yenidogan sepsisin erken tanisinda prokalsitonin. Cocuk Sagligi Hast. Derg. 2003;46(2):90-97. Rec#: 14420. Exclusion Codes: NDE, EXC.
Yildiz O, Aygen B. The role of procalcitonin in diagnosis and following of infectious diseases. Infeksiyon hastaliklarinin tani ve takibinde prokalsitoninin yeri. Erciyes Tip Derg. 2000;22(2):105-109. Rec#: 14800. Exclusion Codes: NDE, EXC.
Yilmaz FM, Yilmaz G, Akay H, Duranay M, Yucel D. Evaluation of a card test for procalcitonin in continuous ambulatory peritoneal dialysis peritonitis. Ann Clin Biochem. 2007;44(Pt 5):482-4. Rec#: 8260. Exclusion Codes: SMN, EXC. [pmid: 17761036].
Yoshihara T, Imamura T, Yokoi K, Shibata M, Kano G, Osone S, Yagi K, Todo S, Murakami Y, Yamada Y, Yamada H, Satomura S, Ishida H. Potential use of procalcitonin concentrations as a diagnostic marker of the PFAPA syndrome. Eur J Pediatr. 2007;166(6):621-2. Rec#: 3110. Exclusion Codes: NRO, EXC. [pmid: 17013596].
Yukioka H, Yoshida G, Kurita S, Kato N. Plasma procalcitonin in sepsis and organ failure. Ann Acad Med Singapore. 2001;30(5):528-31. Rec#: 5650. Exclusion Codes: NRO, EXC. [pmid: 11603140].
Zahedpasha Y, Ahmadpour-Kacho M, Hajiahmadi M, Haghshenas M. Procalcitonin as a marker of neonatal sepsis. Iran. J. Pediatr. 2009;19(2):117-122. Rec#: 12170. Exclusion Codes: NDE, EXC.
Zahorec R, Setvak D, Cintula D, Belovicova C, Blaskova A. Renal rescue therapy in early stage of severe sepsis: a case study approach. Bratisl Lek Listy. 2004;105(10-11):345-52. Rec#: 3990. Exclusion Codes: NDE, EXC. [pmid: 15658572].
Zakariah AN, Cozzi SM, Van Nuffelen M, Clausi CM, Pradier O, Vincent JL. Combination of biphasic transmittance waveform with blood procalcitonin levels for diagnosis of sepsis in acutely ill patients. Crit Care Med. 2008;36(5):1507-12. Rec#: 1840. Exclusion Codes: NDE, EXC. [pmid: 18434897].
Zazula R, Prucha M, Spaleny A, Jaresova M, Vitko S. Procalcitonin not only in the differential diagnosis of the inflammatory response. Prokalcitonin nejen v diferencialni diagnostice zanetlive odpovedi organismu. Anesteziol. Neodkladna Pece. 2002;13(2):86-91. Rec#: 14640. Exclusion Codes: NRD, EXC.
Zeglen S, Wojarski J, Wozniak-Grygiel E, Siola M, Szewczyk M, Kucewicz-Czech E, Nozynski J, Zembala M. Procalcitonin serum concentration during Pneumocystis jiroveci colonization or Pseudomonas aeruginosa infection/colonization in lung transplant recipients. Transplant Proc. 2009;41(8):3225-7. Rec#: 380. Exclusion Codes: NRO, EXC. [pmid: 19857716].
Zeitoun AA, Gad SS, Attia FM, Abu Maziad AS, Bell EF. Evaluation of neutrophilic CD64, interleukin 10 and procalcitonin as diagnostic markers of early- and late-onset neonatal sepsis. Scand J Infect Dis. 2010;42(4):299-305. Rec#: 220. Exclusion Codes: NDE, EXC. [pmid: 20085423].
Zhang D, Lavaux T, Voegeli AC, Lavigne T, Castelain V, Meyer N, Sapin R, Aunis D, Metz-Boutigue MH, Schneider F. Prognostic value of chromogranin A at admission in critically ill patients: a cohort study in a medical intensive care unit. Clin Chem. 2008;54(9):1497-503. Rec#: 1480. Exclusion Codes: NDE, EXC. [pmid: 18635750].
Zycinska K, Wardyn KA, Zielonka TM, Tyszko P, Straburzynski M. Procalcitonin as an indicator of systemic response to infection in active pulmonary Wegener's granulomacytosis. J Physiol Pharmacol. Suppl 6. 2008;59:839-44. Rec#: 7530. Exclusion Codes: NRO, EXC. [pmid: 19218712].