# Search Strategy

The following electronic databases were searched for citations.

- MEDLINE® (inception [1948] through December 16, 2011)
- EMBASE® (inception [1974] through December 16, 2011)
- Cochrane Controlled Trials Register (no date restriction)

MEDLINE search 12/16/11
1. procalcitonin
2. “Systemic Inflammatory Response Syndrome”[MeSH] OR “Pulmonary Disease, Chronic Obstructive”[MeSH] OR “Surgical Wound Infection”[MeSH] OR “Critical Illness”[MeSH] OR “Intensive Care”[MeSH]
3. (“Neutropenia”[MeSH] OR neutropenia) AND febrile
4. sepsis OR septic OR “systematic inflammatory response syndrome” OR ICU OR “critically ill” OR “intensive care unit” OR “postoperative infection*”
5. “Postoperative Complications”[MeSH] OR “Intensive Care Units”[MeSH] Limits: Humans, English
6. (2 OR 3 OR 4 OR 5) AND Limits: Humans, English
7. 1 AND 6 Limits: Humans, English
8. A second result set was created in the database with set number 1 NOT set 7

EMBASE search 12/16/11
1. procalcitonin AND Limit: Humans NOT MEDLINE
2. ‘sepsis’/exp OR septic OR ‘systemic inflammatory response syndrome’/exp OR ‘copd’/exp OR ‘chronic obstructive pulmonary disease’/exp OR ‘febrile neutropenia’/exp OR ‘postoperative infection’/exp OR ‘postoperative infections’/exp OR ‘postoperative complications’/exp OR ‘post-surgical infection’ OR ‘post-surgical infections’ OR ‘critically ill’/exp OR icu OR ‘intensive care’/exp OR ‘intensive care units’/exp AND Limit: Humans
3. 1 AND 2
4. 1 NOT 3

## Search Strategy For Gray Literature

### Regulatory Information

FDA
- Source: http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfpmn/pmn.cfm
- Date searched: 6/3/2011
- Search strategy: key word “procalcitonin assay”
- Records: 3

### Clinical trial registries

NIH database
- Source: http://clinicaltrials.gov/
- Date searched: 7/06/2011
- Search strategy: Procalcitonin [ALL-FIELDS] AND “Completed” [OVERALL-STATUS]
- Records: 29

BioMed central
- Source: http://www.controlled-trials.com/mrct/
- Date searched: 6/16/2011
- Search strategy: “Procalcitonin” for completed trials
- Records:7

PhRMA
- Source: http://www.clinicalstudyresults.org/home/
- Date searched: 6/16/2011
- Search strategy: Search String = “Procalcitonin”
- Records: 0

WHO International Clinical Trials Registry Platform Search Portal
- Source: http://apps.who.int/trialsearch/
- Date searched: 6/16/2011
- Search strategy: Search String = “Procalcitonin” for ALL recruitment status trials
- Records: 55

### Conference papers and abstracts

Cambridge scientific abstracts
- Source: http://www.csa.com/factsheets/cpi-set-c.php
- Date searched: 6/28/2011
- Search strategy: search string “procalcitonin”
- Records:41

Scopus
- Source: http://www.scopus.com/home.url
- Date searched:6/29/2011
- Search strategy:
  1. TITLE-ABS-KEY(sepsis) RESULT 93,988
  2. TITLE-ABS-KEY(biomarker* OR procalcitonin) RESULT 73,083
  3. TITLE-ABS-KEY(screen* OR test*) RESULT 3,391,802
  4. (TITLE-ABS-KEY(sepsis) AND (TITLE-ABS-KEY(biomarker* OR procalcitonin)) AND (TITLE-ABS-KEY(screen* OR test*) RESULT 538
- LIMIT: SUBJAREA(mult OR agri OR bioc OR immu OR neur OR phar OR mult OR medi OR nurs OR vete OR dent OR heal)
- Records:376

Specific conferences and association meetings
- Source:
- Annual meeting of Interscience Conference on Antimicrobial Agents and Chemotherapy (ICAAC)
- Annual meeting of Infectious Diseases Society of America (IDSA)
- Annual meeting of American College of Chest Physicians (ACCP)
- Annual meeting of Pediatric Academic Societies (PAS)
- Date searched: 6/21/2011
- Search strategy: KW: “procalcitonin” or “sepsis” in the title
- Records:33

### Government documents

RePORTER
- Source: http://projectreporter.nih.gov/reporter.cfm
- Date searched: 6/16/2011
- Search strategy: key word “procalcitonin” AND “sepsis”
- Records:2

HSRPROJ
- Source: http://wwwcf.nlm.nih.gov/hsr_project/home_proj.cfm
- Date searched: 6/16/2011
- Search strategy: key word “procalcitonin” AND “sepsis”
- Records:0

AHRQ GOLD
- Source: http://gold.ahrq.gov/projectsearch/
- Date searched: 6/16/2011
- Search strategy: key word “procalcitonin” AND “sepsis”
- Records:1

### Manufacturer database

- Source: Thermo Fisher Scientific
- Date posted: 6/13/2011
- Date searched:6/15/2011
- Search strategy: Not applicable
- Records:67

### Gray Literature searching

- Scopus (performed June 2011) = 376 records
- Conference Papers Index (performed June 2011) = 42 records
- Clinicaltrials.gov = 2 records
- Meeting abstracts from 2006-2010 for:
- Interscience Conference on Antimicrobial Agents and Chemotherapy (ICAAC)
- Infectious Disease Society of America (IDSA)
- American College of Chest Physicians
- Pediatric Academic Societies (PAS)