# Abbreviations

ABT: antibiotic
ACCP: American College of Chest Physicians
AECOPD: acute exacerbations of chronic obstructive pulmonary disease
AIDS: acquired immunodeficiency syndrome
APACHE: acute physiology and chronic health evaluation
ATS: American Thoracic Society
CAP: community acquired pneumonia
CI: confidence interval
COPD: chronic obstructive pulmonary disease
CRP: C-reactive protein
ED: emergency department
EPC: evidence practice center
EPICOT: evidence, population, intervention, comparison, outcome, timestamp
FDA: food and drug administration
GOLD: global initiative for chronic obstructive pulmonary diseases
GRADE: grading of recommendations assessment, development, and evaluation
HIV: human immunodeficiency virus
ICU: intensive care unit
IDSA: Annual Meeting of Infectious Diseases Society of America
IL: interleukin
LOS: length of stay
LRTI: Lower respiratory tract infection
NR: not reported
NSS: not statistically significant
PCT: procalcitonin
PFT: pulmonary function test
PICOTS: patient, intervention, comparator, outcome, timing, and setting
PRORATA: Procalcitonin to Reduce Antibiotic Treatments In Acutely Ill Patients
QOL: quality of life
RCT: randomized controlled trial
RTI: respiratory tract infection
SAPS: simplified acute physiology score
SBI: serious blood infections
SD: standard deviation
SIPs: scientific information packets
SIRS: systemic inflammatory response syndrome
SOE: strength of evidence
SOFA: Sepsis-Related Organ Failure Assessment
TEP: technical expert panel
TOO: Task Order Officer
URTI: upper respiratory tract infection
VAP: ventilator-associated pneumonia
WBC: white blood cells