# Summary and Discussion

## Key Findings

A number of important findings emerged from this review.

### Efficacy of Physical Therapy Interventions

- Pooled analyses demonstrated (Figures 2 and 3) that core physical therapy interventions, including aerobic and aquatic exercise, improved disability measures.
  ○ Aerobic and strengthening exercise reduced pain and improved function.
  ○ Proprioception exercise reduced pain.
- Pooled analyses also found that Tai Chi improved short-term function, but with no sustained benefit, and ultrasound reduced pain and improved function.
- Pooled analyses demonstrated that education programs, diathermy, orthotics, and magnetic stimulation (PEMF) failed to show any benefits.
- The relative reduction in pain or disability with physical therapy interventions was less than 30 percent (Figure 4).
- Research focused on individual physical therapy interventions, whereas typical physical therapy practice uses combined interventions.
- Few physical therapy interventions were effective.
- No single physical therapy intervention improved all outcomes.
- Individual (nonpooled) RCTs failed to show consistent statistically significant, strong, or clinically important changes in outcomes.

Figure 2 Reduction in pain with physical therapy interventions vs. no active treatments at the longest time of followup in adults with knee osteoarthritis, pooled with random effects standardized mean difference from randomized controlled clinical trials

CI = confidence interval; L = low; M = moderate; Large magnitude of effect when reduction is more than 0.8 standard deviations

^*^ The estimate was based on an individual study

Figure 2 is a forest plot diagram depicting reduction in pain at the longest time of followup with physical therapy interventions vs. no active treatment. The data came from pooled with random effects models randomized controlled clinical trials. The plot has two columns. The left-hand column lists the physical therapy interventions and strength of evidence that that interventions decreased pain in adults with knee OA. The right-hand column is a plot of standardized mean differences. Mean difference for each comparisons is presented by a black dot incorporating 95 percent confidence intervals represented by horizontal lines. The figure demonstrates that randomized trials offered low strength of evidence about significant reduction in pain with exercises and ultrasound.

Figure 3 Reduction in disability with physical therapy intervention vs. no active treatment in adults with knee osteoarthritis, pooled with random effects standardized mean difference from randomized controlled clinical trials

CI = confidence interval; L = low; M = moderate; PT = physical therapy; Large magnitude of effect when reduction is more than 0.8 standard deviations

^*^ The estimate was based on an individual study.

Figure 3 is a forest plot diagram depicting reduction in disability at the longest time of followup with physical therapy interventions vs. no active treatment. The data came from pooled with random effects models randomized controlled clinical trials. The plot has two columns. The left-hand column lists the physical therapy interventions and strength of evidence that that interventions decreased disability in adults with knee OA. The right-hand column is a plot of standardized mean differences. Mean difference for each comparisons is presented by a black dot incorporating 95 percent confidence intervals represented by horizontal lines. The figure demonstrates that randomized trials offered low strength of evidence about significant reduction in disability with aerobic and aquatic exercises.

Figure 4 Reduction in pain and disability with physical therapy interventions vs. no active treatments at the longest time of followup in adults with knee osteoarthritis, pooled with random effects ratio of means from randomized controlled clinical trials

Note: Means ratio of less than 1 means reduction in pain or disability.

Figure 4 is a forest plot diagram depicting a percentage reduction in pain and disability at the longest time of followup with physical therapy interventions vs. no active treatment. The data came from pooled with random effects models randomized controlled clinical trials. The plot has two columns. The left-hand column lists the physical therapy interventions and strength of evidence that that interventions decreased pain and disability in adults with knee OA. The right-hand column is a plot of the differences in ratios of means. Ratio of means difference for each comparisons is presented by a black dot incorporating 95 percent confidence intervals represented by horizontal lines. The figure demonstrates that pain was reduced with aerobic, strength, and proprioception exercise, orthotics, and ultrasound. Ultrasound decreased disability measures.

### Comparative Effectiveness of Physical Therapy Interventions

We found limited evidence about comparative effectiveness of physical therapy interventions:

- Pain measures did not differ between aerobic and aquatic exercises in pooled analyses.
- Pain did not differ between electrical stimulation and exercise in pooled analyses.
- Individual RCTs of other treatment comparisons found no consistent clinically important differences in outcomes and did not support robust conclusions about the best treatment option.

### Role of Patient Characteristics in Modifying Treatment Effects

- Evidence from individual RCTs did not permit e robust conclusions about differences in physical therapy effects by patient characteristics.
- Patients with high compliance to exercise tended to have better benefits.

### Role of Duration or Intensity of Treatment

- The duration of examined interventions was not associated with better intermediate or patient-centered outcomes.
- Evidence regarding the association between the dose/intensity/frequency of examined interventions and outcomes did not permit robust conclusions for the majority of comparisons.
- The treatments that demonstrated statistically significant benefits (aerobic, aquatic, and strengthening exercises and ultrasound) did not differ in effect at shorter versus longer times of followup.
- Electrical stimulation improved pain short term but significantly worsened pain at longer followup.

### Adverse Effects of Physical Therapy Interventions

- Adverse events were uncommon and not severe enough to deter patients from continuing treatment.
- Adverse events varied across intervention and included: skin irritation with brace/insole/tape/electrical stimulation, swelling with brace/diathermy/exercise, muscle soreness with electrical stimulation, warming/throbbing sensation with diathermy/electrical stimulation/PEMF, increased pain with diathermy/exercise/insole/PEMF, and falls with insole.

### Association Between Intermediate and Patient-Centered Outcomes

- Gait, mobility restrictions, muscle strength, and range-of-motion measures were associated with disability measures.
- Individual studies did not offer strong evidence for determining which intermediate outcomes strongly and consistently predict patient-centered outcomes.
- Many articles reported validation, but few demonstrated a strong (more than 50 percent) correlation between index and reference method measurements.
- Original studies concluded that tests are valid based on significance, not strength of correlation.
- None of the intermediate outcomes met surrogate criteria for patient-centered outcomes.

### Minimum Clinically Important Differences

- Minimum clinically important differences of the tests were determined using the anchor method, which compares changes in scales with patient perception of improvements.
- Minimum clinically important differences were available as absolute change in score or relative change as a percent difference from baseline levels, which accounts for baseline severity of the disease.
- Patient Acceptable Symptom State (PASS), defined as the highest level of symptom patients can tolerate and still be satisfied with their treatment, was determined for three scales (WOMAC, VAS for pain, and the Patient Global Assessment Scale).
- Validated tools defined threshold values of clinical importance for evaluating treatment success in adults with knee OA. In contrast, more often studies used continuous measures of the outcomes, and provided an average score for all patients in each treatment group. Clinical importance of such averages was not evaluated. Average scores do not provide information how many patients develop disability or experience clinically meaningful improvements in pain, function, or quality of life.

Our report addresses patient-centered outcomes including pain, disability, and quality of life with physical therapy interventions for adults with knee OA. Our findings agree with previously published guidelines9, 17 and systematic reviews18–20 that recommend exercise as an effective physical therapy intervention. However, our analyses demonstrated that few physical therapy interventions were effective, and no single intervention improved all outcomes.

Several factors affected the applicability of the research base. This lessened the degree to which our synthesis can fully and accurately address the efficacy and comparative effectiveness of physical therapy interventions for knee OA. Most important, current standards of physical therapy practice involve combined interventions, whereas published studies have examined individual physical therapy interventions. Our focus on randomized clinical trials, which equally distribute concomitant treatments among groups to accurately estimate the effect of an examined intervention, could not mitigate the impact of this discrepancy for several reasons. First, the trials rarely tested combinations of therapies or provided information about all other treatments or reported outcomes separately in patient subgroups by concomitant treatments. Second, clinical care for adults with knee OA includes pharmacologic interventions, while our review is limited to nonpharmacologic therapies,251–253 thus further complicating our efforts. We tried to examine how pain relievers (an extremely common concomitant treatment) may influence physical therapy outcomes for pain, but rare and inconsistent reporting of drug treatments impeded synthesis of evidence. Finally, heterogeneity in populations, treatments, and definitions of the outcomes hampered strength of evidence to low or moderate in most cases.

Most often, strength of evidence was low due to exclusion of patients from the analyses, inadequate allocation concealment, or unmasked outcome assessment. Few studies reported that the researchers who assessed outcomes were unaware of the treatment status of the patients.87, 95, 103, 111, 254, 255 The majority of trials had moderate risk of bias. We explored how risk of bias could modify treatment effect with meta-regression and subgroup analyses and found no consistent statistically significant changes. We excluded from pooled analyses studies with poorly reported results, as well as trials that enrolled patients with knee or hip OA without separately reporting the outcomes. Many trials failed to provide sufficient details about the interventions themselves, their intensity, or the involvement of a physical therapist.256, 257

Examined physical therapy interventions included balance and coordination training, biofeedback and muscle relaxation techniques, strength, power, and endurance training, and functional training in self-care (Table 11). We tabulated the number of studies that described individual physical therapy modalities as part of physical therapy interventions. Yet, since very few studies precisely described modality type and intensity, we found it difficult to assess how individual modalities contributed to treatment benefits.

Table 11 Reported physical therapy modalities as components of the examined physical therapy interventions

Components of the Intervention (Modalities) | Reporting Intervention Components | Exercise + Education (# of Studies) | Exercise Aerobic (# of Studies) | Exercise Aquatic (# of Studies) | Exercise Proprioception (# of Studies) | Exercise Strength (# of Studies) | Exercise Strength (CER) (# of Studies)
Aerobic capacity | No | 6 | 3 | 2 | 4 | 19 | 12
Aerobic capacity | Unclear | 3 | 0 | 0 | 0 | 0 | 0
Aerobic capacity | Yes | 1 | 29 | 9 | 0 | 6 | 0
Balance, coordination, and agility training | No | 7 | 29 | 8 | 1 | 22 | 10
Balance, coordination, and agility training | Unclear | 3 | 0 | 0 | 0 | 0 | 0
Balance, coordination, and agility training | Yes | 0 | 3 | 3 | 3 | 3 | 2
Education | No | 3 | 17 | 10 | 2 | 24 | 11
Education | Yes | 7 | 15 | 1 | 2 | 1 | 1
Exercise | No | 5 | 1 | 0 | 0 | 2 | 0
Exercise | Yes | 5 | 31 | 11 | 4 | 23 | 12
Flexibility exercise | No | 7 | 16 | 5 | 4 | 14 | 5
Flexibility exercise | Unclear | 3 | 0 | 0 | 0 | 0 | 0
Flexibility exercise | Yes | 0 | 16 | 6 | 0 | 11 | 7
Functional training in self-care | No | 4 | 22 | 11 | 4 | 20 | 9
Functional training in self-care | Yes | 6 | 10 | 0 | 0 | 5 | 3
Gait training | No | 7 | 31 | 11 | 3 | 23 | 12
Gait training | Unclear | 3 | 0 | 0 | 0 | 0 | 0
Gait training | Yes | 0 | 1 | 0 | 1 | 2 | 0
Manual therapy | No | 10 | 31 | 11 | 4 | 24 | 12
Manual therapy | Yes | 0 | 1 | 0 | 0 | 1 | 0
Muscle relaxation technique | No | 7 | 32 | 11 | 4 | 25 | 12
Muscle relaxation technique | Unclear | 3 | 0 | 0 | 0 | 0 | 0
Muscle relaxation technique | Yes | 0 | 0 | 0 | 0 | 0 | 0
Strength, power, and endurance training | No | 7 | 4 | 1 | 2 | 2 | 0
Strength, power, and endurance training | Unclear | 3 | 0 | 0 | 0 | 0 | 0
Strength, power, and endurance training | Yes | 0 | 28 | 10 | 2 | 23 | 12
| Total | 10 | 32 | 11 | 4 | 25 | 12
| | 3.89 | 12.45 | 4.28 | 1.56 | 9.73 | 4.67

CER = Comparative effectiveness review

Even when original studies did describe individual modalities, they rarely examined or reported the role of physical therapists or physical therapist assistants (Figure 5). Fewer than half of the studies described patient education or self-training, two essential components of physical therapy practice.

Figure 5 Physical therapists’ involvement in administering modalities in trials that examined the effectiveness of physical therapy interventions

Note: Horizontal axis-number of studies that reported physical therapists’ involvement in administering each listed physical therapy modality.

Figure 5 is a stacked bar diagram depicting physical therapists’ involvement in administering modalities from trials that examined the effectiveness of physical therapy interventions. Black part of each bar demonstrates a number of the articles that reported no physical therapists’ involvement in education, aerobic capacity, balance, coordination, and agility training, biofeedback, exercise, flexibility exercise, gait training, muscle relaxation technique, strength, power, and endurance training, or functional training in self-care. Grey part of each bar demonstrates a number of the articles with unclear physical therapists’ involvement in administering modalities. Patterned part of each bar demonstrates a number of the articles that reported physical therapists’ involvement in administering modalities. This figure demonstrated that even when original studies did describe individual modalities, they rarely examined or reported the role of physical therapists or physical therapist assistants. Less than half of the studies described patient education or self training, two essential components of physical therapy practice.

The majority of strength exercises reported that physical therapists administered the interventions (Figure 6). In contrast, fewer than half of the trials with aquatic exercise, and only 28 percent of trials of aerobic exercise stated that physical therapists administered interventions. Future efforts are needed to improve reporting quality of physical therapy studies. Consolidated Standards of Reporting Trials of nonpharmacologic treatments258 recommends that studies include a detailed description of the interventional components and, when applicable, individualized treatment recommendations as well as details about standardization of interventions and adherence of care providers with the protocol.258 Such detailed reporting would shed light on how the direct involvement of physical therapists in treatment may contribute to benefits from exercise in adults with knee OA.

Figure 6 Physical therapists’ involvement in trials that examined the effectiveness of physical therapy interventions

CER = comparative effectiveness review; Estim = electrical stimulation; PEMF = pulsed electromagnetic fields

Note: Horizontal axis-percentage of studies that reported physical therapists’ involvement in administering each listed physical therapy intervention.

Figure 6 is a stacked bar diagram depicting physical therapists’ involvement in trials that examined the effectiveness of physical therapy interventions. Black part of each bar demonstrates a number of the articles that reported physical therapists’ involvement in administering specific education, aerobic exercise, aquatic exercise, balance exercise, exercise and education, proprioception exercise, strength exercise, or stretching exercise. Light grey part of each bar demonstrates a number of the articles with unclear physical therapists’ involvement in administering interventions. Dark grey part of each bar demonstrates a number of the articles that reported no physical therapists’ involvement in administering interventions. The majority of strength exercises reported that physical therapists administered the interventions. In contrast, less than half of the trials with aquatic or aerobic exercise stated that physical therapists administered interventions.

### Monitoring Treatment Success

Patients judge treatment success by reduction in pain259 and improvement in quality of life.24 Clinical trials of nonpharmacologic treatments focused on pain and various measures of function.260 Reimbursement for physical therapy practice is currently driven by the validated measures of functional impairments recommended by the American Physical Therapy Association’s (APTA) Guide to Physical Therapist Practice.37 However, APTA’s Guide recommends neither clinically important thresholds of change for such measures nor the monitoring of treatment effects according to patient-centered outcomes. Thus, the Guide provides no clear direction regarding routine assessment of patient-centered outcomes for physical therapists in clinical practice.

Variability in definitions and measurements of outcomes affected our synthesis of evidence. Although outcomes were reported as average scores for all patients in each treatment group, the clinical importance of such averages was not evaluated. Average scores do not reflect how many patients develop disability or experience clinically meaningful improvements in pain, function, or quality of life. OARSI, however, has recommended that treatment success be evaluated according to patient-centered outcomes and clinically important differences in the WOMAC scale.56, 229

MCIDs refer to thresholds of change in outcomes measurements that result in clinically significant improvements in pain, disability, quality of life, and patient satisfaction with treatment. The studies described clinically important differences of 26 validated tests using the anchor method, which compares changes in scales with patient perceptions of improvement.261, 262 A tool that measures patient satisfaction (the Patient Acceptable Symptom State, or PASS) was determined for three scales (WOMAC, VAS for pain, and the Patient Global Assessment). PASS is used to identify the maximum level of symptom state that patients can tolerate and still consider their health satisfactory and their treatment successful. PASS is gaining recognition as a valid and reliable approach across many areas of medical practice, including rheumatology.263 Expanded use of PASS could help to improve both the quality of physical therapy practice and the impact of studies examining physical therapy interventions.

In contrast, the studies we examined did not categorize patients according to meaningful improvement in pain, disability measures, or quality of life. Meaningful improvements in patient-centered outcomes should define treatment success in physical therapy practice. Evidence was lacking to determine the association between patient-centered outcomes and the measurement of functional impairment that currently drive reimbursement for physical therapy services. Future use of WOMAC in clinical trials, along with routine monitoring of treatment success in physical therapy practice, would produce robust cumulative evidence of the benefits of physical therapy modalities and interventions.

## Limitations

Our report has several limitations. We relied on published information and did not contact the principal investigators of poorly reported or unpublished studies. We evaluated selective outcome reporting as described in the methods sections. Very few trials examined quality of life as a clinical outcome. We did not contact the authors to clarify whether the trials did in fact measure quality of life but did not report the results. When articles did not mention quality of life assessment in methods sections, we assumed that the investigators did not aim to examine this important outcome. Future research should identify minimum patient-oriented outcomes for use in clinical trials. All clinical trials examining physical therapy interventions should register in Clinicaltrials.gov and provide a detailed protocol and links to associated publications.

Despite an exhaustive literature search, we cannot precisely estimate publication bias. We found that less than 30 percent of eligible studies in ClinicalTrials.gov were published.

Several additional factors limited the research on this topic. Evidence to answer research questions was low-strength in most cases. Due to variability in definitions of the outcomes, we had to calculate standardized mean differences. Statistically significant differences in this construct do not necessarily reflect the clinical importance of improvement in outcomes. Evidence about treatment effects in patient subgroups did not permit robust recommendations for individualized treatment. Minorities and patients with comorbidities are at higher risk of disability and yet were underrepresented in clinical trials.

We did not evaluate adverse effects related to unmet patient expectations, insufficient use of patient and provider time and resources, or treatments that were not cost effective. Nor did our review include studies of postsurgical physical therapy treatments, where potential late benefits of physical therapy interventions could be evident.

## Future Research

Our report has implications for future research.264 Benefits from physical therapy interventions should be defined as clinically important improvement in pain, independence in ADL, and quality of life. Treatment success should be estimated using rates of the patient-centered outcomes.

Many physical therapy treatments are interventions directed at reducing disability. To best guide future studies, research should address an accepted theoretical framework that describes the relationship between impairments and disability.

Through meta-analyses of individual patient data from previously conducted RCTs, researchers could categorize patients according to the clinical importance of the changes they experience and analyze rates of patient-centered outcomes. Assuming investigators were willing to share their data, meta-analyses of individual patient data could also provide good estimates of treatment effects in patient subpopulations by age, comorbidity, severity of knee OA, and concomitant treatments.

Future RCTs should examine comparative effectiveness of combined physical therapy treatments that consist of effective individual modalities or interventions. Finally, researchers should further examine the extent to which the benefits of exercise for adults with knee OA are affected by the supervision provided by physical therapists or physical therapist assistants.

Our report points to areas for future research. Table 12 links a research agenda with each Key Question.

Table 12 Future research recommendations

Key Question | Results of Literature Review | Types of Studies Needed To Answer Question | Future Research Recommendation
What are the effectiveness and comparative effectiveness of available physical therapy interventions (without drug treatment) for adult patients with chronic knee pain due to OA on intermediate and patient-centered outcomes when compared to no active treatment or another active physical therapy modality? | Few physical therapy interventions were shown to be effective. No single physical therapy intervention was shown to improve all outcomes. Research focused on individual physical therapy interventions, in contrast with common physical therapy practice of combining interventions. Pooled analyses demonstrated that:; - Aerobic and aquatic exercise improved disability measures; - Aerobic and strengthening exercise reduced pain and improved function; - Proprioceptive exercise reduced pain; - Ultrasound improved function; Pooled analyses also demonstrated that the following physical therapy interventions failed to show any benefits:; - Specific education program; - Tai Chi; - Diathermy; - Orthotics; - Magnetic stimulation; Individual (nonpooled) RCTs failed to show consistent statistically significant, strong, or clinically important changes in outcomes. Evidence about comparative effectiveness of physical therapy interventions was limited. Pooled analyses demonstrated that:; - Disability measures did not differ with aerobic exercise vs. aquatic or vs. strengthening exercise; - Pain did not differ with electrical stimulation vs. exercise in pooled analyses; Individual RCTs of other treatment comparisons did not find consistent clinically important differences in outcomes and did not permit robust conclusions about the best treatment option. | Meta-analyses of individual patient data Randomized controlled clinical trials Pragmatic trials | Categorize patient outcomes according to clinically important improvement in pain, disability, function, and quality of life. Examine combined interventions that reflect practice. Provide detailed information about fidelity of the treatments and involvement of physical therapists and physical therapist assistants. Examine preventive exercise interventions and self- management of OA on incidence of disability in community, primary care, and physical therapy settings. Assess the patient-centered outcomes with robust validated scales (WOMAC) and according important (to patients) improvements in pain, function, and quality of life.
Which patient characteristics are associated with the benefits of examined interventions of physical therapy on intermediate and patient-centered outcomes? | Evidence from individual RCTs did not permit robust conclusions about differences in effects by patient characteristics. Better treatment response was consistently reported in exercise subgroups with high compliance. | Meta-analyses of individual patient data Randomized controlled clinical trials Observational studies | Subgroup analyses by patient age, severity of OA, multi-joint OA, prior and concomitant treatments. The association between patient modifiable risk factors for disability due to knee OA and incidence of pain, disability, and impaired quality of life.
Do changes in intermediate and patient-centered outcomes differ by the dose, duration, intensity, and frequency of examined interventions of physical therapy? | The duration of examined interventions was not associated with better intermediate/patient-centered outcomes. Evidence regarding the association between the dose/intensity/frequency of examined interventions and outcomes was very limited for the majority of comparisons and did not permit robust conclusions. | Meta-analyses of individual patient data Randomized controlled clinical trials Observational studies | Request from the authors detailed information about dose, included modalities, duration, intensity, and frequency of examined interventions. Re-analyze the conducted studies according to this information. Design trials that have enough power to detect differences in patient-centered outcomes according to dose, included modalities, duration, intensity, and frequency of examined interventions. Use administrative database to analyze treatment utilization (drug, surgery) according to dose, included modalities, duration, intensity, and frequency of physical therapy interventions.
Do changes in intermediate and patient-centered outcomes differ by the time of followup? | Among those treatments that demonstrated statistically significant improvement in outcomes, the effects of aerobic, aquatic, and strengthening exercises and ultrasound did not differ at shorter vs. longer time of followup. Electrical stimulation improved pain at short term of followup but significantly worsened pain at longer time of followup. | Randomized controlled clinical trials. Observational studies | Design trials that have enough power to detect differences in long-term patient-centered outcomes Analyze treatment utilization (drug, surgery) according to time of followup after physical therapy interventions. Explore whether changes in intermediate outcomes precede changes in disability measures and, if so, by how much.
What is the association between changes in intermediate outcomes with changes in patient-centered outcomes after physical therapy interventions? | Gait, mobility restrictions, muscle strength, and range of motion measures were associated with disability measures. Individual observational studies did not offer strong and consistent evidence for determining which intermediate outcomes strongly and consistently predict patient-centered outcomes. | Meta-analyses of individual patient data Randomized controlled clinical trials Observational studies | Examine the association between responses in intermediate outcomes with responses in patient-centered outcomes. Response must be defined as clinically important changes in measurements and scales. Use administrative databases in prospective and/pr retrospective analyses of treatment utilization (drug, surgery) and incidence of disability according to response in intermediate outcomes driving reimbursement for physical therapy services.
What is the validity of the tests and measures used to determine intermediate outcomes of physical therapy on OA in association with patient-centered outcomes? | Validation was reported in many articles but few demonstrated a strong (more than 50%) correlation between index and reference method measurements. Original studies concluded that tests are valid based on significance, not strength of correlation. | Observational validation studies | Define validity according to strength of the association and diagnostic value of the tests. Explore nonlinear association between intermediate and patient-centered outcomes determining clinically important thresholds in measurements and their predictive value for disability and improved quality of life.
Which intermediate outcomes meet the criteria of surrogates for patient-centered outcomes? | None of the intermediate outcomes met surrogate criteria for patient-centered outcomes. | Randomized controlled clinical trials | Examine the responses in intermediate measurements for predicting patient-centered outcomes with physical therapy interventions. Response must be defined as clinically important changes in measurements and scales. Categorize the changes in intermediate outcomes according to thresholds of clinical importance rather than using linear regression that results on statistically significant coefficients with questionable clinical importance.
What are minimum clinically important differences of the tests and measures used to determine intermediate outcomes? | Minimum clinically important differences of the tests were determined using the anchor method that compared changes in scales with patient perception of improvements. Minimum clinically important differences were available as absolute change in score or relative change as a percent difference from baseline levels counting for baseline severity of the disease. Definition of the PASS that accounted for patient satisfaction was available for WOMAC scale, VAS for pain, and for Patient Global Assessment Scale. Validated tools defined threshold values of clinical importance for evaluating treatment success in adults with knee OA. In contrast, more often studies used continuous measures of the outcomes providing an average score for all patients in each treatment group. Clinical importance of such averages was not evaluated. Average scores did not provide information on how many patients developed disability or experienced clinically meaningful improvement in pain, function, or quality of life. | Randomized controlled clinical trials Observational studies Policy evaluation | Define PASS for intermediate outcomes driving reimbursement for physical therapy services. Examine whether payment decisions based on clinically important improvement in quality of life reduce incidence of disability.
What are the harms from physical therapy interventions available for adult patients with chronic knee pain due to osteoarthritis when compared to no active treatment or active controls? | Adverse events were uncommon and varied across interventions. They included: skin irritation with brace/insole/tape/e-stim, swelling with brace/diathermy/exercise, muscle soreness with e-stim, warming/throbbing sensation with diathermy/e-stim/PEMF, increased pain with diathermy/exercise/insole/PEMF, and falls with insole. Adverse events were not severe enough to deter participants from continuing treatment. | Randomized controlled clinical trials Observational studies Cost effectiveness analyses | Collect information about all undesirable events patient experienced irrespective of provider opinion about relevance to physical therapy interventions.

CER = comparative effectiveness review; OA = osteoarthritis; PASS = patient acceptable symptom state; PEMF = pulsed electromagnetic fields; RCT = randomized clinical trials; VAS = Visual Analog Scale

Note: Methodological recommendations are shown in italics.