# Results

Of 4,266 identified references, we included 576 references for this review. We excluded 1,258 references (Appendix B).

Detailed evidence tables with all included studies can be found at https://netfiles.umn.edu/xythoswfs/webui/_xy-20731563_1-t_wzpHYqhT. Eligible references included published results from individual studies, abstracts presented in scientific meetings, and FDA statistical reviews of several studies (Appendix Table F1). Our search of www.clinicaltrials.gov for completed studies identified 18 publications of 69 relevant studies (26 percent publication rate) (Appendix Table F2). We received no response from manufacturers of physical therapy equipment in response to our requests for scientific information packages (Appendix Table F3).

## Key Question 1 What are the effectiveness and comparative effectiveness of available physical therapy interventions (without drug treatment) for adult patients with chronic knee pain due to OA on intermediate and patient-centered outcomes when compared to no active treatment or another active physical therapy modality?

For Key Questions 1 and 3, we synthesized evidence from 422 references. We calculated treatment effect from 261 references and qualitatively analyzed 161 studies (Appendix Table F4). We evaluated risk of bias and treatment effects but ultimately did not pool the results from RCTs of adults with knee or hip OA that failed to report those outcomes separately (Appendix Table F5). Finally, 212 eligible articles of 193 RCTs contributed to our conclusions, while only 84 RCTs met pooling criteria and were included into meta-analyses.

Most, but not all, studies reported consent of the subjects and ethical approval (Appendix Table F6). Almost half of the studies did not report a funding source; 17 were sponsored exclusively by industry. The studies recruited an average of 103 (standard deviation 110) adults (Appendix Table F7).

Most RCTs had medium risk of bias (55 percent). We could not evaluate risk of bias in poorly reported studies (Appendix Table F6). Most frequently, high risk of bias was due to exclusion of patients from the analyses and differences among treatment groups at baseline (inadequate randomization) (Appendix Table F8).

The studies overall had good applicability to our target population because they primarily recruited older adults with knee OA. On average, women constituted more than 70 percent of the participants. BMI of participants averaged at 29±3kg/m^2^. (Appendix Table F7). Most studies did not report race of participants (Appendix Table F9). Adults in 100 RCTs were taking anti-inflammatory drugs or pain relievers. Half of the studies provided no information about exact pharmacologic treatments. Most studies did not report participants’ occupation, knee injury, comorbidity, duration of condition, or the proportion of subjects with baseline disability. Few studies explicitly stated that they excluded patients with prior knee surgery (Appendix Table F9). Most studies did not report the proportion of patients who had undergone surgery.

For two reasons, we concluded that the studies overall had low applicability to the actual practice of physical therapy. First, most examined an isolated intervention, which is inconsistent with recommended delivery of combined physical therapy modalities. Second, many of the interventions studied were physical agents/modalities (i.e., orthotics, ultrasound, taping, etc.). This also contradicts the recommended practice of physical therapy, in which physical agents/modalities are infrequently used in isolation, but rather combined with other more “active” interventions (i.e., exercises).

Among the studies for pooled analyses, electrical stimulation, strength exercise, and aerobic exercise were the most frequently studied treatments (Appendix Table F10). Outcomes were categorized by comparisons, domains of outcomes, and followup times. The actual instruments used for pain, disability, quality of life, and composite function are presented in Appendix Table F11. Definitions of physical therapy interventions and outcomes varied dramatically among studies; thus, only a small proportion of comparisons met pooling criteria. We prioritized pooled analyses and results at longest time of followup over nonpooled results and short followups (Appendix Table F12).

### Effectiveness of Physical Therapy Interventions

We found very few statistically significant differences in outcomes between active and control treatments. Table A in the Executive Summary shows how many studies examined each outcome, estimated effect sizes, and our level of confidence that the evidence reflects the true effect of the treatment and that the estimate is unlikely to be changed by future research (Appendix Table F13). No single physical therapy intervention improved all outcomes (Table 3). Individual small RCTs may fail to show statistically significant effects due to low statistical power.

Table 3 Outcomes with physical therapy interventions from randomized controlled clinical trials, pooled with random effects models standardized mean differences—using standard deviations as units of the differences

Treatment | Outcome (Sorted by Importance of the Outcomes); Weeks of Followup | Randomized Trials; Subjects | Cohen Standard Mean Difference (95% CI) (Hedges SMD not shown) Heterogeneity Statistics
Efficacy
Education program | Pain 6–13 weeks | Studies: 3^70, 73, 74^ Subjects: 429 | 0.091 (−0.423, 0.604) I-squared=0.826, p-value=0.001
Education program | Pain >26 weeks | Studies: 2^72, 73^ Subjects: 511 | −0.09 (−0.318, 0.138) I-squared=0.415, p-value=0.181
Aerobic exercise | Pain <6 weeks | Studies: 2^76, 78^ Subjects: 137 | −1.00 (−2.25, 0.25) I-squared=0.926, p=0
Aerobic exercise | Pain 6–13 weeks | Studies: 12^70, 73, 76–82, 85, 86, 89^ Subjects: 1242 | −0.326 (−0.567, −0.085) I-squared=0.752, p=0
Aerobic exercise | Pain 14–26 weeks | Studies: 6^72, 78, 81, 86, 89^ Subjects: 953 | −0.063 (−0.187, 0.062) I-squared=0.828, p=0
Aerobic exercise | Pain >26 weeks | Studies: 6^72, 73, 82, 84, 86,83^ Subjects: 1221 | −0.211 (−0.346, −0.075) I-squared=0.284, p-value=0.211
Aerobic exercise | Disability <6 weeks | Studies: 2^75, 76^ Subjects: 117 | −1.737 (−3.359, −0.114) I-squared=0.899, p=0.002
Aerobic exercise | Disability 6–13 weeks | Studies: 8^70, 75–77, 79–82^ Subjects: 739 | −0.46 (−0.963, 0.044) I-squared=0.9, p-value=0
Aerobic exercise | Disability 14–26 weeks | Studies: 2^81, 82^ Subjects: 277 | 0.124 (−0.112, 0.36) I-squared=0, p-value=0.57
Aerobic exercise | Disability >26 weeks | Studies: 4^71, 82–84^ Subjects: 806 | −0.208 (−0.372, −0.043) I-squared=0.255, p-value=0.252
Aerobic exercise | Psychological disability 6–13 weeks | Studies: 4^70, 76, 80, 85^ Subjects: 271 | −0.687 (−1.473, 0.1) I-squared=0.873, p-value=0
Aerobic exercise | Health perception 6–13 weeks | Studies: 2^76, 85^ Subjects: 62 | −1.415 (−3.152, 0.322) I-squared=0.889, p-value=0.003
Aerobic exercise | Health perception >26 weeks | Studies: 3^71, 82, 84^ Subjects: 513 | −0.038 (−0.211, 0.135) I-squared=0, p-value=0.466
Aerobic exercise | Function composite 6–13 weeks | Studies: 3^85–87^ Subjects: 351 | −0.841 (−1.358, −0.325) I-squared=0.785, p-value=0.003
Aerobic exercise | Function composite >26 weeks | Studies: 3^72, 83, 86^ Subjects: 826 | −0.182 (−0.444, 0.08) I-squared=0.717, p-value=0.014
Aerobic exercise | Gait function <6 weeks | Studies: 3^75, 76, 78^ Subjects: 220 | −0.382 (−0.629, −0.134) I-squared=0, p-value=0.542
Aerobic exercise | Gait function 6–13 weeks | Studies: 8^75, 76, 78, 80, 85, 87, 89, 90^ Subjects: 632 | −0.575 (−0.756, −0.393) I-squared=0.271, p-value=0.194
Aerobic exercise | Gait function 14–26 weeks | Studies: 3^72, 78, 89^ Subjects: 459 | −0.445 (−0.624, −0.267) I-squared=0, p-value=0.811
Aerobic exercise | Gait function >26 weeks | Studies: 2^83, 91^ Subjects: 609 | −0.558 (−0.862, −0.254) I-squared=0.7, p=0.036
Aquatic exercise | Pain 6–13 weeks | Studies: 2^94, 95^ Subjects: 99 | −0.25 (−0.646, 0.147) I-squared=0, p=0.376
Aquatic exercise | Pain 14–26 weeks | Studies: 2^93, 94^ Subjects: 303 | −0.168 (−0.394, 0.058) I-squared=0, p-value=0.34
Aquatic exercise | Disability 6–13 weeks | Studies: 2^94, 95^ Subjects: 99 | 0.065 (−0.364, 0.495) I-squared=0.15, p=0.278
Aquatic exercise | Disability 14–26 weeks | Studies: 2^93, 94^ Subjects: 303 | −0.281 (−0.507, −0.054) I-squared=0, p-value=0.511
Aquatic exercise | Function composite 6–13 weeks | Studies: 2^94, 95^ Subjects: 99 | −0.034 (−0.52, 0.452) I-squared=0.33, p=0.22
Aquatic exercise | QL 14–26 weeks | Studies: 2^93, 94^ Subjects: 303 | −0.098 (−0.323, 0.128) I-squared=0, p-value=0.953
Strengthening exercise | Pain 6–13 weeks | Studies: 13^94, 96–98, 100–104, 106, 108, 109^ Subjects: 1404 | −0.64 (−0.886, −0.394) I-squared=0.782, p-value=0
Strengthening exercise | Pain 14–26 weeks | Studies: 4^94, 97, 99, 105^ Subjects: 592 | −0.348 (−0.518, −0.179) I-squared=0.049, p-value=0.379
Strengthening exercise | Pain >26 weeks | Studies: 3^83, 97, 104^ Subjects: 786 (885 knees) | −0.688 (−1.239, −0.137) I-squared=0.937, p-value=0
Strengthening exercise | Disability 6–13 weeks | Studies: 4^94, 96–98^ Subjects: 606 | −0.083 (−0.513, 0.347) I-squared=0.78, p-value=0.004
Strengthening exercise | Disability 14–26 weeks | Studies: 3^94, 97, 99^ Subjects: 490 | −0.187 (−0.364, −0.009) I-squared=0, p-value=0.941
Strengthening exercise | Disability >26 weeks | Studies: 2^83, 97^ Subjects: 687 | −0.158 (−0.478, 0.162) I-squared=0.775, p-value=0.035
Strengthening exercise | QL 6–13 weeks | Studies: 2^94, 98^ Subjects: 194 | −0.324 (−0.72, 0.071) I-squared=0.397, p-value=0.198
Strengthening exercise | Function composite 6–13 weeks | Studies: 6^94, 100–104^ Subjects: 521 | −0.85 (−1.138, −0.562) I-squared=0.65, p-value=0.004
Strengthening exercise | Function composite 14–26 weeks | Studies: 3^99,94,105^ Subjects: 200 | −0.355 (−0.613, −0.097) I-squared=0, p-value=0.89
Strengthening exercise | Function composite >26 weeks | Studies: 2^83, 104^ Subjects: 394 | −1.012 (−1.971, −0.053) I-squared=0.932, p-value=0
Strengthening exercise | Gait function 6–13 weeks | Studies: 9^97, 100–103, 106–109^ Subjects: 958 | −0.479 (−0.797, −0.161) I-squared=0.784, p-value=0
Strengthening exercise | Gait function 14–26 weeks | Studies: 2^97, 105^ Subjects: 494 | −0.464 (−0.841, −0.087) I-squared=0.664, p-value=0.051
Strengthening exercise | Gait function >26 weeks | Studies: 2^83, 97^ Subjects: 687 | −0.392 (−0.586, −0.198) I-squared=0.388, p-value=0.201
Tai chi | Pain 6–13 weeks | Studies: 2^111, 112^ Subjects: 85 | −0.416 (−0.858, 0.027) I-squared=0, p-value=0.716
Tai chi | Disability 6–13 weeks | Studies: 2^111, 112^ Subjects: 85 | −0.244 (−0.684, 0.195) I-squared=0, p-value=0.483
Tai chi | Disability 14–26 weeks | Studies: 2^112, 113^ Subjects: 123 | −0.269 (−0.954, 0.416) I-squared=0.697, p-value=0.069
Tai chi | Function composite 6–13 weeks | Studies: 2^111, 112^ Subjects: 85 | −0.447 (−0.89, −0.005) I-squared=0, p-value=0.937
Tai chi | Function joint 6–13 weeks | Studies: 2^111, 112^ Subjects: 85 | −0.077 (−0.515, 0.361) I-squared=0, p-value=0.661
Proprioception exercise | Pain 6–13 weeks | Studies: 3^100, 104, 114^ Subjects: 198 (264 knees) | −0.716 (−1.315, −0.116) I-squared=0.811, p-value=0.005
Proprioception exercise | Function composite 6–13 weeks | Studies: 3^100, 104, 114^ Subjects: 198 | −1.68(−2.659, 0.402) I-squared=0.955, p=0
Proprioception exercise | Gait function 6–13 weeks | Studies: 3^100, 114, 115^ Subjects: 181 | −0.973 (−2.039, 0.093) I-squared=0.909, p=0
Massage | Function composite 6–13 weeks | Studies: 2^116, 117^ Subjects: 94 | −0.566 (−0.946, −0.187) I-squared=0, p=0.703
Orthotics | Function composite <6 weeks | Studies: 2^122, 123^ Subjects: 138 | −0.583 (−1.191, 0.024) I-squared=0.75, p=0.07
Orthotics | Gait function <6 weeks | Studies: 4^124–127^ Subjects: 101 | −0.009 (−0.22, 0.203) I-squared=0, p=1
Elastic subtalar strapping | Function composite 6–13 weeks | Studies: 3^129–131^ Subjects: 246 | −0.276 (−0.528, −0.025) I-squared=0, p-value=0.546
E-stim | Pain <6 weeks | Studies: 7^141, 148–150^ 151 143 Subjects: 301 | −0.741 (−1.025, −0.456) I-squared=0.339, p-value=0.119
E-stim | Pain 6–13 weeks | Studies: 7^140–142, 147, 150, 152^ Subjects: 304 | −0.086 (−0.311, 0.14) I-squared=0, p-value=0.752
E-stim | Pain 14–26 weeks | Studies: 2^147, 152^ Subjects: 76 | 0.585 (0.087, 1.082) I-squared=0.136, p-value=0.282
E-stim | Disability 6–13 weeks | Studies: 2^140, 141^ Subjects: 98 | −0.275 (−0.687, 0.138) I-squared=0, p-value=0.958
E-stim | Global assessment 6–13 weeks | Studies: 2^140, 141^ Subjects: 98 | −0.43 (−0.862, −0.006) I-squared=0, p-value=0.373
E-stim | Function composite 6–13 weeks | Studies: 3^140–142^ Subjects: 138 | −0.083 (−0.426, 0.26) I-squared=0, p-value=0.608
E-stim | Function joint <6 weeks | Studies: 2^141, 143^ Subjects: 100 | −0.256 (−0.616, 0.103) I-squared=0, p-value=0.81
E-stim | Function joint 6–13 weeks | Studies: 2^140, 141^ Subjects: 98 | −0.294 (−0.707, 0.119) I-squared=0, p-value=1
E-stim | Gait function <6 weeks | Studies: 4^107, 144–146^ Subjects: 191 | −0.19 (−0.697, 0.317) I-squared=0.68, p-value=0.008
E-stim | Gait function 6–13 weeks | Studies: 3^107, 142, 147^ Subjects: 164 | 0.065 (−0.225, 0.355) I-squared=0, p-value=0.743
E-stim | Strength, 120 degree extension, 6–13 weeks | Studies: 2^142, 147^ Subjects: 118 | −0.416 (−0.843, 0.011) I-squared=0.26, p-value=0.259
E-stim | Strength, 60 degree extension, 2 weeks | Studies: 2^107, 142^ Subjects: 146 | −0.56 (−0.894, −0.227) I-squared=0, p-value=0.427
PEMF | Pain <6 weeks | Studies: 2;^154, 155^ Subjects: 145 | 0.013 (−0.417, 0.442) I-squared=0.396, p=0.198
PEMF | Function composite <6 weeks | Studies: 2^154, 155^ Subjects: 145 | −0.127 (−0.607, 0.354) I-squared=0.513, p=0.152
Ultrasound | Pain <6 weeks | Studies: 2^160, 161^ Subjects: 157 | −0.539 (−1.051, −0.027) I-squared=0.669, p-value=0.049
Ultrasound | Pain 6–13 weeks | Studies: 4^142, 158, 159, 162^ Subjects: 227 (360 knees) | −0.52 (−0.85, −0.19) I-squared=0.617, p-value=0.034
Ultrasound | Pain >26 weeks | Studies: 2^142, 158, 159^ Subjects: 160 (320 knees) | −0.744 (−0.952, −0.536) I-squared=0, p-value=0.466
Ultrasound | Disability <6 weeks | Studies: 2^160, 161^ Subjects: 157 | −0.392 (−0.803, 0.018) I-squared=0.496, p-value=0.138
Ultrasound | Function composite 6–13 weeks | Studies: 4^142, 158, 159, 162^ Subjects: 227 | −0.61 (−1.411, 0.024) I-squared=0.892, p-value=0
Ultrasound | Function composite >26 weeks | Studies: 2^158, 159^ Subjects: 160 | −1.154 (−1.613, −0.695) I-squared=0.545, p-value=0.111
Ultrasound | Gait function <6 weeks | Studies: 2^160, 161^ Subjects: 157 | −0.542 (−1.341, 0.258) I-squared=0.861, p-value=0.001
Ultrasound | Gait function 6–13 weeks | Studies: 4^142, 158, 159, 162^ Subjects: 227 | −1.139 (−2.11, −0.168) I-squared=0.915, p-value=0
Ultrasound | Gait function >26 weeks | Studies: 2^158, 159^ Subjects: 160 | −1.503 (−2.111, −0.896) I-squared=0.711, p-value=0.031
Diathermy | Disability <6 weeks | Studies: 4^163–166^ Subjects: 259 | −0.216 (−0.456, 0.025) I-squared=0.139, p-value=0.324
Diathermy | Disability 6–13 weeks | Studies: 2^164, 165^ Subjects: 143 | −0.046 (−0.342, 0.251) I-squared=0, p=0.667
Diathermy | Pain <6 weeks | Studies: 4^163–166^ Subjects: 259 | −0.541 (−0.978, −0.104) I-squared=0.716, p-value=0.002
Diathermy | Pain 6–13 weeks | Studies: 3^142, 164, 165^ Subjects: 183 | −0.007 (−0.274, 0.26) I-squared=0, p-value=0.962
Diathermy | Function composite <6 weeks | Studies: 3^164–166^ Subjects: 229 | −0.475 (−0.964, 0.014) I-squared=0.756, p-value=0.003
Diathermy | Function composite 6–13 weeks | Studies: 3^163–165^ Subjects: 183 | 0.007 (−0.26, 0.273) I-squared=0, p-value=0.998
Diathermy | Function joint <6 weeks | Studies: 2^163–165^ Subjects: 143 | 0.197 (−0.104, 0.499) I-squared=0.026, p=0.358
Diathermy | Function joint 6–13 weeks | Studies: 2^164, 165^ Subjects: 143 | 0.162 (−0.134, 0.459) I-squared=0, p=0.871
Diathermy | Gait function <6 weeks | Studies: 3^163–165^ Subjects: 173 | −0.096 (−0.364, 0.171) I-squared=0, p-value=0.949
Diathermy | Gait function 6–13 weeks | Studies: 3^142, 164, 165^ Subjects: 183 | −0.138 (−0.406, 0.129) I-squared=0, p-value=0.934
Comparative Effectiveness
Aquatic exercise vs. aerobic exercise | Pain 6–13 weeks | Studies: 2^173, 194^ Subjects: 110 | −0.447 (−1.245, 0.35) I-squared=0.762, p-value=0.04
Laterally vs. neutrally wedged insole | Function composite 6–13 weeks | Studies: 2^131, 175^ Subjects: 383 | −0.005 (−0.257, 0.246) I-squared=0.516, p-value=0.083
E-stim vs. exercise | Pain <6 weeks | Studies: 2^178^ Subjects: 81 | −1.298 (−2.992, 0.396) I-squared=0.913, p=0.001
E-stim vs. exercise | Gait function <6 weeks | Studies: 2^107, 178^ Subjects: 81 | 0.198 (−1.181, 1.577) I-squared=0.888, p=0.003

CI = confidence interval; E-stim = electrical stimulation; QL= quality of life; PEMF = pulsed electromagnetic fields; SMD = standard mean differences

Note: Bold indicates statistically significant changes when 95%CI do not include 0.

Pooled analyses provided low-strength evidence that aerobic and aquatic exercise improved disability measures; aerobic exercise, strengthening exercise, and ultrasound reduced pain and improved function; at short- but not long-term followup, proprioception exercise reduced pain and Tai Chi improved function (Table 4). We observed no benefits from specific education programs, diathermy, orthotics, or magnetic stimulation. Individual (nonpooled) RCTs failed to show consistent statistically significant, strong, or clinically important changes in outcomes (Appendix Table F14). Strength of evidence was downgraded due to study risk of bias and heterogeneity in populations, treatments, and definitions of outcomes.

Table 4 Narrative evidence summary of effectiveness of physical therapy interventions for knee osteoarthritis

Comparison | Outcomes at the Longest Time of Followup | Conclusions/Strength of Evidence
Education program | Pain/studies=2, subjects=511 | An education program did not improve pain measures/Low
Education program | Disability/studies=1, subjects=72 | An education program did not improve disability measures/Low
Education program | Psychological disability/studies=1, subjects=316 | An education program did not improve psychological disability measures/Low
Education program | Health perception/studies=1, subjects=316 | An education program improved health perception measures/Low
Education program | Composite function/studies=1, subjects=316 | An education program did not improve composite function measures/Low
Education program | Gait function/studies=1, subjects=316 | An education program did not improve gait function measures/Low
Education program | | An education program improved health perception measures (L) but did not improve pain (L), disability (L), psychological disability (L), gait (L) and composite measures of function (L)
Aerobic exercises | Pain/studies=6, subjects=1,221 | Aerobic exercises improved pain measures/Low
Aerobic exercises | Disability/studies=4, subjects=806 | Aerobic exercises improved disability measures/Low
Aerobic exercises | Psychological disability/studies=4, subjects=271 | Aerobic exercises did not improve psychological disability measures/Low
Aerobic exercises | Global assessment/studies=1, subjects=217 | Aerobic exercises did not improve global assessment measures/Low
Aerobic exercises | Health perception/studies=3, subjects=513 | Aerobic exercises did not improve health perception measures/Low
Aerobic exercises | Composite function/studies=3, subjects=826 | Aerobic exercises did not improve composite function measures/Low
Aerobic exercises | Joint function/studies=1, subjects=28 | Aerobic exercises did not improve joint function measures/Low
Aerobic exercises | Gait function/studies=2, subjects=609 | Aerobic exercises improved gait function measures/Low
Aerobic exercises | Transfer function/studies=1, subjects=293 | Aerobic exercises improved transfer function measures/Low
Aerobic exercises | | Aerobic exercises improved pain (L), disability (L), gait (L), and transfer (L) measures of function but did not improve psychological disability (L), global assessment (L), health perception (L), joint (L), and composite measures of function (L)
Aquatic exercises | Pain/studies=2, subjects=303 | Aquatic exercises did not improve pain measures/Low
Aquatic exercises | Disability/studies=2, subjects=303 | Aquatic exercises improved disability measures/Low
Aquatic exercises | Psychological disability/studies=1, subjects=249 | Aquatic exercises did not improve psychological disability measures/Low
Aquatic exercises | Quality of life/studies=2, subjects=303 | Aquatic exercises did not improve quality of life measures/Low
Aquatic exercises | Composite function/studies=1, subjects=45 | Aquatic exercises did not improve composite function measures/Low
Aquatic exercises | | Aquatic exercises improved disability (L) but did not improve pain (L), psychological disability(L), quality of life (L), and composite measures of function (L)
Strengthening exercises | Pain/studies=3, subjects=786 (885 knees) | Strengthening exercises improved pain measures/Low
Strengthening exercises | Disability/studies=2, subjects=687 | Strengthening exercises did not improve disability measures/Low
Strengthening exercises | Psychological disability/studies=1, subjects=46 | Strengthening exercises improved psychological disability measures/Low
Strengthening exercises | Global assessment/studies=1, subjects=68 | Strengthening exercises improved global assessment measures/Low
Strengthening exercises | Health perception/studies=1, subjects=46 | Strengthening exercises did not improve health perception measures/Low
Strengthening exercises | Quality of life/studies=2, subjects=194 | Strengthening exercises did not improve quality of life measures/Low
Strengthening exercises | Composite function/studies=2, subjects=394 | Strengthening exercises improved composite function measures/Low
Strengthening exercises | Joint function/studies=1, subjects=105 | Strengthening exercises did not improve joint function measures/Low
Strengthening exercises | Gait function/studies=2, subjects=687 | Strengthening exercises improved gait function measures/Low
Strengthening exercises | Transfer function/studies=1, subjects=295 | Strengthening exercises improved transfer function measures/Low
Strengthening exercises | | Strengthening exercises improved pain (L), psychological disability (L), global assessment (L), gait (L), transfer (L), and composite (L) function measures but did not improve disability (L), health perception (L), quality of life (L), and joint (L) function
Tai Chi | Pain/studies=2, subjects=85 | Tai Chi did not improve pain measures/Low
Tai Chi | Disability/studies=2, subjects=123 | Tai Chi did not improve disability measures/Low
Tai Chi | Psychological disability/studies=1, subjects=44 | Tai Chi improved psychological disability measures/Low
Tai Chi | QOL/studies=1, subjects=44 | Tai Chi did not improve quality of life measures/Low
Tai Chi | Composite function/studies=2, subjects=85 | Tai Chi improved composite function measures/Low
Tai Chi | Joint function/studies=2, subjects=85 | Tai Chi did not improve joint function measures/Low
Tai Chi | Gait function/studies=1, subjects=44 | Tai Chi did not improve gait function measures/Low
Tai Chi | | Tai Chi improved psychological disability (L) and composite (L) function measures, but did not improve pain (L), disability (L), quality of life (L), gait (L), and joint (L) function measures
Proprioception exercises | Pain/studies=3, subjects=198 (264 knees) | Proprioception exercises improved pain measures/Low
Proprioception exercises | Composite function/studies=3, subjects=198 | Proprioception exercises did not improve composite function measures/Low
Proprioception exercises | Gait function/studies=3, subjects=181 | Proprioception exercises did not improve gait function measures/Low
Proprioception exercises | | Proprioception exercises improved pain (L) but did not improve gait (L) and composite measures of function (L)
Massage | Disability/studies=1, subjects=68 | Massage improved disability measures/Low
Massage | Composite function/studies=2, subjects=94 | Massage improved composite function measures/Low
Massage | Joint function/studies=1, subjects=68 | Massage improved joint function measures/Low
Massage | Gait function/studies=1, subjects=68 | Massage improved gait function measures/Low
Massage | | Massage improved disability (L), joint (L), gait (L) and composite (L) function measures
Joint mobilization | Pain/studies=1, subjects=43 | Joint mobilization did not improve pain measures/Low
Joint mobilization | Disability/studies=1, subjects=43 | Joint mobilization improved disability measures/Low
Joint mobilization | Global assessment/studies=1, subjects=43 | Joint mobilization improved global assessment measures/Low
Joint mobilization | Gait function/studies=1, subjects=40 | Joint mobilization did not improve gait function measures/Low
Joint mobilization | | Joint mobilization improved disability (L) and global assessment (L), but did not improve pain (L) and gait function measures (L)
Joint mobilization with exercise | Disability/studies=1, subjects=134 | Joint mobilization with exercise improved disability measures/Low
Joint mobilization with exercise | Gait function/studies=1, subjects=134 | Joint mobilization with exercise did not improve gait function measures/Low
Joint mobilization with exercise | | Joint mobilization with exercise improved disability (L) but did not improve gait (L) function measures
Orthotics | Pain/studies=1, subjects=57 | Orthotics improved pain measures/Low
Orthotics | Disability/studies=1, subjects=57 | Orthotics improved disability measures/Low
Orthotics | Psychological disability/studies=1, subjects=57 | Orthotics improved psychological disability measures/Low
Orthotics | Global assessment/studies=1, subjects=125 | Orthotics did not improve global assessment measures/Low
Orthotics | QOL/studies=1, subjects=57 | Orthotics improved quality of life measures/Low
Orthotics | Composite function/studies=2, subjects=138 | Orthotics did not improve composite function measures/Low
Orthotics | Joint function/studies=1, subjects=57 | Orthotics improved joint function measures/Low
Orthotics | Gait function/studies=4, subjects=101 | Orthotics did not improve gait function measures/Low
Orthotics | | Orthotics improved pain (L), disability (L), psychological disability (L), quality of life (L), and joint (L) measures but did not improve global assessment (I), gait (L) and composite (L) function measures
Elastic subtalar strapping | Composite function/studies=3, subjects=246 | Elastic subtalar strapping improved composite function measures/Low
Taping | Pain/studies=1, subjects=58 | Taping did not improve pain measures/Low
Taping | Disability/studies=1, subjects=58 | Taping did not improve disability measures/Low
Taping | Composite function/studies=1, subjects=58 | Taping did not improve composite function measures/Low
Taping | Gait function/studies=1, subjects=18 | Taping did not improve gait function measures/Low
Taping | | Taping did not improve pain (L), disability (L), gait (L) and composite (L) function measures
E-stim | Pain/studies=2, subjects=76 | E-stim worsened pain measures/Low
E-stim | Disability/studies=2, subjects=98 | E-stim did not improve disability measures/Moderate
E-stim | Global assessment/studies=2, subjects=98 | E-stim improved global assessment measures/Low
E-stim | Health perception/studies=1, subjects=40 | E-stim did not improve health perception measures/Low
E-stim | Composite function/studies=3, subjects=138 | E-stim did not improve composite function measures/Low
E-stim | Joint function/studies=2, subjects=98 | E-stim did not improve joint function measures/Moderate
E-stim | Gait function/studies=3, subjects=164 | E-stim did not improve gait function measures/Low
E-stim | Strength/studies=2, subjects=146 | E-stim improved strength measures/Low
E-stim | Transfer function/studies=1, subjects=38 | E-stim did not improve transfer function measures/Low
E-stim | | E-stim improved global assessment (L) and strength (L) measures, but worsened pain (L), and did not improve disability (M), health perception (L), and gait (L), joint (M), transfer (L), and composite (L) function measures,
PEMF | Pain/studies=2, subjects=145 | PEMF did not improve pain measures/Moderate
PEMF | Disability/studies=1, subjects=86 | PEMF did not improve disability measures/Low
PEMF | Global assessment/studies=1, subjects=36 | PEMF improved global assessment measures/Low
PEMF | Composite function/studies=2, subjects=145 | PEMF did not improve composite function measures/Moderate
PEMF | Joint function/studies=1, subjects=90 | PEMF did not improve joint function measures/Low
PEMF | Gait function/studies=1, subjects=36 | PEMF did not improve gait function measures/Low
PEMF | | PEMF improved global assessment (L) but did not improve pain (M), disability (L), and gait (L), joint (L) and composite (M) function measures
Ultrasound | Pain/studies=2, subjects=160 (320 joints) | Ultrasound improved pain measures/Low
Ultrasound | Disability/studies=2, subjects=157 | Ultrasound did not improve disability measures/Low
Ultrasound | Composite function/studies=2, subjects=160 | Ultrasound improved composite function measures/Low
Ultrasound | Joint function/studies=1, subjects=67 | Ultrasound did not improve joint function measures/Low
Ultrasound | Gait function/studies=2, subjects=160 | Ultrasound improved gait function measures/Low
Ultrasound | | Ultrasound improved pain (L), gait (L) and composite (L) function measures but did not improve disability (L), and joint function measures (L)
Diathermy | Pain/studies=3, subjects=183 | Diathermy did not improve pain measures/Low
Diathermy | Disability/studies=2, subjects=143 | Diathermy did not improve disability measures/Low
Diathermy | Psychological disability/studies=1, subjects=40 | Diathermy did not improve psychological disability measures/Low
Diathermy | Global assessment/studies=1, subjects=113 | Diathermy did not improve global assessment measures/Low
Diathermy | Health perception/studies=1, subjects=40 | Diathermy did not improve health perception measures/Low
Diathermy | Quality of life/studies=1, subjects=55 | Diathermy did not improve quality of life/Low
Diathermy | Composite function/studies=3, subjects=183 | Diathermy did not improve composite function measures/Low
Diathermy | Joint function/studies=2, subjects=143 | Diathermy did not improve joint function measures/Low
Diathermy | Gait function/studies=3, subjects=183 | Diathermy did not improve gait function measures/Low
Diathermy | | Diathermy did not improve pain (L), disability (L), psychological disability (L), global assessment (L), health perception (L), quality of life (L), and joint (L), gait (L) and composite (L) function measures
Heat | Disability/studies=1, subjects=34 | Heat improved disability measures/Low
Heat | Quality of life/studies=1, subjects=34 | Heat improved quality of life measures/Low
Heat | Composite function/studies=1, subjects=52 | Heat did not improve composite function measures/Low
Heat | Gait function/studies=1, subjects=40 | Heat did not improve gait function measures/Low
Heat | Pain/studies=1, subjects=34 | Heat did not improve pain measures/Low
Heat | Joint function/studies=1, subjects=52 | Heat did not improve joint function measures/Low
Heat | | Heat improved disability (L) and quality of life (L), but did not improve pain (L), gait (L), joint (L) and composite (L) function measures
Cryotherapy | Disability/studies=1, subjects=34 | Cryotherapy did not improve disability measures/Low
Cryotherapy | Quality of life/studies=1, subjects=34 | Cryotherapy did not improve quality of life measures/Low
Cryotherapy | Composite function/studies=1, subjects=34 | Cryotherapy did not improve composite function measures/Low
Cryotherapy | | Cryotherapy did not improve disability (L), quality of life (L), and composite function measures (L)

E-stim = electrical stimulation; PEMF = pulsed electromagnetic fields; QOL =quality of life

Note: Bold indicates findings with moderate or high strength of evidence. Strength of evidence as L = low; M = moderate; I = insufficient; Strength of evidence was determined according to four domains. (risk of bias, directness, consistency, and precision)

#### Specific Education Programs

We synthesized evidence from five RCTs;70–74 two RCTs with 511 participants contributed to the pooled analyses at the longest time of followup. The results of three articles from two RCTs that examined the effects of specific education programs provided low-strength evidence of no statistically significant effect on pain relief.72, 73

#### Aerobic Exercises

We synthesized evidence from 22 RCTs;70–73, 75–92 11 RCTs with 1,553 participants contributed to the pooled analyses at the longest time of followup.70–73, 76, 80, 82–86, 91, 92 We found low-strength evidence that aerobic exercise resulted in statistically significant improvement in long-term pain72, 73, 82–84, 86 and disability71, 82–84 but not psychological disability70, 76, 80, 85 or health perception.71, 82, 84 Within 3 months, aerobic exercise also improved composite function85–87 and gait function.75, 76, 78, 80, 85, 87, 90 At 12 months the benefits of aerobic exercise continued for gait function83, 91 but not for composite function.72, 83, 86

Magnitude of the effect was generally consistent across the studies, although a few did show statistically significant heterogeneity in pooled estimates. We conducted a meta-regression analysis exploring heterogeneity in pain relief after about 3 months of aerobic exercise compared with placebo. We found no factor that could have consistently modified physical therapy effects (Appendix Table F15). Pain relief around 3 months was consistent in RCTs that reported aerobic exercise under supervision by a physical therapist (Appendix Table F16). By contrast, improvement in composite function 3 months after aerobic exercise was larger in RCTs that reported no physical therapist supervision (Appendix Table F17). A single RCT examined the effects of manual therapy combined with a standardized knee exercise program in the clinic and at home, and found statistically and clinically significant improvements in WOMAC total score and gait function.75

#### Aquatic Exercises

Evidence from three RCTs with 348 participants contributed to the pooled analyses at the longest time of followup.93–95 These RCTs examined the effects of aquatic exercise. Two studies showed low-strength evidence that aquatic exercise reduced disability, but had no statistically significant effects on pain relief or quality of life.93, 94

#### Strengthening Exercises

We synthesized evidence from seventeen RCTs;83, 94, 96–110 nine RCTs with 1,982 participants contributed to the pooled analyses at the longest time of followup.83, 88, 94, 97–99, 104–106

Strengthening exercise had no statistically significant effect on disability (low-strength evidence).83, 97 However, we observed sustained improvement in pain relief, composite function, and gait function at 3 months through more than 12 months followup.83, 94, 96–110 Low-strength evidence demonstrated that strengthening exercise did not improve quality of life.94, 98 Magnitude of the effect differed across the studies.

Meta-regression exploring heterogeneity in gait function or composite function at 3 months after strengthening exercise compared with placebo found no factor that could explain the heterogeneity (Appendix Tables F18-F19). Meta-regression exploring heterogeneity in pain relief around 3 months after strengthening exercise indicated that younger participants had significantly better outcomes (Appendix Table F20). We explored heterogeneity by the involvement of a physical therapist and by study quality and found no consistent association with outcomes (Appendix Tables F21-F24).

#### Tai Chi

Evidence from three RCTs with 167 participants contributed to the pooled analyses at the longest time of followup.111–113 Low-strength evidence from these small trials demonstrated that Tai Chi improved composite function measures around 3 months but had no statistically significant effects on pain or disability. Improvement in function was not sustained at the 6-month followup.

#### Proprioception Exercises

Evidence from four RCTs100, 104, 114, 115 with 247 participants contributed to the pooled analyses at the longest time of followup.100, 104, 114, 115 These RCTs offered low-strength evidence that proprioception exercise led to pain relief but did not improve composite function or gait function. Magnitude of the effect varied across the studies with statistically significant heterogeneity in pooled estimates. Sensitivity analysis restricted to two studies with low risk of bias revealed a larger effect size.100, 104 One study suggested that proprioception exercises improved knee reposition error.100

#### Massage

Evidence from three RCTs with 162 participants contributed to the pooled analyses at the longest time of followup.116–118 We found low-strength evidence that massage somewhat improved composite function.116, 117 Individual studies showed that massage also improved pain,116 disability,118 health perception,116 and gait function;118 however, this evidence did not support robust conclusions.

#### Joint Mobilization

We synthesized evidence from three RCTs with 217 participants119–121 but were unable to perform pooled analyses to support robust conclusions about the impact of joint mobilization. Individual studies showed that joint mobilization with or without exercise reduced disability.119, 120 However, joint mobilization, with or without exercise, did not improve gait function.120, 121

#### Orthotics

Evidence from seven RCTs with 364 participants contributed to the pooled analyses at the longest time of followup.122–128 These RCTs demonstrated low-strength evidence that orthotics had no effect on short-term outcomes of composite function or gait function. Evidence from three Japanese studies offered low-strength evidence that an orthotic intervention involving elastic subtalar strapping improved composite function around 3 months.129–131

#### Brace

We synthesized evidence from five RCTs132–136 but were unable to perform a pooled analysis to draw robust conclusions. In one study, unloader brace improved disability and composite, joint, and gait functions.136

#### Therapeutic Taping

Three RCTs with 119 participants126, 137, 138 examined the effects of taping and found that pain, disability, composite function, and gait function did not differ with therapeutic taping.137, 138 Different reporting formats precluded pooled analyses. Individual RCTs suggested that taping might provide short-term pain relief.137–139

#### Electrical Stimulation

We synthesized evidence from fifteen RCTs.107, 140–153 Seven RCTs with 390 participants contributed to the pooled analyses at the longest time of followup.107, 140–142, 147, 152, 153 Electrical stimulation resulted in statistically significant improvement in short-term pain110, 141, 143, 148–151 and at 3 months after starting the intervention110, 140–142, 147, 150, 152 but worsened pain at 6 months.147, 152 We found low-strength evidence that global assessment140, 141 and muscle strength (measured at 60 degree extension)107, 142 improved significantly with electrical stimulation around 3 months. These statistically significant findings were consistent without substantial heterogeneity across the studies. Pooled analyses provided moderate-strength evidence of no improvement on disability or joint function and low-strength evidence of no improvement on measures of gait or composite function.107, 140–145, 147, 151

#### Pulsed Electromagnetic Fields

Evidence from four RCTs with 267 participants contributed to the pooled analyses at the longest time of followup.154–157 Pulsed electromagnetic fields (PEMF) neither reduced pain nor improved composite function (moderate strength evidence). One study showed that PEMF resulted in statistically significant increase in subjective success.157

#### Ultrasound

Evidence from six RCTs with 387 participants contributed to the pooled analyses at the longest time of followup.142, 158–162 We found low-strength evidence that ultrasound resulted in statistically significant reduction in pain with a moderate effect size and significantly improved composite function and gait function with a large effect size.142, 158, 159 Low-strength evidence also demonstrated that ultrasound did not improve disability.160, 161 Magnitude of the effect on gait function at 3 months varied across the studies, with statistically significant heterogeneity in pooled estimates. We were unable to examine heterogeneity due to the small number of studies.

#### Diathermy

We synthesized evidence from seven RCTs.142, 163–168 Five RCTs with 382 participants contributed to the pooled analyses at the longest time of followup. 142, 164–166, 168 Low-strength evidence demonstrated that diathermy resulted in a statistically significant decrease in pain at 1 month,163–166 but the effect was statistically insignificant at 3 months.142, 164, 165 Low-strength evidence demonstrated that diathermy had no affect on disability, composite function, joint function, or gait function.142, 163–166 A single study also demonstrated no beneficial effects on psychological disability, global assessment, or health perception.165, 168

#### Heat

We synthesized evidence from three RCTs with 126 participants142, 169, 170 but were unable to perform a pooled analysis to draw robust conclusions. In one study, heat improved disability and quality of life169 but had no effect on composite function and gait function.142

#### Cryotherapy

We synthesized evidence from two RCTs with 57 participants151, 169 but were unable to perform a pooled analysis from which to draw robust conclusions. Individual studies showed no statistically significant effects.151, 169

### The Role of Physical Therapist Involvement on Effects With Exercises

We performed subgroup analyses by the involvement of a physical therapist for all outcomes with aerobic or strengthening exercises. We found that for most comparisons, effect sizes with physical therapist involvement were statistically larger than those without. Furthermore, the results in the physical therapist involvement group tended to be consistent without heterogeneity. Although the sample size of the physical therapist involvement subgroup was smaller than the sample size of all pooled studies, the significance of the association and our conclusions remain the same (Appendix Table F25).

### Clinical Importance of Treatment Effects With Physical Therapy Interventions

Original studies used a wide variety of pain measurements, and thus required standardization in pooled analyses. This lack of consistency prevented us from being able to assess whether specific interventions resulted in benefits that were of clinical importance. To assess the clinical importance of pain reduction with interventions, we performed subgroup analyses with a subset of the studies that used the same VAS instrument for pain measures. We then compared the mean reduction in pain with the cutoff for MCIDs in VAS as reported in observational studies. We found that electrical stimulation, diathermy, and ultrasound resulted in clinically significant short-term pain reduction (Appendix Table F26). In long-term followup, however, only strengthening exercise reduced pain with an effect size that exceeded the minimum clinically importance difference. Since we had to exclude studies that used other instruments for pain measurements, we lost power to detect statistically significant findings.

To assess the clinical importance of improvements in disability and quality of life with physical therapy interventions, we transformed SMDs to nonstandardized mean differences in EQ-5D or SF-36. Only aerobic and aquatic exercises led to statistically significant and clinically important benefits for disability (estimated EQ-5D improvements of 0.08 and 0.11, respectively). For quality of life, the benefits of aquatic and strengthening exercise were statistically insignificant (estimated SF-36 physical component summary improvements of 1.1 and 3.5, respectively).

Few individual RCTs categorized patients by clinical importance of the changes in measured pain, disability, or joint function, and most studies failed to demonstrate consistent improvement with physical therapy interventions (Appendix Table F27). Rates of patient-rated treatment success were greater with a brace,136 electrical stimulation,140, 171 mud pack,172 and PEMF.157 Individual RCTs provided no strong evidence for robust conclusions about clinically important improvement with physical therapy interventions.

As a part of planned evidence synthesis, we also compared the differences in continuous measures of pain and disability reported in trials with the MCIDs determined in observational studies and found few clinically important improvements. Aerobic exercise resulted in clinically important improvement in pain, disability, and joint function in the majority of individual RCTs (Appendix Table F28).

### Comparative Effectiveness of Physical Therapy Interventions

Limited direct evidence of comparative effectiveness of physical therapy interventions from single studies was low-strength for the majority of comparisons (Table 5). Aerobic and aquatic exercises had the same benefits on pain,94, 173 a finding consistent with the similar effect sizes demonstrated by these two interventions in efficacy studies. Direct comparisons showed no statistically significant differences between aerobic and strengthening exercises on disability and composite function.83 One study found aerobic exercise was better than strengthening exercise in gait function.83 One study demonstrated that Tai Chi was better than stretching exercises for disability, psychological disability, global assessment, and transfer function.174

Table 5 Narrative evidence summary of comparative effectiveness of physical therapy interventions for knee osteoarthritis

Comparison | Outcomes at the Longest Time of Followup | Conclusions/Strength of Evidence
Aerobic exercises vs. strengthening exercises | Pain/studies=1, subjects=290 | Aerobic exercises did not improve pain measures, compared to strengthening exercises/Low
Aerobic exercises vs. strengthening exercises | Disability/studies=1, subjects=290 | Aerobic exercises did not improve disability measures, compared to strengthening exercises/Low
Aerobic exercises vs. strengthening exercises | Composite function/studies=1, subjects=290 | Aerobic exercises did not improve composite function measures, compared to strengthening exercises/Low
Aerobic exercises vs. strengthening exercises | Gait function/studies=1, subjects=290 | Aerobic exercises improved gait function measures, compared to strengthening exercises/Low
Aerobic exercises vs. strengthening exercises | Transfer function/studies=1, subjects=290 | Aerobic exercises did not improve transfer function measures, compared to strengthening exercises/Low
Aerobic exercises vs. strengthening exercises | | Aerobic exercises improved gait function measures (L) but did not improve pain (L), disability (L), transfer (L), and composite (L) function measures, compared to strengthening exercises
Aquatic exercises vs. aerobic exercises | Disability/studies=1, subjects=64 | Aquatic exercises did not improve disability measures, compared to aerobic exercises/Low
Aquatic exercises vs. aerobic exercises | Pain/studies=2, subjects=110 | Aquatic exercises did not improve pain measures, compared to aerobic exercises/Low
Aquatic exercises vs. aerobic exercises | Composite function/studies=1, subjects=64 | Aquatic exercises did not improve composite function measures, compared to aerobic exercises/Low
Aquatic exercises vs. aerobic exercises | Gait function/studies=1, subjects=64 | Aquatic exercises did not improve gait function measures, compared to aerobic exercises/Low
Aquatic exercises vs. aerobic exercises | | Aquatic exercise did not improve disability (L), pain (L), gait (L) and composite (L) function measures, compared to aerobic exercise
Proprioception exercise vs. strengthening exercise | Composite function/studies=1, subjects=72 | Proprioception exercises worsened composite function measures, compared to strengthening exercises/Low
Proprioception exercise vs. strengthening exercise | Gait function/studies=1, subjects=72 | Proprioception exercises did not improve gait function measures, compared to strengthening exercise/Low
Proprioception exercise vs. strengthening exercise | Pain/studies=1, subjects=72 | Proprioception exercises did not improve pain measures, compared to strengthening exercise/Low
Proprioception exercise vs. strengthening exercise | | Proprioception exercises worsened composite function measures (L) but did not improve pain (L) and gait function (L), compared to strengthening exercises
Tai Chi vs. stretching exercises | Pain/studies=1, subjects=40 | Tai Chi did not improve pain measures, compared to stretching exercise/Low
Tai Chi vs. stretching exercises | Disability/studies=1, subjects=40 | Tai Chi improved disability measures, compared to stretching exercise/Low
Tai Chi vs. stretching exercises | Psychological disability/studies=1, subjects=40 | Tai Chi improved psychological disability measures, compared to stretching exercise/Low
Tai Chi vs. stretching exercises | Global assessment/studies=1, subjects=40 | Tai Chi did not improve global assessment measures, compared to stretching exercise/Low
Tai Chi vs. stretching exercises | Composite function/studies=1, subjects=40 | Tai Chi did not improve composite function measures, compared to stretching exercise/Low
Tai Chi vs. stretching exercises | Joint function/studies=1, subjects=40 | Tai Chi did not improve joint function measures, compared to stretching exercise/Low
Tai Chi vs. stretching exercises | Gait function/studies=1, subjects=40 | Tai Chi did not improve gait function measures, compared to stretching exercise/Low
Tai Chi vs. stretching exercises | Transfer function/studies=1, subjects=40 | Tai Chi improved transfer function measures, compared to stretching exercise/Low
Tai Chi vs. stretching exercises | | Tai Chi improved disability (L), psychological disability (L), and transfer function (L) but did not improve pain (L), global assessment (L), gait (L), joint (L), and composite (L) function measures, compared to stretching exercise
Laterally vs. neutrally wedged insole | Pain/studies=1, subjects=200 | Laterally wedged insole did not improve pain measures, compared to neutrally wedged insole/Low
Laterally vs. neutrally wedged insole | Disability/studies=1, subjects=200 | Laterally wedged insole did not improve disability measures, compared to neutrally wedged insole/Low
Laterally vs. neutrally wedged insole | Global assessment/studies=1, subjects=200 | Laterally wedged insole did not improve global assessment measures, compared to neutrally wedged insole/Low
Laterally vs. neutrally wedged insole | Quality of life/studies=1, subjects=200 | Laterally wedged insole did not improve quality of life measures, compared to neutrally wedged insole/Low
Laterally vs. neutrally wedged insole | Composite function/studies=2, subjects=383 | Laterally wedged insole did not improve composite function measures, compared to neutrally wedged insole/Low
Laterally vs. neutrally wedged insole | Gait function/studies=1, subjects=45 | Laterally wedged insole did not improve gait function measures, compared to neutrally wedged insole/Low
Laterally vs. neutrally wedged insole | Joint function/studies=1, subjects=200 | Laterally wedged insole did not improve joint function measures, compared to neutrally wedged insole/Low
Laterally vs. neutrally wedged insole | | Laterally wedged insole did not improve pain (L), disability (L), global assessment (L), quality of life (L), joint (L), gait (L), and composite (L) function measures, compared to neutrally wedged insole
Orthotics vs. brace | Pain/studies=1, subjects=91 | Orthotics did not improve pain measures, compared to brace/Low
Orthotics vs. brace | Composite function/studies=1, subjects=91 | Orthotics did not improve composite function measures, compared to brace/Low
Orthotics vs. brace | | Orthotics did not improve pain (L) and composite (L) function measures, compared to brace
E-stim vs. exercises | Pain/studies=2, subjects=81 | E-stim did not improve pain measures, compared to exercise/Low
E-stim vs. exercises | Composite function/studies=1, subjects=50 | E-stim improved composite function measures, compared to exercise/Low
E-stim vs. exercises | Joint function/studies=1, subjects=50 | E-stim improved joint function measures, compared to exercise/Low
E-stim vs. exercises | Gait function/studies=2, subjects=81 | E-stim did not improve gait function measures, compared to exercise/Low
E-stim vs. exercises | | E-stim improved joint (L) and composite (L) measures of function but did not improve pain (L) and gait (L) function, compared to exercise
E-stim vs. ultrasound | Pain/studies=1, subjects=40 | E-stim did not improve pain measures, compared to ultrasound/Low
E-stim vs. ultrasound | Composite function/studies=1, subjects=40 | E-stim did not improve composite function measures, compared to ultrasound/Low
E-stim vs. ultrasound | Gait function/studies=1, subjects=40 | E-stim did not improve gait function measures, compared to ultrasound/Low
E-stim vs. ultrasound | | E-stim did not improve pain (L), gait (L) and composite (L) function measures, compared to ultrasound

E-stim = electrical stimulation

Note: Strength of evidence as L = low; Strength of evidence was determined according to four domains (risk of bias, directness, consistency, and precision).

Laterally and neutrally wedged insoles demonstrated similar effects on gait function,131, 175 as did orthotics and brace on composite function.176 A recent study showed that pain, disability, global assessment, quality of life, and joint function did not differ between laterally and neutrally wedged insoles.177 Several small studies found no statistically significant difference between electrical stimulation and exercise for pain relief and gait function.107, 110, 147, 178 One study showed statistically insignificant differences between electrical stimulation and ultrasound on composite and gait function.142

The studies of combined physical therapy modalities demonstrated no statistically significant benefits on the outcomes when compared with aerobic, strength, or proprioception exercise alone. Manual therapy added to aerobic exercise provided benefits similar to aerobic exercise alone.

## Key Question 1a Role of Patient Characteristics on Outcomes

### Compliance

Studies used the percentage of class attendance to capture compliance or adherence. Moderate-strength evidence from three RCTs demonstrated that subgroups with high compliance tended to have better outcomes for exercise (aerobic, aquatic, and strengthening).93, 179–182 The higher compliance group had the lowest risk of incident ADL disability,179 a lower average depression score,180 a higher mean Quality of Well-Being Scale score,93 and greater improvements in both 6-minute walking distance and disability.182

Three articles came from the Fitness Arthritis and Seniors Trial (FAST), which investigated the effects of two exercise programs (aerobic and strengthening) for adults 60 and older.179–181 The authors examined dose-response effects between exercise frequency and three outcome variables: knee pain, self-reported difficulties with ADL, and ADL performance.181 The results indicated that exercise for patients with knee OA should be three times each week with moderate duration (35 minutes). The authors defined exercise compliance for both types of exercise by the percentage of exercise sessions attended and found the lowest risk of ADL disability and a lower average depression score for those in the highest compliance tertile (Figure 1).179, 180 One study performed an economic evaluation of aquatic exercise for persons with osteoarthritis; the mean Quality of Well-Being Scale (QWB) score for adherers was significantly higher than for nonadherers or controls.93 Using multiple linear regression models among an Arthritis, Diet, and Activity Promotion Trial subsample, the authors found that higher exercise compliance was associated with greater improvements in 6-minute walking distance and in disability.182

Figure 1 Risk of developing disability in activities of daily living in compliance subgroups

Note: The attention control group is used as the reference.

Figure 1 is a forest plot diagram depicting a risk of developing disability in activities of daily living in exercise compliance subgroups. The data came from individual trials. The plot has two columns. The left-hand column lists the compliance subgroups with corresponding sample size for strengthening or aerobic exercises. The right-hand column is a plot of relative risk of developing disability in activities of daily living. Mean relative risk for each comparisons is presented by a black dot incorporating 95 percent confidence intervals represented by horizontal lines. The figure demonstrates that adults with high compliance to exercise had significantly lower risk of developing disability in activities of daily living.

### Age

Evidence did not permit conclusions about how age differences affect treatment outcomes. Three studies reported clinical outcomes by age subgroup for bracing, exercise (aerobic or strengthening), or PEMF.83, 134, 155 Heterogeneity across studies (different active and control treatments, outcomes, and definitions of age subgroups) precluded robust conclusions.

In 117 knee OA patients, explorative subgroup analyses showed that patients younger than 60 experienced a slightly better effect of the brace for knee function (measured by an estimated improvement of 3.38 on the Hospital for Special Surgery or HSS score) than patients 60 years and older (estimated HSS score improvement 2.48).134 Pain severity with bracing showed a similar modest trend. Using a cut-off age of 70, the FAST trial found that participants of all ages who were randomized in aerobic or strengthening exercise programs improved in self-reported disability, pain, and 6-minute walk distance compared with the health education group.

While PEMF demonstrated no beneficial symptomatic effect in all patients, those younger than 65 improved significantly after 2 weeks in stiffness155 but not in ADL or pain.

### Malalignment

Two RCTs did not provide robust evidence for how malalignment affects treatment outcomes. RCTs found greater benefits for patients in the genu varus group134 and for those without malalignment.102

Stratified by the alignment, the genu varus group (n = 95) showed a better and statistically significant effect of the brace for knee function score (estimated HSS score improvement 4.15; P = 0.03) compared with the genu valgus group (n = 22) (estimated HSS score improvement 0.20; P = 0.96).134 For pain relief, this trend was similar, but not as prominent.

One study examined the impact of malalignment on the way strengthening exercise affects knee adduction moment, pain, and function.102 The results indicated that strengthening exercise did not significantly alter the knee adduction moment or function in either the more malaligned or the more neutral group, but the latter experienced statistically significant pain reduction.

### Body Mass Index

Evidence for the role of BMI in predicting treatment effects was inconsistent in two studies.83, 183 One study compared treatment with and without a lateral wedge insole and found that those with a BMI of less than 30 kg/m^2^ had a 29 point improvement in the WOMAC Pain subscale, compared with an improvement of only 6 points in those whose BMI was more than 30 kg/m^2^.183 In contrast, the very obese participants (defined by the top tertile) who were assigned to the aerobic exercise or resistance training programs improved in self-reported disability, pain, and 6-minute walk distance compared with the health education group.

### Comorbidity

Evidence from individual studies did not permit robust conclusions about any modifying effect of comorbidity. The FAST study of 439 older adults with knee OA investigated the effects of comorbidity on the benefits of resistance or aerobic exercise.184 The authors defined comorbidity as the presence of knee OA plus other two or more clinical conditions. The results indicated that aerobic exercise improved function and reduced pain irrespective of the presence of comorbidity.

### Depression

Individual studies did not permit robust conclusions about differences in benefits between patients with and without depression. The FAST study investigated the effects of depression on the benefits of exercise.180 Aerobic or resistance exercise significantly improved disability, pain, and walking speed regardless of baseline depressive symptoms. In addition, aerobic (but not resistance) exercise significantly lowered depressive symptoms at 18 months of followup compared with the control educational group. The authors concluded that depression had no substantial impact on the benefits of exercise.

### Sex

Evidence from individual studies did not permit robust conclusions about differences in benefits between men and women. Five studies that reported clinical outcomes of exercise and orthotics in male and female subgroups83, 123, 131, 185, 186 demonstrated no statistically significant difference in effects.

### Race

Evidence from a single study did not permit robust conclusions about differences in benefits between racial groups. This study performed subgroup analysis between whites and African Americans;83 and both groups assigned to the aerobic exercise interventions or the resistance training program improved in self-reported disability, pain, and 6-minute walk distance compared with the health education group.

### Severity

Baseline OA severity may affect the impact of physical therapy interventions on clinical outcomes. However, findings were inconsistent and varied across studies depending on the treatments, outcomes, and/or cut-off grades. Furthermore, RCTs reported post hoc analyses of changes from baseline in functional measures among patients with different baseline severity scores. Six RCTs used the Kellgren and Lawrence Scale (K/L) to grade severity, and one categorized severity according to the Ahlback score.134 Clinical outcomes in severity subgroups were reported in seven RCTs involving brace,134, 176 insole,126, 127, 176, 183 exercise (strengthening or range of motion (ROM),186 and weight reduction and/or electrical stimulation.187 Three RCTs found no consistent modification effect of baseline severity.126, 127, 183 One RCT found pain reduction to be greater in patients with severe OA than in those with mild.134

These inconsistent findings may be due to inconsistent outcomes and/or cutoff grades in the original studies. In a group of 221 older adults randomized to strength training or ROM exercises, the WOMAC Pain subscale did not differ between K/L grade 2–3 and grade 0–1.^186^ Interestingly, percentage of joint space narrowing >0.5mm after a 30-month followup was higher in the strength training arm than in the range of motion arm in subgroup of K/L grade 0–1, but not grade 2–3. This finding is unexplained; further confirmation is warranted.

One study evaluated the effect of weight reduction and/or electrical stimulation on patients with knee osteoarthritis and obesity.187 The study found that subgroups with severity grades 3 and 4 had more pain decrease than the group with grade 2, regardless of whether the treatment arms received weight reduction, electrical stimulation, or weight reduction plus electrical stimulation. However, the study did not examine whether baseline severity modified benefits with manual therapy. Further, patients whose OA severity varied also had different baseline scores in the VAS pain scale.

## Key Question 1b Association between the dose/intensity/frequency of examined interventions and intermediate/patient-centered outcomes

For the majority of possible comparisons, we found no robust evidence for determining the association between the dose/intensity/frequency of examined interventions and outcomes.

### Exercise

Although definitions of intensity differed among studies, evidence indicated similar benefits for low- and high-intensity exercise (defined by one study as 40 percent and 70 percent heart rate reserve, respectively).188 In one study, low- and high-intensity exercises similarly improved function, gait, and pain.188 Another study found that the effects of high-resistance strength training (>60 percent of one repetition maximum) appeared larger than those of low-resistance strength training (10 percent of one repetition maximum), but the differences were statistically insignificant.101 One study examined exercise compliance in order to determine any dose-response effects between exercise frequency and outcomes.181 The results indicated that exercise for patients with knee OA should be three times each week with moderate duration (35 minutes). One study compared frequency of physical therapist visits for patients receiving home-based exercise over 24 weeks, and found no statistically significant difference between groups who received six visits or two visits.189

### Orthotics

For patients with genu varus deformity from OA, medium duration (5–10 hours daily) of insole with subtalar strapping wear was better than short duration (less than 5 hours) and long duration (more than 10 hours).122 One study suggested better comfort and effectiveness for an 8- or 12mm elevated wedged insole than a 16mm elevated wedge.190 Another study also found better comfort for a 5° than a 10° wedge, although the effect of the 5° wedge was smaller.126 Future researchers should consider these findings in designing their studies.

### Electrical Stimulation

We found no short-term clinical difference between low frequency (2 Hz pulse trains) and high frequency (80 Hz) electrical stimulation.191 However, noxious stimulation decreased pain intensity more than innocuous stimulation.192 In one study, Burst Mode and High Rate stimulation had similar effects on stiffness and pain.143 Another study demonstrated that for reducing pain, 40 minutes was the optimal duration of electrical stimulation.193

### Diathermy

Two studies found no statistically significant differences between high and low intensity diathermy on disability and gait function.163, 164

### Ultrasound

In two studies, pulsed ultrasound appeared to be better than continuous ultrasound in improving disability, gait, and composite function.158, 161

## Key Question 1c Association between the duration of examined interventions and intermediate/patient-centered outcomes

The duration of examined interventions varied broadly. For example, exercise programs ranged from 2 to 72 weeks. We found no statistically significant association between the duration of examined interventions and intermediate or patient-centered outcomes. In combining aerobic, aquatic, strengthening, proprioception, and Tai Chi exercises, changes in intermediate and patient-centered outcomes did not differ by the duration of interventions, with all p-values greater than 0.05 (Appendix Figure F1). For this analysis we used the longest followup standardized effect size in each study. While these results might seem to suggest that a 2-week exercise program is sufficient, we emphasize that exercise should be continuous and that higher compliance to exercise led to better improvement. Evidence did not permit robust conclusions about other treatments.

### Association Between Time of Followup and Intermediate/Patient-Centered Outcomes

The association between the time of followup and outcomes differed by examined treatments and outcomes. Outcomes did not differ by followup times for treatments that demonstrated statistically significant benefits (aerobic, aquatic, and strengthening exercises and ultrasound). Nor did intermediate or patient-centered outcomes differ by followup time when the effects of aerobic, aquatic, strengthening, proprioception, and Tai Chi exercises were combined (all p-values greater than 0.05) (Appendix Figure F2). The combined results remained consistent with or without inclusion of Tai Chi. Ultrasound’s effects did not differ by time of followup for pain, gait, and composite function (Appendix Figure F3). Electrical stimulation improved pain at short followups but significantly worsened pain at longer followups (p-value < 0.001) (Appendix Figure F4). In contrast, we observed that diathermy’s benefits for disability increased with longer followups (p-value = 0.009) (Appendix Figure F5).

## Key Question 2 What is the association between changes in intermediate outcomes with changes in patient-centered outcomes after physical therapy interventions?

Evidence for the association between intermediate and clinical outcomes was limited to individual observational studies, which did not show a strong or consistent association between changes in intermediate and patient centered outcomes (Table 6). Substantial variability occurred between index and reference methods, definitions of outcomes, methods of examining diagnostic values, and associations between intermediate and clinical outcomes. Delineating between patient-centered and intermediate outcomes was somewhat artificial. For example, pain (a patient-centered outcome) is an explanatory factor for several intermediate outcomes including gait, range of motion, and balance. Likewise, patient-centered outcomes such as disability, self-reported pain, and observed IADL dependency were determined by composite measures of objective tests including WOMAC or Arthritis Impact Measurement Scale (Appendix Table F29) (intermediate outcomes). Finally, certain associations between patient-centered outcomes are clinically important for predicting treatment effects—for instance, pain or function may predict disability.

Table 6 Association between intermediate and clinical outcomes; low strength of evidence from individual observational studies

Clinical Outcome | Intermediate Outcome | Conclusion
Disability | Physical performance | Physical function assessed with SF-36 and WOMAC tools have conclusive diagnostic value for work limitations
Disability | Physical performance | Several functional tests (VAS: restriction; TUG test; Step test; Walking speed) were associated with impaired adjusted daily activity score
Disability | OA severity | Severity of OA assessed with Osteoarthritis of the Knee Severity Index was negatively associated with role functioning
Disability | Range of motion | Increased range of motion was negatively associated with observed and self reported disability
Disability | Strength | Muscle strength was negatively associated with observed and self reported disability
Physical performance | Balance | Impaired balance was associated with poor physical performance
Pain | Gait | Gait speed was associated with WOMAC pain severity
Pain | Function | Joint laxity (knee instability) was not associated with walking time
Pain | OA severity | Severity of OA assessed with Osteoarthritis of the Knee Severity Index was negatively associated with body pain assessed using SF-36
Function | Balance | Impaired single-leg standing balance was not associated with poor WOMAC function
Function | Disease severity | Self-reported swelling was associated with poor WOMAC function scale
Function | Joint alignment | Fixed flexion deformity was not associated with poor WOMAN function
Function | Joint alignment | Intercondylar and intermalleolar gap in standing were not associated with poor functional outcome
Function | Joint mobility | Duration of morning stiffness was associated with poor WOMAC function
Function | Joint mobility | Hip rotation was not associated with poor WOMAC function
Function | Joint mobility | Knee flexion range of movement was not associated with poor WOMAC function
Function | Joint mobility | Locking: Pseudo-locking was not associated with poor WOMAC function
Function | Joint stability | Anteroposterior instability was not associated with poor WOMAC function
Function | Joint stability | Laxity (knee instability) was associated with poor WOMAC function
Function | Joint stability | Positive Giving Way Test was associated with poor WOMAC function
Function | OA severity | Severity of OA assessed with Osteoarthritis of the Knee Severity Index was negatively associated with physical functioning assessed using SF-36
Function | Proprioception | Proprioceptive inaccuracy was not associated with poor WOMAC function
Function | Strength | Force (quadriceps femoris muscle strength) <20kg was associated with poor WOMAC function
Function | Strength | Hamstring strength(mm Hg): ≤100 vs. ≥185 was associated with poor WOMAC function
Function | Strength | Muscle strength and laxity (knee instability) were associated with reduced walking time
Function | Strength | Muscle strength but not laxity (knee instability) was associated with poor WOMAC function
Function | Strength | Quadriceps strength (mm Hg): ≤140 vs. ≥300 was associated with poor WOMAC function

OA = osteoarthritis; SF-36 = 36-Item Short-Form Health Survey; TUG = timed up and go; VAS = Visual Analog Scale; WOMAC = Western Ontario and McMaster Universities Osteoarthritis Index

Note: Strength of evidence was downgraded because single observational studies did not provide strong consistent and unbiased estimates

We synthesized the evidence of association between intermediate and clinical outcomes from 43 studies of 25,799 adults with knee OA. Mean age averaged 65, and ranged from 55 to 80 (Appendix Table F30). Women constituted 70 percent of participants. Sample size of the studies varied with a median of 149 and mean of 600 participants. Half of all published studies were American or British (13 and seven respectively). Minorities were included only in the American studies, which did not report those results separately.

The studies used different statistical concepts to examine the relationship between outcomes. First, the studies examined sensitivity, specificity, or positive predictive likelihood of index tests for correct identification of the outcomes according to reference tests. When the outcomes—for example, functional disability—were measured with scales, the studies defined thresholds in numeric score to categorize patients as disabled or not. Studies of diagnostic value had only fair quality (Appendix Table F31).

Second, the studies used linear regression to examine association as changes in measurements of patient-centered outcomes corresponding to changes in measurements of intermediate outcomes. Regression coefficients presented a magnitude of the change in continuous measures of patient-centered outcomes (such as pain) corresponding to one unit change in continuous measures of intermediate outcomes (such as muscle strength). However, it is not clear whether such estimates of the association between outcomes have clinical importance.

Third, the studies used logistic or Cox regression to examine association as rates or odds of patient-centered outcomes corresponding to rates or odds of functional impairments. For statistically significant associations, we judged a magnitude as high when relative risk or odds ratio was more than 2 or less than 0.5. Few studies adjusted the regression models to lower the risk of bias. Some studies failed to distinguish patients with definitive diagnoses of knee OA from those with self-reported OA or knee pain.

Some studies examined the association between outcomes at the same time points without collecting followup data. These cross-sectional analyses could point out the association between functional impairments and pain or disability at one time point but could not predict future changes in the outcomes. In contrast, prospective studies examined the association between baseline functional impairments and patient-centered outcomes at future time of followup. Those studies predicted patient-centered outcomes based on the association with intermediate outcomes, after adjustment for confounding factors.

Fourth, some cross-sectional studies calculated the correlation between continuous measurements in the outcomes. Correlation coefficients ranged from −1 (negative correlation) to 0 (no correlation) to 1 (positive correlation). The correlation simply reflected the same linear direction of the changes in intermediate and clinical outcomes, with no consideration of the units of measured outcomes or of the clinical importance of the measures.

### Diagnostic Value of Outcomes

Few studies reported the diagnostic values of intermediate outcomes.

The Cohort Hip and Cohort Knee study (CHECK) found that an SF-36 physical function score <60 had conclusive diagnostic value for work limitations as determined by the Functional Capacity Evaluation.195 Adults with SF-36 physical function score <60 had a large (>10) positive likelihood ratio of work limitations.

In one prospective cohort study, a Pain Numeric Rating Scale score of <4 had a conclusive diagnostic value for patient perception of clinically significant improvement (Appendix Table F32).196 The study examined both absolute and relative changes in pain scores in each of three categories based on cut points using a numeric rating scale and found that clinically significant changes in pain were not uniform across the scale. A reduction of 15 percent in the Pain Numeric Rating Scale score represented minimum clinically important changes, while a reduction of 33 percent represented “much better” improvement in the patient’s global impression of change.196

Another prospective study, Clinical Assessment Study of the Knee (CAS(K)), demonstrated that bilateral knee pain, duration of morning stiffness, and inactivity gelling (stiffness after inactivity) had conclusive diagnostic value for poor WOMAC function at 18 months of followup (positive likelihood ratio = 42 and the area under the receiver operating characteristic curve = 0.73).197

### Association Between Intermediate and Clinical Outcomes Examined With Regression Models

Measures of functional impairment were associated with poor patient-centered outcomes in individual studies (Table 7). Studies were inconsistent in defining intermediate and patient-centered outcomes and in adjusting for confounding factors. The studies examined the association with logistic or Cox regression reporting hazard rate ratios or odds ratios of categorical patient-centered outcomes (Table 8). Patient-centered outcomes were categorized according to clinically important thresholds in scales. Most studies examined the association with linear regression and reported differences in continuous measures of the outcomes corresponding to one unit increase in the measures of intermediate outcomes. No clinical importance of such changes was evident unless the studies proposed regression models estimating quality-of-life index or other patient-centered outcomes based on WOMAC scores.198

Table 7 Regression association between intermediate and clinical outcomes; low strength of evidence from individual observational studies

Intermediate Outcomes | Disability Studies/N=Patients Estimate | Function Studies/Patients Estimate | Pain Studies/Patients Estimate
Balance | | Harrison, 2004^209^/N=50 −0.5^*^ Thomas, 2008^197^/N=621 Not significant HR
Gait speed | Bennell, 2004 200 /N=259 * | Nebel, 2009^248^/N=179 Not significant^*^ | Astephen Wilson, 2011 201 /N=40 *
Range of motion | van Baar, 1998 206 /N=185 * | Thomas, 2008^197^/N=621 Not significant HR | Van Der Esch, 2006 207 /N=86 *
Strength | van Baar, 1998 206 /N=185 * | Thomas, 2008^197^/N=621 1.5 HR Wood, 2008^204^ N=741 5.2 OR Sharma, 2003^205^ N=257 NS OR O’Reilly, 1998^203^ N=300 7.1 OR | O’Reilly, 1998 203 /N=300 18.8 OR
Swelling | | Thomas, 2008 197 /N=621 1.3 HR

HR = hazard rate ratio; OR = odds ratio

Note: Bold = statistically significant association

* Linear regression; strength of evidence was downgraded because single observational studies did not provide strong consistent and unbiased estimates

Table 8 Relative measure of association between intermediate outcomes and functional disability; low strength of evidence from individual observational studies

Author, Year Design Months of Followup | Intermediate Outcome | Definition of Intermediate Outcome | Adjustment | Estimate Mean (95% CI) | Area Under the Receiver Operating Characteristic Curve (ROC)
Thomas^*^, 2008^197^ prospective cohort Months of followup: 72 | Balance | Single-leg standing balance(s): <4 vs. 30 | BMI, anxiety, duration of morning stiffness, bilateral knee pain, age, inactivity gelling, local tender point count | HR 1.21 (0.85 to 1.72) | 0.77
Thomas^*^, 2008^197^ prospective cohort Months of followup: 72 | Balance | Single-leg standing balance(s): <4 vs. 30 | BMI, anxiety, duration of morning stiffness, bilateral knee pain, age, inactivity gelling, local tender point count, prevalent knee radiographic OA | HR 1.21 (0.85 to 1.73) | 0.77
Thomas^*^, 2008^197^ prospective cohort Months of followup: 72 | Balance | Single-leg standing balance(s): <4 vs. 30 | Local tender point count | HR 1.49 (1.09 to 2.04) | 0.68
Thomas^*^, 2008^197^ prospective cohort Months of followup: 72 | Balance | Single-leg standing balance(s): 10–29 vs. 30 | BMI, anxiety, duration of morning stiffness, bilateral knee pain, age, inactivity gelling, local tender point count | HR 1.12 (0.8 to 1.55) | 0.77
Thomas^*^, 2008^197^ prospective cohort Months of followup: 72 | Balance | Single-leg standing balance(s): 10–29 vs. 30 | BMI, anxiety, duration of morning stiffness, bilateral knee pain, age, inactivity gelling, local tender point count, prevalent knee radiographic OA | HR 1.1 (0.79 to 1.54) | 0.77
Thomas^*^, 2008^197^ prospective cohort Months of followup: 72 | Balance | Single-leg standing balance(s): 10–29 vs. 30 | Local tender point count | HR 1.27 (0.92 to 1.74) | 0.68
Thomas^*^, 2008^197^ prospective cohort Months of followup: 72 | Balance | Single-leg standing balance(s): 4–9 vs. 30 | BMI, anxiety, duration of morning stiffness, bilateral knee pain, age, inactivity gelling, local tender point count | HR 1.22 (0.88 to 1.67) | 0.77
Thomas^*^, 2008^197^ prospective cohort Months of followup: 72 | Balance | Single-leg standing balance(s): 4–9 vs. 30 | BMI, anxiety, duration of morning stiffness, bilateral knee pain, age, inactivity gelling, local tender point count, prevalent knee radiographic OA | HR 1.22 (0.89 to 1.68) | 0.77
Thomas^*^, 2008^197^ prospective cohort Months of followup: 72 | Balance | Single-leg standing balance(s): 4–9 vs. 30 | Local tender point count | HR 1.5 (1.12 to 2.01) | 0.68
Thomas^*^, 2008^197^ prospective cohort Months of followup: 72 | Range of motion | Duration of morning stiffness (min): ≤30 vs. none | Bilateral knee pain, inactivity gelling | HR 1.47 (1.13 to 1.89) | 0.69
Thomas^*^, 2008^197^ prospective cohort Months of followup: 72 | Range of motion | Duration of morning stiffness (min): >30 vs. none | Bilateral knee pain, inactivity gelling | HR 1.55 (0.99 to 2.43) | 0.69
Thomas^*^, 2008^197^ prospective cohort Months of followup: 72 | Range of motion | Duration of morning stiffness (min): ≤30 vs. none | BMI, anxiety, inactivity gelling, bilateral knee pain, age | HR 1.32 (1.01 to 1.73) | 0.76
Thomas^*^, 2008^197^ prospective cohort Months of followup: 72 | Range of motion | Duration of morning stiffness (min): ≤30 vs. none | BMI, anxiety, inactivity gelling, bilateral knee pain, age, local tender point count, single-leg standing balance | HR 1.25 (0.95 to 1.65) | 0.77
Thomas^*^, 2008^197^ prospective cohort Months of followup: 72 | Range of motion | Duration of morning stiffness (min): ≤30 vs. none | BMI, anxiety, inactivity gelling, bilateral knee pain, age, local tender point count, single-leg standing balance, prevalent knee radiographic OA | HR 1.25 (0.95 to 1.65) | 0.77
Thomas^*^, 2008^197^ prospective cohort Months of followup: 72 | Range of motion | Duration of morning stiffness (min): ≥30 vs. none | BMI, anxiety, inactivity gelling, bilateral knee pain, age | HR 1.22 (0.75 to 2) | 0.76
Thomas^*^, 2008^197^ prospective cohort Months of followup: 72 | Range of motion | Duration of morning stiffness (min): ≥30 vs. none | BMI, anxiety, inactivity gelling, bilateral knee pain, age, local tender point count, single-leg standing balance | HR 1.15 (0.7 to 1.89) | 0.77
Thomas^*^, 2008^197^ prospective cohort Months of followup: 72 | Range of motion | Duration of morning stiffness (min): ≥30 vs. none | BMI, anxiety, inactivity gelling, bilateral knee pain, age, local tender point count, single-leg standing balance, prevalent knee radiographic OA | HR 1.16 (0.7 to 1.91) | 0.77
Thomas^*^, 2008^197^ prospective cohort Months of followup: 72 | Range of motion | Inactivity gelling: Yes vs. no | Bilateral knee pain, duration of morning stiffness | HR 1.34 (0.98 to 1.83) | NR
Thomas^*^, 2008^197^ prospective cohort Months of followup: 72 | Range of motion | Inactivity gelling: Yes vs. no | BMI, anxiety, duration of morning stiffness, bilateral knee pain, age | HR 1.23 (0.89 to 1.71) | 0.69
Thomas^*^, 2008^197^ prospective cohort Months of followup: 72 | Range of motion | Inactivity gelling: Yes vs. no | BMI, anxiety, duration of morning stiffness, bilateral knee pain, age, local tender point count, single-leg standing balance | HR 1.19 (0.86 to 1.66) | 0.76
Thomas^*^, 2008^197^ prospective cohort Months of followup: 72 | Range of motion | Inactivity gelling: Yes vs. no | BMI, anxiety, duration of morning stiffness, bilateral knee pain, age, local tender point count, single-leg standing balance, prevalent knee radiographic OA | HR 1.19 (0.85 to 1.65) | 0.77
Thomas, 2008^197^ prospective cohort Months of followup: 72 | Strength | Hamstring strength (mm Hg): ≤100 vs. ≥185 | Unadjusted | HR 1.51 (1.12 to 2.02) | NR
Thomas, 2008^197^ prospective cohort Months of followup: 72 | Strength | Hamstring strength (mm Hg): 101–139 vs. ≥185 | Unadjusted | HR 1.31 (0.97 to 1.76) | NR
Thomas, 2008^197^ prospective cohort Months of followup: 72 | Strength | Hamstring strength (mm Hg): 140–184 vs. ≥185 | Unadjusted | HR 1.1 (0.81 to 1.5) | NR
Thomas, 2008^197^ prospective cohort Months of followup: 72 | Strength | Quadriceps strength (mm Hg): 141–200 vs. ≥300 | Unadjusted | HR 1.27 (0.93 to 1.73) | NR
Thomas, 2008^197^ prospective cohort Months of followup: 72 | Strength | Quadriceps strength (mm Hg) ≤140 vs. ≥300 | Unadjusted | HR 1.52 (1.12 to 2.06) | NR
Thomas, 2008^197^ prospective cohort Months of followup: 72 | Strength | Quadriceps strength (mm Hg):200–299 vs. ≥300 | Unadjusted | HR 1.08 (0.79 to 1.47) | NR
Wood^*^, 2008^204^ cross-sectional Months of followup: NA | Strength | ≤10 kg of force (quadriceps femoris muscle strength) vs. >30 kg | NR | OR 5.17 (3.01 to 8.86) | NR
Wood^*^, 2008^204^ cross-sectional Months of followup: NA | Strength | 10–20 kg of force (quadriceps femoris muscle strength) vs. >30kg | NR | OR 2.37 (1.57 to 3.59) | NR
Wood^*^, 2008^204^ cross-sectional Months of followup: NA | Strength | 20–30 kg of force (quadriceps femoris muscle strength) vs. >30kg | NR | OR 1.29 (0.83 to 2.01) | NR
Sharma, 2003^205^ prospective cohort Months of followup: 72 | Strength | Quadriceps strength, ft-lbs | Age, BMI, knee pain intensity, and disease severity (higher K/L grade of the 2 knees) | OR 0.88/20 ft-lbs (0.7 to 1.11) | NR
Sharma, 2003^205^ prospective cohort Months of followup: 72 | Strength | Hamstring strength, ft-lbs | Age, BMI, knee pain intensity, and disease severity (higher K/L grade of the 2 knees) | OR 0.86/20 ft-lbs (0.6 to 1.23) | NR
O’Reily^**^,1998^203^ nested case-control Months of followup: NA | Strength | MVC (Maximum voluntary contraction of quadriceps) (kgF): 20–30 vs. >30 | Age, sex, BMI, depression, anxiety, activation (percent), radiographic score | OR 1.48 (0.37 to 5.93) | NR
O’Reily^**^,1998^203^ nested case-control Months of followup: NA | Strength | MVC (Maximum voluntary contraction of quadriceps) (kgF): 10–20 vs. >30 | Age, sex, BMI, depression, anxiety, activation (percent), radiographic score | OR 4.88 (1.18 to 20.14) | NR
O’Reily^**^,1998^203^ nested case-control Months of followup: NA | Strength | MVC (Maximum voluntary contraction of quadriceps) (kgF): ≤10 vs. >30 | Age, sex, BMI, depression, anxiety, activation (percent), radiographic score | OR 8.23 (1.53 to 44.38) | NR
O’Reily^**^,1998^203^ nested case-control Months of followup: NA | Strength | MVC (Maximum voluntary contraction) (kgF): 30–40 vs. >40 | Age, sex, BMI, depression, anxiety, activation (percent), radiographic score | OR 3.04 (0.86 to 10.71) | NR
O’Reily^**^,1998^203^ nested case-control Months of followup: NA | Strength | MVC (Maximum voluntary contraction) (kgF): 20–30 vs. >40 | Age, sex, BMI, depression, anxiety, activation (percent), radiographic score | OR 3.77 (1.02 to 13.91) | NR
O’Reily^**^,1998^203^ nested case-control Months of followup: NA | Strength | MVC (Maximum voluntary contraction) (kgF): ≤20 vs. >40 | Age, sex, BMI, depression, anxiety, activation (percent), radiographic score | OR 4.98 (1.08 to 22.97) | NR
O’Reilly, 1998^203^ nested case-control Months of followup: NA | Strength | MVC (Maximum voluntary contraction of quadriceps) (kgF): 30–40 vs. >40 | Age, sex, BMI, depression, anxiety, activation, radiographic score | OR 1.49 (0.56 to 3.96) | NR
O’Reilly, 1998^203^ nested case-control Months of followup: NA | Strength | MVC (Maximum voluntary contraction of quadriceps) (kgF): 20–30 vs. >40 | Age, sex, BMI, depression, anxiety, activation, radiographic score | OR 3.17 (1.22 to 8.26) | NR
O’Reilly, 1998^203^ nested case-control Months of followup: NA | Strength | MVC (Maximum voluntary contraction of quadriceps) (kgF): 10–20 vs. >40 | Age, sex, BMI, depression, anxiety, activation, radiographic score | OR 7.1 (2.43 to 20.68) | NR
O’Reilly, 1998^203^ nested case-control Months of followup: NA | Strength | MVC (Maximum voluntary contraction of quadriceps) (kgF): ≤10 vs. >40 | Age, sex, BMI, depression, anxiety, activation, radiographic score | OR 18.83 (4.79 to 74.08) | NR
Thomas, 2008^197^ prospective cohort Months of followup: 72 | Swelling | Self-reported dramatic swelling: Yes vs. no | Unadjusted | HR 1.09 (0.83 to 1.44) | NR
Thomas, 2008^197^ prospective cohort Months of followup: 72 | Swelling | Self-reported swelling in past month: Yes vs. no | Unadjusted | HR 1.27 (1.03 to 1.56) | NR

BMI = Body Mass Index; HR = hazard rate ratio; NA = not applicable; NR = not reported; OA = osteoarthritis; OR = odds ratio; Strength of evidence was downgraded because single observational studies did not provide strong consistent and unbiased estimates;

* Thomas, 2008^197^; Wood, 2008^204^- functional disability was defined using Western Ontario and McMaster Universities Osteoarthritis Index (WOMAC) function scale;

** O’Reilly, 1998^203^ functional disability was defined using WOMAC functional score >19 or SF-36 functional score <90

### Gait

Gait measurements were associated with pain and poor functional outcomes (Appendix Table F33). Baseline stance time on stairs was positively associated with time to climb stairs at followup in a randomized trial of older adults with knee OA.199 In one cross-sectional study, gait speed was positively associated with maximal activity profile (the highest oxygen-demanding activity the participant is still able to perform).200 Adults with pain due to mild to moderate, clinically diagnosed medial-compartment knee OA had impaired walking speed.201 A prospective Multicenter Osteoarthritis Study found that intense pain was associated with 70 percent greater risk of clinically important decline in walking speed.202

### Muscle Strength

Muscle strength was positively associated with better function, but the significance and magnitude of the association differed depending on measures of strength and outcomes (Appendix Table F34). The studies demonstrated the importance of appropriate cut points to categorize muscle strength, and reported a statistically significant relationship between impairments in muscle strength and disability at the higher but not lower levels of impairment.203 197

The strongest association was reported in one large cross-sectional study of more than 6,000 older adults with knee OA.204 Patients with maximal isometric quadriceps femoris muscle strength (force-generating capacity) of 10–20kg had 137 percent relative risk increase of poor function compared with those with >30kg of force after controlling for age, sex, and BMI.204 The association was dose responsive with a greater than 417 percent relative risk increase of poor function in adults with weaker muscles (≤10kg of Force).204 The CAS(K) prospective cohort found that adults with weaker quadriceps or hamstring muscle strength had a 50 percent higher relative risk of poor WOMAC functional outcome.204

Another prospective cohort study, Mechanical Factors in Arthritis of the Knee (MAK), found no statistically significant association between quadriceps and hamstring muscle strength after adjustment for age, BMI, pain intensity, and disease severity.205 This study defined a physical function outcome as a clinically important change in chair-stand performance.205

One cross-sectional study found muscle strength to be negatively associated with both observed and self-reported disability measures.206 Functional disability, as assessed by total WOMAC score, was negatively associated with greater muscle strength.207 The association between muscle strength and functional disability was stronger in patients with high knee joint laxity.207

A single study found statistically significant association between quadriceps torque and balance performance (center of pressure path length) after controlling for disease severity, symptom bother, and WOMAC pain.208

### Impaired Balance Measurements

Impaired balance measurements demonstrated inconsistent association with functional status. A single prospective cohort study of older adults (CAS(K))197 found no statistically significant association between the impaired single-leg standing balance test and poor WOMAC functional outcomes after adjustment for age, BMI, knee pain, and stiffness (Appendix Table F35).197 In contrast, a cross-sectional study of older women found a statistically significant association between balance and outcomes of a functional test consisting of walking for 20 meters, climbing up and down nine stairs, and going from sitting to standing for five repetitions.209 Physical performance time improved in association with better balance.209 We cannot be certain whether study design, population, or balance measurements contributed to different conclusions in the studies.

### Range of Motion

Among other intermediate outcomes, increased range of motion was negatively associated with observed and self-reported disability (Appendix Table F36).206 A small cross-sectional study of 86 adults with knee OA found a statistically significant interaction between joint range of motion, muscle strength, and walking speed.207 A prospective cohort, the CAS(K),197 demonstrated that morning stiffness of 1–30 minutes predicted a 47 percent increase in relative risk of poor function at 18 months followup.197 Another prospective cohort study, the MAK, demonstrated a 58 percent increase in relative risk of poor function at 3 years followup per 3 degree increase in joint laxity after controlling for age, BMI, pain intensity, and disease severity.205

### Knee Mobility and Stability

Knee mobility and stability were weak predictors of functional performance. Joint mobility measures were not associated with poor WOMAC function (Appendix Table F37).197 Joint stability measures demonstrated a weak but statistically significant association with poor WOMAC function (Appendix Table F38).197, 205, 207, 208, 210 Adults with a positive Giving Way Test had a 33 percent relative increase in having a poor WOMAC Function Score.197 Knee instability or laxity was associated with a 58 percent relative increase in having a poor WOMAC Function Score.205, 210

Patient-centered outcomes were associated with a variety of tests (Table 6). Pain was associated with impaired functional status in adults with knee OA (Appendix Table F38). Adults with bilateral knee pain had a 46 percent relative risk increase of having a poor WOMAC Function Score (Appendix Table F39).197 An increased WOMAC Pain Score was also associated with a poor WOMAC Function Score.210 At followup, VAS pain intensity was associated with a 48 percent relative increase in risk of having a poor WOMAC Function Score (Appendix Table F40).205 In contrast, self-reported knee pain211 or local tender point counts were not associated with poor function (Appendix Table F41).197

Disability measures were associated with gait, mobility restrictions, muscle strength, and range of motion (Table 6). Several mobility restriction tests (VAS, Timed up and go [TUG] Test, Step Test, Gait Speed) were associated with impaired adjusted daily activity scores (Appendix Table F42). Mobility restrictions and the TUG Test were negatively associated with Adjusted Activity Score.200 Increased gait speed and step test were positively associated with adjusted daily activity score.200 Greater muscle strength and range of motion of the affected knee(s) were negatively associated with self-reported or observed disability (Appendix Table F36).206 Patients with more severe knee OA had impaired role function with physical limitations.212

We found no studies that reported time to return to work or activities. Patients with self-reported disability had increased risk of total joint replacement within a year of followup (Appendix Table F43). Patients with severe OA according to their Lequesne score had a 137 percent relative risk increase of having knee surgery within 1 year of followup (Adjusted OR 2.37, 95% CI, 1.71 to 3.25).213 Patients who considered themselves disabled had a 57 percent relative risk increase of total joint replacement within 1 year of consultation.213

Several studies examined the importance of self-efficacy and mental health for adults with knee OA (Table 9). Self-efficacy was defined as how patients perceive their ability to manage chronic arthritis, and it was measured using the Arthritis Self-Efficacy Scale.205 The Arthritis Self-Efficacy Scale function subscale is a self-rating of degree of certainty in one’s ability to walk 100 feet on flat ground in 20 seconds, walk down 10 steps in 7 seconds, and get out of an armless chair without using hands for support.205 Higher values correspond to better self-efficacy.205 Adults with good self-efficacy had an 11 percent relative decrease in risk of poor WOMAC function (Table 9).205

Table 9 Regression association between psychological and clinical outcomes; low strength of evidence from individual observational studies

Intermediate Outcomes | Disability Studies/N=Patients Estimate | Function Studies/Patients Estimate | Pain Studies/Patients Estimate | Quality of Life Studies/Patients Estimate
Anxiety | O’Reilly, 1998^203^ / N=300 NS OR | Thomas, 2008^197^ / N=621 1.3 HR O’Reilly, 1998^203^ / N=300^*^ | O’Reilly, 1998^203^ / N=300 NS OR
Baseline self-efficacy | | Rejeski, 1998^199^/ N=439^*^ Maly, 2006^246^ / N= 54 *
Depression | O’Reilly, 1998^203^ / N=300 6.2 OR | Wolfe, 1999^231^ / N=2115 * WOMAC function Wolfe, 1999^231^ / N=2115 * WOMAC stiffness O’Reilly, 1998^203^ / N=300^*^ | Wolfe, 1999^231^ / N=2115^*^ O’Reilly, 1998^203^ / N=300 2.4 OR
Fatigue | | Wolfe, 1999^231^ / N=2115 * WOMAC function Wolfe, 1999^231^ / N=2115 * WOMAC stiffness | Wolfe, 1999^231^ / N=2115^*^
Mental health score | | Sharma, 2003^205^ / N=257 0.6 OR
Role functioning emotional score | | Sharma, 2003^205^ / N=257 NS OR
Psychological well being: cheerfulness | | | van Baar, 1998^206^ / N=185^*^
Self-efficacy score | | Sharma, 2003^205^ / N=257 0.89/2.5points in OR
Functional self-efficacy | | | | Harrison, 2004^209^ / N=50 NS^*^

HR = hazard rate ratio; OR = odds ratio; WOMAC = Western Ontario and McMaster Universities Osteoarthritis Index;

Note: Bold = statistically significant association at 95% confidence level

* Linear regression; Strength of evidence was downgraded because single observational studies did not provide strong consistent and unbiased estimates

Self-reported health outcomes, including anxiety, depression, and fatigue, were associated with poor functional status. Older adults with knee pain and anxiety had higher risk of having poor WOMAC function compared with adults without anxiety (Appendix Table F44).197

Adults with good mental health had lower risk of having poor WOMAC function.205 Adults with greater social support had lower risk of having poor WOMAC function.205 Several studies found that depression and frustration demonstrated strong positive correlation with poor functional status (Appendix Table F45).206, 211, 214–219

In summary, disability measures were associated with gait, mobility restrictions, muscle strength, and range of motion measures, but the magnitude and clinical importance of the associations remain unclear. Individual studies did not offer strong and consistent evidence for determining which intermediate outcomes strongly and consistently predict patient-centered outcomes.

## Key Question 2a What is the validity of the tests and measures used to determine intermediate outcomes of physical therapy on OA in association with patient-centered outcomes?

Validation of the tests and measures used to determine intermediate outcomes of physical therapy on knee OA was reported in 66 studies of 14,563 adults. Many articles reported validation, but few demonstrated a strong (more than 50 percent) correlation between index and reference method measurements (Appendix Table F46). The studies used a variety of reference methods and judged validity on the basis of statistically significant correlation coefficients. Strength of correlation varied across validity types (Appendix Table F47).

We synthesized the evidence of the correlation between intermediate and patient-centered outcomes. Mean age averaged around 64 years, and ranged from 29 to 67 (Appendix Table F48). Women constituted 64 percent of the participants. Sample size of the studies varied with a median of 109 and a mean of 254 participants. The American studies were the only ones to include minorities, but they did not separately report those results. Some studies did not distinguish patients with diagnosed knee OA from those with self-reported OA or knee pain. The studies analyzed correlation coefficients between index and reference methods and did not use strategies to reduce bias.

The correlation strength varied across measurements and reference standards for intermediate outcomes (Appendix Table F49). Balance measures with Standing Balance Test correlated with radiographic degenerative changes.220 The Knee Proprioception Test (quantified as the ability to replicate target knee joint angles using a computerized dynamometer) did not correlate with radiographic degenerative changes.220 Knee range of motion was assessed as self-reported morning stiffness,221 Arthritis Impact Measurement Scale dexterity subscale,222 Knee Patient-Specific Index,223 Lequesne index,224 or WOMAC stiffness subscale224 (Appendix Table F49). A strong correlation was reported for the Knee Patient-Specific Index with the WOMAC Stiffness scale223 and for the Lequesne Index with the WOMAC Stiffness subscale.224 A strong correlation was demonstrated for range of motion to ipsilateral hip abduction with knee flexion on the affected side.225 Other tests demonstrated very weak or no correlation with patient-centered outcomes (Appendix Table F50). Measurements of pain and function in relation to symptom bother were validated with the Short Form Health Questionnaire,226 The Influence of Rheumatic Disease on General Health and Lifestyle mobility subscale,227 or the Global Functional Rating228 (Appendix Table F51).

Many studies used validated WOMAC subscales as a reference standard (Appendix Table F52). The WOMAC scale is recommended to measure clinical outcomes in trials involving adults with knee OA56, 229 because it is a validated instrument with different subscales for pain and stiffness as well as for physical, social, and emotional function.54, 230–232 Several studies examined whether the WOMAC satisfied the Rasch model (Rasch Item Response Theory) (Appendix Table F53). To satisfy Rasch criteria, subscales must be unidimensional by measuring the anticipated concept of pain and function and not have redundant items counting repeatedly toward the overall score. One study of 655 patients with osteoarthritis of the knee or hip concluded that pain and function subscales were unidimensional and did not collect redundant information.233 The second study of 158 patients with knee or hip OA found that pain and function items may represent the same construct and introduce redundancy for calculation of overall score.234 A prospective cohort followed 1,151 adults with knee OA or hip OA for 1 year after arthroplasty.235 The authors concluded that prospectively collected responses evaluate changes in functional status. The study suggested that when monitoring treatment effects with WOMAC, certain items should be omitted, including night pain and pain on standing, heavy domestic duties, getting in and out of the bath, and getting on and off the toilet.235 All studies recommended using WOMAC to measure patient-centered outcomes in adults treated for knee OA.

## Key Question 2b Which intermediate outcomes meet the criteria of surrogates for patient-centered outcomes?

In order to be considered surrogates for patient-centered outcomes, measurements in functional impairments are expected to predict patient-centered outcomes. However, none of the intermediate outcomes met this criterion. TEP members proposed gait as a feasible candidate for a surrogate endpoint; however, no studies examined the association between gait and patient-centered outcomes in adults with knee OA treated with physical therapy interventions. While a single RCT concluded that knee pain and self-efficacy mediated the effects of exercise on stair climb time,199 no evidence supported an association or predictive power between gait change and patient-centered outcome change. A single longitudinal study of older adults demonstrated that impaired gait and Physical Performance Test were independent predictors of nursing home placement.236 Three cohort studies, including The Einstein Aging Study,237 the Chinese Elderly Cohort,238 and the Women’s Health and Aging Study,239 examined the association between gait and nursing home placement (Appendix Table F54). However, these studies included adults with any etiology of gait problem, including neurological diseases or heart failure. Moreover, definitions of impaired gait and magnitude of the association were inconsistent across the studies.

## Key Question 2c What are minimum clinically important differences of the tests and measures used to determine intermediate outcomes?

MCIDs refer to thresholds of change in outcomes measurements that result in statistically significant changes in clinical outcomes. Such thresholds were determined comparing the changes in performance measure with patient perception of improvement. Establishing accurate MCIDs helps to clarify whether statistically significant changes in outcome measures actually equate with patient opinions about treatment success and improved quality of life. MCIDs are necessary for evaluating whether changes in commonly used outcomes measurements or scales are of actual clinical importance to patients.

Thirty studies of 13,138 adults reported MCIDs. The studies used the anchor method, which compares changes in scales with patient perception of improvements. MCIDs were available for 26 tools as absolute change in score or relative change as a percent difference from baseline levels. The latter method incorporated baseline severity of the diseases (Appendix Table F55). Only a few studies defined MCID with the distribution method, which is based on distribution of changes in outcomes measurements and defined MCID as an upper quartile of the distribution.

We identified 16 studies that determined (with slight variation) MCIDs in WOMAC scales and subscales (Appendix Table F55). The Osteoarthritis Research Society International Standing Committee for Clinical Trials determined that patient perception of “high” improvement in pain corresponded to at least a 40 percent relative change in WOMAC with a minimum absolute improvement of 20 to 30 NU (normalized units).240 Patients noticed improvement when WOMAC subscales changed by a margin of 17 to 22 percent of baseline scores.241

Few studies determined Patient Acceptable Symptom State (PASS) for knee OA. PASS is defined as the highest level of symptom patients can tolerate and still be satisfied with their treatment. The studies that determined PASS used the same anchor method as they did for determining MCIDs. However, the anchor questions used by these studies differed by specifically asking patients whether they were satisfied with their functional status in relation to daily activities and quality of life. PASS was determined for three scales (WOMAC, VAS for pain, and the Patient Global Assessment) (Appendix Table F56).242

MCIDs in SF-36 were determined for patients with severe knee OA before or after surgery (Appendix Table F57).243–245 In the SF-36, MCIDs were 12.83 for pain, 0.11 for general health, 0.76 for mental health, and 10.04 for physical functioning.244 At 6 months followup, mean changes of 22 in an SF-36 bodily pain score and of 38 in physical functioning equated to patient reports of feeling “a great deal better.”245 A variety of other tests and scales proposed MCIDs to judge clinical effectiveness of treatments (including the Timed Up and Go,246, 247 the 6-Minute Walk Test,246, 247 and the Short Physical Performance Battery)247 (Appendix Table F58).

### Summary

In individual studies, muscle strength, range of motion, mobility restrictions, and gait were associated with patient-centered outcomes, but individual studies did not provide consistent strong evidence for robust conclusions. Many articles reported validation, but few demonstrated a strong (more than 50 percent) correlation between index and reference method measurements.

Original studies concluded that tests were valid based on significance, not strength of correlation. None of the intermediate outcomes met surrogate criteria for patient-centered outcomes.

Validated tools defined threshold values of clinical importance for evaluating treatment success, but studies more often used continuous measures of outcomes, providing an average score for all patients in each treatment group with no evaluation of clinical importance. Average scores, however, do not reveal how many patients develop disability, or experience clinically meaningful improvement in pain, function, or quality of life.

## Key Question 3 What are the harms from physical therapy interventions for adult patients with chronic knee pain due to osteoarthritis, when compared to no active treatment or active controls?

a. Which patient characteristics are associated with the harms of examined physical therapy interventions?
b. Do harms differ by the duration of the treatment and time of followup?

Adverse events were uncommon and varied across interventions. Skin irritation was reported with brace, insole, tape, and electrical stimulation; swelling with brace, diathermy, and exercise; muscle soreness with electrical stimulation; grumbling, warming, or throbbing sensation with diathermy, electrical stimulation, and PEMF; increased pain with diathermy, exercise, insole, and PEMF; falls with insole; and need for surgery with diathermy. Rates of adverse events did not differ significantly between treatment groups (Table 10). Nor were adverse events severe enough to deter participants from continuing treatment.

Table 10 Adverse events reported with physical therapy for knee osteoarthritis

Treatment | Definition of Adverse Events | Studies | Patients | Relative Risk Number Needed To Treat To Harm | Strength of Evidence
Diathermy vs. placebo | Adverse event including mild pain, mild swelling, feeling of vasodilatation, deterioration of pain, or needed operation | 1^168^ | 113 | 1.13 (0.30 to 4.31) | Low
E-stim vs. placebo | Mild skin reaction | 2^140, 171^ | 136 | 1.02 (0.53 to 1.97) | Low
Interferential (IF) and patterned muscle stimulation vs. low-current transcutaneous electrical nerve stimulation | Adverse event including skin irritation, skin burns, muscle soreness, electrical shock, and unanticipated adverse events | 1^249^ | 109 | 0.57 (0.20 to 1.58) | Low
Aquatic exercise vs. land-based exercise | Increased pain during and after exercise, or swollen knees | 1 94 | 52 | 0.25 (0.08 to 0.80) 3 (2 to 10) | Low
Aquatic exercise vs. land-based exercise | Discontinuation due to adverse effects | 1^94^ | 52 | 0.14 (0.01 to 2.54) | Low
Home based progressive exercise vs. home based control exercise | Adverse event, not specified | 1^250^ | 179 | 0.60 (0.21 to 1.78) | Low
8 mm laterally wedged insole vs. 12 mm laterally wedged insole | Popliteal pain, low back pain, or foot sole pain | 1^190^ | 41 | 0.7 (0.13 to 3.76) | Low
8 mm laterally wedged insole vs. 16 mm laterally wedged insole | Popliteal pain, low back pain, or foot sole pain | 1 190 | 41 | 0.23 (0.06 to 0.95) 3 (2 to 13) | Low
12 mm laterally wedged insole vs. 16 mm laterally wedged insole | Popliteal pain, low back pain, or foot sole pain | 1^190^ | 42 | 0.33 (0.10 to 1.06) | Low
Strapped insole vs. Inserted insole | Popliteal pain, low back pain, or foot sole pain | 1^129^ | 90 | 5.74 (0.72 to 45.77) | Low
5 degree lateral wedge insole vs. neutrally wedged insole | Musculoskeletal symptoms | 1^183^ | 180 | 0.6 (0.231 to 1.58) | Low
5 degree lateral wedge insole vs. neutrally wedged insole | Blisters | 1^183^ | 180 | 0.2 (0.02 to 1.68) | Low
5 degree lateral wedge insole vs. neutrally wedged insole | Falls | 1^183^ | 180 | 1.33 (0.31 to 5.79) | Low
5 degree laterally wedged insole vs. neutrally wedged insole | Self reported problems with insoles | 1 177 | 179 | 2.02 (1.31 to 3.12) 4(3 to 10) | Low
5 degree laterally wedged insole vs. neutrally wedged insole | Back pain | 1 177 | 179 | 9.10 (1.18 to 70.35) 11 (6 to 42) | Low
5 degree laterally wedged insole vs. neutrally wedged insole | Foot pain | 1 177 | 179 | 2.31 (1.33 to 4.03) | Low
5 degree laterally wedged insole vs. neutrally wedged insole | Uncomfortable or difficulty fitting in shoes | 1 177 | 179 | 3.79 (1.31 to 10.99) 5 (3 to 13) | Low
5 degree laterally wedged insole vs. neutrally wedged insole | Increased knee pain | 1^177^ | 179 | 0.40 (0.08 to 2.031) | Low
5 degree laterally wedged insole vs. neutrally wedged insole | Felt unstable | 1^177^ | 179 | 0.34 (0.01 to 8.16) | Low
5 degree laterally wedged insole vs. neutrally wedged insole | Any discomfort | 1 177 | 163 | 1.79 (1.17 to 2.74) | Low
Medial insole vs. neutrally wedged insole | Mild discomfort | 1^177^ | 30 | 0.29 (0.01 to 6.69) | Low
PEMF vs. placebo | Grumbling or throbbing sensation | 1^155^ | 90 | 1 (0.27 to 3.75) | Low
PEMF vs. placebo | Warming sensation | 1^155^ | 90 | 6 (0.75 to 47.85) | Low
PEMF vs. placebo | Aggravation of the osteoarthritic pain in the study knee | 1^155^ | 90 | 2 (0.19 to 21.28) | Low
Therapeutic tape vs. control tape | Skin irritation | 1 137 | 58 | 8 (1.07 to 59.95) 4 (2;15) | Low

E-stim = electrical stimulation; PEMF = pulsed electromagnetic fields

Note: Bold = statistically significant association at 95% confidence level

Only four statistically significant findings were reported. Lund et al. found that adverse events were six times more likely following land-based exercise than aquatic exercise, yet insignificantly led to discontinuation.94 Use of a 16mm lateral wedged insole resulted in more pain than an 8mm lateral wedge.190 Compared with neutrally wedged insoles, laterally wedged insoles led to more back pain, foot pain, and other discomfort.177 Hinman et al. reported that skin irritation was more likely with therapeutic tape than control tape.137 Two studies compared skin reactions with active electrical stimulation and inactive sham stimulation. The pooled analysis140, 171 showed that electrical stimulation did not increase risk of skin irritation.