# References

1 Lawrence RC, Felson DT, Helmick CG, et al. Estimates of the prevalence of arthritis and other rheumatic conditions in the United States. Part II. Arthritis Rheum. Jan. 2008;58(1):26-35. [pmid: 18163497].
2 Johnson CA. Chapter 12. Approach to the Patient with Knee Pain. CURRENT Rheumatology Diagnosis & Treatment. 2e.
3 Jordan JM, Helmick CG, Renner JB, et al. Prevalence of knee symptoms and radiographic and symptomatic knee osteoarthritis in African Americans and Caucasians: the Johnston County Osteoarthritis Project. J Rheumatol. Jan. 2007;34(1):172-80. [pmid: 17216685].
4 Dillon CF, Rasch EK, Gu Q, et al. Prevalence of knee osteoarthritis in the United States: arthritis data from the Third National Health and Nutrition Examination Survey 1991–94. J Rheumatol. Nov. 2006;33(11):2271-9. [pmid: 17013996].
5 Oliveria SA, Felson DT, Reed JI, et al. Incidence of symptomatic hand, hip, and knee osteoarthritis among patients in a health maintenance organization. Arthritis Rheum. Aug. 1995;38(8):1134-41. [pmid: 7639811].
6 Felson DT, Zhang Y, Hannan MT, et al. The incidence and natural history of knee osteoarthritis in the elderly. The Framingham Osteoarthritis Study. Arthritis Rheum. Oct. 1995;38(10):1500-5. [pmid: 7575700].
7 Bernstein AB, Hing E, Moss AJ, et al. Health care in America: Trends in utilization. Hyattsville, Maryland. National Center for Health Statistics. 2003.
8 Imboden J. Chapter 4. Approach to the Patient with Arthritis. CURRENT Rheumatology Diagnosis & Treatment. 2e.
9 American Academy of Orthopaedic Surgeons treatment of osteoarthritis of the knee (non-arthroplasty). American Academy of Orthopaedic Surgeons (AAOS). Dec. 2008;6:263.
10 National Collaborating Centre for Chronic Conditions. Osteoarthritis: national clinical guideline for care and management in adults. Royal College of Physicians. London. 2008.
11 Andersson GBJ, Bouchard J, Bozic KJ, et al. Arthritis and related conditions. The Burden of Musculoskeletal Diseases. Rosemont, IL. Bone and Joint Decade. 2008:71-96.
12 Andersson GBJ, Bouchard J, Bozic KJ, et al. Health care utilization and economic cost of musculoskeletal diseases. The Burden of Musculoskeletal Diseases. Rosemont, IL. Bone and Joint Decade. 2008:195-225.
13 Zhang W, Moskowitz RW, Nuki G, et al. OARSI recommendations for the management of hip and knee osteoarthritis, Part II: OARSI evidence-based, expert consensus guidelines. Osteoarthritis Cartilage. Feb. 2008;16(2):137-62. [pmid: 18279766].
14 Jordan KM, Arden NK, Doherty M, et al. EULAR Recommendations 2003: an evidence based approach to the management of knee osteoarthritis: Report of a Task Force of the Standing Committee for International Clinical Studies Including Therapeutic Trials (ESCISIT). Ann Rheum Dis. Dec. 2003;62(12):1145-55. [pmid: 14644851].
15 Mazzuca SA, Brandt KD, Katz BP, et al. Comparison of general internists, family physicians, and rheumatologists managing patients with symptoms of osteoarthritis of the knee. Arthritis Care Res. Oct. 1997;10(5):289-99. [pmid: 9362595].
16 Ottawa panel evidence-based clinical practice guidelines for therapeutic exercises and manual therapy in the management of osteoarthritis. Physical Therapy. Sep. 2005;85(9):907-71. [pmid: 16117601].
17 Richmond J, Hunter D, Irrgang J, et al. American Academy of Orthopaedic Surgeons clinical practice guideline on the treatment of osteoarthritis (OA) of the knee. Journal of Bone & Joint Surgery - American Volume. Apr. 2010;92(4):990-3. [pmid: 20360527].
18 Rutjes AW, Nuesch E, Sterchi R, et al. Therapeutic ultrasound for osteoarthritis of the knee or hip. Cochrane Database Syst Rev. 2010;20(1):CD003132. [pmid: 20091539].
19 Rutjes AW, Nuesch E, Sterchi R, et al. Transcutaneous electrostimulation for osteoarthritis of the knee. Cochrane Database Syst Rev. 2009;(4):CD002823. [pmid: 19821296].
20 Fransen M, McConnell S. Exercise for osteoarthritis of the knee. Cochrane Database Syst Rev. 2008;(4):CD004376. [pmid: 18843657].
21 Zhang W, Nuki G, Moskowitz RW, et al. OARSI recommendations for the management of hip and knee osteoarthritis: part III: Changes in evidence following systematic cumulative update of research published through January 2009. Osteoarthritis Cartilage. 2010;18(4):476-99. [pmid: 20170770].
22 Helfand M, Balshem H. AHRQ series paper 2: principles for developing guidance: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):484-90. [pmid: 19716268].
23 World Health Organization. International classification of functioning, disability and health: ICF. Geneva. World Health Organization. 2001.
24 Agency for Healthcare Research and Quality. HHS Awards $473 Million in Patient-Centered Outcomes Research Funding. Agency for Healthcase Research and Quality. Rockville, MD. 2010.
25 Tallon D, Chard J, Dieppe P. Exploring the priorities of patients with osteoarthritis of the knee. Arthritis Care Res. Oct. 2000;13(5):312-9. [pmid: 14635301].
26 Bellamy N, Kirwan J, Boers M, et al. Recommendations for a core set of outcome measures for future phase III clinical trials in knee, hip, and hand osteoarthritis. Consensus development at OMERACT III. J Rheumatol. Apr. 1997;24(4):799-802. [pmid: 9101522].
27 Brouwer RW, Jakma TS, Verhagen AP, et al. Braces and orthoses for treating osteoarthritis of the knee. Cochrane Database of Systematic Reviews. 2005;(1):004020. [pmid: 15674927].
28 Brosseau L, Yonge KA, Robinson V, et al. Thermotherapy for treatment of osteoarthritis. Cochrane Database Syst Rev. 2003;(4):CD004522. [pmid: 14584019].
29 Michael JW, Schluter-Brust KU, Eysel P. The epidemiology, etiology, diagnosis, and treatment of osteoarthritis of the knee. Dtsch Arztebl Int. Mar. 2010;107(9):152-62. [pmid: 20305774].
30 Felson DT. Clinical practice. Osteoarthritis of the knee. N Engl J Med. Feb. 23. 2006;354(8):841-8. [pmid: 16495396].
31 Liberati A, Altman DG, Tetzlaff J, et al. The PRISMA statement for reporting systematic reviews and meta-analyses of studies that evaluate health care interventions: explanation and elaboration. Annals of Internal Medicine. Aug. 18. 2009;151(4):W65-94. [pmid: 19622512].
32 White CM, Ip S, McPheeters ML, et al. Using existing systematic reviews to replace de novo processes in conducting Comparative Effectiveness Reviews. Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness Reviews. [posted September 2009]. Rockville, MD. 2009.
33 Norris S, Atkins D, Bruening W, et al. Selecting Observational Studies for Comparing Medical Interventions. 2008. [pmid: 21433401].
34 Chou R, Aronson N, Atkins D, et al. Assessing harms when comparing medical interventions: AHRQ and the Effective Health-Care Program. J Clin Epidemiol. 2008. Sep. 25. [pmid: 18823754].
35 Higgins J, Green S. Cochrane Collaboration. Cochrane handbook for systematic reviews of interventions. Chichester, West Sussex; Hoboken NJ. John Wiley & Sons. 2011.
36 Norris S, Atkins D, Bruening W, et al. Selecting observational studies for comparing medical interventions. Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness Reviews. 2010.
37 Impaired Joint Mobility, Motor Function, Muscle Performance, and Range of Motion Associated with Localized Inflammation. Guide to Physical Therapist Practice. 2nd ed. Phys Ther. 2010.
38 AHRQ. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. 2011.
39 Whiting PF, Weswood ME, Rutjes AW, et al. Evaluation of QUADAS, a tool for the quality assessment of diagnostic accuracy studies. BMC Med Res Methodol. 2006;6:9. [pmid: 16519814].
40 Methods Guide for Medical Test Reviews. Methods Guide for Medical Test Reviews. 2010.
41 Higgins JPT, Green S. Cochrane Collaboration. Cochrane handbook for systematic reviews of interviews. 502 ed. London. Cochrane Collaboration. 2009.
42 Herbison P, Hay-Smith J, Gillespie WJ. Adjustment of meta-analyses on the basis of quality scores should be abandoned. J Clin Epidemiol. Dec. 2006;59(12):1249-56. [pmid: 17098567].
43 Aschengrau A, Seage GR. Essentials of Epidemiology in Public Health. Sudbury, Mass. Jones and Bartlett. 2003.
44 Friedrich JO, Adhikari NK, Beyene J. Ratio of means for analyzing continuous outcomes in meta-analysis performed as well as mean difference methods. Journal of Clinical Epidemiology. May. 2011;64(5):556-64. [pmid: 21447428].
45 Fu R, Gartlehner G, Grant M, et al. Conducting Quantitative Synthesis When Comparing Medical Interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2010;64(11):1187-97. [pmid: 21477993].
46 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-60. [pmid: 12958120].
47 Wallace BC, Schmid CH, Lau J, et al. Meta-Analyst: software for meta-analysis of binary, continuous and diagnostic data. BMC Med Res Methodol. 2009;9:80. [pmid: 19961608].
48 Egger M, Smith GD, Altman DG. Systematic Reviews in Health Care. London. NetLibrary, Inc BMJ Books. 2001.
49 Cohen J. Statistical Power Analysis for the Behavioral Sciences: Second Edition. Hillsdale, New Jersey. Lawrence Erlbaum Associates. 1988.
50 Higgins J, Green S. The Cochrane Collaboration. The Cochrane handbook for systematic reviews of interventions. Chichester, UK. John Wiley & Sons, Ltd, Cochrane Collaboration. 2006. http://www.cochrane.org/sites/default/files/uploads/Handbook4.2.6Sep2006.pdf. Accessed July 2012.
51 Shaw JW, Johnson JA, Coons SJ. US valuation of the EQ-5D health states: development and testing of the D1 valuation model. Med Care. Mar. 2005;43(3):203-20. [pmid: 15725977].
52 Ware JE Jr, Kosinski M, Bayliss MS, et al. Comparison of methods for the scoring and statistical analysis of SF-36 health profile and summary measures: summary of results from the Medical Outcomes Study. Med Care. Apr. 1995;33(4 Suppl):AS264-79. [pmid: 7723455].
53 White DK, Keysor JJ, Lavalley MP, et al. Clinically important improvement in function is common in people with or at high risk of knee OA: the MOST study. J Rheumatol. Jun. 2010;37(6):1244-51. [pmid: 20395640].
54 Lingard EA, Katz JN, Wright RJ, et al. Validity and responsiveness of the Knee Society Clinical Rating System in comparison with the SF-36 and WOMAC. J Bone Joint Surg Am. Dec. 2001;83-A(12):1856-64. [pmid: 11741066].
55 Chou R, Helfand M, Peterson K, et al. Comparative effectiveness and safety of analgesics for osteoarthritis. Comparative effectiveness review No. 4. Agency for Healthcare Research and Quality. Rockville, MD. 2006.
56 Pham T, Van Der Heijde D, Lassere M, et al. Outcome variables for osteoarthritis clinical trials: The OMERACT-OARSI set of responder criteria. Journal of Rheumatology. 2003;30(7):1648-54. [pmid: 12858473].
57 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
58 Viechtbauer W. Confidence intervals for the amount of heterogeneity in meta-analysis. Stat Med. 2006. Feb. 6. [pmid: 16463355].
59 Knapp G, Biggerstaff BJ, Hartung J. Assessing the amount of heterogeneity in random-effects meta-analysis. Biom J. Apr. 2006;48(2):271-85. [pmid: 16708778].
60 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
61 Sterne JA, Sutton AJ, Ioannidis JP, et al. Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011;343:d4002. [pmid: 21784880].
62 Ebrahim S. The use of numbers needed to treat derived from systematic reviews and meta-analysis. Caveats and pitfalls. Eval Health Prof. Jun. 2001;24(2):152-64. [pmid: 11523384].
63 Altman DG. Confidence intervals for the number needed to treat. Bmj. Nov. 7. 1998;317(7168):1309-12. [pmid: 9804726].
64 Altman DG, Bland JM. Diagnostic tests 3: receiver operating characteristic plots. BMJ. Jul. 16. 1994;309(6948):188. [pmid: 8044101].
65 Deeks JJ, Altman DG. Diagnostic tests 4: likelihood ratios. BMJ. Jul. 17. 2004;329(7458):168-9. [pmid: 15258077].
66 Altman DG, Bland JM. Diagnostic tests 2: Predictive values. BMJ. Jul. 9. 1994;309(6947):102. [pmid: 8038641].
67 Lassere MN, Johnson KR, Boers M, et al. Definitions and validation criteria for biomarkers and surrogate endpoints: development and testing of a quantitative hierarchical levels of evidence schema. J Rheumatol. Mar. 2007;34(3):607-15. [pmid: 17343307].
68 Guyatt G, Oxman AD, Kunz R, et al. GRADE guidelines 6. Rating the quality of evidence-imprecision. J Clin Epidemiol. 2011. Aug. 10. [pmid: 21839614].
69 U.S. Preventive Services Task Force. Procedure Manual. AHRQ Publication. 2008. No. 08-05118-EF http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm. Accessed in December 2011.
70 Keefe FJ, Blumenthal J, Baucom D, et al. Effects of spouse-assisted coping skills training and exercise training in patients with osteoarthritic knee pain: a randomized controlled study. Pain. Aug. 2004;110(3):539-49. [pmid: 15288394].
71 Rejeski WJ, Focht BC, Messier SP, et al. Obese, older adults with knee osteoarthritis: weight loss, exercise, and quality of life. Health Psychology. 2002;21(5):419-26. [pmid: 12211508].
72 Messier SP, Loeser RF, Miller GD, et al. Exercise and dietary weight loss in overweight and obese older adults with knee osteoarthritis: the Arthritis, Diet, and Activity Promotion Trial. Arthritis Rheum. May. 2004;50(5):1501-10. [pmid: 15146420].
73 Farr JN, Going SB, McKnight PE, et al. Progressive resistance training improves overall physical activity levels in patients with early osteoarthritis of the knee: a randomized controlled trial. Phys Ther. Mar. 2010;90(3):356-66. [pmid: 20056719].
74 Shakoor MA, Taslim MA, Hossain MS. Effects of activity modification on the patients with osteoarthritis of the knee. Bangladesh Med Res Counc Bull. Aug. 2007;33(2):55-9. [pmid: 18481439].
75 Deyle GD, Henderson NE, Matekel RL, et al. Effectiveness of manual physical therapy and exercise in osteoarthritis of the knee. A randomized, controlled trial. Annals of Internal Medicine. 2000;132(3):173-81. [pmid: 10651597].
76 Aglamis B, Toraman NF, Yaman H. The effect of a 12-week supervised multicomponent exercise program on knee OA in Turkish women. Journal of Back and Musculoskeletal Rehabilitation. 2008;21(2):121-8.
77 Kovar PA, Allegrante JP, MacKenzie CR, et al. Supervised fitness walking in patients with osteoarthritis of the knee. A randomized, controlled trial. Annals of Internal Medicine. Apr. 1. 1992;116(7):529-34. [pmid: 1543305].
78 Messier SP, Thompson CD, Ettinger WH. Effects of long-term aerobic or weight training regimes on gait in an older, osteoarthritic population. Journal of Applied Biomechanics. 1997;13(2):205-25.
79 Bautch JC, Malone DG, Vailas AC. Effects of exercise on knee joints with osteoarthritis: a pilot study of biologic markers. Arthritis Care Res. Feb. 1997;10(1):48-55. [pmid: 9313390].
80 Péloquin L, Bravo G, Gauthier P, et al. Effects of a Cross-Training Exercise Program in Persons with Osteoarthritis of the Knee A Randomized Controlled Trial. J Clin Rheumatol. Jun. 1999;5(3):126-36. [pmid: 19078371].
81 Yip YB, Sit JW, Fung KK, et al. Impact of an Arthritis Self-Management Programme with an added exercise component for osteoarthritic knee sufferers on improving pain, functional outcomes, and use of health care services: An experimental study. Patient Educ Couns. Jan. 2007;65(1):113-21. [pmid: 17010554].
82 Yip YB, Sit JW, Wong DY, et al. A 1-year follow-up of an experimental study of a self-management arthritis programme with an added exercise component of clients with osteoarthritis of the knee. Psychology Health & Medicine. 2008;13(4):402-14. [pmid: 18825579].
83 Ettinger WH Jr, Burns R, Messier SP, et al. A randomized trial comparing aerobic exercise and resistance exercise with a health education program in older adults with knee osteoarthritis. The Fitness Arthritis and Seniors Trial (FAST). Journal - American Medical Association. 1997;277(1):25-31. [pmid: 8980206].
84 Sullivan T, Allegrante JP, Peterson MG, et al. One-year followup of patients with osteoarthritis of the knee who participated in a program of supervised fitness walking and supportive patient education. Arthritis Care Res. Aug. 1998;11(4):228-33. [pmid: 9791321].
85 An B, Dai K, Zhu Z, et al. Baduanjin alleviates the symptoms of knee osteoarthritis. J Altern Complement Med. Mar. 2008;14(2):167-74. [pmid: 18315512].
86 Hay EM, Foster NE, Thomas E, et al. Effectiveness of community physiotherapy and enhanced pharmacy review for knee pain in people aged over 55 presenting to primary care: pragmatic randomised trial. BMJ. Nov. 11. 2006;333(7576):995. [pmid: 17056608].
87 Jan MH, Lin CH, Lin YF, et al. Effects of weight-bearing versus nonweight-bearing exercise on function, walking speed, and position sense in participants with knee osteoarthritis: a randomized controlled trial. Arch Phys Med Rehabil. 2009;90(6):897-904. [pmid: 19480863].
88 Thomas KS, Muir KR, Doherty M, et al. Home based exercise programme for knee pain and knee osteoarthritis: randomised controlled trial. British medical journal. 2002;325(7367):752-5. [pmid: 12364304].
89 Talbot LA, Gaines JM, Huynh TN, et al. A home-based pedometer-driven walking program to increase physical activity in older adults with osteoarthritis of the knee: a preliminary study. J Am Geriatr Soc. Mar. 2003;51(3):387-92. [pmid: 12588583].
90 Peterson MG, Kovar-Toledano PA, Otis JC, et al. Effect of a walking program on gait characteristics in patients with osteoarthritis. Arthritis Care Res. Mar. 1993;6(1):11-6. [pmid: 8443252].
91 Focht BC, Rejeski WJ, Ambrosius WT, et al. Exercise, self-efficacy, and mobility performance in overweight and obese older adults with knee osteoarthritis. Arthritis Rheum. Oct. 15. 2005;53(5):659-65. [pmid: 16208674].
92 Thorstensson CA, Roos EM, Petersson IF, et al. Six-week high-intensity exercise program for middle-aged patients with knee osteoarthritis: a randomized controlled trial. [ISRCTN20244858]. BMC Musculoskeletal Disorders. 2005;6(Journal Article):27. [pmid: 15924620].
93 Patrick DL, Ramsey SD, Spencer AC, et al. Economic evaluation of aquatic exercise for persons with osteoarthritis. Med Care. May. 2001;39(5):413-24. [pmid: 11317090].
94 Lund H, Weile U, Christensen R, et al. A randomized controlled trial of aquatic and land-based exercise in patients with knee osteoarthritis. J Rehabil Med. Feb. 2008;40(2):137-44. [pmid: 18509579].
95 Rooks DS, Huang J, Bierbaum BE, et al. Effect of preoperative exercise on measures of functional status in men and women undergoing total hip and knee arthroplasty. Arthritis Rheum. Oct. 15. 2006;55(5):700-8. [pmid: 17013852].
96 Schilke JM, Johnson GO, Housh TJ, et al. Effects of muscle-strength training on the functional status of patients with osteoarthritis of the knee joint. Nursing Research. Mar–Apr. 1996;45(2):68-72. [pmid: 8604366].
97 Kuptniratsaikul V, Tosayanonda O, Nilganuwong S, et al. The efficacy of a muscle exercise program to improve functional performance of the knee in patients with osteoarthritis. J Med Assoc Thai. Jan. 2002;85(1):33-40. [pmid: 12075718].
98 Doi T, Akai M, Fujino K, et al. Effect of home exercise of quadriceps on knee osteoarthritis compared with nonsteroidal antiinflammatory drugs: a randomized controlled trial. Am J Phys Med Rehabil. 2008;87(4):258-69. [pmid: 18356618].
99 Baker KR, Nelson ME, Felson DT, et al. The efficacy of home based progressive strength training in older adults with knee osteoarthritis: a randomized controlled trial. J Rheumatol. Jul. 2001;28(7):1655-65. [pmid: 11469475].
100 Lin DH, Lin CH, Lin YF, et al. Efficacy of 2 non-weight-bearing interventions, proprioception training versus strength training, for patients with knee osteoarthritis: a randomized clinical trial. J Orthop Sports Phys Ther. 2009;39(6):450-7. [pmid: 19531879].
101 Jan MH, Lin JJ, Liau JJ, et al. Investigation of clinical effects of high- and low-resistance training for patients with knee osteoarthritis: a randomized controlled trial. Phys Ther. 2008;88(4):427-36. [pmid: 18218827].
102 Lim BW, Hinman RS, Wrigley TV, et al. Does knee malalignment mediate the effects of quadriceps strengthening on knee adduction moment, pain, and function in medial knee osteoarthritis? A randomized controlled trial. Arthritis Rheum. 2008;59(7):943-51. [pmid: 18576289].
103 Bennell KL, Hunt MA, Wrigley TV, et al. Hip strengthening reduces symptoms but not knee load in people with medial knee osteoarthritis and varus malalignment: a randomised controlled trial. Osteoarthritis Cartilage. May. 2010;18(5):621-8. Epub 2010 Feb 6.(5):621–8. [pmid: 20175973].
104 Weng MC, Lee CL, Chen CH, et al. Effects of different stretching techniques on the outcomes of isokinetic exercise in patients with knee osteoarthritis. Kaohsiung J Med Sci. 2009;25(6):306-15. [pmid: 19560995].
105 Topp R, Woolley S, Hornyak J 3rd, et al. The effect of dynamic versus isometric resistance training on pain and functioning among adults with osteoarthritis of the knee. Arch Phys Med Rehabil. Sep. 2002;83(9):1187-95. 1187. [pmid: 12235596].
106 Borjesson M, Robertson E, Weidenhielm L, et al. Physiotherapy in knee osteoarthrosis: effect on pain and walking. Physiother Res Int. 1996;1(2):89-97. [pmid: 9238726].
107 Cheing GL, Hui-Chan CW. Would the addition of TENS to exercise training produce better physical performance outcomes in people with knee osteoarthritis than either intervention alone?. Clin Rehabil. Aug. 2004;18(5):487-97. [pmid: 15293483].
108 Gür H, Cakin N, Akova B, et al. Concentric versus combined concentric-eccentric isokinetic training: effects on functional capacity and symptoms in patients with osteoarthrosis of the knee. Arch Phys Med Rehabil. Mar. 2002;83(3):308-16. [pmid: 11887109].
109 Swank AM, Kachelman JB, Bibeau W, et al. Prehabilitation before total knee arthroplasty increases strength and function in older adults with severe osteoarthritis. Journal of Strength & Conditioning Research. Feb. 2011;25(2):318-25. [pmid: 21217530].
110 Cheing GL, Hui-Chan CW, Chan KM. Does four weeks of TENS and/or isometric exercise produce cumulative reduction of osteoarthritic knee pain?. Pain Reviews. 2002;9(3–4):141-51.
111 Lee HJ, Park HJ, Chae Y, et al. Tai Chi Qigong for the quality of life of patients with knee osteoarthritis: a pilot, randomized, waiting list controlled trial. Clin Rehabil. 2009;23(6):504-11. [pmid: 19389743].
112 Brismee JM, Paige RL, Chyu MC, et al. Group and home-based tai chi in elderly subjects with knee osteoarthritis: a randomized controlled trial. Clin Rehabil. Feb. 2007;21(2):99-111. [pmid: 17264104].
113 Song R, Roberts BL, Lee EO, et al. A randomized study of the effects of t’ai chi on muscle strength, bone mineral density, and fear of falling in women with osteoarthritis. Journal of Alternative & Complementary Medicine. Mar. 2010;16(3):227-33. [pmid: 20192907].
114 Tsauo JY, Cheng PF, Yang RS. The effects of sensorimotor training on knee proprioception and function for patients with knee osteoarthritis: a preliminary report. Clin Rehabil. 2008;22(5):448-57. [pmid: 18441041].
115 Jan MH, Tang PF, Lin JJ, et al. Efficacy of a target-matching foot-stepping exercise on proprioception and function in patients with knee osteoarthritis. J Orthop Sports Phys Ther. Jan. 2008;38(1):19-25. [pmid: 18357655].
116 Yip YB, Tam AC. An experimental study on the effectiveness of massage with aromatic ginger and orange essential oil for moderate-to-severe knee pain among the elderly in Hong Kong. Complement Ther Med. Jun. 2008;16(3):131-8. [pmid: 18534325].
117 Ko T, Lee S, Lee D. Manual therapy and exercise for OA knee: Effects on muscle strength, proprioception, and functional performance. Journal of Physical Therapy Science. 2009;21(4):293-9.
118 Perlman AI, Sabina A, Williams AL, et al. Massage therapy for osteoarthritis of the knee: a randomized controlled trial. Arch Intern Med. Dec. 11–25. 2006;166(22):2533-8. [pmid: 17159021].
119 Pollard H, Ward G, Hoskins W, et al. The effect of a manual therapy knee protocol on osteoarthritic knee pain: a randomised controlled trial. J Can Chiropr Assoc. Dec. 2008;52(4):229-42. [pmid: 19066697].
120 Deyle GD, Allison SC, Matekel RL, et al. Physical therapy treatment effectiveness for osteoarthritis of the knee: a randomized comparison of supervised clinical exercise and manual therapy procedures versus a home exercise program. Physical Therapy. 2005;85(12):1301-17. [pmid: 16305269].
121 Moss P, Sluka K, Wright A. The initial effects of knee joint mobilization on osteoarthritic hyperalgesia. Man Ther. May. 2007;12(2):109-18. [pmid: 16777467].
122 Toda Y, Tsukimura N, Segal N. An optimal duration of daily wear for an insole with subtalar strapping in patients with varus deformity osteoarthritis of the knee. Osteoarthritis & Cartilage. 2005;13(4):353-60. [pmid: 15780649].
123 Bar-Ziv Y, Beer Y, Ran Y, et al. A treatment applying a biomechanical device to the feet of patients with knee osteoarthritis results in reduced pain and improved function: a prospective controlled study. BMC Musculoskelet Disord. 2010;11:179. [pmid: 20698991].
124 Hinman RS, Bowles KA, Bennell KL. Laterally wedged insoles in knee osteoarthritis: do biomechanical effects decline after one month of wear? BMC Musculoskelet. Disord. 146. 2009;10:146. [pmid: 19939281].
125 Maly M, Culham E, Costigan P. Static and dynamic biomechanics of foot orthoses in people with medial compartment knee osteoarthritis. Clinical Biomechanics. 2002;17(8):603-10. [pmid: 12243720].
126 Kerrigan DC, Lelas JL, Goggins J, et al. Effectiveness of a lateral-wedge insole on knee varus torque in patients with knee osteoarthritis. Archives of Physical Medicine and Rehabilitation. 2002;83(7):889-93. [pmid: 12098144].
127 Kuroyanagi Y, Nagura T, Matsumoto H, et al. The lateral wedged insole with subtalar strapping significantly reduces dynamic knee load in the medial compartment gait analysis on patients with medial knee osteoarthritis. Osteoarthritis & Cartilage. Aug. 2007;15(8):932-6. [pmid: 17391994].
128 Nigg BM, Emery C, Hiemstra LA. Unstable shoe construction and reduction of pain in osteoarthritis patients. Medicine & Science in Sports & Exercise. 2006;38(10):1701-8. [pmid: 17019290].
129 Toda Y, Segal N, Kato A, et al. Effect of a novel insole on the subtalar joint of patients with medial compartment osteoarthritis of the knee. Journal of Rheumatology. 2001;28(12):2705-10. [pmid: 11764221].
130 Toda Y, Tsukimura N. A six-month followup of a randomized trial comparing the efficacy of a lateral-wedge insole with subtalar strapping and an in-shoe lateral-wedge insole in patients with varus deformity osteoarthritis of the knee. Arthritis & Rheumatism. 2004;50(10):3129-36. [pmid: 15476225].
131 Toda Y, Tsukimura N. Influence of concomitant heeled footwear when wearing a lateral wedged insole for medial compartment osteoarthritis of the knee. Osteoarthritis and Cartilage. 2008;16(2):244-53. [pmid: 17693101].
132 Pajareya K, Chadchavalpanichaya N, Timdang S. Effectiveness of an elastic knee sleeve for patients with knee osteoarthritis: a randomized single-blinded controlled trial. Journal of the Medical Association of Thailand. 2003;86(6):535-42. [pmid: 12924802].
133 Richards JD, Sanchez-Ballester J, Jones RK, et al. A comparison of knee braces during walking for the treatment of osteoarthritis of the medial compartment of the knee. Journal of Bone & Joint Surgery - British Volume. 2005;87(7):937-9. [pmid: 15972906].
134 Brouwer RW, van Raaij TM, Verhaar JA, et al. Brace treatment for osteoarthritis of the knee: a prospective randomized multi-centre trial. Osteoarthritis & Cartilage. 2006;14(8):777-83. [pmid: 16563810].
135 Horlick SG, Loomer RL. Valgus knee bracing for medial gonarthrosis. Clinical Journal of Sport Medicine. 1993;3(4):251-5.
136 Kirkley A, Webster-Bogaert S, Litchfield R, et al. The effect of bracing on varus gonarthrosis. J Bone Joint Surg Am. Apr. 1999;81(4):539-48. [pmid: 10225800].
137 Hinman RS, Crossley KM, McConnell J, et al. Efficacy of knee tape in the management of osteoarthritis of the knee: blinded randomised controlled trial. BMJ. 2003;327(7407):135. [pmid: 12869456].
138 Hinman RS, Bennell KL, Crossley KM, et al. Immediate effects of adhesive tape on pain and disability in individuals with knee osteoarthritis. Rheumatology. 2003;42(7):865-9. [pmid: 12730546].
139 Cushnaghan J, McCarthy C, Dieppe P. Taping the patella medially: a new treatment for osteoarthritis of the knee joint?. BMJ. Mar. 19. 1994;308(6931):753-5. [pmid: 8142829].
140 Garland D, Holt P, Harrington JT, et al. A 3-month, randomized, double-blind, placebo-controlled study to evaluate the safety and efficacy of a highly optimized, capacitively coupled, pulsed electrical stimulator in patients with osteoarthritis of the knee. Osteoarthritis Cartilage. Jun. 2007;15(6):630-7. [pmid: 17303443].
141 Selfe TK, Bourguignon C, Taylor AG. Effects of noninvasive interactive neurostimulation on symptoms of osteoarthritis of the knee: a randomized, sham-controlled pilot study. J Altern Complement Med. 2008;14(9):1075-81. [pmid: 19055333].
142 Cetin N, Aytar A, Atalay A, et al. Comparing hot pack, short-wave diathermy, ultrasound, and TENS on isokinetic strength, pain, and functional status of women with osteoarthritic knees: a single-blind, randomized, controlled trial. Am J Phys Med Rehabil. 2008;87(6):443-51. [pmid: 18496246].
143 Grimmer K. A controlled double blind study comparing the effects of strong burst mode TENS and high rate TENS on painful osteoarthritic knees. Australian Journal of Physiotherapy. 1992;38(1):49-56.
144 Yurtkuran M, Kocagil T. TENS, electroacupuncture and ice massage: comparison of treatment for osteoarthritis of the knee. Am J Acupunct. 1999;27(3–4):133-40. [pmid: 10729968].
145 Law PP, Cheing GL, Tsui AY. Does transcutaneous electrical nerve stimulation improve the physical performance of people with knee osteoarthritis?. J Clin Rheumatol. Dec. 2004;10(6):295-9. [pmid: 17043536].
146 Pietrosimone BG, Saliba SA, Hart JM, et al. Effects of disinhibitory transcutaneous electrical nerve stimulation and therapeutic exercise on sagittal plane peak knee kinematics and kinetics in people with knee osteoarthritis during gait: a randomized controlled trial. Clin Rehabil. Dec. 2010;24(12):1091-101. [pmid: 20713439].
147 Talbot LA, Gaines JM, Ling SM, et al. A home-based protocol of electrical muscle stimulation for quadriceps muscle strength in older adults with osteoarthritis of the knee. J Rheumatol. Jul. 2003;30(7):1571-8. [pmid: 12858461].
148 Law PP, Cheing GL. Optimal stimulation frequency of transcutaneous electrical nerve stimulation on people with knee osteoarthritis. J Rehabil Med. Sep. 2004;36(5):220-5. [pmid: 15626162].
149 Taylor P, Hallett M, Flaherty L. Treatment of osteoarthritis of the knee with transcutaneous electrical nerve stimulation. Pain. Oct. 1981;11(2):233-40. [pmid: 7033891].
150 Itoh K, Hirota S, Katsumi Y, et al. A pilot study on using acupuncture and transcutaneous electrical nerve stimulation (TENS) to treat knee osteoarthritis (OA). Chin Med. 2008;3:2. [pmid: 18312661].
151 Pietrosimone BG, Hart JM, Saliba SA, et al. Immediate effects of transcutaneous electrical nerve stimulation and focal knee joint cooling on quadriceps activation. Med Sci Sports Exerc. Jun. 2009;41(6):1175-81. [pmid: 19461552].
152 Gaines JM, Metter EJ, Talbot LA. The effect of neuromuscular electrical stimulation on arthritis knee pain in older adults with osteoarthritis of the knee. Appl Nurs Res. Aug. 2004;17(3):201-6. [pmid: 15343554].
153 Kang RW, Lewis PB, Kramer A, et al. Prospective randomized single-blinded controlled clinical trial of percutaneous neuromodulation pain therapy device versus sham for the osteoarthritic knee: a pilot study. Orthopedics. Jun. 2007;30(6):439-45. [pmid: 17598487].
154 Ay S, Evcik D. The effects of pulsed electromagnetic fields in the treatment of knee osteoarthritis: a randomized, placebo-controlled trial. Rheumatol Int. 2009;29(6):663-6. [pmid: 19015858].
155 Thamsborg G, Florescu A, Oturai P, et al. Treatment of knee osteoarthritis with pulsed electromagnetic fields: a randomized, double-blind, placebo-controlled study. Osteoarthritis & Cartilage. 2005;13(7):575-81. [pmid: 15979009].
156 Trock DH, Bollet AJ, Markoll R. The effect of pulsed electromagnetic fields in the treatment of osteoarthritis of the knee and cervical spine. Report of randomized, double blind, placebo controlled trials. J Rheumatol. Oct. 1994;21(10):1903-11. [pmid: 7837158].
157 Nicolakis P, Kollmitzer J, Crevenna R, et al. Pulsed magnetic field therapy for osteoarthritis of the knee--a double-blind sham-controlled trial. Wiener klinische Wochenschrift. 2002;114(15–16):678-84. [pmid: 12602111].
158 Huang MH, Lin YS, Lee CL, et al. Use of ultrasound to increase effectiveness of isokinetic exercise for knee osteoarthritis. Arch Phys Med Rehabil. Aug. 2005;86(8):1545-51. [pmid: 16084806].
159 Huang MH, Yang RC, Lee CL, et al. Preliminary results of integrated therapy for patients with knee osteoarthritis. Arthritis Rheum. Dec. 15. 2005;53(6):812-20. [pmid: 16342083].
160 Özgönenel L, Aytekin E, Durmusoglu G. A double-blind trial of clinical effects of therapeutic ultrasound in knee osteoarthritis. Ultrasound Med Biol. Jan. 2009;35(1):44-9. [pmid: 18829151].
161 Tascioglu F, Kuzgun S, Armagan O, et al. Short-term effectiveness of ultrasound therapy in knee osteoarthritis. Journal of International Medical Research. Jul–Aug. 2010;38(4):1233-42. [pmid: 20925995].
162 Loyola-Sánchez A, Richardson J, Beattie KA, et al. Effect of low-intensity pulsed ultrasound on the cartilage repair in people with mild to moderate knee osteoarthritis: a double-blinded, randomized, placebo-controlled pilot study. Arch Phys Med Rehabil. Jan. 2012;93(1):35-42. [pmid: 22200383].
163 Callaghan MJ, Whittaker PE, Grimes S, et al. An evaluation of pulsed shortwave on knee osteoarthritis using radioleucoscintigraphy: a randomised, double blind, controlled trial. Joint Bone Spine. Mar. 2005;72(2):150-5. [pmid: 15797496].
164 Laufer Y, Zilberman R, Porat R, et al. Effect of pulsed short-wave diathermy on pain and function of subjects with osteoarthritis of the knee: a placebo-controlled double-blind clinical trial. Clin Rehabil. May. 2005;19(3):255-63. [pmid: 15859526].
165 Akyol Y, Durmus D, Alayli G, et al. Does short-wave diathermy increase the effectiveness of isokinetic exercise on pain, function, knee muscle strength, quality of life, and depression in the patients with knee osteoarthritis? A randomized controlled clinical study. European journal of physical & rehabilitation medicine. Sep. 2010;46(3):325-36. [pmid: 20926998].
166 Fukuda TY, Alves da Cunha R, Fukuda VO, et al. Pulsed shortwave treatment in women with knee osteoarthritis: a multicenter, randomized, placebo-controlled clinical trial. Phys Ther. Jul. 2011;91(7):1009-17. [pmid: 21642511].
167 Cantarini L, Leo G, Giannitti C, et al. Therapeutic effect of spa therapy and short wave therapy in knee osteoarthritis: a randomized, single blind, controlled trial. Rheumatol Int. Apr. 2007;27(6):523-9. [pmid: 17106661].
168 Rattanachaiyanont M, Kuptniratsaikul V. No additional benefit of shortwave diathermy over exercise program for knee osteoarthritis in peri-/post-menopausal women: an equivalence trial. Osteoarthritis Cartilage. Jul. 2008;16(7):823-8. [pmid: 18178111].
169 Denegar CR, Dougherty DR, Friedman JE, et al. Preferences for heat, cold, or contrast in patients with knee osteoarthritis affect treatment response. Clin Interv Aging. 2010;5:199-206. [pmid: 20711439].
170 Mazzuca SA, Page MC, Meldrum RD, et al. Pilot study of the effects of a heat-retaining knee sleeve on joint pain, stiffness, and function in patients with knee osteoarthritis. Arthritis Rheum. Oct. 15. 2004;51(5):716-21. [pmid: 15478166].
171 Zizic TM, Hoffman KC, Holt PA, et al. The treatment of osteoarthritis of the knee with pulsed electrical stimulation. J Rheumatol. Sep. 1995;22(9):1757-61. [pmid: 8523357].
172 Odabasi E, Turan M, Erdem H, et al. Does mud pack treatment have any chemical effect? A randomized controlled clinical study. J Altern Complement Med. Jun. 2008;14(5):559-65. [pmid: 18564957].
173 Silva LE, Valim V, Pessanha AP, et al. Hydrotherapy versus conventional land-based exercise for the management of patients with osteoarthritis of the knee: a randomized clinical trial. Physical Therapy. 2008;88(1):12-21. [pmid: 17986497].
174 Wang C, Schmid CH, Hibberd PL, et al. Tai Chi is effective in treating knee osteoarthritis: a randomized controlled trial. Arthritis Rheum. 2009;61(11):1545-53. [pmid: 19877092].
175 Maillefert JF, Hudry C, Baron G, et al. Laterally elevated wedged insoles in the treatment of medial knee osteoarthritis: a prospective randomized controlled study. Osteoarthritis and Cartilage. 2001;9(8):738-45. [pmid: 11795993].
176 van Raaij TM, Reijman M, Brouwer RW, et al. Medial Knee Osteoarthritis Treated by Insoles or Braces: A Randomized Trial. Clin Orthop Relat Res. 2010;468(7):1926-32. [pmid: 20177839].
177 Bennell KL, Bowles KA, Payne C, et al. Lateral wedge insoles for medial knee osteoarthritis: 12 month randomised controlled trial. BMJ. 2011;342:d2912. [pmid: 21593096].
178 Durmus D, Alayli G, Canturk F. Effects of quadriceps electrical stimulation program on clinical parameters in the patients with knee osteoarthritis. Clin Rheumatol. May. 2007;26(5):674-8. [pmid: 16897119].
179 Penninx BW, Messier SP, Rejeski WJ, et al. Physical exercise and the prevention of disability in activities of daily living in older persons with osteoarthritis. Archives of Internal Medicine. Oct. 22. 2001;161(19):2309-16. [pmid: 11606146].
180 Penninx BW, Rejeski WJ, Pandya J, et al. Exercise and depressive symptoms: a comparison of aerobic and resistance exercise effects on emotional and physical function in older persons with high and low depressive symptomatology. J Gerontol B Psychol Sci Soc Sci. Mar. 2002;57(2):P124-32. [pmid: 11867660].
181 Rejeski WJ, Brawley LR, Ettinger W, et al. Compliance to exercise therapy in older participants with knee osteoarthritis: implications for treating disability. Medicine & Science in Sports & Exercise. 1997;29(8):977-85. [pmid: 9268953].
182 van Gool CH, Penninx BW, Kempen GI, et al. Effects of exercise adherence on physical function among overweight older adults with knee osteoarthritis. Arthritis Rheum. Feb. 15. 2005;53(1):24-32. [pmid: 15696558].
183 Baker K, Goggins J, Xie H, et al. A randomized crossover trial of a wedged insole for treatment of knee osteoarthritis. Arthritis & Rheumatism. 2007;56(4):1198-203. [pmid: 17393448].
184 Mangani I, Cesari M, Kritchevsky SB, et al. Physical exercise and comorbidity. Results from the Fitness and Arthritis in Seniors Trial (FAST). Aging Clin Exp Res. Oct. 2006;18(5):374-80. [pmid: 17167301].
185 Fisher NM, Gresham G, Pendergast DR. Effects of a quantitative progressive rehabilitation program applied unilaterally to the osteoarthritic knee. Arch Phys Med Rehabil. Dec. 1993;74(12):1319-26. [pmid: 8259900].
186 Mikesky AE, Mazzuca SA, Brandt KD, et al. Effects of strength training on the incidence and progression of knee osteoarthritis. Arthritis Rheum. Oct. 15. 2006;55(5):690-9. [pmid: 17013851].
187 Huang MH, Chen CH, Chen TW, et al. The effects of weight reduction on the rehabilitation of patients with knee osteoarthritis and obesity. Arthritis Care Res. Dec. 2000;13(6):398-405. [pmid: 14635316].
188 Mangione KK, McCully K, Gloviak A, et al. The effects of high-intensity and low-intensity cycle ergometry in older adults with knee osteoarthritis. J Gerontol A Biol Sci Med Sci. Apr. 1999;54(4):M184-90. [pmid: 10219009].
189 Sen A, Gocen Z, Unver B, et al. The frequency of visits by the physiotherapist of patients receiving home-based exercise therapy for knee osteoarthritis. Knee. Apr. 2004;11(2):151-3. [pmid: 15066630].
190 Toda Y, Tsukimura N, Kato A. The effects of different elevations of laterally wedged insoles with subtalar strapping on medial compartment osteoarthritis of the knee. Archives of Physical Medicine & Rehabilitation. 2004;85(4):673-7. [pmid: 15083446].
191 Jensen H, Zesler R, Christensen T. Transcutaneous electrical nerve stimulation (TNS) for painful osteoarthrosis of the knee. Int J Rehabil Res. 1991;14(4):356-8. [pmid: 1783484].
192 Defrin R, Ariel E, Peretz C. Segmental noxious versus innocuous electrical stimulation for chronic pain relief and the effect of fading sensation during treatment. Pain. May. 2005;115(1–2):152-60. [pmid: 15836978].
193 Cheing GL, Tsui AY, Lo SK, et al. Optimal stimulation duration of tens in the management of osteoarthritic knee pain. J Rehabil Med. Mar. 2003;35(2):62-8. [pmid: 12691335].
194 Wyatt FB, Milam S, Manske RC, et al. The effects of aquatic and traditional exercise programs on persons with knee osteoarthritis. Journal of Strength & Conditioning Research. 2001;15(3):337-40. [pmid: 11710661].
195 Bieleman HJ, Reneman MF, van Ittersum MW, et al. Self-reported functional status as predictor of observed functional capacity in subjects with early osteoarthritis of the hip and knee: A diagnostic study in the CHECK cohort. Journal of Occupational Rehabilitation. 2009;19(4):345-53. [pmid: 19557505].
196 Salaffi F, Stancati A, Silvestri CA, et al. Minimal clinically important changes in chronic musculoskeletal pain intensity measured on a numerical rating scale. Eur J Pain. Aug. 2004;8(4):283-91. [pmid: 15207508].
197 Thomas E, Peat G, Mallen C, et al. Predicting the course of functional limitation among older adults with knee pain: do local signs, symptoms and radiographs add anything to general indicators?. Annals of the Rheumatic Diseases. Oct. 2008;67(10):1390-8. [pmid: 18245111].
198 Xie F, Pullenayegum EM, Li SC, et al. Use of a Disease-Specific Instrument in Economic Evaluations: Mapping WOMAC onto the EQ-5D Utility Index. Value Health. Dec. 2010;13(8):873-8. [pmid: 20667055].
199 Rejeski WJ, Ettinger WH Jr, Martin K, et al. Treating disability in knee osteoarthritis with exercise therapy: a central role for self-efficacy and pain. Arthritis Care Res. Apr. 1998;11(2):94-101. [pmid: 9668732].
200 Bennell KL, Hinman RS, Crossley KM, et al. Is the Human Activity Profile a useful measure in people with knee osteoarthritis?. Journal of Rehabilitation Research and Development. 2004;41(4):621-9. [pmid: 15558390].
201 Astephen Wilson JL, Deluzio KJ, Dunbar MJ, et al. The association between knee joint biomechanics and neuromuscular control and moderate knee osteoarthritis radiographic and pain severity. Osteoarthritis Cartilage. Feb. 2011;19(2):186-93. [pmid: 21074628].
202 White DK, Felson DT, Niu J, et al. Reasons for Functional Decline Despite Reductions in Knee Pain: The Multicenter Osteoarthritis Study. Phys Ther. 2011. Oct. 14. [pmid: 22003168].
203 O’Reilly SC, Jones A, Muir KR, et al. Quadriceps weakness in knee osteoarthritis: the effect on pain and disability. Annals of the Rheumatic Diseases. 1998;57(10):588-94. [pmid: 9893569].
204 Wood L, Peat G, Thomas E, et al. Associations between physical examination and self-reported physical function in older community-dwelling adults with knee pain. Physical Therapy. 2008;88(1):33-42. [pmid: 18029391].
205 Sharma L, Cahue S, Song J, et al. Physical functioning over three years in knee osteoarthritis: role of psychosocial, local mechanical, and neuromuscular factors. Arthritis Rheum. Dec. 2003;48(12):3359-70. [pmid: 14673987].
206 van Baar ME, Dekker J, Lemmens JA, et al. Pain and disability in patients with osteoarthritis of hip or knee: the relationship with articular, kinesiological, and psychological characteristics. J Rheumatol. Jan. 1998;25(1):125-33. [pmid: 9458215].
207 Van Der Esch M, Steultjens M, Knol DL, et al. Joint Laxity and the Relationship Between Muscle Strength and Functional Ability in Patients With Osteoarthritis of the Knee. Arthritis Care and Research. 2006;55(6):953-9. [pmid: 17139642].
208 Hunt MA, McManus FJ, Hinman RS, et al. Predictors of single-leg standing balance in individuals with medial knee osteoarthritis. Arthritis Care & Research. Apr. 2010;62(4):496-500. [pmid: 20391504].
209 Harrison AL. The influence of pathology, pain, balance, and self-efficacy on function in women with osteoarthritis of the knee. Phys Ther. Sep. 2004;84(9):822-31. [pmid: 15330695].
210 Kauppila AM, Kyllonen E, Mikkonen P, et al. Disability in end-stage knee osteoarthritis. Disabil Rehabil. 2009;31(5):370-80. [pmid: 18608423].
211 Jadelis K, Miller ME, Ettinger WH Jr, et al. Strength, balance, and the modifying effects of obesity and knee pain: results from the Observational Arthritis Study in Seniors (oasis). Journal of the American Geriatrics Society. Jul. 2001;49(7):884-91. [pmid: 11527479].
212 Clark JA, Spiro A 3rd, Fincke G, et al. Symptom severity of osteoarthritis of the knee: a patient-based measure developed in the veterans health study. J Gerontol A Biol Sci Med Sci. Sep. 1998;53(5):M351-60. [pmid: 9754141].
213 Boutron I, Rannou F, Jardinaud-Lopez M, et al. Disability and quality of life of patients with knee or hip osteoarthritis in the primary care setting and factors associated with general practitioners’ indication for prosthetic replacement within 1 year. Osteoarthritis Cartilage. Sep. 2008;16(9):1024-31. [pmid: 18276169].
214 Summers MN, Haley WE, Reveille JD, et al. Radiographic assessment and psychologic variables as predictors of pain and functional impairment in osteoarthritis of the knee or hip. Arthritis Rheum. Feb. 1988;31(2):204-9. [pmid: 3348824].
215 Bellamy N, Buchanan WW. A preliminary evaluation of the dimensionality and clinical importance of pain and disability in osteoarthritis of the hip and knee. Clin Rheumatol. Jun. 1986;5(2):231-41. [pmid: 3731718].
216 Marks R. Reliability and validity of self-paced walking time measures for knee osteoarthritis. Arthritis Care and Research. 1994;7(1):50-3. [pmid: 7918728].
217 Marks R, Quinney HA, Wessel J. Proprioceptive sensibility in women with normal and osteoarthritic knee joints. Clin Rheumatol. Jun. 1993;12(2):170-5. [pmid: 8358974].
218 Creamer P, Lethbridge-Cejku M, Hochberg MC. Determinants of pain severity in knee osteoarthritis: effect of demographic and psychosocial variables using 3 pain measures. J Rheumatol. Aug. 1999;26(8):1785-92. [pmid: 10451078].
219 Yildiz N, Topuz O, Gungen GO, et al. Health-related quality of life (Nottingham Health Profile) in knee osteoarthritis: correlation with clinical variables and self-reported disability. Rheumatol Int. Nov. 2010;30(12):1595-600. [pmid: 19823830].
220 Birmingham TB, Kramer JF, Kirkley A, et al. Association among neuromuscular and anatomic measures for patients with knee osteoarthritis. Archives of Physical Medicine & Rehabilitation. 2001;82(8):1115-8. [pmid: 11494192].
221 Deniston OL, Jette A. A functional status assessment instrument: validation in an elderly population. Health Serv Res. Spring. 1980;15(1):21-34. [pmid: 7372496].
222 Meenan RF, Gertman PM, Mason JH. Measuring health status in arthritis. The arthritis impact measurement scales. Arthritis Rheum. Feb. 1980;23(2):146-52. [pmid: 7362665].
223 Wright JG, Santaguida PL, Young N, et al. Patient preferences before and after total knee arthroplasty. J Clin Epidemiol. Jul. 2010;63(7):774-82. [pmid: 20004554].
224 Faucher M, Poiraudeau S, LefevreColau MM, et al. Algo-functional assessment of knee osteoarthritis: comparison of the test-retest reliability and construct validity of the Womac and Lequesne indexes. Osteoarthritis and Cartilage. 2002;10(8):602-10. [pmid: 12479381].
225 Steultjens MP, Dekker J, van Baar ME, et al. Muscle strength, pain and disability in patients with osteoarthritis. Clin Rehabil. Jun. 2001;15(3):331-41. [pmid: 11386405].
226 O’Malley KJ, Suarez-Almazor M, Aniol J, et al. Joint-specific multidimensional assessment of pain (J-MAP): factor structure, reliability, validity, and responsiveness in patients with knee osteoarthritis. J Rheumatol. Mar. 2003;30(3):534-43. [pmid: 12610814].
227 Steultjens MP, Dekker J, van Baar ME, et al. Internal consistency and validity of an observational method for assessing disability in mobility in patients with osteoarthritis. Arthritis Care Res. Feb. 1999;12(1):19-25. [pmid: 10513486].
228 Finch E, Kennedy D. The lower extremity activity profile: a health status instrument for measuring lower extremity disability. Physiother Can. Fall. 1995;47(4):239-46. [pmid: 10153394].
229 Pham T, van der Heijde D, Altman RD, et al. OMERACT-OARSI initiative: Osteoarthritis Research Society International set of responder criteria for osteoarthritis clinical trials revisited. Osteoarthritis & Cartilage. 2004;12(5):389-99. [pmid: 15094138].
230 Stucki G, Sangha O, Stucki S, et al. Comparison of the WOMAC (Western Ontario and McMaster Universities) osteoarthritis index and a self-report format of the self-administered Lequesne-Algofunctional index in patients with knee and hip osteoarthritis. Osteoarthritis Cartilage. Mar. 1998;6(2):79-86. [pmid: 9692062].
231 Wolfe F. Determinants of WOMAC function, pain and stiffness scores: evidence for the role of low back pain, symptom counts, fatigue and depression in osteoarthritis, rheumatoid arthritis and fibromyalgia. Rheumatology. 1999;38(4):355-61. [pmid: 10378714].
232 Brazier JE, Harper R, Munro J, et al. Generic and condition-specific outcome measures for people with osteoarthritis of the knee. Rheumatology. 1999;38(9):870-7. [pmid: 10515649].
233 Wolfe F, Kong SX. Rasch analysis of the Western Ontario MacMaster questionnaire (WOMAC) in 2205 patients with osteoarthritis, rheumatoid arthritis, and fibromyalgia. Ann Rheum Dis. Sep. 1999;58(9):563-8. [pmid: 10460190].
234 Ryser L, Wright BD, Aeschlimann A, et al. A new look at the Western Ontario and McMaster Universities Osteoarthritis Index using Rasch analysis. Arthritis Care Res. Oct. 1999;12(5):331-5. [pmid: 11081002].
235 Davis AM, Badley EM, Beaton DE, et al. Rasch analysis of the Western Ontario McMaster (WOMAC) Osteoarthritis Index: results from community and arthroplasty samples. J Clin Epidemiol. Nov. 2003;56(11):1076-83. [pmid: 14614998].
236 Reuben DB, Siu AL, Kimpau S. The predictive validity of self-report and performance-based measures of function and health. J Gerontol. Jul. 1992;47(4):M106-10. [pmid: 1624692].
237 Verghese J, LeValley A, Hall CB, et al. Epidemiology of gait disorders in community-residing older adults. J Am Geriatr Soc. Feb. 2006;54(2):255-61. [pmid: 16460376].
238 Woo J, Ho SC, Yu AL. Walking speed and stride length predicts 36 months dependency, mortality, and institutionalization in Chinese aged 70 and older. J Am Geriatr Soc. Oct. 1999;47(10):1257-60. [pmid: 10522962].
239 Jylha M, Guralnik JM, Balfour J, et al. Walking difficulty, walking speed, and age as predictors of self-rated health: the women’s health and aging study. J Gerontol A Biol Sci Med Sci. Oct. 2001;56(10):M609-17. [pmid: 11584033].
240 Dougados M, Leclaire P, van der Heijde D, et al. Response criteria for clinical trials on osteoarthritis of the knee and hip: a report of the Osteoarthritis Research Society International Standing Committee for Clinical Trials response criteria initiative. Osteoarthritis & Cartilage. Nov. 2000;8(6):395-403. [pmid: 11069723].
241 Angst F, Aeschlimann A, Michel BA, et al. Minimal clinically important rehabilitation effects in patients with osteoarthritis of the lower extremities. J Rheumatol. Jan. 2002;29(1):131-8. [pmid: 11824949].
242 Tubach F, Ravaud P, Baron G, et al. Evaluation of clinically relevant states in patient reported outcomes in knee and hip osteoarthritis: the patient acceptable symptom state. Annals of the Rheumatic Diseases. 2005;64(1):34-7. [pmid: 15130902].
243 Angst F, Aeschlimann A, Stucki G. Smallest detectable and minimal clinically important differences of rehabilitation intervention with their implications for required sample sizes using WOMAC and SF-36 quality of life measurement instruments in patients with osteoarthritis of the lower extremities. Arthritis Rheum. Aug. 2001;45(4):384-91. [pmid: 11501727].
244 Quintana JM, Escobar A, Arostegui I, et al. Health-related quality of life and appropriateness of knee or hip joint replacement. Arch Intern Med. Jan. 23. 2006;166(2):220-6. [pmid: 16432092].
245 Escobar A, Quintana JM, Bilbao A, et al. Responsiveness and clinically important differences for the WOMAC and SF-36 after total knee replacement. Osteoarthritis and Cartilage. 2007;15(3):273-80. [pmid: 17052924].
246 Kennedy DM, Stratford PW, Wessel J, et al. Assessing stability and change of four performance measures: a longitudinal study evaluating outcome following total hip and knee arthroplasty. BMC Musculoskeletal Disorders. 2005;6(Journal Article):3. [pmid: 15679884].
247 Mangione KK, Craik RL, McCormick AA, et al. Detectable changes in physical performance measures in elderly African Americans. Phys Ther. Jun. 2010;90(6):921-7. [pmid: 20395305].
248 Nebel MB, Sims EL, Keefe FJ, et al. The relationship of self-reported pain and functional impairment to gait mechanics in overweight and obese persons with knee osteoarthritis. Arch Phys Med Rehabil. Nov. 2009;90(11):1874-9. [pmid: 19887211].
249 Burch FX, Tarro JN, Greenberg JJ, et al. Evaluating the benefits of patterned stimulation in the treatment of osteoarthritis of the knee: a multi-center, randomized, single-blind, controlled study with an independent masked evaluator. Osteoarthritis Cartilage. Aug. 2008;16(8):865-72. [pmid: 18262443].
250 Petrella RJ, Bartha C. Home based exercise therapy for older patients with knee osteoarthritis: a randomized clinical trial. J Rheumatol. Sep. 2000;27(9):2215-21. [pmid: 10990236].
251 Recommendations for the medical management of osteoarthritis of the hip and knee: 2000 update. American College of Rheumatology Subcommittee on Osteoarthritis Guidelines. Arthritis & Rheumatism. Sep. 2000;43(9):1905-15. [pmid: 11014340].
252 Brand C. Guideline for the non-surgical management of hip and knee osteoarthritis. 2009. July. 2009.
253 Mazieres B, Bannwarth B, Dougados M, et al. EULAR recommendations for the management of knee osteoarthritis. Report of a task force of the Standing Committee for International Clinical Studies Including Therapeutic Trials. Joint, Bone, Spine: Revue du Rhumatisme. 2001;68(3):231-40. [pmid: 11394623].
254 Lund H, Henriksen M, Bartels EM, et al. Can stimulating massage improve joint repositioning error in patients with knee osteoarthritis?. J Geriatr Phys Ther. 2009;32(3):111-6. [pmid: 20128335].
255 Pisters MF, Veenhof C, Schellevis FG, et al. Long-term effectiveness of exercise therapy in patients with osteoarthritis of the hip or knee: a randomized controlled trial comparing two different physical therapy interventions. Osteoarthritis Cartilage. Aug. 2010;18(8):1019-26. [pmid: 20488250].
256 Bruckenthal P, Broderick JE. Assessing treatment fidelity in pilot studies assist in designing clinical trials: an illustration from a nurse practitioner community-based intervention for pain. Advances in Nursing Science. 2007;30(1):E72-84. [pmid: 17299277].
257 Doherty M, Jones A. Design of clinical trials in knee osteoarthritis: practical issues for debate. Osteoarthritis & Cartilage. Nov. 1998;6(6):371-3. [pmid: 10343768].
258 Boutron I, Moher D, Altman DG, et al. Extending the CONSORT statement to randomized trials of nonpharmacologic treatment: explanation and elaboration. Annals of Internal Medicine. Feb. 19. 2008;148(4):295-309. [pmid: 18283207].
259 Bellamy N. Measuring beneficial and adverse events in osteoarthritis clinical trials. Inflammopharmacology. 1996;4(2):141-8.
260 Samson DJ, Grant MD, Ratko TA, et al. Treatment of primary and secondary osteoarthritis of the knee. Evidence Report/Technology Assessment. 2007;(157):1-157. [pmid: 18088162].
261 Terwee CB, Roorda LD, Dekker J, et al. Mind the MIC: large variation among populations and methods. Journal of Clinical Epidemiology. May. 2010;63(5):524-34. [pmid: 19926446].
262 Terwee CB, Roorda LD, Knol DL, et al. Linking measurement error to minimal important change of patient-reported outcomes. Journal of Clinical Epidemiology. Oct. 2009;62(10):1062-7. [pmid: 19230609].
263 Dougados M, Moore A, Yu S, et al. Evaluation of the patient acceptable symptom state in a pooled analysis of two multicentre, randomised, double-blind, placebo-controlled studies evaluating lumiracoxib and celecoxib in patients with osteoarthritis. Arthritis Research & Therapy. 2007;9(1):R11. [pmid: 17266764].
264 Fitzgerald GK, Delitto A. Considerations for planning and conducting clinic-based research in physical therapy. Phys Ther. Aug. 2001;81(8):1446-54. [pmid: 11509074].