# Methods

## Topic Refinement and Review Protocol

We developed the Key Questions with stakeholder input as part of the Effective Health Care Program. We developed an analytic framework after discussions with key informants. Research questions were posted for public comment. Key informants recommended that we focus on patient-centered outcomes and physical therapy interventions relevant for clinical practice in the United States. Key informants also recommended that we review the intermediate outcomes with which physical therapists judge treatment success. Candidates to serve as key informants, technical experts, and peer reviewers were approved by the Task Order Officer from the Agency for Healthcare Research and Quality (AHRQ) after disclosure of conflicts of interest. We developed the protocol following Preferred Reporting Items for Systematic Reviews and Meta-Analyses guidelines 31 (www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=637&pageaction=displayproduct) with input from experts who served on the Technical Expert Panel (TEP).

## Literature Search Strategy

We sought studies from a wide variety of sources, including MEDLINE^®^ (via OVID and PubMed^®^), the Cochrane Library, the Physiotherapy Evidence Database (PEDro), SCIRUS, Allied and Complementary Medicine (AMED), and the Health and Psychosocial Instruments bibliography database up to February 29, 2012. We conducted manual searches of reference lists from systematic reviews and eligible studies.32 We searched for unpublished literature including regulatory documents, conducted clinical trials, and abstracts presented in scientific meetings. We searched clinical trial registries including ClinicalTrials.gov and World Health Organization Clinical Trials for completed trials related to the Key Questions. To find closed studies of physical therapy interventions for adults with knee OA, we searched the website www.clinicaltrials.gov in March 2011.

Our Evidence-based Practice Center (EPC) search strategy used relevant medical subject headings (MeSH) terms, text words, and weighted word frequency algorithms to identify related articles. Members of our TEP and peer reviewers suggested additional published studies. We documented each recommended, included, and excluded study. Our evidence search involved several steps: (1) conduct a comprehensive literature search in the databases listed above to retrieve references in the EndNote reference management software; (2) screen abstracts against pre-established inclusion/exclusion criteria; and (3) retrieve and review full articles on eligible studies to determine potential inclusion in the evidence synthesis. The search strategies for the three research questions are described in Appendix A.

We present the excluded references in Appendix B and our analysis of the results from ongoing studies in Appendix C.

### Inclusion Criteria

For Key Questions 1 and 3 we included:

1. Original epidemiologic studies, including randomized clinical trials (RCTs), nonrandomized multicenter clinical trials, and observational studies that used the strategies to reduce bias (adjustment, stratification, matching, propensity scores).
2. Publication in English after 1970.
3. Target population of community-dwelling adults with knee OA.
4. Eligible intermediate (impaired performance tests) and patient-centered outcomes including pain, disability, and quality of life.
5. Eligible interventions as listed in Table 1.

Table 1 Physical therapy interventions eligible for review

General Modality | Specific Intervention | Definition
Patient/Client-Related Instruction
Instruction, education, and training of patients/clients and caregivers | Current condition Enhancement of performance Health, wellness, and fitness Plan of care Risk factors for pathology/pathophysiology, impairments, functional limitations, or disabilities
Therapeutic exercise | Aerobic capacity/endurance conditioning or reconditioning | Increased workload over time Walking programs Aquatic therapy
Therapeutic exercise | Flexibility exercises | Muscle lengthening Range of motion Stretching
Therapeutic exercise | Gait and locomotion training | Gait training Implement and device training
Therapeutic exercise | Strength, power, and endurance training for limb muscles | Active assistive, active, and resistive exercises Quadriceps strengthening Aquatic programs Standardized, programmatic, complementary exercise approaches Task-specific performance training Body mechanics and postural stabilization Body mechanics training
Therapeutic exercise | Balance, coordination, and agility training | Neuromuscular education or re-education Posture awareness training
Therapeutic exercise | Muscle relaxation technique for pain management
Functional training in self-care, home management, work, community, and leisure integration or reintegration (including ADL, IADL, work hardening, and work conditioning) | ADL training
Functional training in self-care, home management, work, community, and leisure integration or reintegration (including ADL, IADL, work hardening, and work conditioning) | Devices and equipment use and training | Assistive and adaptive device or equipment training during ADL and IADL Orthotic, protective, or supportive device or equipment training during ADL and IADL
Functional training in self-care, home management, work, community, and leisure integration or reintegration (including ADL, IADL, work hardening, and work conditioning) | Functional training programs | Simulated environments and tasks Task adaptation
Functional training in self-care, home management, work, community, and leisure integration or reintegration (including ADL, IADL, work hardening, and work conditioning) | IADL training
Functional training in self-care, home management, work, community, and leisure integration or reintegration (including ADL, IADL, work hardening, and work conditioning) | Injury prevention or reduction | Injury prevention education during self-care, home management, work, community, and leisure integration or reintegration Injury prevention or reduction with use of devices and equipment Safety awareness training during self-care, home management, work, community, and leisure integration and reintegration
Manual therapy techniques (Including mobilization/manipulation) | Detailed examination to reveal impaired movements
Manual therapy techniques (Including mobilization/manipulation) | Manual techniques with reinforcing exercise to improve movement
Manual therapy techniques (Including mobilization/manipulation) | Manual traction
Manual therapy techniques (Including mobilization/manipulation) | Massage | Connective tissue massage Therapeutic massage
Manual therapy techniques (Including mobilization/manipulation) | Mobilization/manipulation | Soft tissue Knee joint, other joints
Manual therapy techniques (Including mobilization/manipulation) | Passive range of motion
Prescription, application of devices and equipment | Adaptive devices | Raised toilet seats
Prescription, application of devices and equipment | Orthotic devices | Braces Shoe inserts Splints
Prescription, application of devices and equipment | Protective devices | Braces Protective patellar taping
Prescription, application of devices and equipment | Supportive devices | Supportive taping
Electrotherapeutic interventions | Electrical stimulation | Electrical muscle stimulation Functional electrical stimulation High-voltage pulsed current Neuromuscular electrical stimulation Transcutaneous electrical nerve stimulation
Physical agents and mechanical interventions | Nonthermal agents | Pulsed electromagnetic fields
Physical agents and mechanical interventions | Aquatic therapy | Pools
Physical agents and mechanical interventions | Sound agents | Ultrasound
Physical agents and mechanical interventions | Thermotherapy | Dry heat Hot packs Diathermy Cold modalities
Physical agents and mechanical interventions | Cryotherapy | Cold packs Ice massage

ADL = activities of daily living; IADL = instrumental activities of daily living

For Key Question 2, we included all studies that examined the association between intermediate and patient-centered outcomes of physical therapy interventions.

We included observational studies when no trial data were available to estimate treatment benefits and harms.33

We included RCTs with subjects who had both knee and hip OA if outcomes for the two groups were reported separately. For Key Question 2, we included studies of tests and measures of functional outcomes in adults with knee OA.

### Exclusion Criteria

1. Studies that involved children, adolescents, hospitalized patients, or patients in long-term care facilities.
2. Studies that included patients with knee or hip OA but did not separately report the outcomes.
3. Studies that involved surgical treatments or pharmacologic treatments for knee OA.
4. Studies that examined physical therapy delivered via rehabilitation programs for adults with knee OA who had undergone knee arthroplasty within 6 months before the study.
5. Studies that validated tests and measures in populations with other diseases.
6. Studies that reported absolute values of the diagnostic tests in adults with knee OA.
7. Studies that did not test associative hypotheses or that did not provide adequate information on tested hypotheses (e.g., least square means, relative risk).
8. Case series when the evidence was available from RCTs or controlled observational studies.
9. Secondary data analyses, nonsystematic reviews, letters, or comments.

We excluded studies that examined drugs as an independent variable, but included them if existing medications were maintained as constant as possible during the physical therapy intervention study.

To assess harms of treatments, we followed the recommendations from the Methods Guide for Effectiveness and Comparative Effectiveness Reviews from AHRQ34 and included published and unpublished evidence of the adverse effects of eligible interventions.

We defined harms as a totality of all possible adverse consequences of an intervention.34 We analyzed harms regardless of how authors perceived causality of treatments.

We did not contact the primary investigators of the studies. The Scientific Resource Center requested Scientific Information Packets from appropriate manufacturers per usual procedures.

### Study Selection

At least two investigators evaluated each study for eligibility according to recommendations from the Cochrane Handbook for Systematic Reviews of Interventions.35 We developed an algorithm to define study eligibility for each research question. We followed the guidelines to select evidence from controlled trials and observational studies.36 We defined the target population, eligible independent and dependent variables, outcomes, time, and setting following the Population, Intervention, Comparator, Outcome, Timing, and Setting (PICOTS) framework (Appendix D). Eligible trials enrolled community-dwelling adults with knee OA and reported pain as an inclusion criterion and/or outcome. Disagreements about the appropriateness of an article were resolved through discussion.

Eligible interventions fell within the scope of physical therapy practice whether or not the articles clearly described physical therapists’ or physical therapist assistants’ involvement in a given study.37 Eligible comparators included sham stimulation, usual care, and no active treatment for analyses of efficacy, and physical therapy interventions for the analysis of comparative effectiveness. Eligible patient-centered outcomes included knee pain, disability, quality of life, perceived health status, and global assessments of treatment effectiveness. Eligible intermediate outcomes included composite function, joint function, gait function, strength, and transfers.

To minimize risk of bias and to obtain valid estimates of benefits and harms, we focused on RCTs. While randomization may distribute the effects of other treatments equally, their impacts still need to be taken into account. Pain relievers and nonsteroidal anti-inflammatory drugs may mask the benefits of physical therapy, especially for pain. Thus, we also reviewed observational studies with multivariate adjustment for concomitant treatments and confounding factors.33, 36, 38

We reviewed the evidence of the efficacy and comparative effectiveness of physical therapy interventions for knee pain secondary to OA. We defined physical therapy and selected interventions and methods to assess the outcomes according to the classifications in the Practice Pattern 4E: Impaired Joint Mobility, Motor Function, Muscle Performance, and Range of Motion Associated with Localized Inflammation from the American Physical Therapy Association’s (APTA’s) Guide to Physical Therapist Practice.37

#### Data Extraction

We used the standard abstraction form to extract the data. One reviewer abstracted an article and a second reviewer checked the data for accuracy. We assessed errors in data extractions by comparing established ranges for each variable and the data charts with the original articles. Any detected discrepancies were discussed. We abstracted information relevant to the PICOT framework for each question. We abstracted minimum datasets to reproduce the results presented by the authors. For categorical variables, we abstracted a number of events among treatment groups. For continuous variables, we abstracted means and standard deviations.

For RCTs, we abstracted the number randomized to each treatment group as the denominator and calculated estimates by applying intention-to-treat principles. We abstracted the time when the outcomes were assessed as weeks from randomization and the time of followup after treatments. We categorized followup times as less than 6 weeks, 6 to 13 weeks, 14 to 26 weeks, or more than 26 weeks. For observational studies we extracted relative measures of the association (relative risk, hazard ratio, odds ratio) with standard error or 95% confidence interval (CI) and reported adjustments for patient characteristics.

For diagnostic studies we abstracted the number of positive (true and false) and negative (true and false) with index diagnostic tests when compared with gold standard.

Data abstraction forms are shown in Appendix E and can be found at https://netfiles.umn.edu/xythoswfs/webui/_xy-20731563_1-t_wzpHYqhT.

We abstracted sponsorship of the studies and conflict of interest by the authors. We abstracted baseline patient characteristics, including eligible and mean age; mean body mass index (BMI); proportion of women and minorities, subjects with disability, severe knee OA, comorbidities, and/or multi-joint OA; baseline physical activity level; occupation; and concomitant drug and physical therapy interventions. We abstracted the proportions of patients taking anti-inflammatory and analgesic medications and the types and doses of the drugs. We abstracted settings and supervision of treatments by physical therapists. We abstracted type, dose, length, and intensity of interventions when reported by the authors.

### Risk of Bias Assessment

We evaluated risk of bias in the studies according to recommendations from the Methods Guide for Effectiveness and Comparative Effectiveness Reviews from the Evidence-based Practice Center Program at AHRQ (www.effectivehealthcare.ahrq.gov)38 and the Cochrane Handbook for Systematic Reviews of Interventions.35

We classified the studies by design to distinguish randomized and nonrandomized controlled clinical trials from observational studies. Then we abstracted predefined criteria for critical appraisal of risk of bias. We evaluated risk of bias with criteria of internal validity. For interventional studies, we used criteria from the AHRQ Methods Guide38 and from the Cochrane risk of bias tool.35

Risk of bias criteria for therapeutic studies included randomization, adequacy of randomization and allocation concealment, masking of the outcomes assessment, and intention-to-treat principles.35 We evaluated disclosure of conflict of interest by the authors of individual studies and funding sources but did not use this information to downgrade quality of individual studies. We did not downgrade methodological quality of poorly reported studies; however, we separately synthesized evidence from these studies.

For observational studies, we evaluated strategies to reduce bias in study design and analysis, including adjustment for confounding and valid outcome measurements. For diagnostic studies, we applied the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) criteria.39, 40

Rather than using a global risk of bias score, we assessed individual risk of bias criteria.41, 42

We defined well-designed RCTs with adequate allocation concealment, intention-to-treat principles in analysis, and adequate randomization as studies with low risk of bias. We defined RCTs as having medium risk of bias if one risk of bias criterion was not met. We defined RCTs as having high risk of bias when two or more criteria were not met.

#### Applicability

We evaluated applicability with criteria of external validity. We estimated applicability of the population by evaluating subject selection in observational studies and clinical trials.43 Studies of community-dwelling adults with knee OA recruited from the general population had high applicability. Large observational cohorts based on national registries, population-based effectiveness trials, and nationally representative administrative and clinical databases had higher applicability, as did studies of interventions conducted by physical therapists and studies with followup times of 3 months, 6 months, or longer.

#### Data Synthesis

We synthesized and presented the evidence according to the classification of physical therapy interventions and modalities from APTA’s Guide to Physical Therapist Practice. We summarized the results into evidence tables (Appendix F).

For categorical variables, we calculated rates, relative risk, and absolute risk differences. For continuous variables, we calculated mean differences with 95% CI. We also calculated ratios of means that describe percentage differences in pain with active versus control interventions.44 If we found more than one study from a particular trial, we used the results from the latest published paper.

We addressed the role of concomitant treatments in association with patient outcomes and synthesized the evidence according to other nonsurgical treatments for knee OA reported in the studies. We then compared the effects of the examined physical therapy interventions across the studies according to the reported proportion of patients taking concomitant drugs and the types of drugs. We conducted sensitivity and subgroup analyses according to concomitant drug treatments when the available data were suitable for pooling. Using a standard preplanned algorithm, we explored heterogeneity by clinical diversity45 (age, sex, race, baseline ADL, IADL, comorbidity, and obesity). We explored heterogeneity by type, dose (when applicable), duration of treatment, and whether the control treatment included education or exercise. We performed subgroup analyses by the involvement of a physical therapist for all outcomes with aerobic or strengthening exercises since other interventions were likely administered by physical therapists. We performed meta-analyses based on examined physical therapy modalities and their combinations and using four followup time categories. We conducted subgroup analyses to examine the association between each physical therapy modality and physical therapy intervention effect size.

Rather than using the global risk of bias score, we explored heterogeneity by risk of bias criteria of individual studies and by the disclosed conflict of interest.42, 45, 46

Following guidelines and recommendations from key informants and TEP members, we focused on patient-centered outcomes including pain, disability, and quality of life.24 We categorized intermediate outcomes as measurements relevant to the practice of physical therapy such as gait, strength, balance, transfers, endurance, joint function, and composite measure of function. We synthesized evidence depending on measurements of the outcomes with validated scales.

We reviewed validity and reliability of the tests within the scope of physical therapy practice. Evidence of the association between intermediate and patient-centered outcomes was synthesized from observational studies that adjusted for treatments and confounding factors. We synthesized evidence from the studies that reported diagnostic values of intermediate outcomes to predict clinical outcomes. In a separate analysis, we synthesized the evidence of the association between intermediate and clinical outcomes from linear, logistic, and Cox regression models.

We calculated differences in relative risk and absolute risk from the abstracted events using Meta-analyst47 and STATA48 software at a 95% CI. We used correction coefficients and forced intention-to-treat to estimate treatment effects among all randomized patients regardless of the authors’ exclusion of subjects from the analyses.35 We calculated nonstandard mean differences in continuous variables from the reported means and standard deviations by using Meta-analyst47 and STATA48 software at a 95% CI. We defined magnitude of the effect using Cohen’s criteria of small, medium, and large effect corresponding to 0–0.5, 0.5–0.8, and >0.8 standardized mean differences in the units of standard deviations.49 We analyzed the adjusted regression coefficients with a standard error of association between intermediate and patient-centered outcomes.

Pooling criteria for Key Questions 1 and 3 required that definitions of physical therapy interventions and outcomes be the same. We grouped different measure instruments within reasonably similar content and structure with respect to pain, disability, quality of life, and composite function. We categorized treatments according to the way in which they were defined and ordered in the Guide to Physical Therapist Practice.37 To address differences in outcomes measures, we analyzed all eligible RCTs with the recommended standardization method, instead of excluding valuable results from eligible RCTs that used different measures of the outcomes.50

We calculated standardized mean differences for different measures of the same outcome with Cohen and Hedges methods. We back transformed standard mean differences (SMDs) to mean differences50 for disability using EQ-5D, a multi-attribute, preference-based health status measuring instrument,51 and for quality of life using the 36-Item Short-Form Health Survey (SF-36).52 We back transformed SMDs to mean differences using several instruments: for pain we used the Visual Analog Scale (VAS),53 for composite function we used the Western Ontario and McMaster Universities Osteoarthritis Index (WOMAC) function score, and for gait function we used walking speed.53 We derived pooled standard deviations of EQ-5D and SF-36 from large population-based studies of noninstitutionalized adults.51 52–54 We multiplied the SMDs by the among-person standard deviation to yield an estimate of the difference in mean outcome scores (with versus without intervention) on EQ-5D (0.38^51^), SF-36 (10.9^52^), VAS (22 in scale 0 to 100),53 WOMAC physical function (18.5),54 and walking speed (0.2 m/s).53 We categorized treatment effects by the clinical importance of differences in intermediate outcomes. We used definitions of MCIDs from published studies and evidence-based reports.55 We categorized the results from each tested hypothesis as either nonsignificant differences in continuous outcomes, or as statistically significant with <20, 20–50, or >50 percent differences from the control interventions.56

We tested consistency in the results by comparing the direction and strength of the association57 and used Chi square and I square tests to assess heterogeneity in study results.58, 59 We explored heterogeneity with meta-regression and sensitivity analysis, and reported the results from random effects models only.60 We chose the random effects model because it incorporates in the pooled analysis differences across trials in patient populations, baseline rates of the outcomes, and definitions of interventions and outcomes.45

We assumed the presence of publication bias and did not use statistical tests for bias (defined as the tendency to publish positive results).35, 61

We used several strategies to reduce study selection bias, including a comprehensive literature search of published and unpublished evidence in several databases, reference lists of systematic reviews, proceedings of scientific meetings, contacts with experts for additional references, and agreement on the eligibility status by several investigators. We examined publication rates among studies registered in ClinicalTrials.gov that examined physical therapy interventions in adults with knee osteoarthritis.

The numbers needed to treat to achieve one event of patient-centered outcome were calculated as reciprocals of the absolute risk differences in rates of outcome events in the active and control groups.48, 62 The number of avoided or excess events (respectively) per population of 1,000 was the difference between the two event rates multiplied by 1,000. We calculated means and 95% CI for treatment events per 1,000 treated, multiplying pooled absolute risk difference by 1,000.^63^

For Key Question 2, we summarized results of individual studies in evidence tables to analyze sensitivity, specificity, predictive values, diagnostic odds ratios, and predictive likelihood ratios. We focused on the latter.64, 65 Ratios of 1 indicated that the tests did not provide likelihood of accurate diagnosis.66 Ratios of more than 10 provided large and often conclusive increases in the likelihood of accurate diagnosis.66 We tabulated each article for results of index diagnostic tests and reference standards. We evaluated validation and the proposed MCIDs in total scores when this information was available. To judge validity from the studies that reported correlation coefficients between index and reference methods, we categorized correlation into the following categories: weak correlation as <20 percent, medium correlation as 20–50 percent, strong correlation as 50–75 percent, and very strong correlation as >75 percent.49

To answer the question of which intermediate outcomes meet the criteria of surrogates for patient-centered outcomes, we used Outcome Measures in Rheumatoid Arthritis Clinical Trials (OMERACT) Criteria for Surrogate Endpoints.56, 67 We examined whether randomized trials evaluated the association between intermediate and patient-centered outcomes.67

### Grading the Evidence for Each Key Question

We assessed strength of evidence by following the guidelines from AHRQ’s Methods Guide and the Grading of Recommendations Assessment, Development, and Evaluation (GRADE) criteria.57 We judged the strength of evidence for each major outcome according to risk of bias, consistency, directness, and precision.57

For pooled analyses, we defined overall risk of bias according to most common risk of bias in individual studies. We focused on direct evidence from head-to-head RCTs. We defined treatment effects as consistent when statistical heterogeneity was insignificant. We defined treatment effect estimates as precise when pooled estimates had reasonably narrow 95% CIs and pooled sample size was greater than 400.^68^ Specifically, because side effects of physical therapy are rare and not serious, we defined the effect size to be precise if the 95% CI of effect size did not include 0. For cases where 95% CI of estimated standardized effect size did include 0, the 95% CI had to be within ±0.5 to be precise enough that we would not miss potential benefits/harms.

When appropriate, we included dose-response association, presence of confounders that would diminish an observed effect, or strength of association. We defined magnitude of the effect using Cohen’s criteria as small, middle, and large effect corresponding to >0.5 and >0.8 standardized mean differences in standard deviation units.49

We assigned high strength of evidence from low risk of bias RCTs that reported consistent precise findings for which future research would be very unlikely to change the estimate of effect. We assigned a moderate strength of evidence if one criterion mentioned above was not met. We assigned a low strength of evidence if at least two criteria mentioned above were not met, or evidence was limited to an individual study with low or medium risk of bias; these are findings for which further research is likely to change the estimate. We defined insufficient evidence as that limited to an individual study with a high risk of bias. We judged whether the overall body of available evidence allowed for conclusions that were sufficiently robust and resistant to bias and errors to inform clinical decisionmaking.35

We followed the criteria of the United States Preventive Services Task Force in assessing strength of evidence from observational studies that examined the association between patient-centered and intermediate outcomes.69

We graded the strength of evidence for primary outcomes across therapeutic studies as illustrated in Table 2.

Table 2 Strength of evidence for primary outcomes across therapeutic studies

Grade | Definition | Operationalization
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect. | Low risk of bias, consistency, precision, and, when appropriate, large effect size.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate. | If one criterion mentioned above was not met.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate. | If at least two criteria mentioned above were not met or evidence is limited to an individual study that is low or medium risk of bias.
Insufficient | Evidence does not permit a conclusion. | Evidence is limited to an individual study with high risk of bias. No studies provided evidence.

#### Applicability

We estimated applicability of the population by evaluating subject selection in observational studies and clinical trials.43 Studies of community-dwelling adults with knee OA recruited from the general population had high applicability. Large observational cohorts based on national registries, population-based effectiveness trials, and nationally representative administrative and clinical databases had higher applicability, as did studies of interventions conducted by physical therapists and studies with followup times of 3 months, 6 months, or longer.