# Introduction

Osteoarthritis (OA), the most common form of arthritis,1 is a progressive disorder in which gradual cartilage loss causes bony spurs and cysts to develop at the surface and margins of the joints. Inflammation, pain, stiffness, limited movement, and possible deformity of the joint may result.2 OA of the knee affects 28 percent of adults over age 45^3^ and 37 percent of adults over age 65 in the United States.3–6 Already, OA is a leading cause of disability among noninstitutionalized adults;4 those affected by it have slower gait velocities and use more assistive walking devices and nonsteroidal anti-inflammatory drugs and narcotics than those not affected. The Centers for Disease Control and Prevention anticipates that the prevalence, health impact, and economic consequences of OA will surge during the next few decades as the population ages.7

Treatments for OA aim to reduce or control pain, improve physical function, prevent disability, and enhance quality of life—all of which constitute clinical outcomes of importance to patients.8, 9 Treatment options include pain relievers, anti-inflammatory drugs, weight loss, general physical exercise, physical therapy, and, when conservative treatments fail, surgery.9, 10

Surgical treatments for knee OA include realignment osteotomy and total knee arthroplasty revisions (knee replacements).11 In the United States, about 556,400 knee replacement surgeries are performed annually,11 a figure that increased by nearly 300 percent between 1990 and 2004.^7, 11, 12^ By 2030, the annual number of total knee arthroplasty revisions in the United States is projected to increase 600 percent.12

The Osteoarthritis Research Society International (OARSI) asserts that optimal OA management combines nonpharmacologic and pharmacologic modalities.9, 10, 13, 14 However, with the exception of exercise, scant evidence exists for the efficacy of adjunct therapies for knee OA.15, 16 Based on the findings of one systematic review,9, 17 OARSI and the American Academy of Orthopedic Surgeons recommend a variety of physical therapy interventions, including low-impact aerobic fitness exercises, range-of-motion/flexibility exercises, quadriceps strengthening, and patellar taping for short-term pain relief.9, 17 The National Institute for Health and Clinical Excellence guidelines10 agree that exercise (including local muscle strengthening and general aerobic fitness) should be a core treatment for osteoarthritis regardless of patient age, comorbidity, pain severity, or disability. The National Institute for Health and Clinical Excellence also suggests other nonpharmacologic physical therapy interventions as adjunct to core treatment.10

Many systematic reviews, including three from the Cochrane Collaboration,18–20 have synthesized data on physical therapy interventions for adult patients with knee OA. However, each published review examines a specific intervention instead of examining and comparing a range of available physical therapies. Most existing studies focus on exercise therapy; however, studies currently underway include physical therapy components such as insole treatment, knee bracing, wedged orthoses, manual therapy, weight loss, home-based exercises, strength training, knee stability training, electrical stimulation, and ultrasound. Publication of substantial new research evidence may alter the calculated risk-benefit ratio for some OA physical therapies and thus necessitate the updating of research evidence.13, 21

## Measuring Outcomes of Physical Therapy Interventions

Measurement of physical therapy benefits should address patient-centered outcomes rather than the results of instrumental tests.22 Additionally, clinicians and policymakers should consider patient-centered outcomes when making treatment and reimbursement decisions.

We need to recognize the importance of the relationship between patient-centered and intermediate outcomes for adult patients with knee OA.23 Intermediate outcome measures, such as measures of gait, muscle strength, or joint function, are helpful to develop individualized treatment plans and to document gradual progress in function. These measures may also help with patient adherence/compliance to the exercise program, and ultimately promote success in achieving desired patient-centered outcomes such as prevention of disability. Research based on patient-centered outcomes provides patients and clinicians valuable information for making decisions about physical therapy and other health care services.24

Patient-centered outcomes for adults with pain secondary to knee OA include reduction in pain and improvement in functional disability and quality of life.25 Some consensus exists that clinical trials for knee OA should examine pain, physical function, patient global assessment, and joint imaging.26 However, published studies have inconsistently interpreted and defined improvement and treatment success.18, 19, 27, 28 Clinical trials have estimated the benefits and harms of physical therapy with validated scales of pain, function, and quality of life.29, 30 Clinicians and researchers have used statistically significant changes in scale scores to define treatment success, without accounting for whether these score changes have clinical importance. Score changes that equate to benefits patients recognize as important are known as minimum clinically important differences, or MCIDs. MCIDs have been determined by individual studies, but have not been systematically reviewed.

Further, studies of physical therapy interventions have examined intermediate outcomes. These outcomes have been defined as improvement (as measured by a variety of assessment tools) in tests of balance, knee joint range of motion, gait speed, or muscle strength. Yet, validation of such measurements of functional impairments has not been systematically reviewed. In addition, clinical trials have concluded benefits with physical therapy interventions according to absolute changes in functional measurements, while ignoring the clinical importance of such changes. Likewise, reimbursement for physical therapy services is currently driven by measurements of gait, transfers, and activities of daily living (ADLs), regardless of how patients perceive improvements.

No systematic reviews or primary studies of physical therapy for adult patients with knee OA have specifically examined the relationship between changes in intermediate outcomes and meaningful changes in patient-centered outcomes, such as disability in activities of daily living, quality of life, or lost work time. Quality of care could be improved by evaluating how clinical effects are measured and documented, as well as by reviewing outcomes information for research.

Our review intends to contribute to evidence-based recommendations by synthesizing published efficacy evidence for physical therapy interventions for knee pain secondary to OA. We systematically reviewed studies that examined physical therapy interventions and assessed intermediate and patient-centered outcomes.

The Key Questions used to guide this study are shown below.

### Key Question 1

What are the effectiveness and comparative effectiveness of available physical therapy interventions (without drug treatment) for adult patients with chronic knee pain due to OA on intermediate and patient-centered outcomes, compared to no active treatment or another active physical therapy modality?

a. Which patient characteristics are associated with the benefits of examined interventions of physical therapy on intermediate and patient-centered outcomes?
b. Do changes in intermediate and patient-centered outcomes differ by the dose, duration, intensity, and frequency of examined interventions of physical therapy?
c. Do changes in intermediate and patient-centered outcomes differ by duration of examined interventions of physical therapy and the time of followup?

### Key Question 2

What is the association between changes in intermediate outcomes with changes in patient-centered outcomes after physical therapy interventions?

a. What is the validity of the tests and measures used to determine intermediate outcomes of physical therapy on OA in association with patient-centered outcomes?
b. Which intermediate outcomes meet the criteria of surrogates for patient-centered outcomes?
c. What are minimum clinically important differences of the tests and measures used to determine intermediate outcomes?

### Key Question 3

What are the harms from physical therapy interventions available for adult patients with chronic knee pain due to osteoarthritis when compared to no active treatment or active controls?

a. Which patient characteristics are associated with the harms of examined physical therapy interventions?
b. Do harms differ by the duration of the treatment and time of followup?