# Technical Expert Panel

Roy Altman, M.D.

University of California

Los Angeles, CA

Mary Bell, M.D.

University of Toronto

Toronto, Ontario

G. Kelley Fitzgerald, Ph.D., P.T., O.C.S., FAPTA

University of Pittsburgh

Pittsburgh, PA

Marc Hochberg, M.D., M.P.H.

University of Maryland School of Medicine

Baltimore, MD

Carol Oatis, Ph.D., P.T.

Arcadia University

Philadelphia, PA

Jennifer Stevens-Lapsley, Ph.D., P.T.

University of Colorado

Denver, CO