# Key Informants

G. Kelley Fitzgerald, Ph.D., P.T., O.C.S., FAPTA

University of Pittsburgh

Pittsburgh, PA

Mark Haubner, B.A.

Huntington, NY

Robin Katzanek, P.T., M.A., Ph.D.

Liberty Physical Therapy

Wakefield, RI

Timothy Kauffman, Ph.D., P.T.

Private Practice

Lancaster, PA

Alex Malter, M.D.

Department of Health & Social Services

Juneau, AK

Marilyn Moffat, P.T., D.P.T., Ph.D., D.Sc. (hon), FAPTA, CSGS, CEEAA

New York University

New York, NY

Pam Snow

Department of Human Resources

Warner Robins, GA