# Executive Summary

## Background

Osteoarthritis (OA), the most common form of arthritis,1 is a progressive joint disorder characterized by gradual loss of cartilage.2 Osteoarthritis of the knee afflicts 28 percent of adults over age 45^3^ and 37 percent of adults over age 65 in the United States.4 As a leading cause of disability among noninstitutionalized adults,4 OA’s prevalence, effect on health, and economic consequences are expected to increase dramatically during the next few decades as the population ages.5

OA treatments aim to reduce or control pain, improve physical function, prevent disability, and enhance quality of life.6 Conservative treatment options include pain relievers, anti-inflammatory drugs, weight loss, general physical exercise, and physical therapy.7, 8 Optimal OA management combines pharmacologic treatments with physical therapy interventions7–10 and, when conservative treatments fail, surgery.7, 8 Surgical treatments for knee OA include realignment osteotomy and knee replacements.11 In the United States, about 556,400 knee replacement surgeries are performed annually.11 By 2030, that number is projected to increase by 600 percent.12

Comprehensive, up-to-date guidelines are available from the Osteoarthritis Research Society International (OARSI), the American Academy of Orthopedic Surgeons, and the National Institute for Health and Clinical Excellence. These guidelines recommend exercise (including local muscle strengthening and general aerobic fitness) as a core treatment for symptomatic osteoarthritis, regardless of patient age, comorbidity, pain severity, or disability.7, 8, 13 Effectiveness has not been clearly established for other nonpharmacologic physical therapy interventions as adjunct to core treatment (e.g., thermal, manipulation, electrical nerve stimulation, and orthotics).7

Patient-centered clinical outcomes include functional status, pain, and quality of life.8 Consumers judge the success of physical therapy interventions by improvement in patient-centered outcomes.14, 15 Some consensus exists that clinical trials for symptomatic knee OA should examine patient-centered clinical outcomes and joint imaging.16 However, published studies inconsistently define treatment success.17–20 In practice, physical therapists evaluate treatment success using intermediate outcomes related to function, including instrumental measurements of gait, balance, and range of motion. Likewise, reimbursement is currently driven by functional outcomes, including gait, transfers, and activities of daily living. Yet, we are not certain whether these outcomes predict pain, disability, or quality of life.

This report synthesizes published evidence about the effectiveness of physical therapy for pain secondary to knee OA in adults. We focused on community-dwelling adults in ambulatory care settings and on interventions applicable to physical therapy practice. Our systematic review is intended to help clinicians, consumers, and policymakers make informed decisions based on synthesized evidence and other relevant factors.

### Input From Stakeholders

We developed our Key Questions with stakeholder input as part of the Effective Health Care Program. We developed an analytic framework (Figure A) after discussions with key informants. Research questions were posted for public comment. Key informants recommended that we focus on patient-centered outcomes and physical therapy interventions relevant for clinical practice in the United States. Key informants also recommended that we review the intermediate outcomes with which physical therapists judge treatment success. Candidates to serve as Key Informants, technical experts, and Peer Reviewers were approved by the Task Order Officer from the Agency for Healthcare Research and Quality (AHRQ) after disclosure of conflicts of interest. We developed the protocol following Preferred Reporting Items for Systematic Reviews and Meta-Analyses guidelines 21 (www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=637&pageaction=displayproduct), with input from members of the Technical Expert Panel (TEP).

Figure A Analytic framework

ADL = activities of daily living; IADL = instrumental activities of daily living; KQ = Key Question

This figure depicts the key questions within the context of the PICOTS. In general, the figure illustrates how different physical therapy interventions in adults with knee osteoarthritis may improve intermediate outcomes (e.g., joint movement, or impairments in performance tests) and patient-centered outcomes (e.g., pain, activities of daily living, decreased disability; return to work/activities, or quality of life). Adverse events may occur at any point after treatment is received. Treatment effects may be modified by age, gender, race, baseline ADL/IADL disability, comorbidity, concomitant/prior treatments, activity level, or occupation. The figure also illustrates the questions about the validity, reliability, and minimum clinically important difference of the tests and measures to determine intermediate outcomes (e.g. joint movement or impairments in performance tests). Dotted line points out the association between changes in intermediate outcomes with the changes in patient-centered outcomes.

## Objectives

For the topic of physical therapy interventions for adults with knee OA, our goal was to conduct (1) a comprehensive review of the literature about the association between intermediate and patient-centered outcomes and (2) a comprehensive synthesis of evidence of the clinical efficacy and comparative effectiveness of the interventions. We followed the principles from the Methods Guide for Effectiveness and Comparative Effectiveness Reviews from AHRQ (http://effectivehealthcare.ahrq.gov/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318). We examined the following questions:

### Key Question 1 What are the effectiveness and comparative effectiveness of available physical therapy interventions (without drug treatment) for adult patients with chronic knee pain due to OA on intermediate and patient-centered outcomes when compared to no active treatment or another active physical therapy modality?

a. Which patient characteristics are associated with the benefits of examined interventions of physical therapy on intermediate and patient-centered outcomes?
b. Do changes in intermediate and patient-centered outcomes differ by the dose, duration, intensity, and frequency of examined interventions of physical therapy?
c. Do changes in intermediate and patient-centered outcomes differ by the time of followup?

### Key Question 2 What is the association between changes in intermediate outcomes with changes in patient-centered outcomes after physical therapy interventions?

a. What is the validity of the tests and measures used to determine intermediate outcomes of physical therapy on knee OA in association with patient-centered outcomes?
b. Which intermediate outcomes meet the criteria of surrogates for patient-centered outcomes?
c. What are the minimum clinically important differences of the tests and measures used to determine intermediate outcomes?

### Key Question 3 What are the harms from physical therapy interventions available for adult patients with chronic knee pain due to osteoarthritis when compared to no active treatment or active controls?

a. Which patient characteristics are associated with the harms of examined physical therapy interventions?
b. Do harms differ by the duration of the treatment and time of followup?

## Methods

### Data Sources

We sought studies from a wide variety of sources, including MEDLINE^®^ via OVID and PubMed^®^, the Cochrane Library, the Physiotherapy Evidence Database (PEDro), SCIRUS, Allied and Complementary Medicine (AMED), and the Health and Psychosocial Instruments bibliography database up to February 29, 2012. We conducted manual searches of reference lists from systematic reviews and eligible studies. The grey literature search included regulatory documents, conducted clinical trials, and abstracts presented in scientific meetings.

### Study Selection

At least two investigators independently evaluated each study for eligibility. Disagreements were resolved by consensus. We defined the target population, eligible independent and dependent variables, outcomes, time, and setting following the PICOTS (Population, Intervention, Comparator, Outcomes, Timing, and Settings) framework developed in the protocol. We included original studies of adults with knee OA published in English after 1970. Eligible trials enrolled community-dwelling adults with knee OA and reported pain as an inclusion criterion and/or outcome. Eligible interventions fell within the scope of physical therapy practice, whether or not the articles clearly described the involvement of physical therapists or physical therapist assistants in a given study.22 For analyses of efficacy, eligible comparators included sham stimulation, usual care, and no active treatment; for comparative effectiveness, eligible comparators were physical therapy interventions. Eligible patient-centered outcomes included knee pain, disability, quality of life, perceived health status, and global assessments of treatment effectiveness. Eligible intermediate outcomes included composite function, joint function, gait function, strength, and transfers.

To minimize risk of bias and to obtain valid estimates of physical therapy benefits and harms, we focused on randomized controlled trials (RCTs). While randomization may distribute the effects of other treatments equally, their efficacy must still be taken into account. Moreover, some nonphysical therapy treatments, such as pain relievers, may in part mask the benefits of physical therapy, especially for pain. We also reviewed observational studies with multivariate adjustment for concomitant treatments and confounding factors.23, 24 We defined physical therapy and selected the interventions and methods to assess the outcomes in accordance with “Practice Pattern 4E: Impaired Joint Mobility, Motor Function, Muscle Performance, and Range of Motion Associated with Localized Inflammation” from the Guide to Physical Therapist Practice.22

For Key Question 2, we included any observational studies that reported the association between intermediate and patient-centered outcomes.

We defined the target population as community-dwelling adults with knee pain secondary to knee OA. We excluded studies involving children, adolescents, hospitalized patients, or patients in long-term care facilities; studies that included patients with knee or hip OA that did not separately report the outcomes in patients with knee OA; and studies that aimed to examine surgical or pharmacologic treatments for knee OA. We also excluded studies that examined physical therapy delivered via rehabilitation programs for adults with knee OA who had undergone knee arthroplasty within 6 months before the study. For Key Question 2, we did not review validation of tests in populations with diseases other than knee OA.

We defined harms as a totality of all possible adverse consequences of an intervention.25 We included published and unpublished evidence of adverse effects with eligible interventions, regardless of how authors perceived causality of treatments.25 We did not contact the primary investigators for further information or clarification about the methodology or results of the trials.

### Data Extraction

We used standardized forms to extract data. We conducted a double independent quality control for the data extracted from RCTs. One reviewer abstracted an article and a second reviewer checked the data for accuracy. We abstracted minimum datasets for therapeutic studies. For categorical variables, we abstracted the number of events among treatment groups. We abstracted means and standard deviations of continuous variables. For RCTs, we abstracted the number randomized to each treatment group. We abstracted the time when the outcomes were assessed as weeks from randomization and the time of followup after treatments; we categorized followups as less than 6 weeks, 6 to 13 weeks, 14 to 26 weeks, or more than 26 weeks. For observational studies, we extracted relative measures of the association (relative risk, hazard ratio, odds ratio) with standard error or 95% confidence interval (CI), and reported adjustments for patient characteristics.

For the studies about the association between intermediate and patient-centered outcomes for Key Question 2, we abstracted the number of positive (true and false) and negative (true and false) with index diagnostic tests when compared with the reference standard.

We abstracted baseline patient characteristics, including eligible and mean age; mean body mass index; proportion of women and minorities; proportion with disability; proportions with severe knee OA, comorbidities, and multijoint OA; baseline physical activity level; occupation; and concomitant drug and physical therapy interventions. We abstracted settings and physical therapist supervision of the treatments. We abstracted type, dose, length, and intensity of physical therapy interventions when reported by the authors.

### Risk of Bias Assessment and Strength of Evidence

Using a modified Cochrane risk of bias tool,26 we evaluated risk of bias in individual studies according to their designs We evaluated random allocation of the subjects to treatment groups, adequacy of randomization and allocation concealment, masking of the treatment status for the outcome assessment, and intention-to-treat principles. We examined sponsorship and conflict of interest but did not increase risk of bias by using this information.

We defined RCTs as having medium risk of bias if one criterion was not met and high risk of bias if two or more criteria were not met.

We evaluated diagnostic studies for Key Question 2 using criteria from the Quality Assessment of Diagnostic Accuracy Studies.27

We assessed strength of evidence from therapeutic studies for each major outcome according to risk of bias, consistency, directness, and precision.28 We focused on direct evidence from head-to-head RCTs. We downgraded strength of evidence if: (1) risk of bias was moderate or high; (2) heterogeneity was statistically significant; or (3) estimates were inconsistent or imprecise. We defined treatment effect estimates as precise when pooled estimates had reasonably narrow 95% CIs and pooled sample size was greater than 400. When appropriate, we included strength of association28 and upgraded the strength of evidence if the standardized effect size was more than 0.8. We defined strength of evidence as low when evidence was limited to an individual study with low or medium risk of bias, and we defined evidence as insufficient if drawn from single studies with high risk of bias.28 We judged whether the overall body of available evidence allowed for conclusions that were sufficiently robust and resistant to bias and errors to guide clinical decisionmaking.26

We followed the criteria of the United States Preventive Services Task Force in assessing strength of evidence from observational studies that examined the association between patient-centered and intermediate outcomes.29

### Applicability

We estimated the applicability of the sample by evaluating the selection of adults in observational studies and clinical trials. For each intervention study, we also examined setting (including the involvement of physical therapists or physical therapist assistants) and exclusion criteria.

### Data Synthesis and Analysis

We synthesized and presented the evidence according to the classification of physical therapy interventions from the American Physical Therapy Association’s (APTA’s) Guide to Physical Therapist Practice.22

For categorical variables, we calculated rates, relative risk, and absolute risk differences. For continuous variables we calculated mean differences with 95% CI. We also calculated ratios of means that describe percentage differences in pain with active versus control interventions.30 We calculated estimates by applying intention-to-treat principles. If we found more than one study from a particular trial, we used the results from the latest published papers.

We examined and synthesized evidence of other nonsurgical treatments for knee OA if reported in the studies. We then compared effects of the examined physical therapy interventions across the studies according to reported concomitant drug treatments. We conducted sensitivity and subgroup analyses according to concomitant drug treatments when the available data were suitable for pooling.

Using a standard preplanned algorithm, we explored heterogeneity by characteristics of clinical diversity, including age, sex, race, and baseline activities of daily living (ADL), instrumental activities of daily living (IADL), comorbidity, obesity, and significant skeletal abnormality.31 We explored heterogeneity by treatment type, dose (when applicable), and duration, as well as by whether the control treatment included education or exercise. We performed subgroup analyses by the involvement of a physical therapist for all outcomes with aerobic or strengthening exercises but not with other interventions that were likely administered by physical therapists. We explored heterogeneity by disclosed conflict of interest31 and by individual risk of bias criteria of individual studies rather than using a global risk of bias score.32, 33

We focused on patient-centered outcomes, including pain, disability, and quality of life.34 We categorized intermediate outcomes as measurements of gait, strength, balance, transfers, endurance, joint function, or composite measure of functional performance. We reviewed validity and reliability of the tests within the scope of physical therapy practice. Evidence of the association between intermediate and patient-centered outcomes of physical therapy interventions was synthesized from observational studies that adjusted for treatments and confounding factors. We synthesized evidence from the studies that reported diagnostic values of intermediate outcomes to predict clinical outcomes. In a separate analysis, we synthesized the evidence of the association between intermediate and clinical outcomes from linear, logistic, or Cox regression models.

Using Meta-analyst35 and STATA36 software at a 95% CI, we calculated differences in relative risk and absolute risk from the abstracted events, and we calculated nonstandard mean differences in continuous variables from the reported means and standard deviations. We used correction coefficients, forced intention to treat, and calculations for missing data as recommended by guidelines.26 Using Cohen’s criteria, we defined magnitude of the effect as small, middle, and large, corresponding 0–0.5, 0.5–0.8, and >0.8 standardized mean differences in standard deviation units.37 Pooling criteria forKey Questions 1 and 3 required that interventions and outcomes be similarly defined.

We categorized eligible physical therapy interventions according to the way in which they were defined and ordered in APTA’s Guide to Physical Therapist Practice.22 To address differences in outcomes measures, we analyzed all eligible RCTs with the recommended standardization method instead of excluding valuable results from eligible RCTs that used different measures of the outcomes.38 We calculated standardized mean differences (SMDs) for different measures of the same outcome with Cohen and Hedges methods. We back transformed SMDs to mean differences38 with several instruments: for disability, we used EQ-5D, a multiattribute, preference-based health status measuring instrument;39 for quality of life, we used the 36-Item Short-Form Health Survey (SF-36);40 for pain, we used the Visual Analog Scale (VAS);41 for composite function, we used the Western Ontario and McMaster Universities Osteoarthritis Index (WOMAC) function score;42 and for gait function, -we used walking speed.41 We derived pooled standard deviations of EQ-5D and SF-36 from large population-based studies of noninstitutionalized adults.39 40–42 We multiplied the SMDs by the among-person standard deviation to yield an estimate of the difference in mean outcome scores (with, versus without, intervention) on EQ-5D (0.38),39 SF-36 (10.9),40 VAS (22 in scale of 0 to 100),41 WOMAC physical function (18.5),42 and walking speed (0.2 m/s).41 We categorized treatment effects from the studies by the clinical importance of differences in intermediate outcomes according to definitions of minimum clinically important differences (MCIDs) from published observational studies and evidence-based reports.43 We categorized the results from each tested hypothesis as nonsignificant differences in continuous outcomes or as statistically significant differences of <20, 20–50, or >50 percent from control interventions.44

We tested consistency of the results by comparing the direction and strength of the association28 and assessed heterogeneity of results using Chi square and I square tests.45, 46 We also explored heterogeneity with meta-regression and sensitivity analysis. Using four followup time categories, we performed meta-analyses based on examined physical therapy modalities and their combinations. We conducted subgroup analyses to examine the association between each component and treatment effect size. We reported the results from random effects models only47 and chose the random effects model to incorporate in the pooled analysis differences across trials in patient populations, concomitant treatments, and definitions of interventions and outcomes.31

We qualitatively synthesized the evidence from poorly reported RCTs and observational studies. For studies that included knee and hip OA, we included the results in pooled analyses if we could isolate knee cases.

For Key Question 2, we summarized results of individual studies in evidence tables to analyze sensitivity, specificity, predictive values, diagnostic odds ratios, and predictive likelihood ratios, with a focus on the latter.48, 49 Ratios of 1 indicated that the tests did not provide a likelihood of accurate diagnosis.49 Ratios of more than 10 provided large, and often conclusive, increases in the likelihood of an accurate diagnosis.49

We tabulated each article for results of index diagnostic tests and reference standards. We evaluated validation and the proposed MCIDs in total scores when this information was available. To judge validity from the studies that reported correlation coefficients between index and reference methods, we categorized correlation as follows: weak correlations as <20 percent, medium correlation as 20–50 percent, strong correlation as 50–75 percent, and very strong correlation as >75 percent.37 To answer the question of which intermediate outcomes met the criteria of surrogates for patient-centered outcomes, we used Outcome Measures in Rheumatoid Arthritis Clinical Trials (OMERACT) Criteria for Surrogate Endpoints.44, 50 We examined whether randomized trials of physical therapy interventions evaluated the association between intermediate outcome change and patient-centered outcome change.50

## Results

Of 4,266 identified references, we included 576 references for this review (Figure B). For Key Questions 1 and 3, we synthesized evidence from 422 references. We calculated treatment effect from 261 references including 212 publications of 193 RCTs, and qualitatively analyzed 161 studies. Only 84 RCTs met pooling criteria and were included into meta-analyses. Definitions of physical therapy interventions and outcomes varied dramatically among studies; thus, only a small proportion of comparisons met pooling criteria. We prioritized pooled analyses and results at longest time of followup over nonpooled results and short followups. Most studies lasted 4 to 6 weeks, with a followup of 6 months.

Figure B Study flow

APTA = American Physical Therapy Association; CSA = Cambridge Scientific Abstracts; FDA = U.S. Food and Drug Administration; PEDro = Physiotherapy Evidence Database; RCT = randomized controlled trials

This figure depicts the study flow. Squared corner rectangles contain the number of retrieved, included, and excluded studies. The investigators retrieved a total of 4,266 references from Medline, the Cochrane library, the Scientific Resource Center, the website of the Federal Drug Administration, manual searches of reference lists, and other sources. They included 576 references.

Overall, RCTs had good applicability to our target population because they primarily recruited older adults with knee OA. More than 70 percent of the participants were female. Body mass index (BMI) of participants averaged 29 kg/m^2^. In 100 RCTs (52 percent), subjects were taking anti-inflammatory drugs or pain relievers. Half the studies provided no information about exact pharmacologic treatments. Few studies specified that they excluded patients with prior knee surgery, and most did not report participants’ occupation, knee injury, comorbidity, or duration of condition, or the proportion of subjects with baseline disability or who had undergone surgery.

Because the studies used different tools to measure the same outcomes, we used standardization in all pooled analyses. The studies examined continuous measures of the outcomes and rarely categorized the patients according to clinical importance of the changes.

The most common reasons for increased risk of bias were unmasking of the treatment status and no planned intention-to-treat analyses. Most RCTs had medium risk of bias.

### Key Questions

#### Key Question 1 Effectiveness of Physical Therapy Interventions

We found very few statistically significant differences in outcomes between active and control treatments. Tables A and C show how many studies examined each outcome, estimated effect sizes, and our level of confidence that the evidence reflects a true estimate of the treatment effect that is not likely to be changed by future research. Tables B and D present our conclusions about effectiveness of physical therapy interventions.

Table A Effectiveness of physical therapy intervention on patient-centered outcomes (standardized mean differences [SMDs] pooled with random effects models, using standardized units of differences-standard deviations)

Outcome, Studies, Sample Size, References | Risk of Bias | Directness | Consistency | Precision | Strength of the Association | Strength of Evidence | Pooled Hedges Standard Mean Difference (95% CI) Converted Mean Difference (95% CI)
Specific Education Programs
Pain 6–13 weeks Studies: 3; Subjects: 429^76–78^ | High | Direct | Inconsistent | Imprecise | NA | Low | 0.09 (−0.42, 0.60) 2.0 (−9.2, 13.2)
Pain >26 weeks Studies: 2; Subjects: 511^76, 79^ | High | Direct | Consistent | Precise | NA | Low | −0.09 (−0.32, 0.14) −2.0 (−7.0, 3.1)
Aerobic Exercise
Disability <6 weeks Studies: 2; Subjects: 117^80, 81^ | High | Direct | Inconsistent | Imprecise | Large | Low | −1.70 (−3.27, −0.13) −0.65 (−1.24, −005)
Disability 6–13 weeks Studies: 8; Subjects: 739^77, 80–86^ | High | Direct | Inconsistent | Imprecise | NA | Low | −0.44 (−0.94, 0.05) −0.17 (−0.36, 0.02)
Disability 13–26 weeks Studies: 2; Subjects: 277^82, 83^ | Medium | Direct | Consistent | Imprecise | NA | Low | 0.12 (−0.11, 0.36) 0.05 (−0.04, 0.14)
Disability >26 weeks Studies: 4; Subjects: 806^54, 83, 87, 88^ | High | Direct | Consistent | Precise | Small | Low | −0.21 (−0.37, −0.04) −0.08 (−0.14; −0.02)
Psychological disability 6–13 weeks Studies: 4; Subjects: 271^77, 81, 86, 89^ | High | Direct | Inconsistent | Imprecise | NA | Low | −0.67 (−1.43, 0.1)
Pain <6 weeks Studies: 2; Subjects: 137^79, 81^ | High | Direct | Inconsistent | Imprecise | NA | Low | −0.98 (−2.19, 0.24) −21.6 (−48.2, 5.3)
Pain 6–13 weeks Studies: 12; Subjects: 1,242^76, 77, 81–86, 89–92^ | High | Direct | Inconsistent | Precise | Small | Low | −0.32 (−0.55, −0.08) −7.0 (−12.1, −1.8)
Pain 13–26 weeks Studies: 6; Subjects: 953^79, 82, 83, 90–92^ | High | Direct | Consistent | Precise | NA | Low | −0.06 (−0.19, 0.06) −1.3 (−4.2, 1.3)
Pain >26 weeks Studies: 6; Subjects: 1,221^54, 76, 79, 83, 87, 92^ | High | Direct | Consistent | Precise | Small | Low | −0.21 (−0.35, −0.08) −4.6 (−7.7, −1.8)
Function composite 6–13 weeks Studies: 3; Subjects: 351^64, 89, 92^ | Medium | Direct | Inconsistent | Imprecise | Large | Low | −0.83 (−1.34, −0.32) −15.4 (− 24.8, −5.92)
Function composite >26 weeks Studies: 3; Subjects: 826^54, 79, 92^ | Medium | Direct | Inconsistent | Precise | NA | Low | −0.18 (−0.44, 0.08) −3.33 (−8.14, 1.48)
Gait function < 6 weeks Studies: 3; Subjects: 220^80, 81, 90^ | High | Direct | Consistent | Imprecise | Small | Low | −0.38 (−0.63, −0.13) −0.08 (−0.13, −0.03)
Gait function 6–13 weeks Studies: 8; Subjects: 632^64, 80, 81, 86, 89–91, 93^ | High | Direct | Consistent | Precise | Moderate | Low | −0.57 (−0.75, −0.39) −0.11 (−0.15, −0.08)
Gait function 13–26 weeks Studies: 3; Subjects: 459^79, 90, 91^ | High | Direct | Consistent | Precise | Small | Low | −0.44 (−0.62, −0.26) −0.09 (−0.12, −0.05)
Gait function >26 weeks Studies: 2; Subjects: 609^54, 94^ | Medium | Direct | Consistent | Precise | Moderate | Low | −0.56 (−0.86, −0.25) −0.11 (−0.17, −0.05)
Health perception 6–13 weeks Studies: 2; Subjects: 62^81, 89^ | High | Direct | Inconsistent | Imprecise | NA | Low | −1.38 (−3.08, 0.32)
Health perception >26 weeks Studies: 3; Subjects: 513^83, 87, 88^ | High | Direct | Consistent | Precise | NA | Low | −0.04 (−0.21, 0.14)
Aquatic Exercise
Disability 6–13 weeks Studies: 2; Subjects: 99^68, 95^ | Medium | Direct | Consistent | Imprecise | NA | Low | 0.06 (−0.36, 0.49) 0.02 (−0.14, 0.19)
Disability 13–26 weeks Studies: 2; Subjects: 303^95, 96^ | Medium | Direct | Consistent | Imprecise | Small | Low | −0.28 (−0.51, −0.05) −0.11 (−0.19; −0.02)
Pain 6–13 weeks Studies: 2; Subjects: 99^68, 95^ | Medium | Direct | Consistent | Imprecise | NA | Low | −0.25 (−0.64, 0.15) −5.5 (−14.1, 3.3)
Pain 13–26 weeks Studies: 2; Subjects: 303^95, 96^ | Medium | Direct | Consistent | Imprecise | NA | Low | −0.17 (−0.39, 0.06) −3.7 (−8.6, 1.3)
QL13–26 weeks Studies: 2; Subjects: 303^95, 96^ | Medium | Direct | Consistent | Imprecise | NA | Low | −0.10 (−0.32, 0.13) −1.06 (−3.51; 1.40)
Function composite 6–13 weeks Studies: 2; Subjects: 99^68, 95^ | Medium | Direct | Consistent | Imprecise | NA | Low | −0.03 (−0.51, 0.44) −0.56 (−9.44, 8.14)
Strengthening Exercise
Disability 6–13 weeks Studies: 4; Subjects: 606^95, 97–99^ | Medium | Direct | Inconsistent | Imprecise | NA | Low | −0.08 (−0.51, 0.35) −0.03 (−0.19, 0.13)
Disability 13–26 weeks Studies: 3; Subjects: 490^95, 98, 100^ | Medium | Direct | Consistent | Precise | Small | Low | −0.19 (−0.36, −0.01) −0.07 (−0.14, −0.00)
Disability >26 weeks Studies: 2; Subjects: 687^54, 98^ | Medium | Direct | Inconsistent | Precise | NA | Low | −0.16 (−0.48, 0.16) −0.06 (−0.18; 0.06)
Pain 6–13 weeks Studies: 13; Subjects: 1,404^63, 95, 97–99, 101–108^ | High | Direct | Inconsistent | Precise | Moderate | Low | −0.63 (−0.87, −0.39) −13.9 (−19.1, −8.6)
Pain 13–26 weeks Studies: 4; Subjects: 592^95, 98, 100, 109^ | Medium | Direct | Consistent | Precise | Small | Low | −0.35 (−0.51, −0.18) −7.7 (−11.2, −4.0)
Pain >26 weeks Studies: 3; Subjects: 786^54, 98, 105^ | Medium | Direct | Inconsistent | Precise | Moderate | Low | −0.68 (−1.23, −0.14) −15.0 (−27.1, −3.1)
QL 6–13 weeks Studies: 2; Subjects: 194^95, 99^ | Medium | Direct | Consistent | Imprecise | NA | Low | −0.32 (−0.72, 0.07) −3.52 (−7.80, 0.77)
Function composite 6–13 weeks Studies: 6; Subjects: 521^63, 95, 103, 105, 106, 108^ | Medium | Direct | Inconsistent | Precise | Large | Low | −0.84 (−1.13, −0.56) −15.5 (−20.9, −10.4)
Function composite 13–26 weeks Studies: 3; Subjects: 200^95, 100, 109^ | Medium | Direct | Consistent | Imprecise | Small | Low | −0.35 (−0.61, −0.09) −6.48 (−11.3, −1.67)
Function composite >26 weeks Studies: 2; Subjects: 394^54, 105^ | Medium | Direct | Inconsistent | Imprecise | Large | Low | −1.00 (−1.95, −0.05) −18.5 (−36.1, −0.93)
Gait function 6–13 weeks Studies: 9; Subjects: 958^63, 98, 101–103, 106–108, 110^ | High | Direct | Inconsistent | Precise | Small | Low | −0.47 (−0.78, −0.16) −0.09 (−0.16, −0.03)
Gait function 13–26 weeks Studies: 2; Subjects: 494^98, 109^ | Medium | Direct | Consistent | Precise | Small | Low | −0.46 (−0.84, −0.08) −0.09 (−0.17, 0.02)
Gait function >26 weeks Studies: 2; Subjects: 687^54, 98^ | Medium | Direct | Consistent | Precise | Small | Low | −0.39 (−0.59, −0.20) −0.08 (−0.12, −0.04)
Tai Chi
Disability 6–13 weeks Studies: 2; Subjects: 85^65, 111^ | Medium | Direct | Consistent | Imprecise | NA | Low | −0.24 (−0.68, 0.2) −0.09 (−0.26, 0.08)
Disability 13–26 weeks Studies: 2; Subjects: 123^111, 112^ | Medium | Direct | Consistent | Imprecise | NA | Low | −0.27 (−0.95, 0.41) −0.10 (−0.36, 0.16)
Pain 6–13 weeks Studies: 2; Subjects: 85^65, 111^ | Medium | Direct | Consistent | Imprecise | NA | Low | −0.41 (−0.85, 0.03) −9.0 (−18.7, 0.7)
Function composite 6–13 weeks Studies: 2; Subjects: 85^65, 111^ | Medium | Direct | Consistent | Imprecise | Small | Low | −0.44 (−0.88, 0.00) −8.14 (−16.3, 0)
Function joint 6–13 weeks Studies: 2; Subjects: 85^65, 111^ | Medium | Direct | Consistent | Imprecise | NA | Low | −0.08 (−0.51, 0.36)
Proprioception Exercise
Pain 6–13 weeks Studies: 3; Subjects: 198^105, 106, 113^ | High | Direct | Inconsistent | Imprecise | Moderate | Low | −0.71 (−1.31, −0.11) −15.6 (−28.8, −2.4)
Function composite 6–13 weeks Studies: 3; Subjects: 198^105, 106, 113^ | High | Direct | Inconsistent | Imprecise | NA | Low | −1.12 (−2.66, 0.41) −20.7 (−49.2, 7.59)
Gait function 6–13 weeks Studies: 3; Subjects: 181^106, 113, 114^ | High | Direct | Inconsistent | Imprecise | NA | Low | −0.96 (−2.00, 0.09) −0.19 (−0.4, 0.02)
Massage
Function composite 6–13 weeks Studies: 2; Subjects: 94^115, 116^ | High | Direct | Consistent | Imprecise | Moderate | Low | −0.55 (−0.93, −0.18) −10.2 (−17.2, −3.33)
Orthotics
Gait function <6 weeks Studies: 4; Subjects: 101^117–120^ | High | Direct | Consistent | Imprecise | NA | Low | −0.01 (−0.22, 0.20) 0.00 (−0.04, 0.04)
Function composite <6 weeks Studies: 2; Subjects: 138^56, 121^ | Medium | Direct | Inconsistent | Imprecise | NA | Low | −0.57 (−1.17, 0.02) −10.5 (−21.6, 0.37)
Taping: Elastic Subtalar Strapping
Function composite 6–13 weeks Studies: 3; Subjects: 246^52, 122, 123^ | High | Direct | Consistent | Imprecise | Small | Low | −0.27 (−0.53, −0.02) −5.00 (−9.81, −0.37)
Electrical Stimulation
Disability 6–13 weeks Studies: 2; Subjects: 98^124, 125^ | Low | Direct | Consistent | Imprecise | NA | Moderate | −0.27 (−0.68, 0.14) −0.10 (−0.26; 0.05)
Pain <6 weeks Studies: 7; Subjects: 301^104, 125–130^ | High | Direct | Consistent | Imprecise | Moderate | Low | −0.71 (−0.98, −0.43) −15.6 (−21.6, −9.5)
Pain 6–13 weeks Studies: 7; Subjects: 304^104, 124, 125, 128, 131–133^ | High | Direct | Consistent | Imprecise | NA | Low | −0.09 (−0.31, 0.14) −2.0 (−6.8, 3.1)
Pain 13–26 weeks Studies: 2; Subjects: 76^132, 133^ | High | Direct | Consistent | Imprecise | Moderate | Low | 0.57 (0.09, 1.06) 12.5 (2.0, 23.3)
Global assessment 6–13 weeks Studies: 2; Subjects: 98^124, 125^ | Low | Direct | Consistent | Imprecise | Small | Low | −0.44 (−0.85, −0.02)
Function composite 6–13 weeks Studies: 3; Subjects: 138^124, 125, 131^ | Medium | Direct | Consistent | Imprecise | NA | Low | −0.08 (−0.43, 0.26) −1.48 (−7.96, 4.81)
Function joint <6 weeks Studies: 2; Subjects: 100^125, 130^ | Medium | Direct | Consistent | Imprecise | NA | Low | −0.25 (−0.61, 0.11)
Function joint 6–13 weeks Studies: 2; Subjects: 98^124, 125^ | Low | Direct | Consistent | Imprecise | NA | Moderate | −0.29 (−0.70, 0.12)
Gait function <6 weeks Studies: 4; Subjects: 191^110, 134–136^ | High | Direct | Inconsistent | Imprecise | NA | Low | −0.19 (−0.69, 0.30) −0.04 (−0.14, 0.06)
Gait function 6–13 weeks Studies: 3; Subjects: 164^110, 131, 133^ | High | Direct | Consistent | Imprecise | NA | Low | 0.06 (−0.23, 0.35) 0.01 (−0.05, 0.07)
Strength, measured as 120 degree extension 6–13 weeks Studies: 2; Subjects: 118^131, 133^ | Medium | Direct | Inconsistent | Imprecise | NA | Low | −0.41 (−0.83, 0.01)
Strength, measured as 60 degree extension 6–13 weeks Studies: 2; Subjects: 146^110, 131^ | High | Direct | Consistent | Imprecise | Moderate | Low | −0.55 (−0.88, −0.22)
Pulsed Electromagnetic Fields
Pain <6 weeks Studies: 2; Subjects: 145^137, 138^ | Low | Direct | Consistent | Imprecise | NA | Moderate | 0.01 (−0.41, 0.44) 0.2 (−9.0, 9.7)
Function composite <6 weeks Studies: 2; Subjects: 145^137, 138^ | Low | Direct | Consistent | Imprecise | NA | Moderate | −0.13 (−0.60, 0.35) −2.41 (−11.1, 6.48)
Ultrasound
Disability <6 weeks Studies: 2; Subjects: 157^139, 140^ | Medium | Direct | Consistent | Imprecise | NA | Low | −0.39 (−0.79, 0.02) −0.15 (−0.30, 0.01)
Pain <6 weeks Studies: 2; Subjects: 157^139, 140^ | Medium | Direct | Inconsistent | Imprecise | Moderate | Low | −0.53 (−1.04, −0.03) −11.7 (−22.9, −0.7)
Pain 6–13 weeks Studies: 4; Subjects: 227^131, 141–143^ | Medium | Direct | Consistent | Imprecise | Moderate | Low | −0.52 (−0.84, −0.19) −11.4 (−18.5, −4.2)
Pain >26 weeks Studies: 2; Subjects: 160^141, 142^ | Medium | Direct | Consistent | Imprecise | Moderate | Low | −0.74 (−0.95, −0.53) −16.3 (−20.9, −11.7)
Function composite 6–13 weeks Studies: 4; Subjects: 227^131, 141–143^ | Medium | Direct | Inconsistent | Imprecise | NA | Low | −0.60 (−1.40, 0.20) −11.2 (−26.0, 3.72)
Function composite >26 weeks Studies: 2; Subjects: 160^141, 142^ | Medium | Direct | Consistent | Imprecise | Large | Low | −1.14 (−1.60, −0.69) −21.2 (−29.8, −12.8)
Gait function <6 weeks Studies: 2; Subjects: 157^139, 140^ | Medium | Direct | Inconsistent | Imprecise | NA | Low | −0.53 (−1.32, 0.25) −0.11 (−0.26, 0.05)
Gait function 6–13 weeks Studies: 4; Subjects: 227^131, 141–143^ | Medium | Direct | Inconsistent | Imprecise | Large | Low | −1.13 (−2.08, −0.17) −0.23 (−0.42, −0.03)
Gait function >26 weeks Studies: 2; Subjects: 160^141, 142^ | Medium | Direct | Inconsistent | Imprecise | Large | Low | −1.48 (−2.08, −0.89) −0.30 (−0.42, −0.18)
Diathermy
Disability <6 weeks Studies: 4; Subjects: 259^144–147^ | High | Direct | Consistent | Imprecise | NA | Low | −0.21 (−0.45, 0.02) −0.08 (−0.17, 0.01)
Disability 6–13 weeks Studies: 2; Subjects: 143^146, 147^ | High | Direct | Consistent | Imprecise | NA | Low | −0.04 (−0.34, 0.25) −0.02 (−0.13, 0.09)
Pain <6 weeks Studies: 4; Subjects: 259^144–147^ | High | Direct | Inconsistent | Imprecise | Moderate | Low | −0.53 (−0.96, −0.10) −11.7 (−21.1, −2.2)
Pain 6–13 weeks Studies: 3; Subjects: 183^131, 146, 147^ | High | Direct | Consistent | Imprecise | NA | Low | −0.01 (−0.27, 0.26) −0.2 (−5.9, 5.7)
Function composite <6 weeks Studies: 3; Subjects: 229^145–147^ | High | Direct | Inconsistent | Imprecise | NA | Low | −0.47 (−0.95, 0.02) −8.70 (−17.6, 0.37)
Function composite 6–13 weeks Studies: 3; Subjects: 183^131, 146, 147^ | High | Direct | Consistent | Imprecise | NA | Low | 0.01 (−0.26, 0.27) 0.19 (−4.81, 5.00)
Function joint <6 weeks Studies: 2; Subjects: 143^146, 147^ | High | Direct | Consistent | Imprecise | NA | Low | 0.20 (−0.10, 0.49)
Function joint 6–13 weeks Studies: 2; Subjects: 143^146, 147^ | High | Direct | Consistent | Imprecise | NA | Low | 0.16 (−0.14, 0.46)
Gait function <6 weeks Studies: 3; Subjects: 173^144, 146, 147^ | High | Direct | Consistent | Imprecise | NA | Low | −0.10 (−0.36, 0.17) −0.02 (−0.07, 0.03)
Gait function 6–13 weeks Studies: 3; Subjects: 183^131, 146, 147^ | High | Direct | Consistent | Imprecise | NA | Low | −0.14 (−0.40, 0.13) −0.03 (−0.08, 0.03)

CI = confidence interval; NA = not applicable; QL = quality of life

Note: Bold indicates significant differences when 95% CIs do not include 0; Negative value means improvement; Converted mean differences are in EQ-5D (0–1) for disability, in SF-36 (0–100) for quality of life, in Visual Analog Scale (0–100) for pain, in Western Ontario and McMaster Universities Osteoarthritis Index for physical function (0–100) for composite function, and in walking speed (m/s) for gait function

Table B Summary of effectiveness of physical therapy interventions for knee osteoarthritis

Physical Therapy Intervention | Studies/Subjects | Conclusions/Strength of Evidence
Specific education programs | Studies=2/Subjects=511 | Specific education programs improved health perception measures (L) but did not improve pain (L), disability (L), psychological disability (L), gait (L) and composite measures of function (L)
Aerobic exercises | Studies=11/Subjects=1,553 | Aerobic exercises improved pain (L), disability (L), gait (L), and transfer (L) measures of function but did not improve psychological disability (L), global assessment (L), health perception (L), joint (L) and composite measures of function (L)
Aquatic exercises | Studies=3/Subjects=348 | Aquatic exercises improved disability (L) but did not improve pain (L), psychological disability (L), quality of life (L), and composite measures of function (L)
Strengthening exercises | Studies=9/Subjects=1,982 | Strengthening exercises improved pain (L), global assessment (L), gait (L), transfer (L), and composite (L) function measures but did not improve disability (L), health perception (L), quality of life (L) and joint (L) function measures
Tai Chi | Studies=3/Subjects=167 | Tai Chi improved psychological disability (L) and composite (L) function measures, but did not improve pain (L), disability (L), quality of life (L), gait (L), and joint (L) function measures
Proprioception exercises | Studies=4/Subjects=247 | Proprioception exercises improved pain (L) but did not improve gait (L) and composite measures of function (L)
Massage | Studies=3/Subjects=162 | Massage improved disability (L), joint (L), gait (L) and composite (L) function measures
Joint mobilization | Studies=2/Subjects=83 | Joint mobilization improved disability (L) and global assessment (L) but did not improve pain (L) and gait (L) function measures
Joint mobilization with exercise | Studies=1/Subjects=134 | Joint mobilization with exercise improved disability (L) but did not improve gait (L) function measures
Orthotics | Studies=7/Subjects=364 | Orthotics improved pain (L), disability (L), psychological disability (L), quality of life (L), and joint measures of function (L) but did not improve global assessment (L), gait (L) and composite (L) function measures
Elastic subtalar strapping | Studies=3/Subjects=246 | Elastic subtalar strapping improved composite function measures (L)
Taping | Studies=2/Subjects=105 | Taping did not improve pain (L), disability (L), gait (L) and composite (L) function measures
E-stim | Studies=7/Subjects=390 | E-stim improved global assessment (L), but worsened pain (L), and did not improve disability (M), health perception (L), and gait (L), joint (M), transfer (L), and composite (L) function measures,
PEMF | Studies=4/Subjects=267 | PEMF improved global assessment (L) but did not improve pain (M), disability (L), and gait (L), joint (L) and composite (M) function measures
Ultrasound | Studies=6/Subjects=387 | Ultrasound improved pain (L), gait (L) and composite (L) function measures but did not improve disability (L), and joint function measures (L)
Diathermy | Studies=5/Subjects=382 | Diathermy did not improve pain (L), disability (L), psychological disability (L), global assessment (L), health perception (L), quality of life (L), and joint (L), gait (L) and composite (L) function measures
Heat | Studies=3/Subjects=126 | Heat improved disability (L) and quality of life (L), but did not improve pain (L), gait (L), joint (L), and composite (L) function measures
Cryotherapy | Studies=2/Subjects=57 | Cryotherapy did not improve disability (L), quality of life (L), and composite function measures (L)

E-stim = electrical stimulation; PEMF = pulsed electromagnetic fields;

Note: Strength of evidence as L = low, M = moderate. Strength of evidence was determined according to four domains (risk of bias, directness, consistency, and precision).

Table C Comparative effectiveness of physical therapy intervention on patient-centered outcomes (standardized mean differences pooled with random effects models, using standardized units of differences-standard deviations)

Outcome, Studies, Sample Size, Reference | Risk of Bias | Directness | Consistency | Precision | Strength of the Association | Strength of Evidence | Pooled Hedges Standard Mean Difference (95% CI) Converted Mean Difference (95% CI)
E-stim vs. Exercise
Pain <6 weeks Studies: 2; Subjects: 81^104, 148^ | High | Direct | Inconsistent | Imprecise | NA | Low | −1.28 (−2.95, 0.40) −28.2 (−64.9, 8.8)
Gait function <6 weeks Studies: 2; Subjects: 81^110, 148^ | Medium | Direct | Inconsistent | Imprecise | NA | Low | 0.20 (−1.15, 1.55) 0.04 (−0.23, 0.31)
Exercise Aquatic vs. Aerobic
Pain 6–13 weeks Studies: 2; Subjects: 110^95, 149^ | Medium | Direct | Inconsistent | Imprecise | NA | Low | −0.44 (−1.22, 0.35) −9.7 (−26.8, 7.7)
Laterally vs. Neutrally Wedged Insole
Function composite 6–13 weeks Studies: 2; Subjects: 383^51, 52^ | Medium | Direct | Consistent | Imprecise | NA | Low | −0.01 (−0.25, 0.25) −0.19 (−4.63, 4.63)

CI = confidence interval; E-stim = electrical stimulation;

Note: Negative value means improvement; converted mean differences are in Visual Analog Scale (0–100) for pain, in Western Ontario and McMaster Universities Osteoarthritis Index for physical function (0–100) for composite function, and in walking speed (m/s) for gait function

Table D Summary of comparative effectiveness of physical therapy interventions for knee osteoarthritis

Active vs. Control Physical Therapy Intervention | Studies/Subjects | Conclusions/Strength of Evidence
Aerobic exercises vs. strengthening exercises | Studies=1/Subjects=290 | Aerobic exercises improved gait function measures (L) but did not improve pain (L), disability (L), transfer (L), and composite (L) function measures, compared to strengthening exercises
Aquatic exercises vs. aerobic exercises | Studies=2/Subjects=110 | Aquatic exercises did not improve pain (L), disability (L), gait (L) and composite (L) function measures, compared to aerobic exercises
Proprioception exercises vs. strengthening exercises | Studies=1/Subjects=72 | Proprioception exercises worsened composite function measures (L) and did not improve pain (L), gait function (L), compared to strengthening exercises
Tai Chi vs. stretching exercises | Studies=1/Subjects=40 | Tai Chi improved disability (L), psychological disability (L), and transfer function (L) but did not improve pain (L), global assessment (L), gait (L), joint (L), and composite (L) function measures, compared to stretching exercise
Laterally vs. neutrally wedged insole | Studies=5/Subjects=613 | Laterally wedged insole did not improve pain (L), disability (L), global assessment (L), quality of life (L), gait (L), joint (L), and composite function measures (L), compared to neutrally wedged insole
Orthotics vs. brace | Studies=1/Subjects=91 | Orthotics did not improve pain (L) and composite function measures (L), compared to brace
E-stim vs. exercises | Studies=2/Subjects=81 | E-stim improved joint (L) and composite (L) measures of function but did not improve pain (L) and gait (L) function, compared to exercises
E-stim vs. ultrasound | Studies=1/Subjects=40 | E-stim did not improve pain (L), gait (L) and composite (L) measures of function, compared to ultrasound

E-stim = electrical stimulation

Note: Strength of evidence as L = low; strength of evidence was determined according to four domains (risk of bias, directness, consistency, and precision).

In pooled analyses, we found low-strength evidence that core physical therapy interventions, including aerobic and aquatic exercise, improved disability measures; aerobic exercise and strengthening exercise reduced pain and improved function. In addition, ultrasound reduced pain and improved function. Proprioception exercise reduced pain, and tai chi improved function at short-term but not long-term followup. No single physical therapy improved all outcomes. We observed no benefits from specific education programs, diathermy, orthotics, or magnetic stimulation. Individual (nonpooled) RCTs failed to show consistent statistically significant, strong, or clinically important changes in outcomes. Individual small RCTs may fail to show statistically significant effects due to low statistical power. Strength of evidence was downgraded due to study risk of bias and heterogeneity in populations, treatments, and definitions of outcomes.

We described the interventions according to definitions and classification from APTA’s Guide to Physical Therapist Practice.22 For each examined intervention, we reported (1) the total number of eligible RCTs that contributed to our findings and (2) conclusions from the studies that contributed to the pooled analyses at the longest time of followup.

##### Specific Education Programs

We synthesized evidence from five RCTs; two RCTs with 511 participants contributed to the pooled analyses at the longest time of followup. The results of three articles from two RCTs that examined the effects of specific education programs provided low-strength evidence of no statistically significant effect on pain relief.

##### Aerobic Exercises

We synthesized evidence from 22 RCTs; 11 RCTs with 1,553 participants contributed to the pooled analyses at the longest time of followup. We found low-strength evidence that aerobic exercise resulted in statistically significant improvement in long-term pain and disability, but it did not improve psychological disability or health perception. Within 3 months, aerobic exercise improved composite function and gait function. At 12 months, the benefits of aerobic exercise continued for gait function, but not for composite function. A single RCT examined the effects of manual therapy combined with a standardized knee exercise program in the clinic and at home, and found statistically and clinically significant improvements in WOMAC total score and gait function.

##### Aquatic Exercises

We synthesized evidence from three RCTs with 348 participants that contributed to the pooled analyses at the longest time of followup. The studies provided low-strength evidence that aquatic exercise reduced disability, but it had no statistically significant effects on pain relief or quality of life.

##### Strengthening Exercises

We synthesized evidence from 17 RCTs; 9 RCTs with 1,982 participants contributed to the pooled analyses at the longest time of followup. Strengthening exercises had no statistically significant effect on disability (low-strength evidence). However, we observed a sustained improvement in pain relief, composite function, and gait function at 3 months through more than 12 months followup. Low-strength evidence demonstrated that strengthening exercises did not improve quality of life.

##### Tai Chi

Evidence from three RCTs with 167 participants contributed to the pooled analyses at the longest time of followup. Low-strength evidence from these small trials demonstrated that tai chi improved composite function measures around 3 months, but it had no statistically significant effect on pain or disability. Function did not improve further at 6 months followup.

##### Proprioception Exercises

Evidence from four RCTs with 247 participants contributed to the pooled analyses at the longest time of followup. These RCTs offered low-strength evidence that proprioception exercises led to pain relief, but they did not improve composite function or gait function.

##### Massage

Evidence from three RCTs with 162 participants contributed to the pooled analyses at the longest time of followup. We found low-strength evidence that massage somewhat improved composite function.

##### Joint Mobilization

We synthesized evidence from three RCTs with 217 participants, but were unable to perform pooled analyses due to differences in outcomes examined, reporting formats, and time to followup. Individual studies showed that joint mobilization with or without exercise reduced disability.

##### Orthotics

Evidence from seven RCTs with 364 participants contributed to the pooled analyses at the longest time of followup. These RCTs demonstrated low-strength evidence that orthotics had no effect on short-term outcomes of composite function or gait function.

##### Therapeutic Taping

Three RCTs with 119 participants examined the effects of therapeutic taping and found no benefits for pain, disability, composite function, or gait function. Different reporting formats precluded pooled analyses. Individual RCTs suggested that taping might provide short-term pain relief.

##### Electrical Stimulation

We synthesized evidence from 15 RCTs, and seven RCTs with 390 participants contributed to the pooled analyses at the longest time of followup. Electrical stimulation resulted in statistically significant improved pain short term and at 3 months after starting the intervention. However, pain worsened at 6 months. We found low-strength evidence that at 3 months followup, global assessment and muscle strength (measured at 60 degree extension) improved significantly with electrical stimulation treatment. These statistically significant findings were consistent without substantial heterogeneity across the studies. Pooled analyses provided moderate-strength evidence of no improvement on disability or joint function and low-strength evidence of no improvement on gait or composite functional measures.

##### Pulsed Electromagnetic Fields

Evidence from four RCTs with 267 participants contributed to the pooled analyses at the longest time of followup. These RCTs offered moderate-strength evidence that pulsed electromagnetic fields (PEMFs) neither reduced pain nor improved composite function.

##### Ultrasound

Evidence from six RCTs with 387 participants contributed to the pooled analyses at the longest time of followup. We found low-strength evidence that ultrasound resulted in statistically significant reduction in pain with a moderate effect size and significantly improved composite function and gait function with a large effect size. Low-strength evidence also demonstrated that ultrasound did not improve disability.

##### Diathermy

We synthesized evidence from seven RCTs; five RCTs with 382 participants contributed to the pooled analyses at the longest time of followup. Low-strength evidence demonstrated that diathermy resulted in a statistically significant decrease in pain at 1 month, but the effect was statistically insignificant at 3 months. Low-strength evidence demonstrated that diathermy did not improve disability, composite function, joint function, or gait function.

##### Heat

We synthesized evidence from three RCTs with 126 participants, but were unable to perform a pooled analysis to draw robust conclusions.

##### Cryotherapy

We synthesized evidence from two RCTs with 57 participants, but were unable to perform a pooled analysis to draw robust conclusions.

#### The Role of Physical Therapist Involvement in Benefits With Exercises

We performed subgroup analyses by involvement of a physical therapist for all outcomes with aerobic or strengthening exercises. For most comparisons, effect sizes with the involvement of a physical therapist were larger than those without. Furthermore, the results in the physical therapist involvement group tended to be consistent without heterogeneity. Although the sample size of the subgroup with physical therapist involvement was smaller than the sample size of all pooled studies, our conclusions remain the same.

#### Clinical Importance of Treatment Effects With Physical Therapy Interventions

Original studies used a wide variety of pain measurements and thus required standardization in pooled analyses. This lack of consistency prevented us from being able to assess whether specific interventions resulted in benefits that were of clinical importance. To assess the clinical importance of pain reduction with interventions, we performed subgroup analyses with a subset of the studies that used the same VAS instrument for pain measures. We then compared mean reduction in pain with the cutoff for MCIDs in VAS as reported in observational studies. We found that electrical stimulation, diathermy, and ultrasound resulted in clinically significant short-term pain reduction.

In long-term followup, however, only strengthening exercise reduced pain with an effect size that exceeded the threshold of MCID.

To assess the clinical importance of improvements in disability and quality of life with physical therapy interventions, we transformed SMDs to nonstandardized mean differences in EQ-5D or SF-36 (Table A).

Only aerobic and aquatic exercises led to statistically significant and clinically important benefits for disability (estimated EQ-5D improvements of 0.08 and 0.11, respectively). However, for quality of life, the benefits of aquatic and strengthening exercise were statistically insignificant (estimated SF-36 physical component summary improvements of 1.1 and 3.5, respectively).

As a part of the evidence synthesis, we also compared the differences in continuous measures of pain and disability reported in trials with the MCIDs determined in observational studies. We found few clinically important improvements. Aerobic exercise resulted in clinically important improvement in pain, disability, and joint function in the majority of individual RCTs.

#### Comparative Effectiveness of Physical Therapy Interventions

Single RCTs that examined comparative effectiveness of physical therapy interventions offered low-strength evidence for the majority of comparisons (Tables C and D). Aerobic and aquatic exercises had the same benefits for improving disability and pain, a finding consistent with the similar effect sizes demonstrated by these two interventions in efficacy studies. Tables E and F show pain and disability outcomes associated with each physical therapy intervention by strength of evidence. One study found no statistically significant differences between aerobic and strengthening exercises for disability and composite function, but gait function improved more with aerobic exercise. One study demonstrated that tai chi was better than stretching exercise for disability, psychological disability, global assessment, and transfer function.

Table E Summary of pain outcome associated with each physical therapy intervention by strength of evidence

Physical Therapy Intervention | Moderate Strength of Evidence | Low Strength of Evidence
Education program | | No improvement
Aerobic exercises | | Improvement
Aquatic exercises | | No improvement
Strengthening exercises | | Improvement
Tai Chi | | No improvement
Proprioception exercises | | Improvement
Massage
Joint mobilization | | No improvement^*^
Joint mobilization + exercise
Orthotics | | Improvement *
Elastic subtalar strapping
Taping | | No improvement^*^
E-stim | | Worse
PEMF | No improvement
Ultrasound | | Improvement
Diathermy | | No improvement
Heat | | No improvement^*^
Cryotherapy

E-stim = electrical stimulation; PEMF = pulsed electromagnetic fields

Note: Bold = improvement

* Result based on a single study

Table F Summary of disability outcome associated with each physical therapy intervention by strength of evidence

Physical Therapy Intervention | Moderate Strength of Evidence | Low Strength of Evidence
Education program | | No improvement^*^
Aerobic exercises | | Improvement
Aquatic exercises | | Improvement
Strengthening exercises | | No improvement
Tai Chi | | No improvement
Proprioception exercises
Massage | | Improvement *
Joint mobilization | | Improvement *
Joint mobilization + exercise | | Improvement *
Orthotics | | Improvement *
Elastic subtalar strapping
Taping | | No improvement^*^
E-stim | No improvement
PEMF | | No improvement^*^
Ultrasound | | No improvement
Diathermy | | No improvement
Heat | | Improvement *
Cryotherapy | | No improvement^*^

E-stim = electrical stimulation; PEMF = pulsed electromagnetic fields

Note: Bold = improvement

* Result based on a single study

We found no statistically significant differences between laterally and neutrally wedged insoles on composite function51, 52 or between orthotics and brace on composite function. A recent study showed that pain, disability, global assessment, quality of life, and joint function did not differ between laterally and neutrally wedged insoles. Several small studies found no statistically significant difference between electrical stimulation and exercise for pain relief and gait function. One study showed statistically insignificant differences between electrical stimulation and ultrasound for composite and gait function.

The studies of combined physical therapy modalities demonstrated no statistically significant benefits on the outcomes when compared with aerobic, strength, or proprioception exercise alone. Manual therapy added to aerobic exercise provided benefits similar to aerobic exercise alone.

#### Key Question 1a Role of Patient Characteristics on Outcomes

The majority of subgroup analyses in individual RCTs lacked robust evidence and thus failed to permit definitive conclusions about the most effective physical therapy treatments in association with patient characteristics.

##### Compliance

Three RCTs showed that subgroups with high compliance tended to have better outcomes for exercise (aerobic, aquatic, and strengthening). The higher exercise compliance group had the lowest risk of incident ADL disability, a lower average depression score, a higher mean Quality of Well-Being Scale score, and greater improvements in both 6-minute walking distance and disability.

##### Age

Robust evidence was lacking for how age differences affect treatment outcomes because three studies were inconsistent with active and control treatments, outcomes, and definitions of age subgroups.

##### Malalignment

Low-strength evidence from two RCTs did not permit robust conclusions about how malalignment affects treatment outcomes. The RCTs found greater benefit in patients with the genu varus group and in those without malalignment.

##### Body Mass Index

Two RCTs provided inconsistent evidence about the role of BMI in predicting treatment effects. Improvement in function by lateral wedge insoles was better in adults of normal weight, while very obese participants (defined by the top tertile) experienced similar benefits from aerobic exercise interventions and resistance training programs.

##### Comorbidity

Evidence from individual studies did not permit robust conclusions about how treatment effects may be modified by comorbidity.

##### Sex

Evidence from individual studies did not permit robust conclusions about how treatment effects may differ between men and women. The five studies that reported clinical outcomes in male and female subgroups for exercise and orthotics52–56 demonstrated no statistically significant differences in outcomes.

##### Race

Evidence from a single study was inconclusive for how racial differences affect treatment outcomes of exercise.

##### Severity

Baseline OA severity may modify the effects of physical therapy interventions on clinical outcomes. However, findings were inconsistent and varied across studies depending on the treatments, outcomes, and/or cutoff grades. Furthermore, RCTs reported post hoc analyses of changes from baseline in functional measures among patients with different baseline severity scores. Clinical outcomes in severity subgroups were reported in seven RCTs, involving brace, insole, exercise (strengthening or range of motion), and weight reduction and/or electrical stimulation. Three RCTs found no consistent modification effect of baseline severity.

#### Key Question 1b Association Between Dose/Duration/Intensity/Frequency of Examined Interventions and Intermediate/Patient-Centered Outcomes

For the majority of comparisons, evidence did not permit robust conclusions about the association between the dose/duration/intensity/frequency of examined interventions and outcomes.

##### Exercise

Included studies variously defined intensity of exercise, yet indicated equal benefits from low- and high-intensity exercise. One study using exercise compliance to examine the potential dose-response relationship between exercise frequency and outcomes showed that exercise for patients with knee OA should be done three times each week.

##### Orthotics

For patients with genu varus deformity from OA, medium duration (between 5 and 10 hours each day) of insole with subtalar strapping wear was better than short duration (fewer than 5 hours) and long duration (more than 10 hours).

##### Electrical Stimulation

We found no short-term clinical difference between low-frequency (2 Hz) and high-frequency (80 Hz) electrical stimulation. However, noxious stimulation decreased pain intensity more than innocuous stimulation. In one study, Burst Mode and High Rate stimulation had similar effects on stiffness and pain. Another study demonstrated that for reducing pain, 40 minutes was the optimal duration of electrical stimulation.

##### Ultrasound

Two RCTs showed that pulsed ultrasound was better than continuous ultrasound in improving disability, gait, and composite function measures.

#### Key Question 1c Association Between Time of Followup and Intermediate/Patient-Centered Outcomes

The association between followup time and outcomes varied by treatments and outcomes of interest. The effects of aerobic, aquatic, and strengthening exercises and ultrasound did not differ at shorter versus longer followups. Further, in a combined analysis of aerobic, aquatic, strengthening, proprioception, and tai chi exercises, changes in intermediate and patient-centered outcomes did not differ by followup time (all p-values greater than 0.05). Results held consistent with or without inclusion of Tai Chi. Outcomes of pain, gait, and composite function after ultrasound did not differ by followup time. Electrical stimulation improved pain at short-term followup but significantly worsened pain at longer followups (p-value <0.001). In contrast, we observed that diathermy’s benefits for disability increased with longer followups (p-value = 0.009).

##### Association Between Duration of Examined Interventions and Intermediate/Patient-Centered Outcomes

The duration of examined interventions varied broadly. For example, exercise programs ranged from 2 to 72 weeks. We found no statistically significant association between the duration of examined interventions and intermediate or patient-centered outcomes. In combined results for aerobic, aquatic, strengthening, proprioception, and tai chi exercises, changes in intermediate and patient-centered outcomes did not differ by the duration of the examined intervention, with all p-values greater than 0.05.

#### Key Question 2 Association Between Intermediate and Patient-Centered Outcomes

Evidence for the association between intermediate and clinical outcomes was limited to individual studies. We found substantial variability in definitions of index and reference methods, definitions of outcomes, and methods of examining diagnostic values and associations between intermediate and clinical outcomes.

We synthesized the evidence of association between intermediate and clinical outcomes from 43 studies that included 25,799 adults with knee OA. Disability measures were associated with gait, mobility restrictions, muscle strength, and range-of-motion measures, but the magnitude and clinical importance of the association were unclear.

#### Key Question 2a Validity of the Tests and Measures Used To Determine Intermediate Outcomes of Physical Therapy on OA in Association With Patient-Centered Outcomes

Validation of the tests and measures used to determine intermediate outcomes of physical therapy on knee OA was reported in 66 studies of 14,563 adults. The studies used a variety of reference methods to judge validity according to statistically significant correlation coefficients. Only a small proportion of the studies demonstrated a strong (more than 50 percent) correlation between index and reference method measurements. Strength of correlation varied across validity types.

#### Key Question 2b Which Intermediate Outcomes Meet the Criteria of Surrogates for Patient-Centered Outcomes?

None of the intermediate outcomes met surrogate criteria for patient-centered outcomes as defined by the OMERACT Criteria for Surrogate Endpoints. TEP members proposed gait as a feasible candidate for a surrogate endpoint. However, no study analyzed the association between gait and patient-centered outcomes of physical therapy for adults with knee OA. One RCT did conclude that knee pain and self-efficacy mediated the effects of exercise on stair-climb time. A single longitudinal study of elderly adults demonstrated that impaired gait and the Physical Performance Test were independent predictors of nursing home placement. Three cohort studies (the Einstein Aging Study, the Chinese Elderly Cohort, and the Women’s Health and Aging Study) examined the association between gait and nursing home placement. However, the studies included adults with any etiology of gait problem, including neurological diseases or heart failure. Further, the definitions of “impaired gait” and magnitude of the association differed across the studies.

#### Key Question 2c What Are Minimum Clinically Important Differences of the Tests and Measures Used To Determine Intermediate Outcomes?

No RCTs of physical therapy interventions determined minimum clinically important differences (MCIDs). However, MCIDs in outcome measurements were reported in 30 observational studies of 13,138 adults. The studies used the anchor method, which compares patient perception of improvement with absolute change in scale score or with percentage difference from baseline levels. The percentage difference from baseline levels incorporated baseline severity of the diseases. MCIDs were available for 26 validated tools.

Few studies determined a Patient Acceptable Symptom State (PASS) for knee OA. PASS is defined as the highest level of symptom patients can tolerate and still be satisfied with treatment. The studies used the same anchor method for determining PASS as they did for determining MCIDs. The difference is in anchoring questions: MCID involves asking for patient perception of clinically important improvement while PASS involves asking patients whether they are satisfied with their functional status in relation to daily activities and quality of life. PASS was determined for three scales—WOMAC, VAS, and Patient Global Assessment.

#### Key Question 3 Harms From Physical Therapy Interventions Available for Adult Patients With Chronic Knee Pain Due to Osteoarthritis

Adverse events were uncommon and varied across interventions. Skin irritation was reported with brace, insole, taping, and electrical stimulation; swelling with brace, diathermy, and exercise; muscle soreness with electrical stimulation; throbbing sensation with diathermy, electrical stimulation, and PEMF; increased pain with diathermy, exercise, insole, and PEMF; falls with insole; and need for surgery with diathermy. Adverse events rates did not differ with statistical significance among treatment groups. Adverse events were not severe enough to deter participants from continuing treatment.

## Discussion

Our report of patient-centered outcomes, including pain, disability, and quality of life with physical therapy interventions for adults with knee OA has implications for clinical practice. Our findings generally agree with previously published guidelines8, 13 and systematic reviews17, 19, 57 that recommend exercise for adults with symptomatic knee OA. Few physical therapy interventions demonstrated any statistically significant effectiveness, and no single intervention improved all outcomes (Tables E and F). Pooled analyses demonstrated that diathermy, orthotics, and magnetic stimulation failed to show any benefits.

This review reflects the discrepancy between the recommended practice of physical therapy and the study designs used to examine the interventions. Current guidelines recommend that physical therapy be delivered with a combination of modalities.22 Published research has focused instead on the marginal effects of individual physical therapy interventions. Our effort was further complicated by the fact that clinical care for adults with knee OA includes pharmacologic interventions,58–60 while our review was limited to nonpharmacologic treatments. To address such complexity, we focused on randomized trials because these equally distribute concomitant treatments among treatment groups and thus provide valid estimates of effects of the examined interventions.

Randomized trials are the gold standard in establishing benefits from health care interventions.61 However, applicability of findings is limited to similar settings, treatments, and patient populations. In our review, for example, randomization might equally distribute the effect of pain relievers (a common concomitant treatment), but it would not prevent the dampening of potential effects from physical therapy interventions. The trials we examined rarely provided information about all other treatments patients might have received. Nor did the trials analyze outcomes separately in patient subgroups by concomitant treatments. We tried to examine the potential influence of pain medication on physical therapy outcomes for pain, but rare and inconsistent reporting of drug treatments impeded the evidence synthesis. Few studies provided information about sustained benefits at long-term followup. One recently published trial concluded sustained improvement in physical function at 30 months after a rehabilitation program combining self-management and exercise.62 Heterogeneity in populations, treatments, and definitions of the outcomes downgraded strength of evidence to low or moderate in most cases.

Low-strength evidence resulted mainly from risk of bias: frequent exclusion of patients from the analysis, inadequate allocation concealment, and unmasked outcome assessment. In addition, small trials did not provide precise estimates of the treatment effects. Few studies reported masking of the outcome assessments.63–68 We could not reproduce the results from several poorly reported studies, and we did not report evidence from individual studies with a high risk of bias. We did not synthesize the evidence from the trials that enrolled patients with knee or hip OA without separately reporting those outcomes. Many trials failed to provide sufficient detail about the nature and intensity of specific interventions or about the involvement of physical therapists, further impeding our ability to draw robust conclusions for decisionmaking.69, 70

Variability in the definitions and measurements of outcomes presented another obstacle. Validated measurements of functional impairments relevant to physical therapy practice are listed in APTA’s Guide to Physical Therapist Practice;22 however, APTA’s Guide recommends neither clinically important thresholds for such measures nor monitoring of treatment effects according to patient-centered outcomes. Most trials reported outcomes as average scores for all patients in each treatment group, with no evaluation of the clinical importance of the averages. Average scores do not reveal how many or which types of patients develop disability or experience clinically meaningful improvements in pain, function, or quality of life.

Furthermore, variability in the definitions of outcomes required us to calculate standardized mean differences. Statistically significant differences in this construct do not necessarily reflect the clinical importance of improvement in outcomes. OARSI has recommended evaluating treatment success according to patient-centered outcomes and clinically important differences in the WOMAC scale.44, 71 In addition, many studies have used the anchor method, which compares changes in scales with patient perception of improvement,72, 73 to determine MCIDs for the 26 validated tests. Yet, published studies of physical therapy interventions have not categorized patients according to meaningful improvements in pain, disability measures, or quality of life. Integrated approaches to evaluating the relationships between impairments in body structures and functions (e.g., strength, range of motion), physical activities (e.g., balance, walking), and participation in activities of daily living would allow better testing of patient-centered outcomes of disability and quality of life.

Treatment success should be measured not just by improvement in scales or performance tests, but by patient satisfaction with improvement in pain and function. The PASS tool is gaining favor as a valid and reliable approach across many areas of medical practice, including rheumatology.74 PASS is used to identify the level of symptom state patients can tolerate while still considering their health satisfactory and their treatment successful. PASS is available for three scales: WOMAC, VAS for pain, and the Patient Global Assessment. Expanded use of PASS would help improve the quality of physical therapy practice, and increase the usefulness of studies examining physical therapy interventions.

Our report has implications for future research. First, consensus is needed regarding methods to judge benefits of physical therapy interventions.75 Benefits should be defined as clinically important improvements in pain, independence in ADL, and quality of life. Treatment success should be estimated using rates of patient-centered outcomes. Through meta-analysis of individual patient data from previously conducted RCTs, researchers would be able to categorize patients according to the clinical importance of any changes they experienced. They would also be able to analyze rates of patient-centered outcomes. This would require that principal investigators of RCTs be willing to share their data. Individual patient data meta-analyses may also provide good estimates of treatment effects in patient subpopulations by age, comorbidity, severity of knee OA, and concomitant treatments. Future RCTs should examine comparative effectiveness of combined physical therapy treatments. Fully powered trials should examine comprehensive and multimodal interventions that more closely resemble physical therapy practice. Future studies should also analyze the effects of concomitant treatments such as pain relievers on pain and function.

## Key Messages

(see Tables E and F)

### Key Question 1

- Effectiveness of physical therapy (PT) interventions.
  ○ Pooled analyses demonstrated the following results for core interventions:
    – Aerobic and aquatic exercise improved disability measures.
    – Aerobic and strengthening exercise reduced pain and improved function.
    – Proprioception exercise reduced pain.
  ○ Pooled analyses also found that:
    – Tai chi improved short-term function, but with no sustained benefit.
    – Ultrasound reduced pain and improved function.
  ○ Pooled analyses demonstrated that the following physical therapy interventions failed to show any benefits:
    – Specific education program.
    – Diathermy.
    – Orthotics.
    – Magnetic stimulation (PEMF).
  ○ Few physical therapy interventions were shown to be effective in general.
  ○ No single physical therapy intervention was shown to improve all examined outcomes.
  ○ Research focused on individual physical therapy interventions, in contrast with the common physical therapy practice of combining interventions.
  ○ Individual (nonpooled) randomized controlled trials (RCTs) failed to show consistent, statistically significant, strong, or clinically important changes in outcomes.
- Comparative effectiveness of physical therapy interventions.
  ○ Evidence about comparative effectiveness of physical therapy interventions was limited.
  ○ Pooled analyses demonstrated that:
    – Pain did not differ between aerobic and aquatic exercises.
    – Pain did not differ between electrical stimulation and exercise in pooled analyses.
  ○ Individual RCTs of other treatment comparisons found no consistent clinically important differences in outcomes and did not support robust conclusions about the best treatment option.
- Which patient characteristics are associated with the benefits of examined physical therapy interventions on intermediate and patient-centered outcomes?
  ○ Evidence from individual randomized controlled clinical trials did not support robust conclusions about differences in physical therapy effects by patient characteristics. Patients with high compliance tended to have a better treatment response with exercise interventions.
- Do changes in intermediate and patient-centered outcomes differ by the dose, duration, intensity, and frequency of examined physical therapy interventions?
  ○ The duration of examined interventions was not associated with better intermediate or patient-centered outcomes.
  ○ Evidence regarding the association between the dose/intensity/frequency of examined interventions and outcomes was not available for the majority of comparisons.
- Do changes in intermediate and patient-centered outcomes differ by the time of followup?
  ○ The effects of the treatments that significantly improved outcomes, including exercise (aerobic, aquatic, and strengthening) and ultrasound did not differ at shorter versus longer followup times.
  ○ Electrical stimulation provided short-term pain improvement, but significantly worsened pain at a longer followup.
  ○ Study risk of bias and heterogeneity in populations and treatments, including concomitant treatments, decreased the strength of evidence to low or moderate in most cases.

### Key Question 2

- What is the association between changes in intermediate outcomes and changes in patient-centered outcomes after physical therapy interventions?
  ○ Gait, mobility restrictions, muscle strength, and range of motion measures were associated with disability measures.
  ○ Individual observational studies failed to provide strong evidence for determining which intermediate outcomes strongly and consistently predict patient-centered outcomes.
- What is the validity of the tests and measures used to determine intermediate outcomes of physical therapy on osteoarthritis (OA) in association with patient-centered outcomes?
  ○ Many articles reported validation, but few demonstrated a strong (more than 50 percent) correlation between index and reference method measurements.
  ○ Original studies concluded that tests are valid based on significance, not strength of correlation.
- Which intermediate outcomes meet the criteria of surrogates for patient-centered outcomes?
  ○ None of the intermediate outcomes met surrogate criteria for patient-centered outcomes.
- What are minimum clinically important differences (MCIDs) of the tests and measures used to determine intermediate outcomes?
  ○ MCIDs of the tests were determined using the anchor method, which compares changes in scales with patient perception of improvements. MCIDs were available as absolute change in score or as relative change as a percentage difference from baseline levels, the latter accounting for baseline severity of the disease.
  ○ The definition of Patient Acceptable Symptom State (PASS) that accounted for patient satisfaction was available for Western Ontario and McMaster Universities Osteoarthritis Index (WOMAC), Visual Analog Scale (VAS) for pain, and for the Patient Global Assessment Scale. PASS defines the highest level of symptom state patients can tolerate and still be satisfied with their treatment.
  ○ Validated tools defined threshold values of clinical importance for evaluating treatment success in adults with knee OA. However, more often studies used continuous measures of the outcomes, providing an average score for all patients in each treatment group, with no evaluation of the clinical importance of these averages. Average scores do not reveal how many or which patients develop disability or experience clinically meaningful improvement in pain, function, or quality of life.

### Key Question 3

- What are the harms from physical therapy interventions available for adult patients with chronic knee pain due to OA when compared with no active treatment or active controls?
  ○ Adverse events were uncommon, varied across interventions, and included skin irritation with brace/insole/tape/electrical stimulation; swelling with brace/diathermy/exercise; muscle soreness with electrical stimulation; warming/throbbing sensation with diathermy/electrical stimulation/PEMF; increased pain with diathermy/exercise/insole/PEMF; and falls with insole. Adverse events were not severe enough to deter participants from continuing treatment.

## References

1 Lawrence RC, Felson DT, Helmick CG, et al. Estimates of the prevalence of arthritis and other rheumatic conditions in the United States. Part II. Arthritis Rheum. Jan. 2008;58(1):26-35. [pmid: 18163497].
2 Johnson CA. Approach to the patient with knee pain. CURRENT Rheumatology Diagnosis & Treatment. 2nd ed. Columbus, OH. The McGraw-Hill Companies. 2007. chapter 12.
3 Jordan JM, Helmick CG, Renner JB, et al. Prevalence of knee symptoms and radiographic and symptomatic knee osteoarthritis in African Americans and Caucasians: the Johnston County Osteoarthritis Project. J Rheumatol. Jan. 2007;34(1):172-80. [pmid: 17216685].
4 Dillon CF, Rasch EK, Gu Q, et al. Prevalence of knee osteoarthritis in the United States: arthritis data from the Third National Health and Nutrition Examination Survey 1991–94. J Rheumatol. Nov. 2006;33(11):2271-9. [pmid: 17013996].
5 Bernstein AB, Hing E, Moss AJ, et al. Health care in America: Trends in utilization. Hyattsville, Maryland. National Center for Health Statistics. 2003.
6 Imboden J. Approach to the Patient with Arthritis. CURRENT Rheumatology Diagnosis & Treatment. 2nd ed. Columbus, OH. The McGraw-Hill Companies. 2007;chapter 4.
7 National Collaborating Centre for Chronic Conditions. Osteoarthritis: national clinical guideline for care and management in adults. Royal College of Physicians. London. 2008.
8 American Academy of Orthopaedic Surgeons treatment of osteoarthritis of the knee (non-arthroplasty). American Academy of Orthopaedic Surgeons (AAOS). Dec. 2008;6:263.
9 Zhang W, Moskowitz RW, Nuki G, et al. OARSI recommendations for the management of hip and knee osteoarthritis, Part II: OARSI evidence-based, expert consensus guidelines. Osteoarthritis Cartilage. Feb. 2008;16(2):137-62. [pmid: 18279766].
10 Jordan KM, Arden NK, Doherty M, et al. EULAR Recommendations 2003: an evidence based approach to the management of knee osteoarthritis: Report of a Task Force of the Standing Committee for International Clinical Studies Including Therapeutic Trials (ESCISIT). Ann Rheum Dis. Dec. 2003;62(12):1145-55. [pmid: 14644851].
11 Andersson GBJ, Bouchard J, Bozic KJ, et al. Arthritis and related conditions. The Burden of Musculoskeletal Diseases. Rosemont, IL. Bone and Joint Decade. 2008:71-96.
12 Andersson GBJ, Bouchard J, Bozic KJ, et al. Health care utilization and economic cost of musculoskeletal diseases. The Burden of Musculoskeletal Diseases. Rosemont, IL. Bone and Joint Decade. 2008:195-225.
13 Richmond J, Hunter D, Irrgang J, et al. American Academy of Orthopaedic Surgeons clinical practice guideline on the treatment of osteoarthritis (OA) of the knee. Journal of Bone & Joint Surgery - American Volume. Apr. 2010;92(4):990-3. [pmid: 20360527].
14 Michael JW, Schluter-Brust KU, Eysel P. The epidemiology, etiology, diagnosis, and treatment of osteoarthritis of the knee. Dtsch Arztebl Int. Mar. 2010;107(9):152-62. [pmid: 20305774].
15 Felson DT. Clinical practice. Osteoarthritis of the knee. N Engl J Med. Feb. 23. 2006;354(8):841-8. [pmid: 16495396].
16 Bellamy N, Kirwan J, Boers M, et al. Recommendations for a core set of outcome measures for future phase III clinical trials in knee, hip, and hand osteoarthritis. Consensus development at OMERACT III. J Rheumatol. Apr. 1997;24(4):799-802. [pmid: 9101522].
17 Rutjes AW, Nuesch E, Sterchi R, et al. Transcutaneous electrostimulation for osteoarthritis of the knee. Cochrane Database Syst Rev. 2009;(4):CD002823. [pmid: 19821296].
18 Brouwer RW, Jakma TS, Verhagen AP, et al. Braces and orthoses for treating osteoarthritis of the knee. Cochrane Database of Systematic Reviews. 2005;(1):004020. [pmid: 15674927].
19 Rutjes AW, Nuesch E, Sterchi R, et al. Therapeutic ultrasound for osteoarthritis of the knee or hip. Cochrane Database Syst Rev. 2010;20(1):CD003132. [pmid: 20091539].
20 Brosseau L, Yonge KA, Robinson V, et al. Thermotherapy for treatment of osteoarthritis. Cochrane Database Syst Rev. 2003;(4):CD004522. [pmid: 14584019].
21 Liberati A, Altman DG, Tetzlaff J, et al. The PRISMA statement for reporting systematic reviews and meta-analyses of studies that evaluate health care interventions: explanation and elaboration. Annals of Internal Medicine. Aug. 18. 2009;151(4):W65-94. [pmid: 19622512].
22 Impaired Joint Mobility, Motor Function, Muscle Performance, and Range of Motion Associated with Localized Inflammation. Guide to Physical Therapist Practice. 2nd ed. Phys Ther. 2010.
23 Norris S, Atkins D, Bruening W, et al. Selecting observational studies for comparing medical interventions. Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness Reviews. 2010.
24 Norris S, Atkins D, Bruening W, et al. Selecting Observational Studies for Comparing Medical Interventions. Methods Guide for Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2008. [pmid: 21433401].
25 Chou R, Aronson N, Atkins D, et al. Assessing harms when comparing medical interventions: AHRQ and the Effective Health-Care Program. J Clin Epidemiol. 2008. Sep. 25. [pmid: 18823754].
26 Higgins J, Green S. Cochrane Collaboration. Cochrane handbook for systematic reviews of interventions. Chichester, West Sussex ; Hoboken NJ. John Wiley & Sons. 2008.
27 Whiting PF, Weswood ME, Rutjes AW, et al. Evaluation of QUADAS, a tool for the quality assessment of diagnostic accuracy studies. BMC Med Res Methodol. 2006;6:9. [pmid: 16519814].
28 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
29 US Preventive Services Task Force. Procedure Manual. AHRQ Publication No. 08-05118-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2008. www.preventiveservices.ahrq.gov. Accessed December 2011.
30 Friedrich JO, Adhikari NK, Beyene J. Ratio of means for analyzing continuous outcomes in meta-analysis performed as well as mean difference methods. Journal of Clinical Epidemiology. May. 2011;64(5):556-64. [pmid: 21447428].
31 Fu R, Gartlehner G, Grant M, et al. Conducting Quantitative Synthesis When Comparing Medical Interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2010;64(11):1187-97. [pmid: 21477993].
32 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-60. [pmid: 12958120].
33 Herbison P, Hay-Smith J, Gillespie WJ. Adjustment of meta-analyses on the basis of quality scores should be abandoned. J Clin Epidemiol. Dec. 2006;59(12):1249-56. [pmid: 17098567].
34 Agency for Healthcare Research and Quality. HHS Awards $473 Million in Patient-Centered Outcomes Research Funding. Agency for Healthcare Research and Quality. Rockville, MD. 2010.
35 Wallace BC, Schmid CH, Lau J, et al. Meta-Analyst: software for meta-analysis of binary, continuous and diagnostic data. BMC Med Res Methodol. 2009;9:80. [pmid: 19961608].
36 Egger M, Smith GD, Altman DG. Systematic Reviews in Health Care. London. NetLibrary, Inc. BMJ Books. 2001.
37 Cohen J. Statistical Power Analysis for the Behavioral Sciences: Second Edition. Hillsdale, New Jersey. Lawrence Erlbaum Associates. 1988.
38 Higgins J, Green S. The Cochrane Collaboration. The Cochrane handbook for systematic reviews of interventions. Chichester, UK. John Wiley & Sons, Ltd. Cochrane Collaboration. 2006. http://www.cochrane.org/sites/default/files/uploads/Handbook4.2.6Sep2006.pdf. Accessed July 2012.
39 Shaw JW, Johnson JA, Coons SJ. US valuation of the EQ-5D health states: development and testing of the D1 valuation model. Med Care. Mar. 2005;43(3):203-20. [pmid: 15725977].
40 Ware JE Jr, Kosinski M, Bayliss MS, et al. Comparison of methods for the scoring and statistical analysis of SF-36 health profile and summary measures: summary of results from the Medical Outcomes Study. Med Care. Apr. 1995;33(4 Suppl):AS264-79. [pmid: 7723455].
41 White DK, Keysor JJ, Lavalley MP, et al. Clinically important improvement in function is common in people with or at high risk of knee OA: the MOST study. J Rheumatol. Jun. 2010;37(6):1244-51. [pmid: 20395640].
42 Lingard EA, Katz JN, Wright RJ, et al. Validity and responsiveness of the Knee Society Clinical Rating System in comparison with the SF-36 and WOMAC. J Bone Joint Surg Am. Dec. 2001;83-A(12):1856-64. [pmid: 11741066].
43 Chou R, Helfand M, Peterson K, et al. Comparative effectiveness and safety of analgesics for osteoarthritis. Comparative effectiveness review No. 4. Agency for Healthcare Research and Quality. Rockville, MD. 2006.
44 Pham T, Van Der Heijde D, Lassere M, et al. Outcome variables for osteoarthritis clinical trials: The OMERACT-OARSI set of responder criteria. Journal of Rheumatology. 2003;30(7):1648-54. [pmid: 12858473].
45 Viechtbauer W. Confidence intervals for the amount of heterogeneity in meta-analysis. Stat Med. 2006. Feb. 6. [pmid: 16463355].
46 Knapp G, Biggerstaff BJ, Hartung J. Assessing the amount of heterogeneity in random-effects meta-analysis. Biom J. Apr. 2006;48(2):271-85. [pmid: 16708778].
47 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
48 Deeks JJ, Altman DG. Diagnostic tests 4: likelihood ratios. BMJ. Jul. 17. 2004;329(7458):168-9. [pmid: 15258077].
49 Altman DG, Bland JM. Diagnostic tests 3: receiver operating characteristic plots. BMJ. Jul. 16. 1994;309(6948):188. [pmid: 8044101].
50 Lassere MN, Johnson KR, Boers M, et al. Definitions and validation criteria for biomarkers and surrogate endpoints: development and testing of a quantitative hierarchical levels of evidence schema. J Rheumatol. Mar. 2007;34(3):607-15. [pmid: 17343307].
51 Maillefert JF, Hudry C, Baron G, et al. Laterally elevated wedged insoles in the treatment of medial knee osteoarthritis: a prospective randomized controlled study. Osteoarthritis and Cartilage. 2001;9(8):738-45. [pmid: 11795993].
52 Toda Y, Tsukimura N. Influence of concomitant heeled footwear when wearing a lateral wedged insole for medial compartment osteoarthritis of the knee. Osteoarthritis and Cartilage. 2008;16(2):244-53. [pmid: 17693101].
53 Fisher NM, Gresham G, Pendergast DR. Effects of a quantitative progressive rehabilitation program applied unilaterally to the osteoarthritic knee. Arch Phys Med Rehabil. Dec. 1993;74(12):1319-26. [pmid: 8259900].
54 Ettinger WH Jr, Burns R, Messier SP, et al. A randomized trial comparing aerobic exercise and resistance exercise with a health education program in older adults with knee osteoarthritis. The Fitness Arthritis and Seniors Trial (FAST). Journal - American Medical Association. 1997;277(1):25-31. [pmid: 8980206].
55 Mikesky AE, Mazzuca SA, Brandt KD, et al. Effects of strength training on the incidence and progression of knee osteoarthritis. Arthritis Rheum. Oct. 15. 2006;55(5):690-9. [pmid: 17013851].
56 Bar-Ziv Y, Beer Y, Ran Y, et al. A treatment applying a biomechanical device to the feet of patients with knee osteoarthritis results in reduced pain and improved function: a prospective controlled study. BMC Musculoskelet Disord. 2010;11:179. [pmid: 20698991].
57 Fransen M, McConnell S. Exercise for osteoarthritis of the knee. Cochrane Database Syst Rev. 2008;(4):CD004376. [pmid: 18843657].
58 Recommendations for the medical management of osteoarthritis of the hip and knee: 2000 update. American College of Rheumatology Subcommittee on Osteoarthritis Guidelines. Arthritis & Rheumatism. Sep. 2000;43(9):1905-15. [pmid: 11014340].
59 Brand C. Guideline for the non-surgical management of hip and knee osteoarthritis. The Royal Australian College of General Practitioners. July. 2009.
60 Mazieres B, Bannwarth B, Dougados M, et al. EULAR recommendations for the management of knee osteoarthritis. Report of a task force of the Standing Committee for International Clinical Studies Including Therapeutic Trials. Joint, Bone, Spine: Revue du Rhumatisme. 2001;68(3):231-40. [pmid: 11394623].
61 Higgins J, Green S. Cochrane Collaboration. Cochrane handbook for systematic reviews of interventions. Chichester, West Sussex ; Hoboken NJ. John Wiley & Sons. 2011.
62 Hurley MV, Walsh NE, Mitchell H, et al. Long-term outcomes and costs of an integrated rehabilitation program for chronic knee pain: a pragmatic, cluster randomized, controlled trial. Arthritis Care Res (Hoboken). Feb. 2012;64(2):238-47. [pmid: 21954131].
63 Bennell KL, Hunt MA, Wrigley TV, et al. Hip strengthening reduces symptoms but not knee load in people with medial knee osteoarthritis and varus malalignment: a randomised controlled trial. Osteoarthritis Cartilage. May. 2010;18(5):621-8. Epub 2010 Feb 6.(5):621–8. [pmid: 20175973].
64 Jan MH, Lin CH, Lin YF, et al. Effects of weight-bearing versus nonweight-bearing exercise on function, walking speed, and position sense in participants with knee osteoarthritis: a randomized controlled trial. Arch Phys Med Rehabil. 2009;90(6):897-904. [pmid: 19480863].
65 Lee HJ, Park HJ, Chae Y, et al. Tai Chi Qigong for the quality of life of patients with knee osteoarthritis: a pilot, randomized, waiting list controlled trial. Clin Rehabil. 2009;23(6):504-11. [pmid: 19389743].
66 Lund H, Henriksen M, Bartels EM, et al. Can stimulating massage improve joint repositioning error in patients with knee osteoarthritis?. J Geriatr Phys Ther. 2009;32(3):111-6. [pmid: 20128335].
67 Pisters MF, Veenhof C, Schellevis FG, et al. Long-term effectiveness of exercise therapy in patients with osteoarthritis of the hip or knee: a randomized controlled trial comparing two different physical therapy interventions. Osteoarthritis Cartilage. Aug. 2010;18(8):1019-26. [pmid: 20488250].
68 Rooks DS, Huang J, Bierbaum BE, et al. Effect of preoperative exercise on measures of functional status in men and women undergoing total hip and knee arthroplasty. Arthritis Rheum. Oct. 15. 2006;55(5):700-8. [pmid: 17013852].
69 Bruckenthal P, Broderick JE. Assessing treatment fidelity in pilot studies assist in designing clinical trials: an illustration from a nurse practitioner community-based intervention for pain. Advances in Nursing Science. 2007;30(1):E72-84. [pmid: 17299277].
70 Doherty M, Jones A. Design of clinical trials in knee osteoarthritis: practical issues for debate. Osteoarthritis & Cartilage. Nov. 1998;6(6):371-3. [pmid: 10343768].
71 Pham T, van der Heijde D, Altman RD, et al. OMERACT-OARSI initiative: Osteoarthritis Research Society International set of responder criteria for osteoarthritis clinical trials revisited. Osteoarthritis & Cartilage. 2004;12(5):389-99. [pmid: 15094138].
72 Terwee CB, Roorda LD, Dekker J, et al. Mind the MIC: large variation among populations and methods. Journal of Clinical Epidemiology. May. 2010;63(5):524-34. [pmid: 19926446].
73 Terwee CB, Roorda LD, Knol DL, et al. Linking measurement error to minimal important change of patient-reported outcomes. Journal of Clinical Epidemiology. Oct. 2009;62(10):1062-7. [pmid: 19230609].
74 Dougados M, Moore A, Yu S, et al. Evaluation of the patient acceptable symptom state in a pooled analysis of two multicentre, randomised, double-blind, placebo-controlled studies evaluating lumiracoxib and celecoxib in patients with osteoarthritis. Arthritis Research & Therapy. 2007;9(1):R11. [pmid: 17266764].
75 Fitzgerald GK, Delitto A. Considerations for planning and conducting clinic-based research in physical therapy. Phys Ther. Aug. 2001;81(8):1446-54. [pmid: 11509074].
76 Farr JN, Going SB, McKnight PE, et al. Progressive resistance training improves overall physical activity levels in patients with early osteoarthritis of the knee: a randomized controlled trial. Phys Ther. Mar. 2010;90(3):356-66. [pmid: 20056719].
77 Keefe FJ, Blumenthal J, Baucom D, et al. Effects of spouse-assisted coping skills training and exercise training in patients with osteoarthritic knee pain: a randomized controlled study. Pain. Aug. 2004;110(3):539-49. [pmid: 15288394].
78 Shakoor MA, Taslim MA, Hossain MS. Effects of activity modification on the patients with osteoarthritis of the knee. Bangladesh Med Res Counc Bull. Aug. 2007;33(2):55-9. [pmid: 18481439].
79 Messier SP, Loeser RF, Miller GD, et al. Exercise and dietary weight loss in overweight and obese older adults with knee osteoarthritis: the Arthritis, Diet, and Activity Promotion Trial. Arthritis Rheum. May. 2004;50(5):1501-10. [pmid: 15146420].
80 Deyle GD, Henderson NE, Matekel RL, et al. Effectiveness of manual physical therapy and exercise in osteoarthritis of the knee. A randomized, controlled trial. Annals of Internal Medicine. 2000;132(3):173-81. [pmid: 10651597].
81 Aglamis B, Toraman NF, Yaman H. The effect of a 12-week supervised multicomponent exercise program on knee OA in Turkish women. Journal of Back and Musculoskeletal Rehabilitation. 2008;21(2):121-8.
82 Yip YB, Sit JW, Fung KK, et al. Impact of an Arthritis Self-Management Programme with an added exercise component for osteoarthritic knee sufferers on improving pain, functional outcomes, and use of health care services: An experimental study. Patient Educ Couns. Jan. 2007;65(1):113-21. [pmid: 17010554].
83 Yip YB, Sit JW, Wong DY, et al. A 1-year follow-up of an experimental study of a self-management arthritis programme with an added exercise component of clients with osteoarthritis of the knee. Psychology Health & Medicine. 2008;13(4):402-14. [pmid: 18825579].
84 Kovar PA, Allegrante JP, MacKenzie CR, et al. Supervised fitness walking in patients with osteoarthritis of the knee. A randomized, controlled trial. Annals of Internal Medicine. Apr. 1. 1992;116(7):529-34. [pmid: 1543305].
85 Bautch JC, Malone DG, Vailas AC. Effects of exercise on knee joints with osteoarthritis: a pilot study of biologic markers. Arthritis Care Res. Feb. 1997;10(1):48-55. [pmid: 9313390].
86 Péloquin L, Bravo G, Gauthier P, et al. Effects of a Cross-Training Exercise Program in Persons with Osteoarthritis of the Knee A Randomized Controlled Trial. J Clin Rheumatol. Jun. 1999;5(3):126-36. [pmid: 19078371].
87 Sullivan T, Allegrante JP, Peterson MG, et al. One-year followup of patients with osteoarthritis of the knee who participated in a program of supervised fitness walking and supportive patient education. Arthritis Care Res. Aug. 1998;11(4):228-33. [pmid: 9791321].
88 Rejeski WJ, Focht BC, Messier SP, et al. Obese, older adults with knee osteoarthritis: weight loss, exercise, and quality of life. Health Psychology. 2002;21(5):419-26. [pmid: 12211508].
89 An B, Dai K, Zhu Z, et al. Baduanjin alleviates the symptoms of knee osteoarthritis. J Altern Complement Med. Mar. 2008;14(2):167-74. [pmid: 18315512].
90 Messier SP, Thompson CD, Ettinger WH. Effects of long-term aerobic or weight training regimes on gait in an older, osteoarthritic population. Journal of Applied Biomechanics. 1997;13(2):205-25.
91 Talbot LA, Gaines JM, Huynh TN, et al. A home-based pedometer-driven walking program to increase physical activity in older adults with osteoarthritis of the knee: a preliminary study. J Am Geriatr Soc. Mar. 2003;51(3):387-92. [pmid: 12588583].
92 Hay EM, Foster NE, Thomas E, et al. Effectiveness of community physiotherapy and enhanced pharmacy review for knee pain in people aged over 55 presenting to primary care: pragmatic randomised trial. BMJ. Nov. 11. 2006;333(7576):995. [pmid: 17056608].
93 Peterson MG, Kovar-Toledano PA, Otis JC, et al. Effect of a walking program on gait characteristics in patients with osteoarthritis. Arthritis Care Res. Mar. 1993;6(1):11-6. [pmid: 8443252].
94 Focht BC, Rejeski WJ, Ambrosius WT, et al. Exercise, self-efficacy, and mobility performance in overweight and obese older adults with knee osteoarthritis. Arthritis Rheum. Oct. 15. 2005;53(5):659-65. [pmid: 16208674].
95 Lund H, Weile U, Christensen R, et al. A randomized controlled trial of aquatic and land-based exercise in patients with knee osteoarthritis. J Rehabil Med. Feb. 2008;40(2):137-44. [pmid: 18509579].
96 Patrick DL, Ramsey SD, Spencer AC, et al. Economic evaluation of aquatic exercise for persons with osteoarthritis. Med Care. May. 2001;39(5):413-24. [pmid: 11317090].
97 Schilke JM, Johnson GO, Housh TJ, et al. Effects of muscle-strength training on the functional status of patients with osteoarthritis of the knee joint. Nursing Research. Mar–Apr. 1996;45(2):68-72. [pmid: 8604366].
98 Kuptniratsaikul V, Tosayanonda O, Nilganuwong S, et al. The efficacy of a muscle exercise program to improve functional performance of the knee in patients with osteoarthritis. J Med Assoc Thai. Jan. 2002;85(1):33-40. [pmid: 12075718].
99 Doi T, Akai M, Fujino K, et al. Effect of home exercise of quadriceps on knee osteoarthritis compared with nonsteroidal antiinflammatory drugs: a randomized controlled trial. Am J Phys Med Rehabil. 2008;87(4):258-69. [pmid: 18356618].
100 Baker KR, Nelson ME, Felson DT, et al. The efficacy of home based progressive strength training in older adults with knee osteoarthritis: a randomized controlled trial. J Rheumatol. Jul. 2001;28(7):1655-65. [pmid: 11469475].
101 Swank AM, Kachelman JB, Bibeau W, et al. Prehabilitation before total knee arthroplasty increases strength and function in older adults with severe osteoarthritis. Journal of Strength & Conditioning Research. Feb. 2011;25(2):318-25. [pmid: 21217530].
102 Gür H, Cakin N, Akova B, et al. Concentric versus combined concentric-eccentric isokinetic training: effects on functional capacity and symptoms in patients with osteoarthrosis of the knee. Arch Phys Med Rehabil. Mar. 2002;83(3):308-16. [pmid: 11887109].
103 Jan MH, Lin JJ, Liau JJ, et al. Investigation of clinical effects of high- and low-resistance training for patients with knee osteoarthritis: a randomized controlled trial. Phys Ther. 2008;88(4):427-36. [pmid: 18218827].
104 Cheing GL, Hui-Chan CW, Chan KM. Does four weeks of TENS and/or isometric exercise produce cumulative reduction of osteoarthritic knee pain?. Pain Reviews. 2002;9(3–4):141-51.
105 Weng MC, Lee CL, Chen CH, et al. Effects of different stretching techniques on the outcomes of isokinetic exercise in patients with knee osteoarthritis. Kaohsiung J Med Sci. 2009;25(6):306-15. [pmid: 19560995].
106 Lin DH, Lin CH, Lin YF, et al. Efficacy of 2 non-weight-bearing interventions, proprioception training versus strength training, for patients with knee osteoarthritis: a randomized clinical trial. J Orthop Sports Phys Ther. 2009;39(6):450-7. [pmid: 19531879].
107 Borjesson M, Robertson E, Weidenhielm L, et al. Physiotherapy in knee osteoarthrosis: effect on pain and walking. Physiother Res Int. 1996;1(2):89-97. [pmid: 9238726].
108 Lim BW, Hinman RS, Wrigley TV, et al. Does knee malalignment mediate the effects of quadriceps strengthening on knee adduction moment, pain, and function in medial knee osteoarthritis? A randomized controlled trial. Arthritis Rheum. 2008;59(7):943-51. [pmid: 18576289].
109 Topp R, Woolley S, Hornyak J 3rd, et al. The effect of dynamic versus isometric resistance training on pain and functioning among adults with osteoarthritis of the knee. Arch Phys Med Rehabil. Sep. 2002;83(9):1187-95. 1187. [pmid: 12235596].
110 Cheing GL, Hui-Chan CW. Would the addition of TENS to exercise training produce better physical performance outcomes in people with knee osteoarthritis than either intervention alone?. Clin Rehabil. Aug. 2004;18(5):487-97. [pmid: 15293483].
111 Brismee JM, Paige RL, Chyu MC, et al. Group and home-based tai chi in elderly subjects with knee osteoarthritis: a randomized controlled trial. Clin Rehabil. Feb. 2007;21(2):99-111. [pmid: 17264104].
112 Song R, Roberts BL, Lee EO, et al. A randomized study of the effects of t’ai chi on muscle strength, bone mineral density, and fear of falling in women with osteoarthritis. Journal of Alternative & Complementary Medicine. Mar. 2010;16(3):227-33. [pmid: 20192907].
113 Tsauo JY, Cheng PF, Yang RS. The effects of sensorimotor training on knee proprioception and function for patients with knee osteoarthritis: a preliminary report. Clin Rehabil. 2008;22(5):448-57. [pmid: 18441041].
114 Jan MH, Tang PF, Lin JJ, et al. Efficacy of a target-matching foot-stepping exercise on proprioception and function in patients with knee osteoarthritis. J Orthop Sports Phys Ther. Jan. 2008;38(1):19-25. [pmid: 18357655].
115 Yip YB, Tam AC. An experimental study on the effectiveness of massage with aromatic ginger and orange essential oil for moderate-to-severe knee pain among the elderly in Hong Kong. Complement Ther Med. Jun. 2008;16(3):131-8. [pmid: 18534325].
116 Ko T, Lee S, Lee D. Manual therapy and exercise for OA knee: Effects on muscle strength, proprioception, and functional performance. Journal of Physical Therapy Science. 2009;21(4):293-9.
117 Hinman RS, Bowles KA, Bennell KL. Laterally wedged insoles in knee osteoarthritis: do biomechanical effects decline after one month of wear?. BMC Musculoskelet Disord. 146. 2009;10:146. [pmid: 19939281].
118 Maly M, Culham E, Costigan P. Static and dynamic biomechanics of foot orthoses in people with medial compartment knee osteoarthritis. Clinical Biomechanics. 2002;17(8):603-10. [pmid: 12243720].
119 Kerrigan DC, Lelas JL, Goggins J, et al. Effectiveness of a lateral-wedge insole on knee varus torque in patients with knee osteoarthritis. Archives of Physical Medicine and Rehabilitation. 2002;83(7):889-93. [pmid: 12098144].
120 Kuroyanagi Y, Nagura T, Matsumoto H, et al. The lateral wedged insole with subtalar strapping significantly reduces dynamic knee load in the medial compartment gait analysis on patients with medial knee osteoarthritis. Osteoarthritis & Cartilage. Aug. 2007;15(8):932-6. [pmid: 17391994].
121 Toda Y, Tsukimura N, Segal N. An optimal duration of daily wear for an insole with subtalar strapping in patients with varus deformity osteoarthritis of the knee. Osteoarthritis & Cartilage. 2005;13(4):353-60. [pmid: 15780649].
122 Toda Y, Segal N, Kato A, et al. Effect of a novel insole on the subtalar joint of patients with medial compartment osteoarthritis of the knee. Journal of Rheumatology. 2001;28(12):2705-10. [pmid: 11764221].
123 Toda Y, Tsukimura N. A six-month followup of a randomized trial comparing the efficacy of a lateral-wedge insole with subtalar strapping and an in-shoe lateral-wedge insole in patients with varus deformity osteoarthritis of the knee. Arthritis & Rheumatism. 2004;50(10):3129-36. [pmid: 15476225].
124 Garland D, Holt P, Harrington JT, et al. A 3-month, randomized, double-blind, placebo-controlled study to evaluate the safety and efficacy of a highly optimized, capacitively coupled, pulsed electrical stimulator in patients with osteoarthritis of the knee. Osteoarthritis Cartilage. Jun. 2007;15(6):630-7. [pmid: 17303443].
125 Selfe TK, Bourguignon C, Taylor AG. Effects of noninvasive interactive neurostimulation on symptoms of osteoarthritis of the knee: a randomized, sham-controlled pilot study. J Altern Complement Med. 2008;14(9):1075-81. [pmid: 19055333].
126 Taylor P, Hallett M, Flaherty L. Treatment of osteoarthritis of the knee with transcutaneous electrical nerve stimulation. Pain. Oct. 1981;11(2):233-40. [pmid: 7033891].
127 Law PP, Cheing GL. Optimal stimulation frequency of transcutaneous electrical nerve stimulation on people with knee osteoarthritis. J Rehabil Med. Sep. 2004;36(5):220-5. [pmid: 15626162].
128 Itoh K, Hirota S, Katsumi Y, et al. A pilot study on using acupuncture and transcutaneous electrical nerve stimulation (TENS) to treat knee osteoarthritis (OA). Chin Med. 2008;3:2. [pmid: 18312661].
129 Pietrosimone BG, Hart JM, Saliba SA, et al. Immediate effects of transcutaneous electrical nerve stimulation and focal knee joint cooling on quadriceps activation. Med Sci Sports Exerc. Jun. 2009;41(6):1175-81. [pmid: 19461552].
130 Grimmer K. A controlled double blind study comparing the effects of strong burst mode TENS and high rate TENS on painful osteoarthritic knees. Australian Journal of Physiotherapy. 1992;38(1):49-56.
131 Cetin N, Aytar A, Atalay A, et al. Comparing hot pack, short-wave diathermy, ultrasound, and TENS on isokinetic strength, pain, and functional status of women with osteoarthritic knees: a single-blind, randomized, controlled trial. Am J Phys Med Rehabil. 2008;87(6):443-51. [pmid: 18496246].
132 Gaines JM, Metter EJ, Talbot LA. The effect of neuromuscular electrical stimulation on arthritis knee pain in older adults with osteoarthritis of the knee. Appl Nurs Res. Aug. 2004;17(3):201-6. [pmid: 15343554].
133 Talbot LA, Gaines JM, Ling SM, et al. A home-based protocol of electrical muscle stimulation for quadriceps muscle strength in older adults with osteoarthritis of the knee. J Rheumatol. Jul. 2003;30(7):1571-8. [pmid: 12858461].
134 Yurtkuran M, Kocagil T. TENS, electroacupuncture and ice massage: comparison of treatment for osteoarthritis of the knee. Am J Acupunct. 1999;27(3–4):133-40. [pmid: 10729968].
135 Law PP, Cheing GL, Tsui AY. Does transcutaneous electrical nerve stimulation improve the physical performance of people with knee osteoarthritis?. J Clin Rheumatol. Dec. 2004;10(6):295-9. [pmid: 17043536].
136 Pietrosimone BG, Saliba SA, Hart JM, et al. Effects of disinhibitory transcutaneous electrical nerve stimulation and therapeutic exercise on sagittal plane peak knee kinematics and kinetics in people with knee osteoarthritis during gait: a randomized controlled trial. Clin Rehabil. Dec. 2010;24(12):1091-101. [pmid: 20713439].
137 Ay S, Evcik D. The effects of pulsed electromagnetic fields in the treatment of knee osteoarthritis: a randomized, placebo-controlled trial. Rheumatol Int. 2009;29(6):663-6. [pmid: 19015858].
138 Thamsborg G, Florescu A, Oturai P, et al. Treatment of knee osteoarthritis with pulsed electromagnetic fields: a randomized, double-blind, placebo-controlled study. Osteoarthritis & Cartilage. 2005;13(7):575-81. [pmid: 15979009].
139 Tascioglu F, Kuzgun S, Armagan O, et al. Short-term effectiveness of ultrasound therapy in knee osteoarthritis. Journal of International Medical Research. Jul–Aug. 2010;38(4):1233-42. [pmid: 20925995].
140 Özgönenel L, Aytekin E, Durmusoglu G. A double-blind trial of clinical effects of therapeutic ultrasound in knee osteoarthritis. Ultrasound Med Biol. Jan. 2009;35(1):44-9. [pmid: 18829151].
141 Huang MH, Yang RC, Lee CL, et al. Preliminary results of integrated therapy for patients with knee osteoarthritis. Arthritis Rheum. Dec. 15. 2005;53(6):812-20. [pmid: 16342083].
142 Huang MH, Lin YS, Lee CL, et al. Use of ultrasound to increase effectiveness of isokinetic exercise for knee osteoarthritis. Arch Phys Med Rehabil. Aug. 2005;86(8):1545-51. [pmid: 16084806].
143 Loyola-Sánchez A, Richardson J, Beattie KA, et al. Effect of low-intensity pulsed ultrasound on the cartilage repair in people with mild to moderate knee osteoarthritis: a double-blinded, randomized, placebo-controlled pilot study. Arch Phys Med Rehabil. Jan. 2012;93(1):35-42. [pmid: 22200383].
144 Callaghan MJ, Whittaker PE, Grimes S, et al. An evaluation of pulsed shortwave on knee osteoarthritis using radioleucoscintigraphy: a randomised, double blind, controlled trial. Joint Bone Spine. Mar. 2005;72(2):150-5. [pmid: 15797496].
145 Fukuda TY, Alves da Cunha R, Fukuda VO, et al. Pulsed shortwave treatment in women with knee osteoarthritis: a multicenter, randomized, placebo-controlled clinical trial. Phys Ther. Jul. 2011;91(7):1009-17. [pmid: 21642511].
146 Laufer Y, Zilberman R, Porat R, et al. Effect of pulsed short-wave diathermy on pain and function of subjects with osteoarthritis of the knee: a placebo-controlled double-blind clinical trial. Clin Rehabil. May. 2005;19(3):255-63. [pmid: 15859526].
147 Akyol Y, Durmus D, Alayli G, et al. Does short-wave diathermy increase the effectiveness of isokinetic exercise on pain, function, knee muscle strength, quality of life, and depression in the patients with knee osteoarthritis? A randomized controlled clinical study. European journal of physical & rehabilitation medicine. Sep. 2010;46(3):325-36. [pmid: 20926998].
148 Durmus D, Alayli G, Canturk F. Effects of quadriceps electrical stimulation program on clinical parameters in the patients with knee osteoarthritis. Clin Rheumatol. May. 2007;26(5):674-8. [pmid: 16897119].
149 Wyatt FB, Milam S, Manske RC, et al. The effects of aquatic and traditional exercise programs on persons with knee osteoarthritis. Journal of Strength & Conditioning Research. 2001;15(3):337-40. [pmid: 11710661].

## Abbreviations

ADL: Activities of Daily Living
AHRQ: Agency for Healthcare Research and Quality
AMED: Allied and Complementary Medicine
APTA: American Physical Therapy Association
BMI: Body Mass Index
CI: Confidence Interval
EQ-5D: European Quality of Life-5 Dimension
E-stim: Electrical Stimulation
IADL: Instrumental Activities of Daily Living
MCID: Minimal Clinically Important Difference
OA: Osteoarthritis
OARSI: Osteoarthritis Research Society
OMERACT: Outcomes Measures in Rheumatoid Arthritis Clinical Trials
PASS: Patient Acceptable Symptom State
PEDro: Physiotherapy Evidence Database
PEMF: Pulsed Electromagnetic Fields
PICOTS: Population, Intervention, Comparator, Outcome, Timing, and Setting
PT: Physical Therapy
RCT: Randomized Controlled Trial
SF-36: Medical Outcomes Study 36-Item Short-Form Health Survey
SMD: Standard Mean Difference
STATA: Statistics and Data Analysis Software
TEP: Technical Expert Panel
VAS: Visual Analog Scale
WOMAC: Western Ontario and McMaster Universities Osteoarthritis Index