# Evidence Tables and Figures

Appendix Table F1 FDA review of medical devices for physical therapy interventions in adults with knee OA

Appendix Table F2 Registered in clinicaltrials.gov closed studies of physical therapy interventions in adults with knee OA

Appendix Table F3 Scientific Information Package requests

Appendix Table F4 Poorly reported RCTs, and nonrandomized studies

Appendix Table F5 Therapeutic studies of physical therapy interventions that did not contribute to synthesis of evidence due to poor quality or inclusion of patients with hip OA

Appendix Table F6 Consent of the subjects, sponsorship, and risk of bias in the studies of physical therapy interventions

Appendix Table F7 Sample size, proportion of women, and an average BMI in adults with knee OA participating in the studies of physical therapy interventions

Appendix Table F8 Risk of bias in therapeutic studies of physical therapy for adults with pain secondary to knee OA

Appendix Table F9 Characteristics of included subjects in the studies of physical therapy interventions

Appendix Table F10 Sample size and intensity of examined physical therapy interventions

Appendix Table F11 Actual measurement and frequency of outcomes-disability, pain, quality of life, and composite function in the pooled analyses

Appendix Table F12 Efficacy and comparative effectiveness of physical therapy interventions, pooled with random effects results from randomized controlled clinical trials

Appendix Table F13 Strength of evidence of differences in outcomes with physical therapy interventions for adults with knee OA

Appendix Table F14 Effectiveness of physical therapy intervention; results from individual RCTs

Appendix Table F15 Exploring heterogeneity in pain relief around 3 months after aerobic exercise, compared to placebo; results from meta-regression

Appendix Table F16 Exploring heterogeneity by quality of study in pain relief around 3 months after aerobic exercise, compared to placebo; results from subgroup analyses

Appendix Table F17 Exploring heterogeneity by quality of study in composite function 3 months after aerobic exercise compared to placebo; results from subgroup analyses

Appendix Table F18 Exploring heterogeneity in gait function around 3 months after strengthening exercise compared to placebo; results from meta-regression

Appendix Table F19 Exploring heterogeneity in function composite around 3 months after strengthening exercise compared to placebo; results from meta-regression

Appendix Table F20 Exploring heterogeneity in pain relief around 3 months after strengthening exercise, compared to placebo; results from meta-regression

Appendix Table F21 Exploring heterogeneity by quality of study in pain relief 3 months after strengthening exercise, compared to placebo; results from subgroup analyses

Appendix Table F22 Exploring heterogeneity by quality of study in gait function 3 months after strengthening exercise compared to placebo, results from subgroup analyses

Appendix Table F23 Exploring heterogeneity by quality of study in composite function 3 months after strengthening exercise compared to placebo; results from subgroup analyses

Appendix Table F24 Exploring heterogeneity by quality of study in long term pain relief after strengthening exercise compared to placebo; results from subgroup analyses

Appendix Table F25 Subgroup analyses on PT involvement with aerobic or strengthening exercises for adults with knee OA

Appendix Table F26 Pooled subgroup analyses: Assess clinical importance of treatment effects of physical therapy interventions on pain measured with VAS for adults with knee OA

Appendix Table F27 Effects of physical therapy interventions on clinically important improvement in pain, and global assessment of treatment success; results from individual RCTs

Appendix Table F28 Significant effects of aerobic exercise on minimal clinically important differences (MCID) in outcomes; results from individual RCTs

Appendix Figure F1 Associations between duration of treatment and intermediate/patient-centered outcomes, after exercise (including aerobic, strengthening, aquatic, proprioception, and Tai Chi)

The longest followup standardized effect size in each study was used for this analysis

Figure F1 is a scatter diagram with regression line depicting associations between duration of treatment and intermediate/patient-centered outcomes, after exercise (including aerobic, strengthening, aquatic, proprioception, and Tai Chi). The data came from 42 studies. The diagram has four graphs where the top-left graph is for disability, top-right for function composite, bottom-left for pain, and bottom-right for gait function. The x-axis is the duration of treatment and the y-axis is standardized effect size. All p-values of the correlation coefficients are greater than 0.05. The results indicate that exercise’s effects did not differ by the duration of treatment for disability, pain, gait, and composite function.

Appendix Figure F2 Associations between the time of followup and intermediate/ patient-centered outcomes, after exercise (including aerobic, strengthening, aquatic, proprioception, and Tai Chi)

Figure F2 is a scatter diagram with regression line depicting associations between the time of followup and intermediate/ patient-centered outcomes, after exercise (including aerobic, strengthening, aquatic, proprioception, and Tai Chi). The data came from 42 studies. The diagram has four graphs where the top-left graph is for disability, top-right for function composite, bottom-left for pain, and bottom-right for gait function. The x-axis is the time of followup and the y-axis is standardized effect size. All p-values of the correlation coefficients are greater than 0.05. The results indicate that exercise’s effects did not differ by time of followup for disability, pain, gait, and composite function.

Appendix Figure F3 Associations between the time of followup and outcomes after ultrasound

Figure F3 is a scatter diagram with regression line depicting associations between the time of followup and intermediate/ patient-centered outcomes, after ultrasound. The data came from 6 studies. The diagram has four graphs where the top-left graph is for disability, top-right for function composite, bottom-left for pain, and bottom-right for gait function. The x-axis is the time of followup and the y-axis is standardized effect size. All p-values of the correlation coefficients are greater than 0.05. The results indicate that ultrasound’s effects did not differ by time of followup for all presented outcomes.

Appendix Figure F4 Associations between the time of followup and intermediate/ patient-centered outcomes, after electrical stimulation

Figure F4 is a scatter diagram with regression line depicting associations between the time of followup and intermediate/ patient-centered outcomes, after electrical stimulation. The data came from 15 studies. The diagram has four graphs where the top-left graph is for disability, top-right for function composite, bottom-left for pain, and bottom-right for gait function. The x-axis is the time of followup and the y-axis is standardized effect size. All p-values of the correlation coefficients are greater than 0.05, except that of pain (p-value < 0.001). The results indicate that electrical stimulation improved pain at short followups but significantly worsened pain at longer follow-ups.

Appendix Figure F5 Association between time of followup and intermediate/ patient-centered outcomes, after diathermy

Figure F5 is a scatter diagram with regression line depicting associations between the time of followup and intermediate/ patient-centered outcomes, after diathermy. The data came from 5 studies. The diagram has four graphs where the top-left graph is for disability, top-right for function composite, bottom-left for pain, and bottom-right for gait function. The x-axis is the time of followup and the y-axis is standardized effect size. All p-values of the correlation coefficients are greater than 0.05, except that of disability (p-value = 0.009). The results indicate that diathermy’s benefits for disability increase with longer followups

Appendix Table F29 Description of tools

Appendix Table F30 Average size, percentage of women, and patient age in the studies of the association between intermediate and clinical outcomes

Appendix Table F31 Quality of diagnostic studies

Appendix Table F32 Association between intermediate and clinical outcomes-diagnostic value of the tests

Appendix Table F33 Association between gait and functional performance

Appendix Table F34 Association between strength and functional performance

Appendix Table F35 Association between balance and functional performance

Appendix Table F36 Association between intermediate outcomes and disability

Appendix Table F37 Association between joint mobility and functional performance

Appendix Table F38 Association between joint stability and alignment with functional performance

Appendix Table F39 Association between pain and poor functional status

Appendix Table F40 Association between intermediate outcomes with pain and physical performance

Appendix Table F41 Association between pain and functional performance

Appendix Table F42 Association between intermediate outcomes and Adjusted Activity Score, derived by subtracting the number of activities the participant is no longer able to perform from the value of the MAS; reflective of an individual’s typical daily physical activities

Appendix Table F43 Association between intermediate outcomes and doctor indication for patients to undergo total joint replacement within a year after consultation

Appendix Table F44 Association between self reported health outcomes and poor functional status

Appendix Table F45 Correlation between intermediate and clinical outcomes in adults with knee OA

Appendix Table F46 Strength of correlation in validation testing of the tools to measure outcomes in adults with knee OA

Appendix Table F47 Strength of correlation by validity type of the tools to measure outcomes in adults with knee OA

Appendix Table F48 Average size, percentage of women, and patient age in studies with validation of the tool to measure outcomes in adults with knee OA

Appendix Table F49 Correlation between index methods to measure intermediate outcomes and reference standards in patients with knee OA

Appendix Table F50 Validity of the functional tests in patients with knee OA

Appendix Table F51 Validity of the scales in patients with knee OA

Appendix Table F52 Validity of Western Ontario and McMaster Universities Osteoarthritis Index

Appendix Table F53 Rasch analysis of Western Ontario McMaster Universities Osteoarthritis Index

Appendix Table F54 Association between gait and patient centered outcomes

Appendix Table F55 Minimum clinically important differences in the Western Ontario McMaster Universities Osteoarthritis Index

Appendix Table F56 Minimum clinically important differences in the Visual Analogue Scale (anchor method)

Appendix Table F57 Minimum clinically important differences in the Short-Form Questionnaire-36 (SF-36)

Appendix Table F58 Minimum clinically important differences in the tools to assess outcomes in patients with knee OA

## References for Appendix F

1 Murphy SL, Strasburg DM, Lyden AK, et al. Effects of activity strategy training on pain and physical activity in older adults with knee or hip osteoarthritis: a pilot study. Arthritis Rheum. 2008;59(10):1480-7. [pmid: 18821646].
2 Pisters MF, Veenhof C, de Bakker DH, et al. Behavioural graded activity results in better exercise adherence and more physical activity than usual care in people with osteoarthritis: A cluster-randomised trial. Australian Journal of Physiotherapy. 2010;56(1):41-7. [pmid: 20500136].
3 Pisters MF, Veenhof C, Schellevis FG, et al. Long-term effectiveness of exercise therapy in patients with osteoarthritis of the hip or knee: a randomized controlled trial comparing two different physical therapy interventions. Osteoarthritis Cartilage. Aug. 2010;18(8):1019-26. [pmid: 20488250].
4 Messier SP, Legault C, Mihalko S, et al. The Intensive Diet and Exercise for Arthritis (IDEA) trial: design and rationale. BMC Musculoskelet Disord. 93. 2009;10:93. [pmid: 19638215].
5 Riecke BF, Christensen R, Christensen P, et al. Comparing two low-energy diets for the treatment of knee osteoarthritis symptoms in obese patients: a pragmatic randomized clinical trial. Osteoarthritis Cartilage. Jun. 2010;18(6):746-54. [pmid: 20206314].
6 Fransen M, Nairn L, Winstanley J, et al. Physical activity for osteoarthritis management: a randomized controlled clinical trial evaluating hydrotherapy or Tai Chi classes. Arthritis Rheum. Apr. 15. 2007;57(3):407-14. [pmid: 17443749].
7 Hunter DJ, Harvey W, Gross KD, et al. A randomized trial of patellofemoral bracing for treatment of patellofemoral osteoarthritis. Osteoarthritis Cartilage. 2011. Jan. 11. [pmid: 21232620].
8 Rattanachaiyanont M, Kuptniratsaikul V. No additional benefit of shortwave diathermy over exercise program for knee osteoarthritis in peri-/post-menopausal women: an equivalence trial. Osteoarthritis Cartilage. Jul. 2008;16(7):823-8. [pmid: 18178111].
9 McKnight PE, Kasle S, Going S, et al. A comparison of strength training, self-management, and the combination for early osteoarthritis of the knee. Arthritis Care Res (Hoboken.). 2010;62(1):45-53. [pmid: 20191490].
10 Farr JN, Going SB, McKnight PE, et al. Progressive resistance training improves overall physical activity levels in patients with early osteoarthritis of the knee: a randomized controlled trial. Phys Ther. Mar. 2010;90(3):356-66. [pmid: 20056719].
11 Farr JN, Going SB, Lohman TG, et al. Physical activity levels in patients with early knee osteoarthritis measured by accelerometry. Arthritis Rheum. Sep. 15. 2008;59(9):1229-36. [pmid: 18759320].
12 Ravaud P, Flipo RM, Boutron I, et al. ARTIST (osteoarthritis intervention standardized) study of standardised consultation versus usual care for patients with osteoarthritis of the knee in primary care in France: pragmatic randomised controlled trial. BMJ. 2009;338:b421. [doi: 10.1136/bmj.b421]. b421. [pmid: 19237406].
13 Allen KD, Oddone EZ, Coffman CJ, et al. Telephone-based self-management of osteoarthritis: A randomized trial. Annals of Internal Medicine. Nov. 2. 2010;153(9):570-9. [pmid: 21041576].
14 Sled EA, Khoja L, Deluzio KJ, et al. Effect of a home program of hip abductor exercises on knee joint loading, strength, function, and pain in people with knee osteoarthritis: a clinical trial. Physical Therapy. Jun. 2010;90(6):895-904. 2. [pmid: 20378679].
15 Palmieri-Smith RM, Thomas AC, Karvonen-Gutierrez C, et al. A clinical trial of neuromuscular electrical stimulation in improving quadriceps muscle strength and activation among women with mild and moderate osteoarthritis. Phys Ther. Oct. 2010;90(10):1441-52. [pmid: 20671100].
16 Baker K, Goggins J, Xie H, et al. A randomized crossover trial of a wedged insole for treatment of knee osteoarthritis. Arthritis & Rheumatism. 2007;56(4):1198-203. [pmid: 17393448].
17 Helmark IC, Mikkelsen UR, Borglum J, et al. Exercise increases interleukin-10 levels both intraarticularly and peri-synovially in patients with knee osteoarthritis: a randomized controlled trial. Arthritis Research & Therapy. 2010;12(4):R126. [pmid: 20594330].
18 Hansson EE, Jonsson-Lundgren M, Ronnheden AM, et al. Effect of an education programme for patients with osteoarthritis in primary care - a randomized controlled trial. BMC Musculoskelet Disord. 2010;11:244. [pmid: 20969809].
19 Perlman AI, Sabina A, Williams AL, et al. Massage therapy for osteoarthritis of the knee: a randomized controlled trial. Arch Intern Med. Dec. 11–25. 2006;166(22):2533-8. [pmid: 17159021].
20 Lim BW, Hinman RS, Wrigley TV, et al. Does knee malalignment mediate the effects of quadriceps strengthening on knee adduction moment, pain, and function in medial knee osteoarthritis? A randomized controlled trial. Arthritis Rheum. 2008;59(7):943-51. [pmid: 18576289].
21 Rodrigues PT, Ferreira AF, Pereira RM, et al. Effectiveness of medial-wedge insole treatment for valgus knee osteoarthritis. Arthritis & Rheumatism. 2008;59(5):603-8. [pmid: 18438931].
22 Lin SY, Davey RC, Cochrane T. Community rehabilitation for older adults with osteoarthritis of the lower limb: a controlled clinical trial. Clin Rehabil. Feb. 2004;18(1):92-101. [pmid: 14763724].
23 Foley A, Halbert J, Hewitt T, et al. Does hydrotherapy improve strength and physical function in patients with osteoarthritis--a randomised controlled trial comparing a gym based and a hydrotherapy based strengthening programme. Annals of the Rheumatic Diseases. 2003;62(12):1162-7. [pmid: 14644853].
24 Wang TJ, Belza B, Elaine Thompson F, et al. Effects of aquatic exercise on flexibility, strength and aerobic fitness in adults with osteoarthritis of the hip or knee. J Adv Nurs. Jan. 2007;57(2):141-52. [pmid: 17214750].
25 Forestier R. Magnitude and duration of the effects of two spa therapy courses on knee and hip osteoarthritis: an open prospective study in 51 consecutive patients. Joint Bone Spine. 2000;67(4):296-304. [pmid: 10963077].
26 Guillemin F, Virion JM, Escudier P, et al. Effect on osteoarthritis of spa therapy at Bourbonne-les-Bains. Joint Bone Spine. Dec. 2001;68(6):499-503. [pmid: 11808987].
27 Gaal J, Varga J, Szekanecz Z, et al. Balneotherapy in elderly patients: effect on pain from degenerative knee and spine conditions and on quality of life. Isr Med Assoc J. May. 2008;10(5):365-9. [pmid: 18605361].
28 Evcik D, Kavuncu V, Yeter A, et al. The efficacy of balneotherapy and mud-pack therapy in patients with knee osteoarthritis. Joint Bone Spine. Jan. 2007;74(1):60-5. [pmid: 17223602].
29 Yilmaz B, Goktepe AS, Alaca R, et al. Comparison of a generic and a disease specific quality of life scale to assess a comprehensive spa therapy program for knee osteoarthritis. Joint Bone Spine. Nov. 2004;71(6):563-6. [pmid: 15589440].
30 Jan MH, Chai HM, Wang CL, et al. Effects of repetitive shortwave diathermy for reducing synovitis in patients with knee osteoarthritis: an ultrasonographic study. Physical Therapy. 2006;86(2):236-44. [pmid: 16445337].
31 Quirk AS, Newman RJ, Newman KJ. An evaluation of interferential therapy, shortwave diathermy and exercise in the treatment of osteoarthrosis of the knee. Physiotherapy. 1985;71:55-7.
32 Dalury DF, Jiranek W, Pierson J, et al. The long-term outcome of total knee patients with moderate loss of motion. J Knee Surg. Oct. 2003;16(4):215-20. [pmid: 14584834].
33 Emery CF, Keefe FJ, France CR, et al. Effects of a brief coping skills training intervention on nociceptive flexion reflex threshold in patients having osteoarthritic knee pain: a preliminary laboratory study of sex differences. J Pain Symptom Manage. Mar. 2006;31(3):262-9. [pmid: 16563320].
34 Blagojevic M, Jinks C, Jordan KP. The influence of consulting primary care on knee pain in older people: a prospective cohort study. Annals of the Rheumatic Diseases. 2008;67(12):1702-9. [pmid: 18245113].
35 Ettinger WH, Davis, Neuhaus JM, et al. Long-term physical functioning in persons with knee osteoarthritis from NHANES. I: Effects of comorbid medical conditions. J Clin Epidemiol. 1994;47(7):809-15. [pmid: 7722594].
36 Dunlop DD, Semanik P, Song J, et al. Moving to maintain function in knee osteoarthritis: evidence from the osteoarthritis initiative. Archives of Physical Medicine & Rehabilitation. 2010;91(5):714-21. [pmid: 20434608].
37 Fitzgerald GK, Childs JD, Ridge TM, et al. Agility and perturbation training for a physically active individual with knee osteoarthritis. Physical Therapy. 2002;82(4):372-82. [pmid: 11922853].
38 Roddy E, Zhang W, Doherty M. Home based exercise for osteoarthritis. Annals of the Rheumatic Diseases. Jan. 2005;64(1):170. author reply -1. [pmid: 15608328].
39 Scopaz KA, Piva SR, Gil AB, et al. Effect of baseline quadriceps activation on changes in quadriceps strength after exercise therapy in subjects with knee osteoarthritis. Arthritis Rheum. Jul. 15. 2009;61(7):951-7. [pmid: 19565548].
40 Aglamis B, Toraman NF, Yaman H. Change of quality of life due to exercise training in knee osteoarthritis: SF-36 and WOMAC. J Back Musculoskelet Rehabil. 2009;22(1):43-5. 7. 8. 6. [pmid: 20023363].
41 Schank JA, Herdman SJ, Bloyer RG. Physical therapy in the multidisciplinary assessment and management of osteoarthritis. Clin Ther. Suppl B. 1986;9:14-23. [pmid: 3829092].
42 Diracoglu D, Baskent A, Celik A, et al. Long-term effects of kinesthesia/balance and strengthening exercises on patients with knee osteoarthritis: A one-year follow-up study. Journal of Back and Musculoskeletal Rehabilitation. 2008;21(4):253-62.
43 Focht BC, Ewing V, Gauvin L, et al. The unique and transient impact of acute exercise on pain perception in older, overweight, or obese adults with knee osteoarthritis. Annals of Behavioral Medicine. 2002;24(3):201-10. [pmid: 12173677].
44 Toda Y. The effect of energy restriction, walking, and exercise on lower extremity lean body mass in obese women with osteoarthritis of the knee. J Orthop Sci. 2001;6(2):148-54. [pmid: 11484101].
45 Damush TM, Perkins SM, Mikesky AE, et al. Motivational factors influencing older adults diagnosed with knee osteoarthritis to join and maintain an exercise program. J Aging Phys Act. Jan. 2005;13(1):45-60. [pmid: 15677835].
46 Konishi I, Tanabe N, Seki N, et al. Physiotherapy program through home visits for community-dwelling elderly Japanese women with mild knee pain. Tohoku J Exp Med. Oct. 2009;219(2):91-9. [pmid: 19776525].
47 Coupe VM, Veenhof C, van Tulder MW, et al. The cost effectiveness of behavioural graded activity in patients with osteoarthritis of hip and/or knee. Ann Rheum Dis. Feb. 2007;66(2):215-21. [pmid: 16880195].
48 Foy CG, Penninx BW, Shumaker SA, et al. Long-term exercise therapy resolves ethnic differences in baseline health status in older adults with knee osteoarthritis. J Am Geriatr Soc. Sep. 2005;53(9):1469-75. [pmid: 16137274].
49 French HP, Keogan F, Gilsenan C, et al. Measuring patient satisfaction with exercise therapy for knee osteoarthritis: evaluating the utility of the physiotherapy outpatient survey. Musculoskeletal Care. Jun. 2010;8(2):61-7. [pmid: 20077576].
50 Dias RC, Dias JM, Ramos LR. Impact of an exercise and walking protocol on quality of life for elderly people with OA of the knee. Physiother Res Int. 2003;8(3):121-30. [pmid: 14533368].
51 Bulthuis Y, Drossaers-Bakker KW, Taal E, et al. Arthritis patients show long-term benefits from 3 weeks intensive exercise training directly following hospital discharge. Rheumatology. 2007;46(11):1712-7. [pmid: 17956917].
52 Iwamoto J, Takeda T, Sato Y. Effect of muscle strengthening exercises on the muscle strength in patients with osteoarthritis of the knee. Knee. Jun. 2007;14(3):224-30. [pmid: 17395467].
53 Cooper C, Coggon D. Physical activity and knee osteoarthritis. Lancet. Jun. 1999. 1999;26;353(9171):8.
54 Fisher NM, Pendergast DR, Gresham GE, et al. Muscle rehabilitation: its effect on muscular and functional performance of patients with knee osteoarthritis. Archives of Physical Medicine and Rehabilitation. 1991;72(6):367-74. [pmid: 2059102].
55 Goldman RJ, Reinbold KA, Iglarsh ZA, et al. Phase I design and evaluation of an isometric muscle reeducation device for knee osteoarthritis rehabilitation. J Rehabil Res Dev. Mar–Apr. 2003;40(2):95-107. [pmid: 15077636].
56 Seto H, Ikeda H, Hisaoka H, et al. Effect of heat- and steam-generating sheet on daily activities of living in patients with osteoarthritis of the knee: randomized prospective study. J Orthop Sci. 2008;13(3):187-91. [pmid: 18528650].
57 Courtney CA, Witte PO, Chmell SJ, et al. Heightened flexor withdrawal response in individuals with knee osteoarthritis is modulated by joint compression and joint mobilization. J Pain. Feb. 2010;11(2):179-85. [pmid: 19945353].
58 Cliborne AV, Wainner RS, Rhon DI, et al. Clinical hip tests and a functional squat test in patients with knee osteoarthritis: reliability, prevalence of positive test findings, and short-term response to hip mobilization. J Orthop Sports Phys Ther. Nov. 2004;34(11):676-85. [pmid: 15609488].
59 Chen CY, Chen CL, Hsu SC, et al. Effect of magnetic knee wrap on quadriceps strength in patients with symptomatic knee osteoarthritis. Arch Phys Med Rehabil. 2008;89(12):2258-64. [pmid: 18976982].
60 Chen Y. Treatment of genual osteoarthritis by massotherapy. J Tradit Chin Med. Sep. 2000;20(3):191-4. [pmid: 11038981].
61 Hewitt BA, Refshauge KM, Kilbreath SL. Kinesthesia at the knee: the effect of osteoarthritis and bandage application. Arthritis & Rheumatism. Oct. 15. 2002;47(5):479-83. [pmid: 12382295].
62 Draper ER, Cable JM, Sanchez-Ballester J, et al. Improvement in function after valgus bracing of the knee. An analysis of gait symmetry. Journal of Bone & Joint Surgery - British Volume. Sep. 2000;82(7):1001-5. [pmid: 11041589].
63 Dennis DA, Komistek RD, Nadaud MC, et al. Evaluation of off-loading braces for treatment of unicompartmental knee arthrosis. Journal of Arthroplasty. Jun. 2006;21(4 Suppl 1):2-8. [pmid: 16781418].
64 Giori NJ. Load-shifting brace treatment for osteoarthritis of the knee: a minimum 2 1/2-year follow-up study. Journal of Rehabilitation Research & Development. Mar. 2004;41(2):187-94. [pmid: 15558372].
65 Keating EM, Faris PM, Ritter MA, et al. Use of lateral heel and sole wedges in the treatment of medial osteoarthritis of the knee. Orthop Rev. Aug. 1993;22(8):921-4. [pmid: 8265230].
66 Lindenfeld TN, Hewett TE, Andriacchi TP. Joint loading with valgus bracing in patients with varus gonarthrosis. Clin Orthop Relat Res. Nov. 1997;(344):290-7. [pmid: 9372780].
67 Powers CM, Ward SR, Chan LD, et al. The effect of bracing on patella alignment and patellofemoral joint contact area. Med Sci Sports Exerc. Jul. 2004;36(7):1226-32. [pmid: 15235330].
68 Hewett TE, Noyes FR, Barber-Westin SD, et al. Decrease in knee joint pain and increase in function in patients with medial compartment arthrosis: a prospective analysis of valgus bracing. Orthopedics. Feb. 1998;21(2):131-8. [pmid: 9507265].
69 Butler RJ, Barrios JA, Royer T, et al. Effect of laterally wedged foot orthoses on rearfoot and hip mechanics in patients with medial knee osteoarthritis. Prosthet Orthot Int. Jun. 2009;33(2):107-16. [pmid: 19367514].
70 Finger S, Paulos LE. Clinical and biomechanical evaluation of the unloading brace. The Journal of Knee Surgery. 2002;15(3):155-8. [pmid: 12152976].
71 Pollo FE, Otis JC, Backus SI, et al. Reduction of medial compartment loads with valgus bracing of the osteoarthritic knee. American Journal of Sports Medicine. 2002;30(3):414-21. [pmid: 12016084].
72 Birmingham TB, Kramer JF, Kirkley A, et al. Knee bracing for medial compartment osteoarthritis: effects on proprioception and postural control. Rheumatology. 2001;40(3):285-9. [pmid: 11285375].
73 Chan GN, Smith AW, Kirtley C, et al. Changes in knee moments with contralateral versus ipsilateral cane usage in females with knee osteoarthritis. Clinical Biomechanics. 2005;20(4):396-404. [pmid: 15737447].
74 Gaasbeek RD, Groen BE, Hampsink B, et al. Valgus bracing in patients with medial compartment osteoarthritis of the knee: A gait analysis study of a new brace. Gait and Posture. 2007;26(1):3-10. [pmid: 16962329].
75 Fang MA, Taylor CE, Nouvong A, et al. Effects of footwear on medial compartment knee osteoarthritis. Journal of Rehabilitation Research and Development. 2006;43(4):427-34. [pmid: 17123182].
76 Rubin R, Menz HB. Use of laterally wedged custom foot orthoses to reduce pain associated with medial knee osteoarthritis: a preliminary investigation. Journal - American Podiatric Medical Association. 2005;95(4):347-52.
77 Draganich L, Reider B, Rimington T, et al. The effectiveness of self-adjustable custom and off-the-shelf bracing in the treatment of varus gonarthrosis. J Bone Joint Surg Am. Dec. 2006;88(12):2645-52. [pmid: 17142415].
78 Butler RJ, Marchesi S, Royer T, et al. The effect of a subject-specific amount of lateral wedge on knee mechanics in patients with medial knee osteoarthritis. J Orthop Res. Sep. 2007;25(9):1121-7. [pmid: 17469197].
79 Matsuno H, Kadowaki KM, Tsuji H. Generation II knee bracing for severe medial compartment osteoarthritis of the knee. Arch Phys Med Rehabil. Jul. 1997;78(7):745-9. [pmid: 9228878].
80 Katsuragawa Y, Fukui N, Nakamura K. Change of bone mineral density with valgus knee bracing. International orthopaedics. 1999;23(3):164-7. [pmid: 10486029].
81 Pascual E. Shoes and lower limb osteoarthritis. Journal of Epidemiology & Community Health. Oct. 2003;57(10):763-5. [pmid: 14573568].
82 Kemp G, Crossley KM, Wrigley TV, et al. Reducing joint loading in medial knee osteoarthritis: shoes and canes. Arthritis Rheum. May. 15. 2008;59(5):609-14. [pmid: 18438932].
83 Hinman RS, Bowles KA, Payne C, et al. Effect of length on laterally-wedged insoles in knee osteoarthritis. Arthritis & Rheumatism. Jan. 15. 2008;59(1):144-7. [pmid: 18163399].
84 Barnes CL, Cawley PW, Hederman B. Effect of CounterForce brace on symptomatic relief in a group of patients with symptomatic unicompartmental osteoarthritis: a prospective 2-year investigation. Am J Orthop (Belle Mead NJ). Jul. 2002;31(7):396-401. [pmid: 12180625].
85 Barrios JA, Crenshaw JR, Royer TD, et al. Walking shoes and laterally wedged orthoses in the clinical management of medial tibiofemoral osteoarthritis: a one-year prospective controlled trial. Knee. 2009;16(2):136-42. [pmid: 19097797].
86 Kirkley A, Webster-Bogaert S, Litchfield R, et al. The effect of bracing on varus gonarthrosis. J Bone Joint Surg Am. Apr. 1999;81(4):539-48. [pmid: 10225800].
87 Felson DT, Gross KD, Nevitt MC, et al. The effects of impaired joint position sense on the development and progression of pain and structural damage in knee osteoarthritis. Arthritis & Rheumatism. Aug. 15. 2009;61(8):1070-6. [pmid: 19644911].
88 Bal S, Turan Y, Gurgan A. The effectiveness of transcutaneous electrical nerve stimulation in patients with knee osteoarthritis. Journal of Rheumatology and Medical Rehabilitation. 2007;18(1):1-5.
89 Foxworth J, Absher R, Brito J, et al. The effectiveness of soft shoe inserts on impact loading and ground reaction forces in persons with osteoarthritis of the knee. 2006. 2006 Combined Sections Meeting of the Specialty Sections of the American Physical Therapy Association (CSM 2006). San Diego Convention Center, San Diego, California (USA). 1–5 Feb 2006.
90 Kuo F, Yang S, Hsieh LF. Effect of combined knee brace and lateral wedge soles in management of subjects with osteoarthritic knee. 2006. XVth International Conference on Mechanics in Medicine and Biology (ICMMB - 15). Furama Reverfront Hotel, Singapore City (Singapore). 6–8 Dec 2006.
91 Richards JD. Biomechanical changes in the conservative treatment of medical compartment OA of the knee using valgus bracing. 2006. 6th Symposium of the International Cartilage Repair Society (ICRS 2006). San Diego, Marriott Hotel & Marina, San Diego, California (USA). 8–11 Jan 2006.
92 Lankhorst GJ, van de Stadt RJ, van der Korst JK, et al. Relationship of isometric knee extension torque and functional variables in osteoarthrosis of the knee. Scand J Rehabil Med. 1982;14(1):7-10. [pmid: 7063820].
93 Jamtvedt G, Dahm KT, Holm I, et al. Choice of treatment modalities was not influenced by pain, severity or co-morbidity in patients with knee osteoarthritis. Physiother Res Int. Mar. 2010;15(1):16-23. [pmid: 20033888].
94 Clarke GR, Willis LA, Stenners L, et al. Evaluation of physiotherapy in the treatment of osteoarthrosis of the knee. Rheumatol Rehabil. Nov. 1974;13(4):190-7. [pmid: 4445714].
95 Axford J, Heron C, Ross F, et al. Management of knee osteoarthritis in primary care: pain and depression are the major obstacles. J Psychosom Res. May. 2008;64(5):461-7. [pmid: 18440398].
96 Fary RE, Briffa NK, Briffa TG. Effectiveness of pulsed electrical stimulation in the management of osteoarthritis of the knee: three case reports. Physiother Theory Pract. Jan–Feb. 2009;25(1):21-9. [pmid: 19140079].
97 Pfeiffer K. Pulsed electromagnetic field therapy in the management of knee OA. Annals of the Rheumatic Diseases. Jul. 2001;60(7):717. [pmid: 11436855].
98 Picaza JA, Cannon BW, Hunter SE, et al. Pain suppression by peripheral nerve stimulation. Part I. Observations with transcutaneous stimuli. Surg Neurol. Jul. 1975;4(1):105-14. [pmid: 1080893].
99 Mont MA, Hungerford DS, Caldwell JR, et al. Pulsed electrical stimulation to defer TKA in patients with knee osteoarthritis. Orthopedics. Oct. 2006;29(10):887-92. [pmid: 17061414].
100 Farr J, Mont MA, Garland D, et al. Pulsed electrical stimulation in patients with osteoarthritis of the knee: follow up in 288 patients who had failed non-operative therapy. Surg Technol Int. 2006;15:227-33. [pmid: 17029181].
101 Smith CR, Lewith GT, Machin D. TNS and osteo-arthritic pain. Preliminary study to establish a controlled method of assessing transcutaneous nerve stimulation as a treatment for the pain caused by osteo-arthritis of the knee. Physiotherapy. Aug. 10. 1983;69(8):266-8. [pmid: 6351130].
102 Lewis B, Lewis D, Cumming G. The comparative analgesic efficacy of transcutaneous electrical nerve stimulation and a non-steroidal anti-inflammatory drug for painful osteoarthritis. British Journal of Rheumatology. May. 1994;33(5):455-60. [pmid: 8173850].
103 Fransen M, Margiotta E, Crosbie J, et al. A revised group exercise program for osteoarthritis of the knee. Physiother Res Int. 1997;2(1):30-41. [pmid: 9238749].
104 Lewis D, Lewis B, Sturrock RD. Transcutaneous electrical nerve stimulation in osteoarthrosis: a therapeutic alternative?. Ann Rheum Dis. Feb. 1984;43(1):47-9. [pmid: 6364997].
105 Danao-Camara T, Tabrah FL. The use of pulsed electromagnetic fields (PEMF) in osteoarthritis (OA) of the knee preliminary report. Hawaii medical journal. 2001;60(11):288. [pmid: 11797493].
106 Paul S, Spector T. Pilot study to investigate the efficacy and safety of microcurrect therapy in the short term managment of primary knee osteoarthritis. 2006. 2006 Annual European Congree of Rheumatology (EULAR 2006). Amsterdam (Netherlands (The)). 21–24 Jun 2006.
107 Adler PA. The effects of Tai Chi on pain and funcion in older adults with osteoarthritis: Frances Payne Bolton School of Nursing/Case Western Reserve University. 2007.
108 Lindahl O. Clinical effect of ultrasonic waves in chondromalacic and osteoarthritic changes in the knee. Rheumatism. Apr. 1952;8(2):36-7. [pmid: 14942226].
109 Bukowski EL, Conway A, Glentz LA, et al. The effect of iyengar yoga and strengthening exercises for people living with osteoarthritis of the knee: a case series. Int Q Community Health Educ. 2006;26(3):287-305. [pmid: 17827096].
110 Ramsey DK, Briem K, Axe MJ, et al. A mechanical theory for the effectiveness of bracing for medial compartment osteoarthritis of the knee. J Bone Joint Surg Am. Nov. 2007;89(11):2398-407. [pmid: 17974881].
111 Ravaud P, Giraudeau B, Logeart I, et al. Management of osteoarthritis (OA) with an unsupervised home based exercise programme and/or patient administered assessment tools. A cluster randomised controlled trial with a 2×2 factorial design. Annals of the Rheumatic Diseases. 2004;63(6):703-8. [pmid: 15140778].
112 Hinman RS, Heywood SE, Day AR. Aquatic physical therapy for hip and knee osteoarthritis: results of a single-blind randomized controlled trial. Physical Therapy. 2007;87(1):32-43. [pmid: 17142642].
113 Harlow T, Greaves C, White A, et al. Randomised controlled trial of magnetic bracelets for relieving pain in osteoarthritis of the hip and knee. BMJ. 2004;329(7480):1450-4. [pmid: 15604181].
114 Cochrane T, Davey RC, Matthes Edwards SM. Randomised controlled trial of the cost-effectiveness of water-based therapy for lower limb osteoarthritis. Health Technol Assess. Aug. 2005;9(31):iii-iv. ix. xi. 1. 114. [pmid: 16095546].
115 Pisters MF, Veenhof C, Schellevis FG, et al. Exercise adherence improving long-term patient outcome in patients with osteoarthritis of the hip and/or knee. Arthritis Care & Research. 2010;62(8):1087-94. [pmid: 20235201].
116 Hurley MV, Walsh NE, Mitchell HL, et al. Clinical effectiveness of a rehabilitation program integrating exercise, self-management, and active coping strategies for chronic knee pain: a cluster randomized trial. Arthritis Rheum. Oct. 15. 2007;57(7):1211-9. [pmid: 17907147].
117 Heuts PH, de Bie R, Drietelaar M, et al. Self-management in osteoarthritis of hip or knee: a randomized clinical trial in a primary healthcare setting. J Rheumatol. Mar. 2005;32(3):543-9. [pmid: 15742451].
118 Veenhof C, Koke AJ, Dekker J, et al. Effectiveness of behavioral graded activity in patients with osteoarthritis of the hip and/or knee: A randomized clinical trial. Arthritis Rheum. Dec. 15. 2006;55(6):925-34. [pmid: 17139639].
119 van Baar ME, Dekker J, Oostendorp RA, et al. Effectiveness of exercise in patients with osteoarthritis of hip or knee: nine months’ follow up. Annals of the Rheumatic Diseases. 2001;60(12):1123-30. [pmid: 11709454].
120 Halbert J, Crotty M, Weller D, et al. Primary care-based physical activity programs: effectiveness in sedentary older patients with osteoarthritis symptoms. Arthritis Rheum. Jun. 2001;45(3):228-34. [pmid: 11409662].
121 Hughes SL, Seymour RB, Campbell R, et al. Impact of the fit and strong intervention on older adults with osteoarthritis. Gerontologist. Apr. 2004;44(2):217-28. [pmid: 15075418].
122 Minor MA, Hewett JE, Webel RR, et al. Efficacy of physical conditioning exercise in patients with rheumatoid arthritis and osteoarthritis. Arthritis Rheum. Nov. 1989;32(11):1396-405. [pmid: 2818656].
123 Moffett JA, Richardson PH, Frost H, et al. A placebo controlled double blind trial to evaluate the effectiveness of pulsed short wave therapy for osteoarthritic hip and knee pain. Pain. Sep. 1996;67(1):121-7. [pmid: 8895239].
124 Hopman-Rock M, Westhoff MH. The effects of a health educational and exercise program for older adults with osteoarthritis for the hip or knee. J Rheumatol. Aug. 2000;27(8):1947-54. [pmid: 10955337].
125 Wetzels R, van Weel C, Grol R, et al. Family practice nurses supporting self-management in older patients with mild osteoarthritis: a randomized trial. BMC Family Practice. 2008;9(Journal Article):7. [pmid: 18226255].
126 Trock DH, Bollet AJ, Dyer RH Jr, et al. A double-blind trial of the clinical effects of pulsed electromagnetic fields in osteoarthritis. J Rheumatol. Mar. 1993;20(3):456-60. [pmid: 8478852].
127 Belza B, Topolski T, Kinne S, et al. Does adherence make a difference? Results from a community-based aquatic exercise program. Nursing Research. Sep–Oct. 2002;51(5):285-91. [pmid: 12352776].
128 Song R, Lee EO, Lam P, et al. Effects of a Sun-style Tai Chi exercise on arthritic symptoms, motivation and the performance of health behaviors in women with osteoarthritis. Daehan Ganho Haghoeji. Mar. 2007;37(2):249-56. [pmid: 17435410].
129 Hughes SL, Seymour RB, Campbell RT, et al. Long-term impact of Fit and Strong! on older adults with osteoarthritis. Gerontologist. Dec. 2006;46(6):801-14. [pmid: 17169935].
130 van Baar ME, Dekker J, Oostendorp RA, et al. The effectiveness of exercise therapy in patients with osteoarthritis of the hip or knee: a randomized clinical trial. J Rheumatol. Dec. 1998;25(12):2432-9. [pmid: 9858441].
131 Cadmus L, Patrick MB, Maciejewski ML, et al. Community-based aquatic exercise and quality of life in persons with osteoarthritis. Med Sci Sports Exerc. Jan. 2010;42(1):8-15. [pmid: 20010135].
132 Gill SD, McBurney H, Schulz DL. Land-based versus pool-based exercise for people awaiting joint replacement surgery of the hip or knee: results of a randomized controlled trial. Arch Phys Med Rehabil. 2009;90(3):388-94. [pmid: 19254601].
133 Evcik D, Sonel B. Effectiveness of a home-based exercise therapy and walking program on osteoarthritis of the knee. Rheumatol Int. Jul. 2002;22(3):103-6. [pmid: 12111084].
134 Sen A, Gocen Z, Unver B, et al. The frequency of visits by the physiotherapist of patients receiving home-based exercise therapy for knee osteoarthritis. Knee. Apr. 2004;11(2):151-3. [pmid: 15066630].
135 Jan MH, Lai JS. The effects of physiotherapy on osteoarthritic knees of females. Journal of the Formosan Medical Association. Oct. 1991;90(10):1008-13. [pmid: 1685166].
136 Svarcova J, Trnavsky K, Zvarova J. The influence of ultrasound, galvanic currents and shortwave diathermy on pain intensity in patients with osteoarthritis. Scand J Rheumatol Suppl. 1987;67:83-5. [pmid: 3502576].
137 Hill S, Eckett MJ, Paterson C, et al. A pilot study to evaluate the effects of floatation spa treatment on patients with osteoarthritis. Complementary Therapies in Medicine. Dec. 1999;7(4):235-8. [pmid: 10709308].
138 Hurley MV, Scott DL. Improvements in quadriceps sensorimotor function and disability of patients with knee osteoarthritis following a clinically practicable exercise regime. Br J Rheumatol. Nov. 1998;37(11):1181-7. [pmid: 9851266].
139 Tohyama H, Yasuda K, Kaneda K. Treatment of osteoarthritis of the knee with heel wedges. Int Orthop. 1991;15(1):31-3. [pmid: 2071278].
140 Sasaki T, Yasuda K. Clinical evaluation of the treatment of osteoarthritic knees using a newly designed wedged insole. Clin Orthop Relat Res. Aug. 1987;(221):181-7. [pmid: 3608298].
141 Norton CO, Hoobler K, Welding AB, et al. Effectiveness of aquatic exercise in the treatment of women with osteoarthritis. The Journal of Aquatic Physical Therapy. 1999;5(3):8-15.
142 de Jong ORW, Hopman-Rock M, Tak ECMP, et al. An implementation study of two evidence-based exercise and health education programmes for older adults with osteoarthritis of the knee and hip. Health Education Research. Jun. 2004;19(3):316-25. [pmid: 15140851].
143 Domaille M, Mascarenhas R, Dayal N, et al. Evaluation of the Bristol Royal Infirmary physiotherapy programme for the management of patients with osteoarthritis of the knee. Musculoskeletal Care. Jun. 2006;4(2):78-87. [pmid: 17042019].
144 Coleman S, Briffa K, Conroy H, et al. Short and medium-term effects of an education self-management program for individuals with osteoarthritis of the knee, designed and delivered by health professionals: a quality assurance study. BMC Musculoskeletal Disorders. 2008;9:117. [pmid: 18778467].
145 Fisher NM, Gresham G, Pendergast DR. Effects of a quantitative progressive rehabilitation program applied unilaterally to the osteoarthritic knee. Arch Phys Med Rehabil. Dec. 1993;74(12):1319-26. [pmid: 8259900].
146 Elbaz A, Mor A, Segal G, et al. APOS therapy improves clinical measurements and gait in patients with knee osteoarthritis. Clin Biomech (Bristol, Avon). Nov. 2010;25(9):920-5. [pmid: 20637534].
147 Erhart JC, Mundermann A, Elspas B, et al. A variable-stiffness shoe lowers the knee adduction moment in subjects with symptoms of medial compartment knee osteoarthritis. Journal of Biomechanics. 2008;41(12):2720-5. [pmid: 18675981].
148 Kilicoglu O, Donmez A, Karagulle Z, et al. Effect of balneotherapy on temporospatial gait characteristics of patients with osteoarthritis of the knee. Rheumatol Int. Apr. 2010;30(6):739-47. [pmid: 19588141].
149 King LK, Birmingham TB, Kean CO, et al. Resistance training for medial compartment knee osteoarthritis and malalignment. Medicine & Science in Sports & Exercise. 2008;40(8):1376-84. [pmid: 18614957].
150 Shimada S, Kobayashi S, Wada M, et al. Effects of disease severity on response to lateral wedged shoe insole for medial compartment knee osteoarthritis. Arch Phys Med Rehabil. Nov. 2006;87(11):1436-41. [pmid: 17084116].
151 Huang MH, Chen CH, Chen TW, et al. The effects of weight reduction on the rehabilitation of patients with knee osteoarthritis and obesity. Arthritis Care Res. Dec. 2000;13(6):398-405. [pmid: 14635316].
152 Adedoyin RA, Olaogun MOB, Fagbeja OO. Effect of interferential current stimulation in management of osteo-arthritic knee pain. Physiotherapy. 2005;88(8):493-9.
153 Adedoyin RA, Olaogun MO, Oyeyemi AL. Transcutaneous electrical nerve stimulation and interferential current combined with exercise for the treatment of knee osteoarthritis: a randomised controlled trial. Hong Kong Physiotherapy Journal. 2005;23(Journal Article):13-9.
154 Aglamis B, Toraman NF, Yaman H. The effect of a 12-week supervised multicomponent exercise program on knee OA in Turkish women. Journal of Back and Musculoskeletal Rehabilitation. 2008;21(2):121-8.
155 Akyol Y, Durmus D, Alayli G, et al. Does short-wave diathermy increase the effectiveness of isokinetic exercise on pain, function, knee muscle strength, quality of life, and depression in the patients with knee osteoarthritis? A randomized controlled clinical study. European journal of physical & rehabilitation medicine. Sep. 2010;46(3):325-36. [pmid: 20926998].
156 Alcidi L, Beneforti E, Maresca M, et al. Low power radiofrequency electromagnetic radiation for the treatment of pain due to osteoarthritis of the knee. Reumatismo. Apr–Jun. 2007;59(2):140-5. [pmid: 17603694].
157 An B, Dai K, Zhu Z, et al. Baduanjin alleviates the symptoms of knee osteoarthritis. J Altern Complement Med. Mar. 2008;14(2):167-74. [pmid: 18315512].
158 Aoki O, Tsumura N, Kimura A, et al. Home stretching exercise is effective for improving knee range of motion and gait in patients with knee osteoarthritis. Journal of Physical Therapy Science. 2009;21(2):113-9.
159 Ay S, Evcik D. The effects of pulsed electromagnetic fields in the treatment of knee osteoarthritis: a randomized, placebo-controlled trial. Rheumatol Int. 2009;29(6):663-6. [pmid: 19015858].
160 Baker KR, Nelson ME, Felson DT, et al. The efficacy of home based progressive strength training in older adults with knee osteoarthritis: a randomized controlled trial. J Rheumatol. Jul. 2001;28(7):1655-65. [pmid: 11469475].
161 Balint GP, Buchanan WW, Adam A, et al. The effect of the thermal mineral water of Nagybaracska on patients with knee joint osteoarthritis--a double blind study. Clin Rheumatol. Jun. 2007;26(6):890-4. [pmid: 17089219].
162 Bansil CK, Joshi JB. Effectiveness of shortwave diathermy and ultrasound in the treatment of osteo-arthritis of the knee joint. Med J Zambia. Oct–Nov. 1975;9(5):138-9. [pmid: 1224784].
163 Bar-Ziv Y, Beer Y, Ran Y, et al. A treatment applying a biomechanical device to the feet of patients with knee osteoarthritis results in reduced pain and improved function: a prospective controlled study. BMC Musculoskelet Disord. 2010;11:179. [pmid: 20698991].
164 Battisti E, Piazza E, Rigato M, et al. Efficacy and safety of a musically modulated electromagnetic field (TAMMEF) in patients affected by knee osteoarthritis. Clinical & Experimental Rheumatology. 2004;22(5):568-72. [pmid: 15485009].
165 Bautch JC, Malone DG, Vailas AC. Effects of exercise on knee joints with osteoarthritis: a pilot study of biologic markers. Arthritis Care Res. Feb. 1997;10(1):48-55. [pmid: 9313390].
166 Bennell KL, Bowles KA, Payne C, et al. Lateral wedge insoles for medial knee osteoarthritis: 12 month randomised controlled trial. BMJ. 2011;342:d2912. [pmid: 21593096].
167 Bennell KL, Hunt MA, Wrigley TV, et al. Hip strengthening reduces symptoms but not knee load in people with medial knee osteoarthritis and varus malalignment: a randomised controlled trial. Osteoarthritis Cartilage. May. 2010;18(5):621-8. Epub 2010 Feb 6.(5):621–8. [pmid: 20175973].
168 Bennell KL, Hinman RS, Metcalf BR, et al. Efficacy of physiotherapy management of knee joint osteoarthritis: a randomised, double blind, placebo controlled trial. Annals of the Rheumatic Diseases. 2005;64(6):906-12. [pmid: 15897310].
169 Bezalel T, Carmeli E, Katz-Leurer M. The effect of a group education programme on pain and function through knowledge acquisition and home-based exercise among patients with knee osteoarthritis: a parallel randomised single-blind clinical trial. Physiotherapy. Jun. 2010;96(2):137-43. [pmid: 20420960].
170 Borjesson M, Robertson E, Weidenhielm L, et al. Physiotherapy in knee osteoarthrosis: effect on pain and walking. Physiother Res Int. 1996;1(2):89-97. [pmid: 9238726].
171 Brismee JM, Paige RL, Chyu MC, et al. Group and home-based tai chi in elderly subjects with knee osteoarthritis: a randomized controlled trial. Clin Rehabil. Feb. 2007;21(2):99-111. [pmid: 17264104].
172 Brouwer RW, van Raaij TM, Verhaar JA, et al. Brace treatment for osteoarthritis of the knee: a prospective randomized multi-centre trial. Osteoarthritis & Cartilage. 2006;14(8):777-83. [pmid: 16563810].
173 Bryk FF, Jesus JF, Fukuda TY, et al. Immediate effect of the elastic knee sleeve use on individuals with osteoarthritis. Rev Bras Reumatol. Nov. 2011;51(5):440-6. [pmid: 21952996].
174 Burch FX, Tarro JN, Greenberg JJ, et al. Evaluating the benefits of patterned stimulation in the treatment of osteoarthritis of the knee: a multi-center, randomized, single-blind, controlled study with an independent masked evaluator. Osteoarthritis Cartilage. Aug. 2008;16(8):865-72. [pmid: 18262443].
175 Callaghan MJ, Whittaker PE, Grimes S, et al. An evaluation of pulsed shortwave on knee osteoarthritis using radioleucoscintigraphy: a randomised, double blind, controlled trial. Joint Bone Spine. Mar. 2005;72(2):150-5. [pmid: 15797496].
176 Callaghan MJ, Oldham JA. An evaluation of exercise regimes for patients with osteoarthritis of the knee: a single-blind randomized controlled trial. Clin Rehabil. 1995;9:213-8.
177 Cantarini L, Leo G, Giannitti C, et al. Therapeutic effect of spa therapy and short wave therapy in knee osteoarthritis: a randomized, single blind, controlled trial. Rheumatol Int. Apr. 2007;27(6):523-9. [pmid: 17106661].
178 Cetin N, Aytar A, Atalay A, et al. Comparing hot pack, short-wave diathermy, ultrasound, and TENS on isokinetic strength, pain, and functional status of women with osteoarthritic knees: a single-blind, randomized, controlled trial. Am J Phys Med Rehabil. 2008;87(6):443-51. [pmid: 18496246].
179 Chaipinyo K, Karoonsupcharoen O. No difference between home-based strength training and home-based balance training on pain in patients with knee osteoarthritis: a randomised trial. Aust J Physiother. 2009;55(1):25-30. [pmid: 19226239].
180 Chamberlain MA, Care G, Harfield B. Physiotherapy in osteoarthrosis of the knees. A controlled trial of hospital versus home exercises. Int Rehabil Med. 1982;4(2):101-6. [pmid: 7174213].
181 Cheing GL, Hui-Chan CW, Chan KM. Does four weeks of TENS and/or isometric exercise produce cumulative reduction of osteoarthritic knee pain?. Pain Reviews. 2002;9(3–4):141-51.
182 Cheing GL, Hui-Chan CW. Would the addition of TENS to exercise training produce better physical performance outcomes in people with knee osteoarthritis than either intervention alone?. Clin Rehabil. Aug. 2004;18(5):487-97. [pmid: 15293483].
183 Cheing GL, Tsui AY, Lo SK, et al. Optimal stimulation duration of tens in the management of osteoarthritic knee pain. J Rehabil Med. Mar. 2003;35(2):62-8. [pmid: 12691335].
184 Chen CY, Fu TC, Hu CF, et al. Influence of magnetic knee wraps on joint proprioception in individuals with osteoarthritis: a randomized controlled pilot trial. Clin Rehabil. Mar. 2011;25(3):228-37. [pmid: 20980352].
185 Chuang S-H, Huang M-H, Chen T-W, et al. Effect of knee sleeve on static and dynamic balance in patients with knee osteoarthritis. Kaohsiung Journal of Medical Sciences. Aug. 2007;23(8):405-11. [pmid: 17666307].
186 Cushnaghan J, McCarthy C, Dieppe P. Taping the patella medially: a new treatment for osteoarthritis of the knee joint?. BMJ. Mar. 19. 1994;308(6931):753-5. [pmid: 8142829].
187 Defrin R, Ariel E, Peretz C. Segmental noxious versus innocuous electrical stimulation for chronic pain relief and the effect of fading sensation during treatment. Pain. May. 2005;115(1–2):152-60. [pmid: 15836978].
188 Denegar CR, Dougherty DR, Friedman JE, et al. Preferences for heat, cold, or contrast in patients with knee osteoarthritis affect treatment response. Clin Interv Aging. 2010;5:199-206. [pmid: 20711439].
189 Deyle GD, Henderson NE, Matekel RL, et al. Effectiveness of manual physical therapy and exercise in osteoarthritis of the knee. A randomized, controlled trial. Annals of Internal Medicine. 2000;132(3):173-81. [pmid: 10651597].
190 Deyle GD, Allison SC, Matekel RL, et al. Physical therapy treatment effectiveness for osteoarthritis of the knee: a randomized comparison of supervised clinical exercise and manual therapy procedures versus a home exercise program. Physical Therapy. 2005;85(12):1301-17. [pmid: 16305269].
191 Diracoglu D, Aydin R, Baskent A, et al. Effects of kinesthesia and balance exercises in knee osteoarthritis. JCR: Journal of Clinical Rheumatology. 2005;11(6):303-10. [pmid: 16371799].
192 Doi T, Akai M, Fujino K, et al. Effect of home exercise of quadriceps on knee osteoarthritis compared with nonsteroidal antiinflammatory drugs: a randomized controlled trial. Am J Phys Med Rehabil. 2008;87(4):258-69. [pmid: 18356618].
193 Durmus D, Alayli G, Canturk F. Effects of quadriceps electrical stimulation program on clinical parameters in the patients with knee osteoarthritis. Clin Rheumatol. May. 2007;26(5):674-8. [pmid: 16897119].
194 Erhart JC, Mundermann A, Elspas B, et al. Changes in knee adduction moment, pain, and functionality with a variable-stiffness walking shoe after 6 months. Journal of Orthopaedic Research. Jul. 2010;28(7):873-9. [pmid: 20058261].
195 Ettinger WH Jr, Burns R, Messier SP, et al. A randomized trial comparing aerobic exercise and resistance exercise with a health education program in older adults with knee osteoarthritis. The Fitness Arthritis and Seniors Trial (FAST). Journal - American Medical Association. 1997;277(1):25-31. [pmid: 8980206].
196 Eyigor S, Hepguler S, Capaci K. A comparison of muscle training methods in patients with knee osteoarthritis. Clin Rheumatol. Apr. 2004;23(2):109-15. [pmid: 15045623].
197 Falconer J, Hayes KW, Chang RW. Effect of ultrasound on mobility in osteoarthritis of the knee. A randomized clinical trial. Arthritis Care Res. Mar. 1992;5(1):29-35. [pmid: 1581369].
198 Fargas-Babjak A, Rooney P, Gerecz E. Randomized trial of Codetron for pain control in osteoarthritis of the hip/knee. Clin J Pain. Jun. 1989;5(2):137-41. [pmid: 2520394].
199 Fary RE, Carroll GJ, Briffa TG, et al. The effectiveness of pulsed electrical stimulation in the management of osteoarthritis of the knee: results of a double-blind, randomized, placebo-controlled, repeated-measures trial. Arthritis Rheum. May. 2011;63(5):1333-42. [pmid: 21312188].
200 Fioravanti A, Iacoponi F, Bellisai B, et al. Short- and long-term effects of spa therapy in knee osteoarthritis. American Journal of Physical Medicine & Rehabilitation. 2010;89(2):125-32. [pmid: 19884812].
201 Fitzgerald GK, Piva SR, Gil AB, et al. Agility and perturbation training techniques in exercise therapy for reducing pain and improving function in people with knee osteoarthritis: a randomized clinical trial. Phys Ther. Apr. 2011;91(4):452-69. [pmid: 21330451].
202 Forestier R, Desfour H, Tessier JM, et al. Spa therapy in the treatment of knee osteoarthritis: a large randomised multicentre trial. Ann Rheum Dis. Apr. 2010;69(4):660-5. [pmid: 19734131].
203 Foroughi N, Smith RM, Lange AK, et al. Lower limb muscle strengthening does not change frontal plane moments in women with knee osteoarthritis: A randomized controlled trial. Clin Biomech (Bristol, Avon). Feb. 2011;26(2):167-74. [pmid: 20888096].
204 Fransen M, Crosbie J, Edmonds J. Physical therapy is effective for patients with osteoarthritis of the knee: a randomized controlled clinical trial. J Rheumatol. Jan. 2001;28(1):156-64. [pmid: 11196518].
205 Fukuda TY, Alves da Cunha R, Fukuda VO, et al. Pulsed shortwave treatment in women with knee osteoarthritis: a multicenter, randomized, placebo-controlled clinical trial. Phys Ther. Jul. 2011;91(7):1009-17. [pmid: 21642511].
206 Gaines JM, Metter EJ, Talbot LA. The effect of neuromuscular electrical stimulation on arthritis knee pain in older adults with osteoarthritis of the knee. Appl Nurs Res. Aug. 2004;17(3):201-6. [pmid: 15343554].
207 Garland D, Holt P, Harrington JT, et al. A 3-month, randomized, double-blind, placebo-controlled study to evaluate the safety and efficacy of a highly optimized, capacitively coupled, pulsed electrical stimulator in patients with osteoarthritis of the knee. Osteoarthritis Cartilage. Jun. 2007;15(6):630-7. [pmid: 17303443].
208 Giombini A, Di Cesare A, Di Cesare M, et al. Localized hyperthermia induced by microwave diathermy in osteoarthritis of the knee: a randomized placebo-controlled double-blind clinical trial. Knee Surgery, Sports Traumatology, Arthroscopy. Jun. 2011;19(6):980-7. [pmid: 21161171].
209 Gordon A, Merenstein JH, D’Amico F, et al. The effects of therapeutic touch on patients with osteoarthritis of the knee. Journal of Family Practice. 1998;47(4):271-7. [pmid: 9789512].
210 Gremion G, Gaillard D, Leyvraz PF, et al. Effect of biomagnetic therapy versus physiotherapy for treatment of knee osteoarthritis: a randomized controlled trial. J Rehabil Med. 2009;41(13):1090-5. 1090. [pmid: 19894007].
211 Grimmer K. A controlled double blind study comparing the effects of strong burst mode TENS and high rate TENS on painful osteoarthritic knees. Australian Journal of Physiotherapy. 1992;38(1):49-56.
212 Gür H, Cakin N, Akova B, et al. Concentric versus combined concentric-eccentric isokinetic training: effects on functional capacity and symptoms in patients with osteoarthrosis of the knee. Arch Phys Med Rehabil. Mar. 2002;83(3):308-16. [pmid: 11887109].
213 Hassan BS, Mockett S, Doherty M. Influence of elastic bandage on knee pain, proprioception, and postural sway in subjects with knee osteoarthritis. Annals of the Rheumatic Diseases. 2002;61(1):24-8. [pmid: 11779753].
214 Hay EM, Foster NE, Thomas E, et al. Effectiveness of community physiotherapy and enhanced pharmacy review for knee pain in people aged over 55 presenting to primary care: pragmatic randomised trial. BMJ. Nov. 11. 2006;333(7576):995. [pmid: 17056608].
215 Hinman RS, Crossley KM, McConnell J, et al. Efficacy of knee tape in the management of osteoarthritis of the knee: blinded randomised controlled trial. BMJ. 2003;327(7407):135. [pmid: 12869456].
216 Hinman RS, Payne C, Metcalf BR, et al. Lateral wedges in knee osteoarthritis: what are their immediate clinical and biomechanical effects and can these predict a three-month clinical outcome? Arthritis &. Rheumatism. 2008;59(3):408-15. [pmid: 18311763].
217 Hinman MR, Ford J, Heyl H. Effects of static magnets on chronic knee pain and physical function: a double-blind study. Altern Ther Health Med. Jul–Aug. 2002;8(4):50-5. [pmid: 12126173].
218 Hinman RS, Bowles KA, Bennell KL. Laterally wedged insoles in knee osteoarthritis: do biomechanical effects decline after one month of wear? BMC Musculoskelet. Disord. 146. 2009;10:146. [pmid: 19939281].
219 Hinman RS, Bennell KL, Crossley KM, et al. Immediate effects of adhesive tape on pain and disability in individuals with knee osteoarthritis. Rheumatology. 2003;42(7):865-9. [pmid: 12730546].
220 Horlick SG, Loomer RL. Valgus knee bracing for medial gonarthrosis. Clinical Journal of Sport Medicine. 1993;3(4):251-5.
221 Huang MH, Lin YS, Yang RC, et al. A comparison of various therapeutic exercises on the functional status of patients with knee osteoarthritis. Semin Arthritis Rheum. Jun. 2003;32(6):398-406. [pmid: 12833248].
222 Huang MH, Lin YS, Lee CL, et al. Use of ultrasound to increase effectiveness of isokinetic exercise for knee osteoarthritis. Arch Phys Med Rehabil. Aug. 2005;86(8):1545-51. [pmid: 16084806].
223 Huang MH, Yang RC, Lee CL, et al. Preliminary results of integrated therapy for patients with knee osteoarthritis. Arthritis Rheum. Dec. 15. 2005;53(6):812-20. [pmid: 16342083].
224 Itoh K, Hirota S, Katsumi Y, et al. A pilot study on using acupuncture and transcutaneous electrical nerve stimulation (TENS) to treat knee osteoarthritis (OA). Chin Med. 2008;3:2. [pmid: 18312661].
225 Jacobson JI, Gorman R, Yamanashi WS, et al. Low-amplitude, extremely low frequency magnetic fields for the treatment of osteoarthritic knees: a double-blind clinical study. Alternative Therapies in Health & Medicine. 2001;7(5):54-64. [pmid: 11565402].
226 Jan MH, Lin CH, Lin YF, et al. Effects of weight-bearing versus nonweight-bearing exercise on function, walking speed, and position sense in participants with knee osteoarthritis: a randomized controlled trial. Arch Phys Med Rehabil. 2009;90(6):897-904. [pmid: 19480863].
227 Jan MH, Lin JJ, Liau JJ, et al. Investigation of clinical effects of high- and low-resistance training for patients with knee osteoarthritis: a randomized controlled trial. Phys Ther. 2008;88(4):427-36. [pmid: 18218827].
228 Jan MH, Tang PF, Lin JJ, et al. Efficacy of a target-matching foot-stepping exercise on proprioception and function in patients with knee osteoarthritis. J Orthop Sports Phys Ther. Jan. 2008;38(1):19-25. [pmid: 18357655].
229 Jensen H, Zesler R, Christensen T. Transcutaneous electrical nerve stimulation (TNS) for painful osteoarthrosis of the knee. Int J Rehabil Res. 1991;14(4):356-8. [pmid: 1783484].
230 Jessep SA, Walsh NE, Ratcliffe J, et al. Long-term clinical benefits and costs of an integrated rehabilitation programme compared with outpatient physiotherapy for chronic knee pain. Physiotherapy. Jun. 2009;95(2):94-102. [pmid: 19627690].
231 Kang RW, Lewis PB, Kramer A, et al. Prospective randomized single-blinded controlled clinical trial of percutaneous neuromodulation pain therapy device versus sham for the osteoarthritic knee: a pilot study. Orthopedics. Jun. 2007;30(6):439-45. [pmid: 17598487].
232 Karagulle M, Karagulle MZ, Karagulle O, et al. A 10-day course of SPA therapy is beneficial for people with severe knee osteoarthritis. A 24-week randomised, controlled pilot study. Clin Rheumatol. Dec. 2007;26(12):2063-71. [pmid: 17431728].
233 Keefe FJ, Blumenthal J, Baucom D, et al. Effects of spouse-assisted coping skills training and exercise training in patients with osteoarthritic knee pain: a randomized controlled study. Pain. Aug. 2004;110(3):539-49. [pmid: 15288394].
234 Kerrigan DC, Lelas JL, Goggins J, et al. Effectiveness of a lateral-wedge insole on knee varus torque in patients with knee osteoarthritis. Archives of Physical Medicine and Rehabilitation. 2002;83(7):889-93. [pmid: 12098144].
235 Kitay GS, Koren MJ, Helfet DL, et al. Efficacy of combined local mechanical vibrations, continuous passive motion and thermotherapy in the management of osteoarthritis of the knee. Osteoarthritis Cartilage. 2009;17(10):1269-74. [pmid: 19433134].
236 Ko T, Lee S, Lee D. Manual therapy and exercise for OA knee: Effects on muscle strength, proprioception, and functional performance. Journal of Physical Therapy Science. 2009;21(4):293-9.
237 Kovacs I, Bender T. The therapeutic effects of Cserkeszolo thermal water in osteoarthritis of the knee: a double blind, controlled, follow-up study. Rheumatol Int. Apr. 2002;21(6):218-21. [pmid: 12036207].
238 Kovar PA, Allegrante JP, MacKenzie CR, et al. Supervised fitness walking in patients with osteoarthritis of the knee. A randomized, controlled trial. Annals of Internal Medicine. Apr. 1. 1992;116(7):529-34. [pmid: 1543305].
239 Kreindler H, Lewis CB, Rush S, et al. Effects of three exercise protocols on strength of persons with osteoarthritis of the knee. Top Geriatr Rehabil. 1989;4:32-9.
240 Kuptniratsaikul V, Tosayanonda O, Nilganuwong S, et al. The efficacy of a muscle exercise program to improve functional performance of the knee in patients with osteoarthritis. J Med Assoc Thai. Jan. 2002;85(1):33-40. [pmid: 12075718].
241 Kuroyanagi Y, Nagura T, Matsumoto H, et al. The lateral wedged insole with subtalar strapping significantly reduces dynamic knee load in the medial compartment gait analysis on patients with medial knee osteoarthritis. Osteoarthritis & Cartilage. Aug. 2007;15(8):932-6. [pmid: 17391994].
242 Laufer Y, Zilberman R, Porat R, et al. Effect of pulsed short-wave diathermy on pain and function of subjects with osteoarthritis of the knee: a placebo-controlled double-blind clinical trial. Clin Rehabil. May. 2005;19(3):255-63. [pmid: 15859526].
243 Law PP, Cheing GL. Optimal stimulation frequency of transcutaneous electrical nerve stimulation on people with knee osteoarthritis. J Rehabil Med. Sep. 2004;36(5):220-5. [pmid: 15626162].
244 Law PP, Cheing GL, Tsui AY. Does transcutaneous electrical nerve stimulation improve the physical performance of people with knee osteoarthritis?. J Clin Rheumatol. Dec. 2004;10(6):295-9. [pmid: 17043536].
245 Lee HJ, Park HJ, Chae Y, et al. Tai Chi Qigong for the quality of life of patients with knee osteoarthritis: a pilot, randomized, waiting list controlled trial. Clin Rehabil. 2009;23(6):504-11. [pmid: 19389743].
246 Lim BW. A comparative study of open and closed kinetic chain exercise regimes in patients with knee osteoarthritis. Physiotherapy Singapore. 2002;5(2):34-40.
247 Lin DH, Lin CH, Lin YF, et al. Efficacy of 2 non-weight-bearing interventions, proprioception training versus strength training, for patients with knee osteoarthritis: a randomized clinical trial. J Orthop Sports Phys Ther. 2009;39(6):450-7. [pmid: 19531879].
248 Lin DH, Lin YF, Chai HM, et al. Comparison of proprioceptive functions between computerized proprioception facilitation exercise and closed kinetic chain exercise in patients with knee osteoarthritis. Clin Rheumatol. Apr. 2007;26(4):520-8. [pmid: 16786252].
249 Loyola-Sánchez A, Richardson J, Beattie KA, et al. Effect of low-intensity pulsed ultrasound on the cartilage repair in people with mild to moderate knee osteoarthritis: a double-blinded, randomized, placebo-controlled pilot study. Arch Phys Med Rehabil. Jan. 2012;93(1):35-42. [pmid: 22200383].
250 Lund H, Weile U, Christensen R, et al. A randomized controlled trial of aquatic and land-based exercise in patients with knee osteoarthritis. J Rehabil Med. Feb. 2008;40(2):137-44. [pmid: 18509579].
251 Lund H, Henriksen M, Bartels EM, et al. Can stimulating massage improve joint repositioning error in patients with knee osteoarthritis?. J Geriatr Phys Ther. 2009;32(3):111-6. [pmid: 20128335].
252 Maillefert JF, Hudry C, Baron G, et al. Laterally elevated wedged insoles in the treatment of medial knee osteoarthritis: a prospective randomized controlled study. Osteoarthritis and Cartilage. 2001;9(8):738-45. [pmid: 11795993].
253 Maly M, Culham E, Costigan P. Static and dynamic biomechanics of foot orthoses in people with medial compartment knee osteoarthritis. Clinical Biomechanics. 2002;17(8):603-10. [pmid: 12243720].
254 Mangani I, Cesari M, Kritchevsky SB, et al. Physical exercise and comorbidity. Results from the Fitness and Arthritis in Seniors Trial (FAST). Aging Clin Exp Res. Oct. 2006;18(5):374-80. [pmid: 17167301].
255 Mangione KK, McCully K, Gloviak A, et al. The effects of high-intensity and low-intensity cycle ergometry in older adults with knee osteoarthritis. J Gerontol A Biol Sci Med Sci. Apr. 1999;54(4):M184-90. [pmid: 10219009].
256 Maurer BT, Stern AG, Kinossian B, et al. Osteoarthritis of the knee: isokinetic quadriceps exercise versus an educational intervention. Arch Phys Med Rehabil. Oct. 1999;80(10):1293-9. [pmid: 10527090].
257 Mazzuca SA, Page MC, Meldrum RD, et al. Pilot study of the effects of a heat-retaining knee sleeve on joint pain, stiffness, and function in patients with knee osteoarthritis. Arthritis Rheum. Oct. 15. 2004;51(5):716-21. [pmid: 15478166].
258 McCarthy CJ, Mills PM, Pullen R, et al. Supplementation of a home-based exercise programme with a class-based programme for people with osteoarthritis of the knees: a randomised controlled trial and health economic analysis. Health Technol Assess. Nov. 2004;8(46):iii-iv. 1. 61. [pmid: 15527668].
259 Mikesky AE, Mazzuca SA, Brandt KD, et al. Effects of strength training on the incidence and progression of knee osteoarthritis. Arthritis Rheum. Oct. 15. 2006;55(5):690-9. [pmid: 17013851].
260 Moss P, Sluka K, Wright A. The initial effects of knee joint mobilization on osteoarthritic hyperalgesia. Man Ther. May. 2007;12(2):109-18. [pmid: 16777467].
261 Ng MM, Leung MC, Poon DM. The effects of electro-acupuncture and transcutaneous electrical nerve stimulation on patients with painful osteoarthritic knees: a randomized controlled trial with follow-up evaluation. J Altern Complement Med. Oct. 2003;9(5):641-9. [pmid: 14629842].
262 Nguyen M, Revel M, Dougados M. Prolonged effects of 3 week therapy in a spa resort on lumbar spine, knee and hip osteoarthritis: follow-up after 6 months. A randomized controlled trial. British Journal of Rheumatology. Jan. 1997;36(1):77-81. [pmid: 9117181].
263 Ni GX, Song L, Yu B, et al. Tai chi improves physical function in older Chinese women with knee osteoarthritis. J Clin Rheumatol. 2010;16(2):64-7. [pmid: 20130482].
264 Nicolakis P, Kollmitzer J, Crevenna R, et al. Pulsed magnetic field therapy for osteoarthritis of the knee--a double-blind sham-controlled trial. Wiener klinische. Wochenschrift. 2002;114(15–16):678-84. [pmid: 12602111].
265 Nigg BM, Emery C, Hiemstra LA. Unstable shoe construction and reduction of pain in osteoarthritis patients. Medicine & Science in Sports & Exercise. 2006;38(10):1701-8. [pmid: 17019290].
266 Odabasi E, Turan M, Erdem H, et al. Does mud pack treatment have any chemical effect? A randomized controlled clinical study. J Altern Complement Med. Jun. 2008;14(5):559-65. [pmid: 18564957].
267 Oldham JA, Howe T, Petterson T, et al. Electrotherapeutic rehabilitation of the quadriceps in elderly osteoarthritic patients: a double blind assessment of patterned neuromuscular stimulation. Clin Rehabil. Feb. 1995;9(1):10-20.
268 O’Reilly SC, Muir KR, Doherty M. Effectiveness of home exercise on pain and disability from osteoarthritis of the knee: a randomised controlled trial. Annals of the Rheumatic Diseases. 1999;58(1):15-9. [pmid: 10343535].
269 Ozdincler AR, Yeldan I, Kinali P. The effects of closed kinetic chain exercise on pain and functional performance of patients with knee osteoarthritis. The Pain Clinic. 2005;1:107-15.
270 Özgönenel L, Aytekin E, Durmusoglu G. A double-blind trial of clinical effects of therapeutic ultrasound in knee osteoarthritis. Ultrasound Med Biol. Jan. 2009;35(1):44-9. [pmid: 18829151].
271 Ozgüçlü E, Cetin A, Cetin M, et al. Additional effect of pulsed electromagnetic field therapy on knee osteoarthritis treatment: a randomized, placebo-controlled study. Clin Rheumatol. Aug. 2010;29(8):927-31. [pmid: 20473540].
272 Pajareya K, Chadchavalpanichaya N, Timdang S. Effectiveness of an elastic knee sleeve for patients with knee osteoarthritis: a randomized single-blinded controlled trial. Journal of the Medical Association of Thailand. 2003;86(6):535-42. [pmid: 12924802].
273 Patrick DL, Ramsey SD, Spencer AC, et al. Economic evaluation of aquatic exercise for persons with osteoarthritis. Med Care. May. 2001;39(5):413-24. [pmid: 11317090].
274 Péloquin L, Bravo G, Gauthier P, et al. Effects of a Cross-Training Exercise Program in Persons with Osteoarthritis of the Knee A Randomized Controlled Trial. J Clin Rheumatol. Jun. 1999;5(3):126-36. [pmid: 19078371].
275 Petrella RJ, Bartha C. Home based exercise therapy for older patients with knee osteoarthritis: a randomized clinical trial. J Rheumatol. Sep. 2000;27(9):2215-21. [pmid: 10990236].
276 Pietrosimone BG, Hart JM, Saliba SA, et al. Immediate effects of transcutaneous electrical nerve stimulation and focal knee joint cooling on quadriceps activation. Med Sci Sports Exerc. Jun. 2009;41(6):1175-81. [pmid: 19461552].
277 Pietrosimone BG, Saliba SA, Hart JM, et al. Effects of disinhibitory transcutaneous electrical nerve stimulation and therapeutic exercise on sagittal plane peak knee kinematics and kinetics in people with knee osteoarthritis during gait: a randomized controlled trial. Clin Rehabil. Dec. 2010;24(12):1091-101. [pmid: 20713439].
278 Pipitone N, Scott DL. Magnetic pulse treatment for knee osteoarthritis: a randomised, double-blind, placebo-controlled study. Current Medical Research & Opinion. 2001;17(3):190-6. [pmid: 11900312].
279 Pollard H, Ward G, Hoskins W, et al. The effect of a manual therapy knee protocol on osteoarthritic knee pain: a randomised controlled trial. J Can Chiropr Assoc. Dec. 2008;52(4):229-42. [pmid: 19066697].
280 Rejeski WJ, Focht BC, Messier SP, et al. Obese, older adults with knee osteoarthritis: weight loss, exercise, and quality of life. Health Psychology. 2002;21(5):419-26. [pmid: 12211508].
281 Richards JD, Sanchez-Ballester J, Jones RK, et al. A comparison of knee braces during walking for the treatment of osteoarthritis of the medial compartment of the knee. Journal of Bone & Joint Surgery - British Volume. 2005;87(7):937-9. [pmid: 15972906].
282 Rogind H, Bibow-Nielsen B, Jensen B, et al. The effects of a physical training program on patients with osteoarthritis of the knees. Arch Phys Med Rehabil. Nov. 1998;79(11):1421-7. [pmid: 9821904].
283 Rooks DS, Huang J, Bierbaum BE, et al. Effect of preoperative exercise on measures of functional status in men and women undergoing total hip and knee arthroplasty. Arthritis Rheum. Oct. 15. 2006;55(5):700-8. [pmid: 17013852].
284 Sayers SP, Gibson K, Cook CR. Effect of high-speed power training on muscle performance, function, and pain in older adults with knee osteoarthritis: a pilot investigation. Arthritis Care Res (Hoboken). Jan. 2012;64(1):46-53. [pmid: 22012877].
285 Schilke JM, Johnson GO, Housh TJ, et al. Effects of muscle-strength training on the functional status of patients with osteoarthritis of the knee joint. Nursing Research. Mar–Apr. 1996;45(2):68-72. [pmid: 8604366].
286 Segal NA, Foster NA, Dhamani S, et al. Effects of concurrent use of an ankle support with a laterally wedged insole for medial knee osteoarthritis. PMR. 2009;1(3):214-22. [pmid: 19627897].
287 Selfe TK, Bourguignon C, Taylor AG. Effects of noninvasive interactive neurostimulation on symptoms of osteoarthritis of the knee: a randomized, sham-controlled pilot study. J Altern Complement Med. 2008;14(9):1075-81. [pmid: 19055333].
288 Shakoor MA, Taslim MA, Hossain MS. Effects of activity modification on the patients with osteoarthritis of the knee. Bangladesh Med Res Counc Bull. Aug. 2007;33(2):55-9. [pmid: 18481439].
289 Sherman G, Zeller L, Avriel A, et al. Intermittent balneotherapy at the Dead Sea area for patients with knee osteoarthritis. Isr Med Assoc J. 2009;11(2):88-93. [pmid: 19432036].
290 Silva LE, Valim V, Pessanha AP, et al. Hydrotherapy versus conventional land-based exercise for the management of patients with osteoarthritis of the knee: a randomized clinical trial. Physical Therapy. 2008;88(1):12-21. [pmid: 17986497].
291 Song R, Lee EO, Lam P, et al. Effects of tai chi exercise on pain, balance, muscle strength, and perceived difficulties in physical functioning in older women with osteoarthritis: a randomized clinical trial. J Rheumatol. Sep. 2003;30(9):2039-44. [pmid: 12966613].
292 Song R, Roberts BL, Lee EO, et al. A randomized study of the effects of t’ai chi on muscle strength, bone mineral density, and fear of falling in women with osteoarthritis. Journal of Alternative & Complementary Medicine. Mar. 2010;16(3):227-33. [pmid: 20192907].
293 Swank AM, Kachelman JB, Bibeau W, et al. Prehabilitation before total knee arthroplasty increases strength and function in older adults with severe osteoarthritis. Journal of Strength & Conditioning Research. Feb. 2011;25(2):318-25. [pmid: 21217530].
294 Talbot LA, Gaines JM, Huynh TN, et al. A home-based pedometer-driven walking program to increase physical activity in older adults with osteoarthritis of the knee: a preliminary study. J Am Geriatr Soc. Mar. 2003;51(3):387-92. [pmid: 12588583].
295 Talbot LA, Gaines JM, Ling SM, et al. A home-based protocol of electrical muscle stimulation for quadriceps muscle strength in older adults with osteoarthritis of the knee. J Rheumatol. Jul. 2003;30(7):1571-8. [pmid: 12858461].
296 Tascioglu F, Kuzgun S, Armagan O, et al. Short-term effectiveness of ultrasound therapy in knee osteoarthritis. Journal of International Medical Research. Jul–Aug. 2010;38(4):1233-42. [pmid: 20925995].
297 Taylor P, Hallett M, Flaherty L. Treatment of osteoarthritis of the knee with transcutaneous electrical nerve stimulation. Pain. Oct. 1981;11(2):233-40. [pmid: 7033891].
298 Thamsborg G, Florescu A, Oturai P, et al. Treatment of knee osteoarthritis with pulsed electromagnetic fields: a randomized, double-blind, placebo-controlled study. Osteoarthritis & Cartilage. 2005;13(7):575-81. [pmid: 15979009].
299 Thomas KS, Muir KR, Doherty M, et al. Home based exercise programme for knee pain and knee osteoarthritis: randomised controlled trial. British medical journal. 2002;325(7367):752-5. [pmid: 12364304].
300 Thorstensson CA, Roos EM, Petersson IF, et al. Six-week high-intensity exercise program for middle-aged patients with knee osteoarthritis: a randomized controlled trial. [ISRCTN20244858]. BMC Musculoskeletal Disorders. 2005;6(Journal Article):27. [pmid: 15924620].
301 Tishler M, Rosenberg O, Levy O, et al. The effect of balneotherapy on osteoarthritis. Is an intermittent regimen effective? Eur J Intern Med. Apr. 2004;15(2):93-6. [pmid: 15172023].
302 Toda Y, Tsukimura N, Kato A. The effects of different elevations of laterally wedged insoles with subtalar strapping on medial compartment osteoarthritis of the knee. Archives of Physical Medicine & Rehabilitation. 2004;85(4):673-7. [pmid: 15083446].
303 Toda Y, Tsukimura N, Segal N. An optimal duration of daily wear for an insole with subtalar strapping in patients with varus deformity osteoarthritis of the knee. Osteoarthritis & Cartilage. 2005;13(4):353-60. [pmid: 15780649].
304 Toda Y, Segal N, Kato A, et al. Effect of a novel insole on the subtalar joint of patients with medial compartment osteoarthritis of the knee. Journal of Rheumatology. 2001;28(12):2705-10. [pmid: 11764221].
305 Toda Y, Tsukimura N. Influence of concomitant heeled footwear when wearing a lateral wedged insole for medial compartment osteoarthritis of the knee. Osteoarthritis and Cartilage. 2008;16(2):244-53. [pmid: 17693101].
306 Toda Y, Segal N. Usefulness of an insole with subtalar strapping for analgesia in patients with medial compartment osteoarthritis of the knee. Arthritis & Rheumatism. 2002;47(5):468-73. [pmid: 12382293].
307 Toda Y, Tsukimura N. A six-month followup of a randomized trial comparing the efficacy of a lateral-wedge insole with subtalar strapping and an in-shoe lateral-wedge insole in patients with varus deformity osteoarthritis of the knee. Arthritis & Rheumatism. 2004;50(10):3129-36. [pmid: 15476225].
308 Toda Y, Tsukimura N. A 2-year follow-up of a study to compare the efficacy of lateral wedged insoles with subtalar strapping and in-shoe lateral wedged insoles in patients with varus deformity osteoarthritis of the knee. Osteoarthritis & Cartilage. Mar. 2006;14(3):231-7. [pmid: 16271485].
309 Tok F, Aydemir K, Peker F, et al. The effects of electrical stimulation combined with continuous passive motion versus isometric exercise on symptoms, functional capacity, quality of life and balance in knee osteoarthritis: randomized clinical trial. Rheumatol Int. 2009. [pmid: 20012051].
310 Topp R, Woolley S, Hornyak J 3rd, et al. The effect of dynamic versus isometric resistance training on pain and functioning among adults with osteoarthritis of the knee. Arch Phys Med Rehabil. Sep. 2002;83(9):1187-95. 1187. [pmid: 12235596].
311 Trans T, Aaboe J, Henriksen M, et al. Effect of whole body vibration exercise on muscle strength and proprioception in females with knee osteoarthritis. Knee. 2009;16(4):256-61. [pmid: 19147365].
312 Trock DH, Bollet AJ, Markoll R. The effect of pulsed electromagnetic fields in the treatment of osteoarthritis of the knee and cervical spine. Report of randomized, double blind, placebo controlled trials. J Rheumatol. Oct. 1994;21(10):1903-11. [pmid: 7837158].
313 Tsauo JY, Cheng PF, Yang RS. The effects of sensorimotor training on knee proprioception and function for patients with knee osteoarthritis: a preliminary report. Clin Rehabil. 2008;22(5):448-57. [pmid: 18441041].
314 Tuzun EH, Aytar A, Eker L, et al. Effectiveness of two different physical therapy programmes in the treatment of knee osteoarthritis. Pain Clinic. 2004;16(4):379-87.
315 van Raaij TM, Reijman M, Brouwer RW, et al. Medial Knee Osteoarthritis Treated by Insoles or Braces: A Randomized Trial. Clin Orthop Relat Res. 2010;468(7):1926-32. [pmid: 20177839].
316 Victor CR, Triggs E, Ross F, et al. Lack of benefit of a primary care-based nurse-led education programme for people with osteoarthritis of the knee. Clin Rheumatol. Aug. 2005;24(4):358-64. [pmid: 15937632].
317 Wang C, Schmid CH, Hibberd PL, et al. Tai Chi is effective in treating knee osteoarthritis: a randomized controlled trial. Arthritis Rheum. 2009;61(11):1545-53. [pmid: 19877092].
318 Weiner DK, Rudy TE, Morone N, et al. Efficacy of periosteal stimulation therapy for the treatment of osteoarthritis-associated chronic knee pain: an initial controlled clinical trial. J Am Geriatr Soc. Oct. 2007;55(10):1541-7. [pmid: 17908057].
319 Weng MC, Lee CL, Chen CH, et al. Effects of different stretching techniques on the outcomes of isokinetic exercise in patients with knee osteoarthritis. Kaohsiung J Med Sci. 2009;25(6):306-15. [pmid: 19560995].
320 Williamson L, Wyatt MR, Yein K, et al. Severe knee osteoarthritis: a randomized controlled trial of acupuncture, physiotherapy (supervised exercise) and standard management for patients awaiting knee replacement. Rheumatology. 2007;46(9):1445-9. [pmid: 17604311].
321 Wolsko PM, Eisenberg DM, Simon LS, et al. Double-blind placebo-controlled trial of static magnets for the treatment of osteoarthritis of the knee: results of a pilot study. Altern Ther Health Med. 2004;10(2):36-43. [pmid: 15055092].
322 Wyatt FB, Milam S, Manske RC, et al. The effects of aquatic and traditional exercise programs on persons with knee osteoarthritis. Journal of Strength & Conditioning Research. 2001;15(3):337-40. [pmid: 11710661].
323 Yilmaz OO, Senocak O, Sahin E, et al. Efficacy of EMG-biofeedback in knee osteoarthritis. Rheumatol Int. May. 2010;30(7):887-92. [pmid: 19693508].
324 Yip YB, Sit JW, Fung KK, et al. Impact of an Arthritis Self-Management Programme with an added exercise component for osteoarthritic knee sufferers on improving pain, functional outcomes, and use of health care services: An experimental study. Patient Educ Couns. Jan. 2007;65(1):113-21. [pmid: 17010554].
325 Yip YB, Tam AC. An experimental study on the effectiveness of massage with aromatic ginger and orange essential oil for moderate-to-severe knee pain among the elderly in Hong Kong. Complement Ther Med. Jun. 2008;16(3):131-8. [pmid: 18534325].
326 Yip YB, Sit JW, Wong DY, et al. A 1-year follow-up of an experimental study of a self-management arthritis programme with an added exercise component of clients with osteoarthritis of the knee. Psychology Health & Medicine. 2008;13(4):402-14. [pmid: 18825579].
327 Yurtkuran M, Kocagil T. TENS, electroacupuncture and ice massage: comparison of treatment for osteoarthritis of the knee. Am J Acupunct. 1999;27(3–4):133-40. [pmid: 10729968].
328 Yurtkuran M, Alp A, Nasircilar A, et al. Balneotherapy and tap water therapy in the treatment of knee osteoarthritis. Rheumatol Int. Nov. 2006;27(1):19-27. [pmid: 16832639].
329 Zizic TM, Hoffman KC, Holt PA, et al. The treatment of osteoarthritis of the knee with pulsed electrical stimulation. J Rheumatol. Sep. 1995;22(9):1757-61. [pmid: 8523357].
330 Messier SP, Loeser RF, Miller GD, et al. Exercise and dietary weight loss in overweight and obese older adults with knee osteoarthritis: the Arthritis, Diet, and Activity Promotion Trial. Arthritis Rheum. May. 2004;50(5):1501-10. [pmid: 15146420].
331 Sullivan T, Allegrante JP, Peterson MG, et al. One-year followup of patients with osteoarthritis of the knee who participated in a program of supervised fitness walking and supportive patient education. Arthritis Care Res. Aug. 1998;11(4):228-33. [pmid: 9791321].
332 Messier SP, Thompson CD, Ettinger WH. Effects of long-term aerobic or weight training regimes on gait in an older, osteoarthritic population. Journal of Applied Biomechanics. 1997;13(2):205-25.
333 Peterson MG, Kovar-Toledano PA, Otis JC, et al. Effect of a walking program on gait characteristics in patients with osteoarthritis. Arthritis Care Res. Mar. 1993;6(1):11-6. [pmid: 8443252].
334 Focht BC, Rejeski WJ, Ambrosius WT, et al. Exercise, self-efficacy, and mobility performance in overweight and obese older adults with knee osteoarthritis. Arthritis Rheum. Oct. 15. 2005;53(5):659-65. [pmid: 16208674].
335 Thomas KS, Miller P, Doherty M, et al. Cost effectiveness of a two-year home exercise program for the treatment of knee pain. Arthritis Rheum. Jun. 15. 2005;53(3):388-94. [pmid: 15934131].
336 Salaffi F, Stancati A, Silvestri CA, et al. Minimal clinically important changes in chronic musculoskeletal pain intensity measured on a numerical rating scale. Eur J Pain. Aug. 2004;8(4):283-91. [pmid: 15207508].
337 Baron G, Tubach F, Ravaud P, et al. Validation of a short form of the Western Ontario and McMaster Universities Osteoarthritis Index function subscale in hip and knee osteoarthritis. Arthritis Rheum. May. 15. 2007;57(4):633-8. [pmid: 17471534].
338 Ware JE Jr, Sherbourne CD. The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Med Care. Jun. 1992;30(6):473-83. [pmid: 1593914].
339 Quintana JM, Escobar A, Arostegui I, et al. Health-related quality of life and appropriateness of knee or hip joint replacement. Arch Intern Med. Jan. 23. 2006;166(2):220-6. [pmid: 16432092].
340 Johanson NA, Liang MH, Daltroy L, et al. American Academy of Orthopaedic Surgeons lower limb outcomes assessment instruments. Reliability, validity, and sensitivity to change. J Bone Joint Surg Am. May. 2004;86-A(5):902-9. [pmid: 15118030].
341 Bellamy N, Bell MJ, Pericak D, et al. BLISS index for analyzing knee osteoarthritis trials data. Journal of clinical epidemiology. 2007;60(2):124-32. [pmid: 17208118].
342 Thomas E, Dunn KM, Mallen C, et al. A prognostic approach to defining chronic pain: application to knee pain in older adults. Pain. Oct. 15. 2008;139(2):389-97. [pmid: 18583051].
343 Von Korff M, Ormel J, Keefe FJ, et al. Grading the severity of chronic pain. Pain. Aug. 1992;50(2):133-49. [pmid: 1408309].
344 Cecchi F, Molino-Lova R, Di Iorio A, et al. Measures of physical performance capture the excess disability associated with hip pain or knee pain in older persons. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2009;64(12):1316-24. [pmid: 19797345].
345 Guralnik JM, Simonsick EM, Ferrucci L, et al. A short physical performance battery assessing lower extremity function: association with self-reported disability and prediction of mortality and nursing home admission. J Gerontol. Mar. 1994;49(2):M85-94. [pmid: 8126356].
346 Kennedy DM, Stratford PW, Wessel J, et al. Assessing stability and change of four performance measures: a longitudinal study evaluating outcome following total hip and knee arthroplasty. BMC Musculoskeletal Disorders. 2005;6(Journal Article):3. [pmid: 15679884].
347 Redelmeier DA, Lorig K. Assessing the clinical importance of symptomatic improvements. An illustration in rheumatology. Arch Intern Med. Jun. 14. 1993;153(11):1337-42. [pmid: 8507124].
348 Fries JF, Spitz PW, Young DY. The dimensions of health outcomes: the health assessment questionnaire, disability and pain scales. J Rheumatol. Sep–Oct. 1982;9(5):789-93. [pmid: 7175852].
349 Tanner SM, Dainty KN, Marx RG, et al. Knee-specific quality-of-life instruments: which ones measure symptoms and disabilities most important to patients?. American Journal of Sports Medicine. Sep. 2007;35(9):1450-8. [pmid: 17502427].
350 Irrgang JJ, Anderson AF, Boland AL, et al. Development and validation of the international knee documentation committee subjective knee form. American Journal of Sports Medicine. Sep–Oct. 2001;29(5):600-13. [pmid: 11573919].
351 Fransen M, Crosbie J, Edmonds J. Isometric muscle force measurement for clinicians treating patients with osteoarthritis of the knee. Arthritis Care and Research. 2003;49(1):29-35. [pmid: 12579591].
352 Roos EM, Roos HP, Lohmander LS, et al. Knee Injury and Osteoarthritis Outcome Score (KOOS)--development of a self-administered outcome measure. J Orthop Sports Phys Ther. Aug. 1998;28(2):88-96. [pmid: 9699158].
353 Stucki G, Sangha O, Stucki S, et al. Comparison of the WOMAC (Western Ontario and McMaster Universities) osteoarthritis index and a self-report format of the self-administered Lequesne-Algofunctional index in patients with knee and hip osteoarthritis. Osteoarthritis Cartilage. Mar. 1998;6(2):79-86. [pmid: 9692062].
354 Ren XS, Kazis L, Meenan RF. Short-form Arthritis Impact Measurement Scales 2: tests of reliability and validity among patients with osteoarthritis. Arthritis Care Res. Jun. 1999;12(3):163-71. [pmid: 10513506].
355 Guillemin F, Coste J, Pouchot J, et al. The AIMS2-SF: a short form of the Arthritis Impact Measurement Scales 2. French Quality of Life in Rheumatology Group. Arthritis Rheum. Jul. 1997;40(7):1267-74. [pmid: 9214427].
356 Duncan PW, Weiner DK, Chandler J, et al. Functional reach: a new clinical measure of balance. J Gerontol. Nov. 1990;45(6):M192-7. [pmid: 2229941].
357 Peat G, Lawton H, Hay E, et al. Development of the Knee Standardized Clinical Interview: a research tool for studying the primary care clinical epidemiology of knee problems in older adults. Rheumatology (Oxford). Oct. 2002;41(10):1101-8. [pmid: 12364627].
358 Hill K, Bernhardt J, McGann A, et al. A new test of dynamic standing balance for stroke patients: reliability, validity, and comparison with healthy elderly. Physiother Can. 1996;48:257-62.
359 Harrison AL. The influence of pathology, pain, balance, and self-efficacy on function in women with osteoarthritis of the knee. Phys Ther. Sep. 2004;84(9):822-31. [pmid: 15330695].
360 Maly MR, Costigan PA, Olney SJ. Determinants of self efficacy for physical tasks in people with knee osteoarthritis. Arthritis Rheum. Feb. 15. 2006;55(1):94-101. [pmid: 16463419].
361 Lorig K, Chastain RL, Ung E, et al. Development and evaluation of a scale to measure perceived self-efficacy in people with arthritis. Arthritis Rheum. Jan. 1989;32(1):37-44. [pmid: 2912463].
362 Wood L, Peat G, Thomas E, et al. Associations between physical examination and self-reported physical function in older community-dwelling adults with knee pain. Physical Therapy. 2008;88(1):33-42. [pmid: 18029391].
363 Hurkmans EJ, van der Esch M, Ostelo RWJG, et al. Reproducibility of the measurement of knee joint proprioception in patients with osteoarthritis of the knee. Arthritis & Rheumatism. Dec. 15. 2007;57(8):1398-403. [pmid: 18050179].
364 Wright JG, Santaguida PL, Young N, et al. Patient preferences before and after total knee arthroplasty. J Clin Epidemiol. Jul. 2010;63(7):774-82. [pmid: 20004554].
365 Steultjens MP, Dekker J, van Baar ME, et al. Range of joint motion and disability in patients with osteoarthritis of the knee or hip. Rheumatology (Oxford). Sep. 2000;39(9):955-61. [pmid: 10986299].
366 Evers AW, Taal E, Kraaimaat FW, et al. A comparison of two recently developed health status instruments for patients with arthritis: Dutch-AIMS2 and IRGL. Arthritis Impact Measurement Scales. Impact of Rheumatic diseases on General health and Lifestyle. British Journal of Rheumatology. Feb. 1998;37(2):157-64. [pmid: 9569070].
367 Bieleman HJ, Reneman MF, van Ittersum MW, et al. Self-reported functional status as predictor of observed functional capacity in subjects with early osteoarthritis of the hip and knee: A diagnostic study in the CHECK cohort. Journal of Occupational Rehabilitation. 2009;19(4):345-53. [pmid: 19557505].
368 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. Nov. 10. 2003;3:25. [pmid: 14606960].
369 Rejeski WJ, Ettinger WH Jr, Martin K, et al. Treating disability in knee osteoarthritis with exercise therapy: a central role for self-efficacy and pain. Arthritis Care Res. Apr. 1998;11(2):94-101. [pmid: 9668732].
370 Bennell KL, Hinman RS, Crossley KM, et al. Is the Human Activity Profile a useful measure in people with knee osteoarthritis?. Journal of Rehabilitation Research and Development. 2004;41(4):621-9. [pmid: 15558390].
371 Topp R, Woolley S, Khuder S, et al. Predictors of four functional tasks in patients with osteoarthritis of the knee. Orthopaedic Nursing. Sep–Oct. 2000;19(5):49-58. [pmid: 11153386].
372 Nebel MB, Sims EL, Keefe FJ, et al. The relationship of self-reported pain and functional impairment to gait mechanics in overweight and obese persons with knee osteoarthritis. Arch Phys Med Rehabil. Nov. 2009;90(11):1874-9. [pmid: 19887211].
373 Thomas E, Peat G, Mallen C, et al. Predicting the course of functional limitation among older adults with knee pain: do local signs, symptoms and radiographs add anything to general indicators?. Annals of the Rheumatic Diseases. Oct. 2008;67(10):1390-8. [pmid: 18245111].
374 Van Der Esch M, Steultjens M, Knol DL, et al. Joint Laxity and the Relationship Between Muscle Strength and Functional Ability in Patients With Osteoarthritis of the Knee. Arthritis Care and Research. 2006;55(6):953-9. [pmid: 17139642].
375 Hunt MA, McManus FJ, Hinman RS, et al. Predictors of single-leg standing balance in individuals with medial knee osteoarthritis. Arthritis Care & Research. Apr. 2010;62(4):496-500. [pmid: 20391504].
376 Jadelis K, Miller ME, Ettinger WH Jr, et al. Strength, balance, and the modifying effects of obesity and knee pain: results from the Observational Arthritis Study in Seniors (oasis). Journal of the American Geriatrics Society. Jul. 2001;49(7):884-91. [pmid: 11527479].
377 Sharma L, Cahue S, Song J, et al. Physical functioning over three years in knee osteoarthritis: role of psychosocial, local mechanical, and neuromuscular factors. Arthritis Rheum. Dec. 2003;48(12):3359-70. [pmid: 14673987].
378 Maly MR, Costigan PA, Olney SJ. Self-efficacy mediates walking performance in older adults with knee osteoarthritis. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. Oct. 2007;62(10):1142-6. [pmid: 17921428].
379 van der Esch M, Steultjens M, Harlaar J, et al. Varus-valgus motion and functional ability in patients with knee osteoarthritis. Ann Rheum Dis. Apr. 2008;67(4):471-7. [pmid: 17604283].
380 O’Reilly SC, Jones A, Muir KR, et al. Quadriceps weakness in knee osteoarthritis: the effect on pain and disability. Annals of the Rheumatic Diseases. 1998;57(10):588-94. [pmid: 9893569].
381 van Baar ME, Dekker J, Lemmens JA, et al. Pain and disability in patients with osteoarthritis of hip or knee: the relationship with articular, kinesiological, and psychological characteristics. J Rheumatol. Jan. 1998;25(1):125-33. [pmid: 9458215].
382 Clark JA, Spiro A 3rd, Fincke G, et al. Symptom severity of osteoarthritis of the knee: a patient-based measure developed in the veterans health study. J Gerontol A Biol Sci Med Sci. Sep. 1998;53(5):M351-60. [pmid: 9754141].
383 van Dijk GM, Veenhof C, Lankhorst GJ, et al. Limitations in activities in patients with osteoarthritis of the hip or knee: the relationship with body functions, comorbidity and cognitive functioning. Disabil Rehabil. 2009;31(20):1685-91. [pmid: 19479564].
384 Maly MR, Costigan PA, Olney SJ. Role of knee kinematics and kinetics on performance and disability in people with medial compartment knee osteoarthritis. Clin Biomech (Bristol, Avon). Dec. 2006;21(10):1051-9. [pmid: 16956703].
385 Kauppila AM, Kyllonen E, Mikkonen P, et al. Disability in end-stage knee osteoarthritis. Disabil Rehabil. 2009;31(5):370-80. [pmid: 18608423].
386 Wolfe F. Determinants of WOMAC function, pain and stiffness scores: evidence for the role of low back pain, symptom counts, fatigue and depression in osteoarthritis, rheumatoid arthritis and fibromyalgia. Rheumatology. 1999;38(4):355-61. [pmid: 10378714].
387 Astephen Wilson JL, Deluzio KJ, Dunbar MJ, et al. The association between knee joint biomechanics and neuromuscular control and moderate knee osteoarthritis radiographic and pain severity. Osteoarthritis Cartilage. Feb. 2011;19(2):186-93. [pmid: 21074628].
388 Boutron I, Rannou F, Jardinaud-Lopez M, et al. Disability and quality of life of patients with knee or hip osteoarthritis in the primary care setting and factors associated with general practitioners’ indication for prosthetic replacement within 1 year. Osteoarthritis Cartilage. Sep. 2008;16(9):1024-31. [pmid: 18276169].
389 Riddle DL, Kong X, Fitzgerald GK. Psychological health impact on 2-year changes in pain and function in persons with knee pain: data from the Osteoarthritis Initiative. Osteoarthritis Cartilage. Sep. 2011;19(9):1095-101. [pmid: 21723400].
390 Snijders GF, van den Ende CH, Fransen J, et al. Fatigue in knee and hip osteoarthritis: the role of pain and physical function. Rheumatology (Oxford). Oct. 2011;50(10):1894-900. [pmid: 21750001].
391 Collins E, O’Connell S, Jelinek CD, et al. Evaluation of psychometric properties of Walking Impairment Questionnaire in overweight patients with osteoarthritis of knee. Journal of Rehabilitation Research and Development. 2008;45(4):559-66. [pmid: 18712641].
392 Possley D, BudimanMak E, O’Connell S, et al. Relationship between depression and functional measures in overweight and obese persons with osteoarthritis of the knee. Journal of Rehabilitation Research and Development. 2009;46(9):8. [pmid: 20437315].
393 Barker K, Lamb SE, Toye F, et al. Association between radiographic joint space narrowing, function, pain and muscle power in severe osteoarthritis of the knee. Clinical rehabilitation. 2004;18(7):793-800. [pmid: 15573836].
394 Gibson K, Sayers SP, Minor MA. Measurement of varus/valgus alignment in obese individuals with knee osteoarthritis. Arthritis Care Res (Hoboken). May. 2010;62(5):690-6. [pmid: 20191467].
395 Birmingham TB, Kramer JF, Kirkley A, et al. Association among neuromuscular and anatomic measures for patients with knee osteoarthritis. Archives of Physical Medicine & Rehabilitation. 2001;82(8):1115-8. [pmid: 11494192].
396 Deniston OL, Jette A. A functional status assessment instrument: validation in an elderly population. Health Serv Res. Spring. 1980;15(1):21-34. [pmid: 7372496].
397 Meenan RF, Gertman PM, Mason JH. Measuring health status in arthritis. The arthritis impact measurement scales. Arthritis Rheum. Feb. 1980;23(2):146-52. [pmid: 7362665].
398 Faucher M, Poiraudeau S, LefevreColau MM, et al. Algo-functional assessment of knee osteoarthritis: comparison of the test-retest reliability and construct validity of the Womac and Lequesne indexes. Osteoarthritis and Cartilage. 2002;10(8):602-10. [pmid: 12479381].
399 Bruce B, Fries J. Longitudinal comparison of the Health Assessment Questionnaire (HAQ) and the Western Ontario and McMaster Universities Osteoarthritis Index (WOMAC). Arthritis Rheum. Oct. 15. 2004;51(5):730-7. [pmid: 15478152].
400 Yang KG, Raijmakers NJ, Verbout AJ, et al. Validation of the short-form WOMAC function scale for the evaluation of osteoarthritis of the knee. Journal of Bone and Joint Surgery (British). 2007;89(1):50-6. [pmid: 17259416].
401 Steultjens MP, Dekker J, van Baar ME, et al. Muscle strength, pain and disability in patients with osteoarthritis. Clin Rehabil. Jun. 2001;15(3):331-41. [pmid: 11386405].
402 Lin YC, Davey RC, Cochrane T. Tests for physical function of the elderly with knee and hip osteoarthritis. Scand J Med Sci Sports. Oct. 2001;11(5):280-6. [pmid: 11696212].
403 Rejeski WJ, Ettinger WH Jr, Shumaker S, et al. The evaluation of pain in patients with knee osteoarthritis: the knee pain scale. J Rheumatol. Jun. 1995;22(6):1124-9. [pmid: 7674241].
404 Piva SR, Fitzgerald GK, Irrgang JJ, et al. Get up and go test in patients with knee osteoarthritis. Arch Phys Med Rehabil. Feb. 2004;85(2):284-9. [pmid: 14966715].
405 Steultjens MP, Dekker J, van Baar ME, et al. Internal consistency and validity of an observational method for assessing disability in mobility in patients with osteoarthritis. Arthritis Care Res. Feb. 1999;12(1):19-25. [pmid: 10513486].
406 O’Malley KJ, Suarez-Almazor M, Aniol J, et al. Joint-specific multidimensional assessment of pain (J-MAP): factor structure, reliability, validity, and responsiveness in patients with knee osteoarthritis. J Rheumatol. Mar. 2003;30(3):534-43. [pmid: 12610814].
407 Lingard EA, Katz JN, Wright RJ, et al. Validity and responsiveness of the Knee Society Clinical Rating System in comparison with the SF-36 and WOMAC. J Bone Joint Surg Am. Dec. 2001;83-A(12):1856-64. [pmid: 11741066].
408 Finch E, Kennedy D. The lower extremity activity profile: a health status instrument for measuring lower extremity disability. Physiother Can. Fall. 1995;47(4):239-46. [pmid: 10153394].
409 Salaffi F, Cavalieri F, Nolli M, et al. Analysis of disability in knee osteoarthritis. Relationship with age and psychological variables but not with radiographic score. J Rheumatol. Oct. 1991;18(10):1581-6. [pmid: 1765985].
410 Ornetti P, Dougados M, Paternotte S, et al. Validation of a numerical rating scale to assess functional impairment in hip and knee osteoarthritis: comparison with the WOMAC function scale. Ann Rheum Dis. May. 2011;70(5):740-6. [pmid: 21149497].
411 Roos EM, Klassbo M, Lohmander LS. WOMAC osteoarthritis index. Reliability, validity, and responsiveness in patients with arthroscopically assessed osteoarthritis. Western Ontario and MacMaster Universities. Scand J Rheumatol. 1999;28(4):210-5. [pmid: 10503556].
412 Brazier JE, Harper R, Munro J, et al. Generic and condition-specific outcome measures for people with osteoarthritis of the knee. Rheumatology. 1999;38(9):870-7. [pmid: 10515649].
413 Fransen M, Edmonds J. Reliability and validity of the EuroQol in patients with osteoarthritis of the knee. Rheumatology (Oxford). Sep. 1999;38(9):807-13. [pmid: 10515639].
414 Angst F, Ewert T, Lehmann S, et al. The factor subdimensions of the Western Ontario and McMaster Universities Osteoarthritis Index (WOMAC) help to specify hip and knee osteoarthritis. a prospective evaluation and validation study. J Rheumatol. Jul. 2005;32(7):1324-30. [pmid: 15996072].
415 Seror R, Tubach F, Baron G, et al. Individualising the Western Ontario and McMaster Universities osteoarthritis index (WOMAC) function subscale: incorporating patient priorities for improvement to measure functional impairment in hip or knee osteoarthritis. Ann Rheum Dis. Apr. 2008;67(4):494-9. [pmid: 17704063].
416 Wolfe F, Kong SX. Rasch analysis of the Western Ontario MacMaster questionnaire (WOMAC) in 2205 patients with osteoarthritis, rheumatoid arthritis, and fibromyalgia. Ann Rheum Dis. Sep. 1999;58(9):563-8. [pmid: 10460190].
417 Ryser L, Wright BD, Aeschlimann A, et al. A new look at the Western Ontario and McMaster Universities Osteoarthritis Index using Rasch analysis. Arthritis Care Res. Oct. 1999;12(5):331-5. [pmid: 11081002].
418 Davis AM, Badley EM, Beaton DE, et al. Rasch analysis of the Western Ontario McMaster (WOMAC) Osteoarthritis Index: results from community and arthroplasty samples. J Clin Epidemiol. Nov. 2003;56(11):1076-83. [pmid: 14614998].
419 Verghese J, LeValley A, Hall CB, et al. Epidemiology of gait disorders in community-residing older adults. J Am Geriatr Soc. Feb. 2006;54(2):255-61. [pmid: 16460376].
420 Woo J, Ho SC, Yu AL. Walking speed and stride length predicts 36 months dependency, mortality, and institutionalization in Chinese aged 70 and older. J Am Geriatr Soc. Oct. 1999;47(10):1257-60. [pmid: 10522962].
421 Jylha M, Guralnik JM, Balfour J, et al. Walking difficulty, walking speed, and age as predictors of self-rated health: the women’s health and aging study. J Gerontol A Biol Sci Med Sci. Oct. 2001;56(10):M609-17. [pmid: 11584033].
422 Onder G, Penninx BW, Ferrucci L, et al. Measures of physical performance and risk for progressive and catastrophic disability: results from the Women’s Health and Aging Study. J Gerontol A Biol Sci Med Sci. Jan. 2005;60(1):74-9. [pmid: 15741286].
423 Dougados M, Leclaire P, van der Heijde D, et al. Response criteria for clinical trials on osteoarthritis of the knee and hip: a report of the Osteoarthritis Research Society International Standing Committee for Clinical Trials response criteria initiative. Osteoarthritis & Cartilage. Nov. 2000;8(6):395-403. [pmid: 11069723].
424 Angst F, Aeschlimann A, Stucki G. Smallest detectable and minimal clinically important differences of rehabilitation intervention with their implications for required sample sizes using WOMAC and SF-36 quality of life measurement instruments in patients with osteoarthritis of the lower extremities. Arthritis Rheum. Aug. 2001;45(4):384-91. [pmid: 11501727].
425 Angst F, Aeschlimann A, Michel BA, et al. Minimal clinically important rehabilitation effects in patients with osteoarthritis of the lower extremities. J Rheumatol. Jan. 2002;29(1):131-8. [pmid: 11824949].
426 Bellamy N, Campbell J, Hill J, et al. A comparative study of telephone versus onsite completion of the WOMAC 3.0 osteoarthritis index. J Rheumatol. Apr. 2002;29(4):783-6. [pmid: 11950022].
427 Link TM, Steinbach LS, Ghosh S, et al. Osteoarthritis: MR imaging findings in different stages of disease and correlation with clinical findings. Radiology. Feb. 2003;226(2):373-81. [pmid: 12563128].
428 Tubach F, Ravaud P, Baron G, et al. Evaluation of clinically relevant states in patient reported outcomes in knee and hip osteoarthritis: the patient acceptable symptom state. Annals of the Rheumatic Diseases. 2005;64(1):34-7. [pmid: 15130902].
429 Tubach F, Ravaud P, Baron G, et al. Evaluation of clinically relevant changes in patient reported outcomes in knee and hip osteoarthritis: the minimal clinically important improvement. Annals of the Rheumatic Diseases. 2005;64(1):29-33. [pmid: 15208174].
430 Tubach F, Wells GA, Ravaud P, et al. Minimal clinically important difference, low disease activity state, and patient acceptable symptom state: methodological issues. J Rheumatol. Oct. 2005;32(10):2025-9. [pmid: 16206363].
431 Weigl M, Angst F, Aeschlimann A, et al. Predictors for response to rehabilitation in patients with hip or knee osteoarthritis: a comparison of logistic regression models with three different definitions of responder. Osteoarthritis & Cartilage. 2006;14(7):641-51. [pmid: 16513373].
432 Stratford PW, Kennedy DM, Woodhouse LJ, et al. Measurement properties of the WOMAC LK 3.1 pain scale. Osteoarthritis Cartilage. Mar. 2007;15(3):266-72. [pmid: 17046290].
433 White DK, Keysor JJ, Lavalley MP, et al. Clinically important improvement in function is common in people with or at high risk of knee OA: the MOST study. J Rheumatol. Jun. 2010;37(6):1244-51. [pmid: 20395640].
434 Escobar A, Quintana JM, Bilbao A, et al. Responsiveness and clinically important differences for the WOMAC and SF-36 after total knee replacement. Osteoarthritis and Cartilage. 2007;15(3):273-80. [pmid: 17052924].
435 Bellamy N, Carr A, Dougados M, et al. Towards a definition of “difference” in osteoarthritis. J Rheumatol. Feb. 2001;28(2):427-30. [pmid: 11246691].
436 Belo JN, Berger MY, Koes BW, et al. The prognostic value of the clinical ACR classification criteria of knee osteoarthritis for persisting knee complaints and increase of disability in general practice. Osteoarthritis Cartilage. Oct. 2009;17(10):1288-92. [pmid: 19410034].
437 Ehrich EW, Davies GM, Watson DJ, et al. Minimal perceptible clinical improvement with the Western Ontario and McMaster Universities osteoarthritis index questionnaire and global assessments in patients with osteoarthritis. J Rheumatol. Nov. 2000;27(11):2635-41. [pmid: 11093446].
438 Mangione KK, Craik RL, McCormick AA, et al. Detectable changes in physical performance measures in elderly African Americans. Phys Ther. Jun. 2010;90(6):921-7. [pmid: 20395305].
439 Lequesne MG. The algofunctional indices for hip and knee osteoarthritis. J Rheumatol. Apr. 1997;24(4):779-81. [pmid: 9101517].