# Data Abstraction Forms

Abstraction Form for Questions 1–3

Abstraction Form for question 2