# Review Questions According to Population, Intervention, Comparator, Outcomes, Timing, and Settings (PICOTS) Framework

## Question 1

What are the effectiveness and comparative effectiveness of available physical therapy interventions (without drug treatment) for adult patients with chronic knee pain due to OA on intermediate and patient-centered outcomes when compared to no active treatment or another active physical therapy modality?

a. Which patient characteristics are associated with the benefits of examined interventions of physical therapy on intermediate and patient-centered outcomes?
b. Do changes in intermediate and patient-centered outcomes differ by the dose, duration, intensity, and frequency of examined interventions of physical therapy?
c. Do changes in intermediate and patient-centered outcomes differ by duration of examined interventions of physical therapy and the time of followup?

### Population

○ Adults with knee pain secondary to knee osteoarthritis in outpatient settings, including home-based therapy.
○ Chronic OA is defined as meeting diagnostic criteria and having symptoms of OA for >2 months.

#### Excluded

○ Adults with knee OA who had knee arthroplasty on the “study limb” within 6 months before the study
○ Adults with osteonecrosis
○ Adults with acute knee injuries
○ Adults with inflammatory arthritis
○ Adults with arthritis secondary to systemic disease
○ Adults with physical therapy treatment combined with drug treatment

#### Relevant population characteristics that may modify treatment effects

○ Age
○ Gender
○ Race
○ Baseline activities of daily living (ADL)/instrumental activities of daily living (IADL)
○ Disability
○ Comorbidity
○ Obesity
○ Concomitant/prior treatments including history of prior knee surgery or injury
○ Presence of significant skeletal abnormality
○ Activity level
○ Occupation

- Intervention
  Physical therapy (monotherapy with one physical therapy intervention or combined physical therapy interventions). Studies examining the marginal effects of drugs combined with physical therapy will be excluded.

Physical therapy interventions eligible for review

General Modality | Specific Intervention | Definition
Patient/client-related instruction
Instruction, education, and training of patients/clients and caregivers | Current condition Enhancement of performance Health, wellness, and fitness Plan of care Risk factors for pathology/ pathophysiology, impairments, functional limitations, or disabilities
Therapeutic exercise | Aerobic capacity/endurance conditioning or reconditioning | Increased workload over time Walking programs Aquatic therapy
Therapeutic exercise | Flexibility exercises | Muscle lengthening Range of motion Stretching
Therapeutic exercise | Gait and locomotion training | Gait training Implement and device training
Therapeutic exercise | Strength, power, and endurance training for limb muscles | Active assistive, active, and resistive exercises Quadriceps strengthening Aquatic programs Standardized, programmatic, complementary exercise approaches Task-specific performance training Body mechanics and postural stabilization Body mechanics training
Therapeutic exercise | Balance, coordination, and agility training | Neuromuscular education or re-education Posture awareness training
Therapeutic exercise | Muscle relaxation technique for pain management
Functional training in self-care, home management, work, community, and leisure integration or reintegration (including ADL, IADL, work hardening, and work conditioning) | ADL training
Functional training in self-care, home management, work, community, and leisure integration or reintegration (including ADL, IADL, work hardening, and work conditioning) | Devices and equipment use and training | Assistive and adaptive device or equipment training during ADL and IADL Orthotic, protective, or supportive device or equipment training during ADL and IADL
Functional training in self-care, home management, work, community, and leisure integration or reintegration (including ADL, IADL, work hardening, and work conditioning) | Functional training programs | Simulated environments and tasks Task adaptation
Functional training in self-care, home management, work, community, and leisure integration or reintegration (including ADL, IADL, work hardening, and work conditioning) | IADL training
Functional training in self-care, home management, work, community, and leisure integration or reintegration (including ADL, IADL, work hardening, and work conditioning) | Injury prevention or reduction | Injury prevention education during self-care, home management, work, community, and leisure integration or reintegration Injury prevention or reduction with use of devices and equipment Safety awareness training during self-care, home management, work, community, and leisure integration and reintegration
Manual therapy techniques (Including mobilization/ manipulation) | Detailed examination to reveal impaired movements
Manual therapy techniques (Including mobilization/ manipulation) | Manual techniques with reinforcing exercise to improve movement
Manual therapy techniques (Including mobilization/ manipulation) | Manual traction
Manual therapy techniques (Including mobilization/ manipulation) | Massage | Connective tissue massage Therapeutic massage
Manual therapy techniques (Including mobilization/ manipulation) | Mobilization/manipulation | Soft tissue Knee joint, other joints
Manual therapy techniques (Including mobilization/ manipulation) | Passive range of motion
Prescription, application of devices and equipment | Adaptive devices | Raised toilet seats
Prescription, application of devices and equipment | Assistive devices | Canes Crutches Walkers Long-handled reachers Power devices Static and dynamic splints Grab bars and tub chairs
Prescription, application of devices and equipment | Orthotic devices | Braces Shoe inserts Splints
Prescription, application of devices and equipment | Protective devices | Braces Protective patellar taping
Prescription, application of devices and equipment | Supportive devices | Supportive taping
Electrotherapeutic interventions | Electrotherapeutic delivery of medications | Iontophoresis
Electrotherapeutic interventions | Electrical stimulation | Electrical muscle stimulation Functional electrical stimulation High-voltage pulsed current Neuromuscular electrical stimulation Transcutaneous electrical nerve stimulation
Physical agents and mechanical interventions | Nonthermal agents | Pulsed electromagnetic fields
Physical agents and mechanical interventions | Aquatic therapy | Pools
Physical agents and mechanical interventions | Sound agents | Ultrasound
Physical agents and mechanical interventions | Thermotherapy | Dry heat Hot packs Diathermy Cold modalities
Physical agents and mechanical interventions | Cryotherapy | Cold packs Ice massage

Abbreviations: ADL = activities of daily living; IADL = instrumental activities of daily living.

#### Comparator

Analysis of efficacy:

○ No active treatment (sham stimulation)

Analysis of comparative effectiveness:

○ Active control as above
○ Monotherapy with one physical therapy intervention compared to combined therapy of more than physical therapy interventions

- Outcomes
  Patient-centered outcomes:
  ○ Pain
  ○ Independence in ADL and IADL, with or without devices and equipment
  ○ Ability to assume or resume required self-care, home management, work, community, and leisure roles
  ○ Walking, general physical activity
  ○ Patient satisfaction global assessment
  ○ Time to return to work/activities
  ○ Quality of life
  Intermediate outcomes:
  ○ Joint swelling, inflammation, or restriction
  ○ Impaired physical performance
  ○ Tolerance of positions and activities

## Question 2

What is the association between changes in intermediate outcomes with changes in patient-centered outcomes after physical therapy interventions?

d What is the validity of the tests and measures used to determine intermediate outcomes of physical therapy on OA in association with patient-centered outcomes?
e Which intermediate outcomes meet the criteria of surrogates for patient-centered outcomes?
f What are minimal clinically important differences of the tests and measures used to determine intermediate outcomes?

- Population
  Same as KQ1
- Interventions
  Tests and measurements (intermediate outcomes of physical therapy):
  ○ Muscle performance or strength tests:
    – Manual muscle test
    – Hand-held dynamometer
    – Isokinetic dynamometer
    – Knee goniometry
    – Lower extremity activity profile
    – Measure of balance including single-leg stance test or tandem stance
    – Aerobic capacity
  ○ Markers of inflammation:
    – Girth measurements for swelling/edema
  ○ Self-reported patient scales and questionnaires:
    – Knee Pain Screening Tool (KNEST)
    – Extra Short Musculoskeletal Function Assessment questionnaire (XSMFA-D)
    – 12-item Oxford Knee Score
- Comparator
  ○ Normal ranges of the tests and measurements described above
- Outcomes
  Patient-centered outcomes:
  ○ Independence in activities of daily living (Activities of Daily Living Scale of the Knee Outcome Survey)
    – 6 Minute Walk Test
    – Gait Speed (potential surrogate for clinical outcomes)
    – Functional Status Index
    – Timed Get Up and Go Test
    – Fifty-foot Timed Walk Measure
    – Aggregate Functional Performance Time Measure
    – Lequesne Index for Knee Osteoarthritis
    – Algofunctional Index for Knee Osteoarthritis
    – Lower Extremity Functional Scale (LEFS)
  ○ Time to return to work/activities
  ○ Quality of life measured with:
    – Short Form 36 (SF-36)
    – Mapping the Osteoarthritis Knee and Hip Quality of Life (OAKHQOL)
  ○ Pain measured with:
    – Anterior Knee Pain Questionnaire
    – Knee pain osteoarthritis Visual Analogue Scale (VAS)
    – Knee Pain Scale (KPS)
    – Western Ontario McMaster Osteoarthritis Index (WOMAC) Pain subscale
    – Patient Global Assessment
    – Arthritis Impact Measurement Scales
    – Outcome Measures in Rheumatology
    – OMERACT outcome measures including:
      ▪ Pain
      ▪ Physical function
      ▪ Patient global assessment
      ▪ Joint imaging (for studies of 1 year or longer)
      ▪ Health-related quality of life measure
      ▪ Physician global assessment
  ○ Patient Specific Functional Scale (PSFS)
  ○ Knee Injury and Osteoarthritis Outcome Score (KOOS)
  ○ Outpatient Physical Therapy Improvement in Movement Assessment Log (OPTIMAL)

## Question 3

What are the harms from physical therapy interventions available for adult patients with chronic knee pain due to osteoarthritis when compared to no active treatment or active controls?

c Which patient characteristics are associated with the harms of examined physical therapy interventions?
d Do harms differ by the duration of the treatment and time of followup?

- Population
  Same as KQ 1
- Interventions
  Same as KQ 1
- Comparators
  Same as KQ 1
- Outcomes
  All reported adverse events

## Questions 1–3

- Timing
  ○ At the end of the treatment
  ○ Short-term outcomes (0–6 weeks up to 3 months)
  ○ Long-term outcomes (3–6 months or >6 months)
- Settings
  Outpatient and home-based care settings