# Excluded Studies

## Not Eligible Outcomes

1 Trombini-Souza F, Kimura A, Ribeiro AP, et al. Inexpensive footwear decreases joint loading in elderly women with knee osteoarthritis. Gait Posture. May. 2011;34(1):126-30. [pmid: 21536443].
2 Altman RD, Bloch DA, Dougados M, et al. Measurement of structural progression in osteoarthritis of the hip: the Barcelona consensus group. Osteoarthritis & Cartilage. Jul. 2004;12(7):515-24. [pmid: 15219566].
3 Astephen JL, Deluzio KJ. A multivariate gait data analysis technique: application to knee osteoarthritis. Proceedings - IME.Part H: Journal of Engineering in Medicine. 2004;218(4):271-9.
4 Bautch JC, Clayton MK, Chu Q, et al. Synovial fluid chondroitin sulphate epitopes 3B3 and 7D4, and glycosaminoglycan in human knee osteoarthritis after exercise. Annals of the Rheumatic Diseases. Nov. 2000;59(11):887-91. [pmid: 11053067].
5 Bejek Z, Paróczai R, et al. The influence of walking speed on gait parameters in healthy people and in patients with osteoarthritis. Knee Surgery, Sports Traumatology, Arthroscopy. Jul. 2006;14(7):612-22. [pmid: 16331521].
6 Benito MJ, Veale DJ, FitzGerald O, et al. Synovial tissue inflammation in early and late osteoarthritis. Annals of the Rheumatic Diseases. Sep. 2005;64(9):1263-7. [pmid: 15731292].
7 Berry PA, Maciewicz RA, Wluka AE, et al. Relationship of serum markers of cartilage metabolism to imaging and clinical outcome measures of knee joint structure. Annals of the Rheumatic Diseases. Oct. 2010;69(10):1816-22. [pmid: 20551154].
8 Bhagat S, Ostor AJK. Diagnosing joint pain in the older people. Practitioner. Jan. 2010;254(1725):17-21. [pmid: 20198931].
9 Bierma-Zeinstra SMA, Oster JD, Bernsen RMD, et al. Joint space narrowing and relationship with symptoms and signs in adults consulting for hip pain in primary care. Journal of Rheumatology. Aug. 2002;29(8):1713-8. [pmid: 12180735].
10 Birrell F, Croft P, Cooper C, et al. Predicting radiographic hip osteoarthritis from range of movement. Rheumatology. May. 2001;40(5):506-12. [pmid: 11371658].
11 Briem K, Snyder-Mackler L. Proximal gait adaptations in medial knee OA. J Orthop Res. Jan. 2009;27(1):78-83. [pmid: 18634012].
12 Cho HJ, Chang CB, Yoo JH, et al. Gender differences in the correlation between symptom and radiographic severity in patients with knee osteoarthritis. Clin Orthop Relat Res. Jul. 2010;468(7):1749-58. [pmid: 20204559].
13 Cicuttini F, Morris KF, Glisson M, et al. Slice thickness in the assessment of medial and lateral tibial cartilage volume and accuracy for the measurement of change in a longitudinal study. J Rheumatol. Dec. 2004;31(12):2444-8. [pmid: 15570649].
14 Clark AG, Jordan JM, Vilim V, et al. Serum cartilage oligomeric matrix protein reflects osteoarthritis presence and severity: the Johnston County Osteoarthritis Project. Arthritis & Rheumatism. Nov. 1999;42(11):2356-64. [pmid: 10555031].
15 Davies AP, Vince AS, Shepstone L, et al. The radiologic prevalence of patellofemoral osteoarthritis. Clin Orthop Relat Res. Sep. 2002;(402):206-12. [pmid: 12218486].
16 Futani H, Okayama A, Matsui K, et al. Relation between interleukin-18 and PGE2 in synovial fluid of osteoarthritis: a potential therapeutic target of cartilage degradation. J Immunother. Mar–Apr. Suppl 1. 2002;25:S61-4. [pmid: 12048352].
17 Guo M, Axe MJ, Manal K. The influence of foot progression angle on the knee adduction moment during walking and stair climbing in pain free individuals with knee osteoarthritis. Gait and Posture. 2007;26(3):436-41. [pmid: 17134902].
18 Hawker GA, Wright JG, Coyte PC, et al. Determining the need for hip and knee arthroplasty: the role of clinical severity and patients’ preferences. Medical care. 2001;39(3):206-16. [pmid: 11242316].
19 Huang SC, Wei IP, Chien HL, et al. Effects of severity of degeneration on gait patterns in patients with medial knee osteoarthritis. Medical Engineering & Physics. Oct. 2008;30(8):997-1003. [pmid: 18417411].
20 Hurley MV, Walsh NE, Mitchell HL, et al. Economic evaluation of a rehabilitation program integrating exercise, self-management, and active coping strategies for chronic knee pain. Arthritis Rheum. Oct. 15. 2007;57(7):1220-9. [pmid: 17907207].
21 Iwamoto J, Takeda T, Ichimura S. Forearm bone mineral density in postmenopausal women with osteoarthritis of the knee. J Orthop Sci. 2002;7(1):19-25. [pmid: 11819127].
22 Kakihana W, Akai M, Nakazawa K, et al. Inconsistent Knee Varus Moment Reduction Caused by a Lateral Wedge in Knee Osteoarthritis. American Journal of Physical Medicine and Rehabilitation. 2007;86(6):446-54. [pmid: 17515683].
23 Kauffmann C, Gravel P, Godbout B, et al. Computer-aided method for quantification of cartilage thickness and volume changes using MRI: validation study using a synthetic model. IEEE Transactions on Biomedical Engineering. Aug. 2003;50(8):978-88. [pmid: 12892325].
24 Marini S, Fasciglione GF, Monteleone G, et al. A correlation between knee cartilage degradation observed by arthroscopy and synovial proteinases activities. Clin Biochem. Jun. 2003;36(4):295-304. [pmid: 12810159].
25 Miller GD, Nicklas BJ, Davis CC, et al. Is serum leptin related to physical function and is it modifiable through weight loss and exercise in older adults with knee osteoarthritis?. Int J Obes Relat Metab Disord. Nov. 2004;28(11):1383-90. [pmid: 15278105].
26 Miller GD, Nicklas BJ, Loeser RF. Inflammatory biomarkers and physical function in older, obese adults with knee pain and self-reported osteoarthritis after intensive weight-loss therapy. J Am Geriatr Soc. Apr. 2008;56(4):644-51. [pmid: 18312558].
27 Moyer RF, Birmingham TB, Chesworth BM, et al. Alignment, body mass and their interaction on dynamic knee joint load in patients with knee osteoarthritis. Osteoarthritis Cartilage. Jul. 2010;18(7):888-93. [pmid: 20417288].
28 Naito K, Takahashi M, Kushida K, et al. Measurement of matrix metalloproteinases (MMPs) and tissue inhibitor of metalloproteinases-1 (TIMP-1) in patients with knee osteoarthritis: comparison with generalized osteoarthritis. Rheumatology. Jun. 1999;38(6):510-5. [pmid: 10402070].
29 Ogino S, Sasho T, Nakagawa K, et al. Detection of pain-related molecules in the subchondral bone of osteoarthritic knees. Clinical Rheumatology. Dec. 2009;28(12):1395-402. [pmid: 19730932].
30 Oosterveld FG, Rasker JJ. Effects of local heat and cold treatment on surface and articular temperature of arthritic knees. Arthritis Rheum. Nov. 1994;37(11):1578-82. [pmid: 7980668].
31 Qazi AA, Folkesson J, Pettersen PC, et al. Separation of healthy and early osteoarthritis by automatic quantification of cartilage homogeneity. Osteoarthritis & Cartilage. Oct. 2007;15(10):1199-206. [pmid: 17493841].
32 Reilly K, Barker K, Shamley D, et al. The role of foot and ankle assessment of patients with lower limb osteoarthritis. Physiotherapy. Sep. 2009;95(3):164-9. [pmid: 19635335].
33 Roos EM, Roos HP, Ekdahl C, et al. Knee injury and Osteoarthritis Outcome Score (KOOS)--validation of a Swedish version. Scand J Med Sci Sports. Dec. 1998;8(6):439-48. [pmid: 9863983].
34 Schmidt-Rohlfing B, Schneider U, Thomsen M, et al. Correlation of a novel matrix protein with the degree of cartilage degradation. Rheumatol Int. Aug. 2002;22(4):165-9. [pmid: 12172957].
35 Sevick MA, Bradham DD, Muender M, et al. Cost-effectiveness of aerobic and resistance exercise in seniors with knee osteoarthritis. Medicine & Science in Sports & Exercise. 2000;32(9):1534-40. [pmid: 10994901].
36 Sevick MA, Miller GD, Loeser RF, et al. Cost-effectiveness of exercise and diet in overweight and obese adults with knee osteoarthritis. Med Sci Sports Exerc. Jun. 2009;41(6):1167-74. [pmid: 19461553].
37 Spector TD, Hart DJ, Nandra D, et al. Low-level increases in serum C-reactive protein are present in early osteoarthritis of the knee and predict progressive disease. Arthritis Rheum. Apr. 1997;40(4):723-7. [pmid: 9125256].
38 Thiengwittayaporn S, Wetpiryakul P, Foosakun Y, et al. Comparison of the accuracy of quadriceps isometric exercise between using quadriceps education device (QED) and not using QED for osteoarthritic knee patients: a randomized controlled trial. Journal of the Medical Association of Thailand. Dec. Suppl 6. 2009;92:S33-8. [pmid: 20120663].
39 Thompson PW, Spector TD, James IT, et al. Urinary collagen crosslinks reflect the radiographic severity of knee osteoarthritis. British Journal of Rheumatology. Nov. 1992;31(11):759-61. [pmid: 1450798].
40 Tiderius CJ, Olsson LE, Leander P, et al. Delayed gadolinium-enhanced MRI of cartilage (dGEMRIC) in early knee osteoarthritis. Magn Reson Med. Mar. 2003;49(3):488-92. [pmid: 12594751].
41 van Gool CH, Penninx BW, Kempen GI, et al. Determinants of high and low attendance to diet and exercise interventions among overweight and obese older adults. Results from the arthritis, diet, and activity promotion trial. Contemporary Clinical Trials. 2006;27(3):227-37. [pmid: 16387555].
42 Vignon E, Piperno M, Le Graverand MP, et al. Measurement of radiographic joint space width in the tibiofemoral compartment of the osteoarthritic knee: comparison of standing anteroposterior and Lyon schuss views. Arthritis Rheum. Feb. 2003;48(2):378-84. [pmid: 12571846].
43 Watt EW, Bui AA. Evaluation of a dynamic bayesian belief network to predict osteoarthritic knee pain using data from the osteoarthritis initiative. AMIA Annu Symp Proc. 2008:788-92. [pmid: 18999030].
44 Wright JG, Young NL. The patient-specific index: asking patients what they want. J Bone Joint Surg Am. Jul. 1997;79(7):974-83. [pmid: 9234873].

## Not Eligible Target Population

1 Ipach I, Schafer R, Lahrmann J, et al. Stiffness after knee arthrotomy: evaluation of prevalence and results after manipulation under anaesthesia. Orthopaedics & traumatology, surgery & research. May. 2011;97(3):292-6. [pmid: 21481664].
2 Rossi MD, Brown LE, Whitehurst M. Knee extensor function before and 1 year after simultaneous bilateral total knee arthroplasty: is there asymmetry between limbs?. Am J Orthop (Belle Mead NJ). Jan. 2011;40(1):29-33. [pmid: 21720583].
3 Stevens-Lapsley JE, Schenkman ML, Dayton MR. Comparison of self-reported knee injury and osteoarthritis outcome score to performance measures in patients after total knee arthroplasty. Pm & R. Jun. 2011;3(6):541-9. quiz 9. [pmid: 21665167].
4 Thorlund JB, Roos EM, Aagaard P. Neuromuscular function during stair descent in meniscectomized patients and controls. Med Sci Sports Exerc. Jul. 2011;43(7):1272-9. [pmid: 21131867].
5 van Jonbergen HP, Scholtes VA, van Kampen A, et al. A randomised, controlled trial of circumpatellar electrocautery in total knee replacement without patellar resurfacing. J Bone Joint Surg Br. Aug. 2011;93(8):1054-9. [pmid: 21768628].
6 Williams NH, Amoakwa E, Belcher J, et al. Activity Increase Despite Arthritis (AIDA): phase II randomised controlled trial of an active management booklet for hip and knee osteoarthritis in primary care. Br J Gen Pract. Aug. 2011;61(589):e452-8. [pmid: 21801537].
7 Metabolic Risk Factors Questionnaire. The Journal of rheumatology. 1995;22(Journal Article):1118-23. [pmid: 7674240].
8 Western Ontario and McMaster Universities Osteoarthritis Index. Journal of Rheumatology. 1995;22(Journal Article):1193-6. [pmid: 7674255].
9 Kellgren-Lawrence Scales. Journal of Rheumatology. 1997;24(Journal Article):702-7. [pmid: 9101505].
10 Framingham Physical Activity Index. Arthritis and Rheumatism. 1997;40(Journal Article):728-33. [pmid: 9125257].
11 Adams ME, Ho YA. Localization of glycosaminoglycans in human and canine menisci and their attachments. Connect Tissue Res. 1987;16(3):269-79. [pmid: 2956053].
12 Ageberg E, Link A, Roos EM. Feasibility of neuromuscular training in patients with severe hip or knee OA: the individualized goal-based NEMEX-TJR training program. BMC Musculoskelet Disord. 2010;11:126. [pmid: 20565735].
13 Aichroth PM. A Knee Function Assessment Chart. The Journal of Bone and Joint Surgery. 1978;60-B(3):2.
14 Aiken AB, Harrison MM, Atkinson M, et al. Easing the burden for joint replacement wait times: the role of the expanded practice physiotherapist. Healthc Q. 2008;11(2):62-6. [pmid: 18362522].
15 Altman RD, Abadie E, Avouac B, et al. Total joint replacement of hip or knee as an outcome measure for structure modifying trials in osteoarthritis. Osteoarthritis & Cartilage. Jan. 2005;13(1):13-9. [pmid: 15639632].
16 AlvarezNemegyei J, BautistaBotello A, DavilaVelazquez J. Association of complementary or alternative medicine use with quality of life, functional status or cumulated damage in chronic rheumatic diseases. Clinical rheumatology. 2009;28(5):547-51. [pmid: 19139949].
17 Anderson C, Laubscher S, Burns R. Validation of the Short Form 36 (SF-36) health survey questionnaire among stroke patients. Stroke. Oct. 1996;27(10):1812-6. [pmid: 8841336].
18 Anderson JJ, Ruwe M, Miller DR, et al. Relative costs and effectiveness of specialist and general internist ambulatory care for patients with 2 chronic musculoskeletal conditions. Journal of Rheumatology. 2002;29(7):1488-95. [pmid: 12136910].
19 Andresen EM, Fouts BS, Romeis JC, et al. Performance of health-related quality-of-life instruments in a spinal cord injured population. Arch Phys Med Rehabil. Aug. 1999;80(8):877-84. [pmid: 10453762].
20 Andriacchi TP, Briant PL, Bevill SL, et al. Rotational changes at the knee after ACL injury cause cartilage thinning. Clin Orthop Relat Res. Jan. 2006;442:39-44. [pmid: 16394737].
21 Andriolo RB, El Dib RP, Ramos L, et al. Aerobic exercise training programmes for improving physical and psychosocial health in adults with Down syndrome. Cochrane Database Syst Rev. 2010;(5):CD005176. [pmid: 20464738].
22 Angst F, Aeschlimann A, Steiner W, et al. Responsiveness of the WOMAC osteoarthritis index as compared with the SF-36 in patients with osteoarthritis of the legs undergoing a comprehensive rehabilitation intervention. Annals of the Rheumatic Diseases. 2001;60(9):834-40. [pmid: 11502609].
23 Anne Reilly K, Louise Barker K, Shamley D, et al. Influence of foot characteristics on the site of lower limb osteoarthritis. Foot Ankle Int. Mar. 2006;27(3):206-11. [pmid: 16539904].
24 Arden NK, Lane NE, Parimi N, et al. Defining incident radiographic hip osteoarthritis for epidemiologic studies in women. Arthritis & Rheumatism. Apr. 2009;60(4):1052-9. [pmid: 19333950].
25 Arnold CM, Faulkner RA. The effect of aquatic exercise and education on lowering fall risk in older adults with hip osteoarthritis. J Aging Phys Act. Jul. 2010;18(3):245-60. [pmid: 20651413].
26 Assche DV, Caspel DV, Staes F, et al. Implementing one standardized rehabilitation protocol following autologous chondrocyte implantation or microfracture in the knee results in comparable physical therapy management. Physiother Theory Pract. Feb. 2011;27(2):125-36. [pmid: 20690878].
27 Auleley GR, Giraudeau B, Dougados M, et al. Radiographic assessment of hip osteoarthritis progression: impact of reading procedures for longitudinal studies. Annals of the Rheumatic Diseases. Jun. 2000;59(6):422-7. [pmid: 10834858].
28 Bach CM, Biedermann R, Goebel G, et al. Reproducible assessment of radiolucent lines in total knee arthroplasty. Clinical Orthopaedics & Related Research. 2005;(434):183-8. [pmid: 15864050].
29 Bachmann GF, Basad E, Rauber K, et al. Degenerative joint disease on MRI and physical activity: a clinical study of the knee joint in 320 patients. European Radiology. 1999;9(1):145-52. [pmid: 9933399].
30 Badhe N, Dewnany G, Livesley PJ. Should the patella be replaced in total knee replacement?. International Orthopaedics. 2001;25(2):97-9. [pmid: 11409461].
31 Bae DK, Yoon KH, Song SJ. Cartilage healing after microfracture in osteoarthritic knees. Arthroscopy. 2006;22(4):367-74. [pmid: 16581448].
32 Bae SC, Lee HS, Yun HR, et al. Cross-cultural adaptation and validation of Korean Western Ontario and McMaster Universities (WOMAC) and Lequesne osteoarthritis indices for clinical research. Osteoarthritis Cartilage. Nov. 2001;9(8):746-50. [pmid: 11795994].
33 Baeten D, Peene I, Union A, et al. Specific presence of intracellular citrullinated proteins in rheumatoid arthritis synovium: relevance to antifilaggrin autoantibodies. Arthritis Rheum. Oct. 2001;44(10):2255-62. [pmid: 11665966].
34 Baker V, Bennell K, Stillman B, et al. Abnormal knee joint position sense in individuals with patellofemoral pain syndrome. J Orthop Res. Mar. 2002;20(2):208-14. [pmid: 11918299].
35 Barrios JA, Davis IS, Higginson JS, et al. Lower extremity walking mechanics of young individuals with asymptomatic varus knee alignment. Journal of Orthopaedic Research. 2009;27(11):9. [pmid: 1414].
36 Basora M, Deulofeu R, Salazar F, et al. Improved preoperative iron status assessment by soluble transferrin receptor in elderly patients undergoing knee and hip replacement. Clin Lab Haematol. Dec. 2006;28(6):370-5. [pmid: 17105489].
37 Berend ME, Ritter MA, Meding JB, et al. Tibial component failure mechanisms in total knee arthroplasty. Clinical Orthopaedics & Related Research. 2004;(428):26-34. [pmid: 15534515].
38 Beyaert C, Haumont T, Paysant J, et al. The effect of inturning of the foot on knee kinematics and kinetics in children with treated idiopathic clubfoot. Clinical Biomechanics. 2003;18(7):670-6. [pmid: 12880715].
39 Bhattacharya R, Kumar V, Safawi E, et al. The knee skyline radiograph: its usefulness in the diagnosis of patello-femoral osteoarthritis. Int Orthop. Apr. 2007;31(2):247-52. [pmid: 16783548].
40 Binder EF, Schechtman KB, Ehsani AA, et al. Effects of exercise training on frailty in community-dwelling older adults: results of a randomized, controlled trial. J Am Geriatr Soc. Dec. 2002;50(12):1921-8. [pmid: 12473001].
41 Binkley JM, Stratford PW, Lott SA, et al. The Lower Extremity Functional Scale (LEFS): scale development, measurement properties, and clinical application. North American Orthopaedic Rehabilitation Research Network. Phys Ther. Apr. 1999;79(4):371-83. [pmid: 10201543].
42 Birmingham TB, Hunt MA, Jones IC, et al. Test-retest reliability of the peak knee adduction moment during walking in patients with medial compartment knee osteoarthritis. Arthritis Rheum. Aug. 15. 2007;57(6):1012-7. [pmid: 17665490].
43 Bittner V, Weiner DH, Yusuf S, et al. Prediction of mortality and morbidity with a 6-minute walk test in patients with left ventricular dysfunction. SOLVD Investigators. JAMA. Oct. 13. 1993;270(14):1702-7. [pmid: 8411500].
44 Boeer J, Mueller O, Krauss I, et al. Effects of a sensory-motor exercise program for older adults with osteoarthritis or prosthesis of the hip using measurements made by the Posturomed oscillatory platform. Journal of Geriatric Physical Therapy. Jan–Mar. 2010;33(1):10-5. [pmid: 20503728].
45 Bohannon RW. Comfortable and maximum walking speed of adults aged 20– 79 years: reference values and determinants. Age & Ageing. Jan. 1997;26(1):15-9. [pmid: 9143432].
46 Bombardier C, Melfi CA, Paul J, et al. Comparison of a generic and a disease-specific measure of pain and physical function after knee replacement surgery. Med Care. Apr. 1995;33(4 Suppl):AS131-44. [pmid: 7723441].
47 Borjesson M, Weidenhielm L, Elfving B, et al. Tests of walking ability at different speeds in patients with knee osteoarthritis. Physiotherapy Research International. Jun. 2007;12(2):115-21. [pmid: 17536649].
48 Brooks S, Morgan M. Accuracy of clinical diagnosis in knee arthroscopy. Annals of the Royal College of Surgeons of England. Jul. 2002;84(4):265-8. [pmid: 12215031].
49 Brosseau L, Casimiro L, Welch V, et al. Therapeutic ultrasound for treating patellofemoral pain syndrome. Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2001.
50 Brown MD, Gomez-Marin O, Brookfield KFW, et al. Differential diagnosis of hip disease versus spine disease. Clinical Orthopaedics & Related Research. Feb. 2004;(419):280-4. [pmid: 15021166].
51 Browning RC, Kram R. Effects of Obesity on the Biomechanics of Walking at Different Speeds. Med Sci Sport Exerc. Sep. 2007;39(9):41.
52 Bruni D, Iacono F, Russo A, et al. Minimally invasive unicompartmental knee replacement: retrospective clinical and radiographic evaluation of 83 patients. Knee Surgery, Sports Traumatology, Arthroscopy. Jun. 2010;18(6):710-7. [pmid: 19763541].
53 Bruyere O, Henrotin YE, Honore A, et al. Impact of the joint space width measurement method on the design of knee osteoarthritis studies. Aging Clin Exp Res. Apr. 2003;15(2):136-41. [pmid: 12889845].
54 Buszewicz M, Rait G, Griffin M, et al. Self management of arthritis in primary care: randomised controlled trial. BMJ. 2006;333(7574):879. [pmid: 17040926].
55 Cahalin L, Pappagianopoulos P, Prevost S, et al. The relationship of the 6-min walk test to maximal oxygen consumption in transplant candidates with end-stage lung disease. Chest. Aug. 1995;108(2):452-9. [pmid: 7634883].
56 Cahalin LP, Mathier MA, Semigran MJ, et al. The six-minute walk test predicts peak oxygen uptake and survival in patients with advanced heart failure. Chest. Aug. 1996;110(2):325-32. [pmid: 8697828].
57 Calder JD, Hine AL, Pearse MF, et al. The relationship between osteonecrosis of the proximal femur identified by MRI and lesions proven by histological examination. Journal of Bone & Joint Surgery - British Volume. Feb. 2008;90(2):154-8. [pmid: 18256080].
58 Callaghan MJ, McCarthy CJ, Oldham J. The reliability of surface electromyography to assess quadriceps fatigue during multi joint tasks in healthy and painful knees. Journal of Electromyography and Kinesiology. 2009;19(1):172-80. [pmid: 17629711].
59 Chaganti RK, Kelman A, Lui L, et al. Change in serum measurements of cartilage oligomeric matrix protein and association with the development and worsening of radiographic hip osteoarthritis. Osteoarthritis & Cartilage. May. 2008;16(5):566-71. [pmid: 17950630].
60 Cheing GL, HuiChan CW. The motor dysfunction of patients with knee osteoarthritis in a Chinese population. Arthritis Care and Research. 2001;45(1):62-8. [pmid: 11308063].
61 Chen HL, Lu TW, Wang TM, et al. Biomechanical strategies for successful obstacle crossing with the trailing limb in older adults with medial compartment knee osteoarthritis. Journal of Biomechanics. 2008;41(4):753-61. [pmid: 18177877].
62 Chevalier X, Conrozier T, Gehrmann M, et al. Tissue inhibitor of metalloprotease-1 (TIMP-1) serum level may predict progression of hip osteoarthritis. Osteoarthritis & Cartilage. May. 2001;9(4):300-7. [pmid: 11399093].
63 Chevalier X, Marre JP, de Butler J, et al. Questionnaire survey of management and prescription of general practitioners in knee osteoarthritis: a comparison with 2000 EULAR recommendations. Clinical & Experimental Rheumatology. Mar–Apr. 2004;22(2):205-12. [pmid: 15083888].
64 Chien MY, Huang TY, Wu YT. Prevalence of sarcopenia estimated using a bioelectrical impedance analysis prediction equation in community-dwelling elderly people in Taiwan. J Am Geriatr Soc. Sep. 2008;56(9):1710-5. [pmid: 18691288].
65 Chokkhanchitchai S, Tangarunsanti T, Jaovisidha S, et al. The effect of religious practice on the prevalence of knee osteoarthritis. Clin Rheumatol. Jan. 2010;29(1):39-44. [pmid: 19830384].
66 Chow TP, Ng GY. Active, passive and proprioceptive neuromuscular facilitation stretching are comparable in improving the knee flexion range in people with total knee replacement: a randomized controlled trial. Clin Rehabil. Oct. 2010;24(10):911-8. [pmid: 20685725].
67 Chung WK, Liu D, Foo LSS. Mini-incision total hip replacement--surgical technique and early results. Journal of Orthopaedic Surgery. Jun. 2004;12(1):19-24. [pmid: 15237117].
68 Chung YL, Mitchell HL, Houssien DA, et al. A comparative study of outcome in myositis and other musculoskeletal disorders assessed using the Nottingham health profile. Clin Exp Rheumatol. Jul–Aug. 2001;19(4):447-50. [pmid: 11491502].
69 Cicuttini FM, Wluka AE, Wang Y, et al. Compartment differences in knee cartilage volume in healthy adults. J Rheumatol. Mar. 2002;29(3):554-6. [pmid: 11908572].
70 Cila E, Guzel V, Ozalay M, et al. Subvastus versus medial parapatellar approach in total knee arthroplasty. Archives of Orthopaedic & Trauma Surgery. Mar. 2002;122(2):65-8. [pmid: 11880904].
71 Claessens AA, Schouten JS, van den Ouweland FA, et al. Do clinical findings associate with radiographic osteoarthritis of the knee?. Ann Rheum Dis. Oct. 1990;49(10):771-4. [pmid: 2241266].
72 Clemens U, Miehlke RK. Experience using the latest OrthoPilot TKA software: a comparative study. Surgical Technology International. 2003;11:265-73. [pmid: 12931310].
73 Confalonieri N, Manzotti A, Pullen C, et al. Computer-assisted technique versus intramedullary and extramedullary alignment systems in total knee replacement: a radiological comparison. Acta Orthopaedica Belgica. Dec. 2005;71(6):703-9. [pmid: 16459861].
74 Conrozier T, Chappuis-Cellier C, Richard M, et al. Increased serum C-reactive protein levels by immunonephelometry in patients with rapidly destructive hip osteoarthritis. Revue du Rhumatisme (English Edition). Dec. 1998;65(12):759-65. [pmid: 9923044].
75 Conrozier T, Saxne T, Fan CS, et al. Serum concentrations of cartilage oligomeric matrix protein and bone sialoprotein in hip osteoarthritis: a one year prospective study. Annals of the Rheumatic Diseases. Sep. 1998;57(9):527-32. [pmid: 9849311].
76 Cook JL, Kuroki K, Kenter K, et al. Bipolar and monopolar radiofrequency treatment of osteoarthritic knee articular cartilage: acute and temporal effects on cartilage compressive stiffness, permeability, cell synthesis, and extracellular matrix composition. The Journal of Knee Surgery. Apr. 2004;17(2):99-108. [pmid: 15124662].
77 Coulter CL, Weber JM, Scarvell JM. Group physiotherapy provides similar outcomes for participants after joint replacement surgery as 1-to-1 physiotherapy: a sequential cohort study. Arch Phys Med Rehabil. Oct. 2009;90(10):1727-33. [pmid: 19801063].
78 Cowan DN, Jones BH, Robinson JR. Foot morphologic characteristics and risk of exercise-related injury. Arch Fam Med. Jul. 1993;2(7):773-7. [pmid: 7906597].
79 Cowan SM, Bennell KL, Crossley KM, et al. Physical therapy alters recruitment of the vasti in patellofemoral pain syndrome. Med Sci Sports Exerc. Dec. 2002;34(12):1879-85. [pmid: 12471291].
80 Cowan SM, Bennell KL, Hodges PW, et al. Delayed onset of electromyographic activity of vastus medialis obliquus relative to vastus lateralis in subjects with patellofemoral pain syndrome. Arch Phys Med Rehabil. Feb. 2001;82(2):183-9. [pmid: 11239308].
81 Cowan SM, Bennell KL, Hodges PW, et al. Simultaneous feedforward recruitment of the vasti in untrained postural tasks can be restored by physical therapy. J Orthop Res. May. 2003;21(3):553-8. [pmid: 12706031].
82 Cowan SM, Blackburn MS, McMahon K, et al. Current Australian physiotherapy management of hip osteoarthritis. Physiotherapy. Dec. 2010;96(4):289-95. [pmid: 21056163].
83 Cowan SM, Hodges PW, Bennell KL, et al. Altered vastii recruitment when people with patellofemoral pain syndrome complete a postural task. Arch Phys Med Rehabil. Jul. 2002;83(7):989-95. [pmid: 12098160].
84 Cowan SM, Hodges PW, Crossley KM, et al. Patellar taping does not change the amplitude of electromyographic activity of the vasti in a stair stepping task. Br J Sports Med. Jan. 2006;40(1):30-4. [pmid: 16371487].
85 Crossley K, Bennell K, Green S, et al. Physical therapy for patellofemoral pain: a randomized, double-blinded, placebo-controlled trial. American Journal of Sports Medicine. Nov–Dec. 2002;30(6):857-65. [pmid: 12435653].
86 Crossley KM, Cowan SM, McConnell J, et al. Physical therapy improves knee flexion during stair ambulation in patellofemoral pain. Med Sci Sports Exerc. Feb. 2005;37(2):176-83. [pmid: 15692311].
87 Crossley KM, Vicenzino B, Pandy MG, et al. Targeted physiotherapy for patellofemoral joint osteoarthritis: a protocol for a randomised, single-blind controlled trial. BMC Musculoskeletal Disorders. 2008;9:122. [pmid: 18793446].
88 Dahaghin S, Tehrani-Banihashemi SA, Faezi ST, et al. Squatting, sitting on the floor, or cycling: are life-long daily activities risk factors for clinical knee osteoarthritis? Stage III results of a community-based study. Arthritis & Rheumatism. Oct. 15. 2009;61(10):1337-42. [pmid: 19790110].
89 Dahle LK, Mueller MJ, Delitto A, et al. Visual assessment of foot type and relationship of foot type to lower extremity injury. Journal of Orthopaedic & Sports Physical Therapy. 1991;14(2):70-4. [pmid: 18796826].
90 Dai SM, Han XH, Zhao DB, et al. Prevalence of rheumatic symptoms, rheumatoid arthritis, ankylosing spondylitis, and gout in Shanghai, China: a COPCORD study. J Rheumatol. Oct. 2003;30(10):2245-51. [pmid: 14528524].
91 Davies GM, Watson DJ, Bellamy N. Comparison of the responsiveness and relative effect size of the western Ontario and McMaster Universities Osteoarthritis Index and the short-form Medical Outcomes Study Survey in a randomized, clinical trial of osteoarthritis patients. Arthritis Care Res. Jun. 1999;12(3):172-9. [pmid: 10513507].
92 Davis AM, Perruccio AV, Canizares M, et al. Comparative, validity and responsiveness of the HOOS-PS and KOOS-PS to the WOMAC physical function subscale in total joint replacement for osteoarthritis. Osteoarthritis & Cartilage. 2009;17(7):843-7. [pmid: 19215728].
93 Dawson J, Juszczak E, Thorogood M, et al. Distant past exercise in women: measures may be reliable, but are they valid? Medicine & Science in Sports &. Exercise. 2003;35(5):862-6. [pmid: 12750598].
94 de Groot IB, Bussmann JB, Stam HJ, et al. Actual everyday physical activity in patients with end-stage hip or knee osteoarthritis compared with healthy controls. Osteoarthritis and Cartilage. 2008;16(4):436-42. [pmid: 17900934].
95 de Groot IB, Reijman M, Terwee CB, et al. Validation of the Dutch version of the Hip disability and Osteoarthritis Outcome Score. Osteoarthritis & Cartilage. Jan. 2007;15(1):104-9. [pmid: 16890460].
96 Deshmukh AJ, Thakur RR, Goyal A, et al. Accuracy of diagnostic injection in differentiating source of atypical hip pain. J Arthroplasty. Sep. 2010;25(6 Suppl):129-33. [pmid: 20570105].
97 DeVita P, Hortobagyi T. Obesity is not associated with increased knee joint torque and power during level walking. Journal of Biomechanics. Sep. 2003;36(9):62. [pmid: 12893044].
98 Dixon J, Howe TE. Activation of vastus medialis oblique is not delayed in patients with osteoarthritis of the knee compared to asymptomatic participants during open kinetic chain activities. Manual Therapy. 2007;12(3):219-25. [pmid: 16971164].
99 Dougherty CM, Dewhurst T, Nichol WP, et al. Comparison of three quality of life instruments in stable angina pectoris: Seattle Angina Questionnaire, Short Form Health Survey (SF-36), and Quality of Life Index-Cardiac Version III. J Clin Epidemiol. Jul. 1998;51(7):569-75. [pmid: 9674663].
100 DRKS00000401. CTS 100 - Comparison of electronic-balanced energy extraction vs. cryotherapy after TKR 2010.
101 Du H, Chen SL, Bao CD, et al. Prevalence and risk factors of knee osteoarthritis in Huang-Pu District, Shanghai, China. Rheumatol Int. Oct. 2005;25(8):585-90. [pmid: 15309503].
102 Duncan R, Peat G, Thomas E, et al. How do pain and function vary with compartmental distribution and severity of radiographic knee osteoarthritis?. Rheumatology. Nov. 2008;47(11):1704-7. [pmid: 18805874].
103 Ebert JR, Robertson WB, Lloyd DG, et al. Traditional vs accelerated approaches to post-operative rehabilitation following matrix-induced autologous chondrocyte implantation (MACI): comparison of clinical, biomechanical and radiographic outcomes. Osteoarthritis & Cartilage. 2008;16(10):1131-40. [pmid: 18434214].
104 Eingartner C, Volkmann R, Winter E, et al. Results of a cemented titanium alloy straight femoral shaft prosthesis after 10 years of follow-up. International Orthopaedics. 2001;25(2):81-4. [pmid: 11409457].
105 Eitzen I, Moksnes H, Oiestad BE, et al. Total Rupture at the Anterior Cruciate Ligament - Testing of Function, Rehabilitation, and Long Term Implications. Fysioterapeuten. 2008;2008(11):22-8.
106 Elkayam O, Wigler I, Tishler M, et al. Effect of spa therapy in Tiberias on patients with rheumatoid arthritis and osteoarthritis. J Rheumatol. Dec. 1991;18(12):1799-803. [pmid: 1795315].
107 Elleuch MH, Guermazi M, Mezghanni M, et al. Knee osteoarthritis in 50 former top-level soccer players: a comparative study. Ann Readapt Med Phys. Apr. 2008;51(3):174-8. [pmid: 18374445].
108 Elliott AL, Kraus VB, Fang F, et al. Joint-specific hand symptoms and self-reported and performance-based functional status in African Americans and Caucasians: The Johnston County Osteoarthritis Project. Annals of the Rheumatic Diseases. Dec. 2007;66(12):1622-6. [pmid: 17504840].
109 Emrani A, Reza Hadian M, Reza Olyaei G. Isokinetic Strength and Functional Status in Knee Osteoarthritis. Journal of Physical Therapy Science. 2006;19(2):107-14.
110 Engh CA, Massin P, Suthers KE. Roentgenographic assessment of the biologic fixation of porous-surfaced femoral components. [Erratum appears in Clin Orthop 1992 Nov;(284):310–2]. Clinical Orthopaedics & Related Research. Aug. 1990;(257):107-28. [pmid: 2199114].
111 Englund M. The role of the meniscus in osteoarthritis genesis. Rheumatic Diseases Clinics of North America. Aug. 2008;34(3):573-9. [pmid: 18687273].
112 Epifanio I, Avila C, Page A, et al. Analysis of multiple waveforms by means of functional principal component analysis: normal versus pathological patterns in sit-to-stand movement. Medical & Biological Engineering & Computing. Jun. 2008;46(6):551-61. [pmid: 18392871].
113 Esmat N. Treatment of arthrosis deformans by simultaneous application of interferential current and ultrasonic waves. J Egypt Med Assoc. 1975;58(5–6):328-33. [pmid: 1085303].
114 Faraj AA, Kumaraguru P, Kosygan K. Intra-articular bupivacaine hip injection in differentiation of coxarthrosis from referred thigh pain: a 10 year study. Acta Orthopaedica Belgica. Dec. 2003;69(6):518-21. [pmid: 14748108].
115 Fernandes L, Storheim K, Nordsletten L, et al. Development of a therapeutic exercise program for patients with osteoarthritis of the hip. Phys Ther. Apr. 2010;90(4):592-601. [pmid: 20185613].
116 Fernandez-Chimeno M, Houghton Pamela E, Holey L. Electrical stimulation for chronic wounds. Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2004.
117 Fernandez-Lopez JC, Laffon A, Blanco FJ, et al. Prevalence, risk factors, and impact of knee pain suggesting osteoarthritis in Spain. Clin Exp Rheumatol. Mar–Apr. 2008;26(2):324-32. [pmid: 18565256].
118 Filippucci E, Riveros MG, Georgescu D, et al. Hyaline cartilage involvement in patients with gout and calcium pyrophosphate deposition disease. An ultrasound study. Osteoarthritis Cartilage. Feb. 2009;17(2):178-81. [pmid: 18657999].
119 Fink B, Makowiak C, Fuerst M, et al. The value of synovial biopsy, joint aspiration and C-reactive protein in the diagnosis of late peri-prosthetic infection of total knee replacements. Journal of Bone & Joint Surgery - British Volume. Jul. 2008;90(7):874-8. [pmid: 18591595].
120 Fitts SS, Guthrie MR. Six-minute walk by people with chronic renal failure. Assessment of effort by perceived exertion. Am J Phys Med Rehabil. Jan–Feb. 1995;74(1):54-8. [pmid: 7873114].
121 Fitzsimmons SE, Vazquez EA, Bronson MJ. How to treat the stiff total knee arthroplasty?: a systematic review. Clinical Orthopaedics & Related Research. 2010;468(4):1096-106. [pmid: 20087698].
122 Foroughi N, Smith RM, Lange AK, et al. Dynamic alignment and its association with knee adduction moment in medial knee osteoarthritis. Knee. Jun. 2010;17(3):210-6. [pmid: 19896383].
123 Franklin J, Ingvarsson T, Englund M, et al. Natural history of radiographic hip osteoarthritis: A retrospective cohort study with 11–28 years of followup. Arthritis Care Res (Hoboken). May. 2011;63(5):689-95. [pmid: 21557524].
124 Franz JR, Dicharry J, O Riley P, et al. The Influence of Arch Supports on Knee Torques Relevant to Knee Osteoarthritis. Medicine and science in sports and exercise. 2008;40(5):913-7. [pmid: 18408606].
125 Frost H, Lamb SE, Robertson S. A randomized controlled trial of exercise to improve mobility and function after elective knee arthroplasty. Feasibility, results and methodological difficulties. Clin Rehabil. Mar. 2002;16(2):200-9. [pmid: 11911518].
126 Fusi S, Campailla E, Causero A, et al. The locomotory index: a new proposal for evaluating walking impairments. Int J Sports Med. Feb. 2002;23(2):105-11. [pmid: 11842357].
127 Gammaitoni AR, Galer BS, Onawola R, et al. Lidocaine patch 5% and its positive impact on pain qualities in osteoarthritis: results of a pilot 2-week, open-label study using the Neuropathic Pain Scale. Current Medical Research & Opinion. Suppl 2. 2004;20:S13-9. [pmid: 15563742].
128 Garfinkel MS, Schumacher HR Jr, Husain A, et al. Evaluation of a yoga based regimen for treatment of osteoarthritis of the hands. J Rheumatol. Dec. 1994;21(12):2341-3. [pmid: 7699639].
129 Garnero P, Charni N, Juillet F, et al. Increased urinary type II collagen helical and C telopeptide levels are independently associated with a rapidly destructive hip osteoarthritis. Annals of the Rheumatic Diseases. Dec. 2006;65(12):1639-44. [pmid: 16569684].
130 Garnero P, Conrozier T, Christgau S, et al. Urinary type II collagen C-telopeptide levels are increased in patients with rapidly destructive hip osteoarthritis. Annals of the Rheumatic Diseases. Oct. 2003;62(10):939-43. [pmid: 12972471].
131 Geiger F, Schneider U, Lukoschek M, et al. External fixation in proximal tibial osteotomy: a comparison of three methods. International Orthopaedics. 1999;23(3):160-3. [pmid: 10486028].
132 Giaquinto S, Ciotola E, Dall'armi V, et al. Hydrotherapy after total hip arthroplasty: a follow-up study. Archives of Gerontology & Geriatrics. Jan–Feb. 2010;50(1):92-5. [pmid: 19282040].
133 Gibbons CE, Solan MC, Ricketts DM, et al. Cryotherapy compared with Robert Jones bandage after total knee replacement: a prospective randomized trial. International Orthopaedics. 2001;25(4):250-2. [pmid: 11561502].
134 Gibson JN, Morrison WL, Scrimgeour CM, et al. Effects of therapeutic percutaneous electrical stimulation of atrophic human quadriceps on muscle composition, protein synthesis and contractile properties. European Journal of Clinical Investigation. Apr. 1989;19(2):206-12. [pmid: 2499480].
135 Gill TM, Baker DI, Gottschalk M, et al. A program to prevent functional decline in physically frail, elderly persons who live at home. New England Journal of Medicine. Oct. 3. 2002;347(14):1068-74. [pmid: 12362007].
136 Godfrey CM, Jayawardena H, Quance TA, et al. Comparison of electro-stimulation and isometric exercise in strengthening the quadriceps muscle. Physiotherapy Canada. 1979;31(5):265-7.
137 Goerres GW, Frey D, Hany TF, et al. Digital X-ray radiogrammetry better identifies osteoarthritis patients with a low bone mineral density than quantitative ultrasound. Eur Radiol. Apr. 2007;17(4):965-74. [pmid: 16953374].
138 Golec J, Rozek K, Kazana M. Assesment scores of functional efficiency in hip osteoathritis. Ortopedia Traumatologia Rehabilitacja. May–Jun. 2010;12(3):273-7. [pmid: 20675869].
139 Golightly YM, Hannan MT, Shi XA, et al. Association of foot symptoms with self-reported and performance-based measures of physical function: The Johnston County osteoarthritis project. Arthritis Care Res (Hoboken). May. 2011;63(5):654-9. [pmid: 21225678].
140 Gomes Carreira AC, Jones A, Natour J. Assessment of the effectiveness of a functional splint for osteoarthritis of the trapeziometacarpal joint on the dominant hand: a randomized controlled study. Journal of Rehabilitation Medicine. May. 2010;42(5):469-74. [pmid: 20544159].
141 Gorski JA, Westbrook AC. Use of differential reinforcement to treat medical non-compliance in a paediatric patient with leukocyte adhesion deficiency. Pediatric Rehabilitation. Jan–Mar. 2002;5(1):29-35. [pmid: 12396849].
142 Green CP, Porter CB, Bresnahan DR, et al. Development and evaluation of the Kansas City Cardiomyopathy Questionnaire: a new health status measure for heart failure. J Am Coll Cardiol. Apr. 2000;35(5):1245-55. [pmid: 10758967].
143 Gremeaux V, Renault J, Pardon L, et al. Low-frequency electric muscle stimulation combined with physical therapy after total hip arthroplasty for hip osteoarthritis in elderly patients: a randomized controlled trial. Arch Phys Med Rehabil. Dec. 2008;89(12):2265-73. [pmid: 19061737].
144 Griffin JE, Echternach JL, Bowmaker KL. Results of frequency differences in ultrasonic therapy. Phys Ther. Apr. 1970;50(4):481-6. [pmid: 5434953].
145 Gulmans VA, van Veldhoven NH, de Meer K, et al. The six-minute walking test in children with cystic fibrosis: reliability and validity. Pediatr Pulmonol. Aug. 1996;22(2):85-9. [pmid: 8875580].
146 Guyatt GH, Sullivan MJ, Thompson PJ, et al. The 6-minute walk: a new measure of exercise capacity in patients with chronic heart failure. Can Med Assoc J. Apr. 15. 1985;132(8):919-23. [pmid: 3978515].
147 Hamilton DM, Haennel RG. Validity and reliability of the 6-minute walk test in a cardiac rehabilitation population. J Cardiopulm Rehabil. May–Jun. 2000;20(3):156-64. [pmid: 10860197].
148 Harding ML. Human meniscal chondrocyte culture and matrix infiltration with specific reference to meniscal generation. Knee. Mar. 2003;10(1):43-5. [pmid: 12649025].
149 Harris-Love MO, Shrader JA. Patellofemoral knee pain in an adult with radiographic osteoarthritis and human immunodeficiency virus infection. Journal of Orthopaedic & Sports Physical Therapy. Aug. 2009;39(8):612-7. [pmid: 19648722].
150 Hartwick M, Meeuwisse W, Vandertuin J, et al. Knee pain in the ACL-deficient osteoarthritic knee and its relationship to quality of life. Physiotherapy Research International. 2003;8(2):83-92. [pmid: 12879730].
151 Harvey WF, Yang M, Cooke TD, et al. Association of leg-length inequality with knee osteoarthritis a cohort study. Annals of Internal Medicine. 2010;152(5):287-95. [pmid: 20194234].
152 Hassan Mockett S, Doherty M. Static postural sway, proprioception, and maximal voluntary quadriceps contraction in patients with knee osteoarthritis and normal control subjects. Annals of the Rheumatic Diseases. 2001;60(6):612-8. [pmid: 11350851].
153 Havranek EP, McGovern KM, Weinberger J, et al. Patient preferences for heart failure treatment: utilities are valid measures of health-related quality of life in heart failure. J Card Fail. Jun. 1999;5(2):85-91. [pmid: 10404347].
154 Hawker GA, Wright JG, Coyte PC, et al. Differences between men and women in the rate of use of hip and knee arthroplasty. New England Journal of Medicine. Apr. 6. 2000;342(14):1016-22. [pmid: 10749964].
155 Heiden TL, Lloyd DG, Ackland TR. Knee extension and flexion weakness in people with knee osteoarthritis: is antagonist cocontraction a factor?. Journal of Orthopaedic & Sports Physical Therapy. Nov. 2009;39(11):807-15. [pmid: 19881006].
156 Henriksen M, Aaboe J, Simonsen EB, et al. Experimentally reduced hip abductor function during walking: Implications for knee joint loads. Journal of Biomechanics. Jun. 19. 2009;42(9):40.
157 Hettrich CM, Crawford D, Rodeo SA. Cartilage repair: third-generation cell-based technologies--basic science, surgical techniques, clinical outcomes. Sports Medicine & Arthroscopy Review. 2008;16(4):230-5. [pmid: 19011555].
158 Hillstrom HJ, Brower DJ, Bhimji S, et al. Assessment of conservative realignment therapies for the treatment of varus knee osteoarthritis: biomechanics and joint pathophysiology. Gait and Posture. 2000;11:170.
159 Hinman RS, Bennell KL, Metcalf BR, et al. Temporal activity of vastus medialis obliquus and vastus lateralis in symptomatic knee osteoarthritis. American Journal of Physical Medicine and Rehabilitation. 2002;81(9):684-90. [pmid: 12172521].
160 Hinman RS, Bennell KL, Metcalf BR, et al. Delayed onset of quadriceps activity and altered knee joint kinematics during stair stepping in individuals with knee osteoarthritis. Archives of Physical Medicine & Rehabilitation. 2002;83(8):1080-6. [pmid: 12161828].
161 Hinman RS, Cowan SM, Crossley KM, et al. Age-related changes in electromyographic quadriceps activity during stair descent. J Orthop Res. Mar. 2005;23(2):322-6. [pmid: 15734243].
162 Hochberg MC. Risk factors for the development and progression of hip osteoarthritis. Journal of Rheumatology. Jun. 2005;32(6):1135-6. [pmid: 15977344].
163 Hoeksma HL, Van Den Ende CHM, Ronday HK, et al. Comparison of the responsiveness of the Harris Hip Score with generic measures for hip function in osteoarthritis of the hip. Annals of the Rheumatic Diseases. Oct. 2003;62(10):935-8. [pmid: 12972470].
164 Holmberg S, Thelin A, Thelin N. Knee osteoarthritis and body mass index: a population-based case-control study. Scandinavian journal of rheumatology. 2005;34(1):59-64. [pmid: 15903028].
165 Holstege MS, Lindeboom R, Lucas C. Preoperative quadriceps strength as a predictor for short-term functional outcome after total hip replacement. Arch Phys Med Rehabil. Feb. 2011;92(2):236-41. [pmid: 21272719].
166 Hoyland JA, Thomas JT, Donn R, et al. Distribution of type X collagen mRNA in normal and osteoarthritic human cartilage. Bone Miner. Nov. 1991;15(2):151-63. [pmid: 1764631].
167 Hube R, Birke A, Hein W, et al. CT-based and fluoroscopy-based navigation for cup implantation in total hip arthroplasty (THA). Surgical Technology International. 2003;11:275-80. [pmid: 12931311].
168 Hughes SL, Edelman PL, Singer RH, et al. Joint impairment and self-reported disability in elderly persons. J Gerontol. Mar. 1993;48(2):S84-92. [pmid: 8473709].
169 Husby VS, Helgerud J, Bj, et al. Early postoperative maximal strength training improves work efficiency 6–12 months after osteoarthritis-induced total hip arthroplasty in patients younger than 60 years. American Journal of Physical Medicine & Rehabilitation. Apr. 2010;89(4):304-14. [pmid: 20134307].
170 Husby VS, Helgerud J, Bjorgen S, et al. Early maximal strength training is an efficient treatment for patients operated with total hip arthroplasty. Arch Phys Med Rehabil. Oct. 2009;90(10):1658-67. [pmid: 19801053].
171 Iannone F, Moretti B, Notarnicola A, et al. Extracorporeal shock waves increase interleukin-10 expression by human osteoarthritic and healthy osteoblasts in vitro. Clinical & Experimental Rheumatology. Sep–Oct. 2009;27(5):794-9. [pmid: 19917162].
172 Illgen RL 2nd, Honkamp NJ, Weisman MH, et al. The diagnostic and predictive value of hip anesthetic arthrograms in selected patients before total hip arthroplasty. Journal of Arthroplasty. Aug. 2006;21(5):724-30. [pmid: 16877160].
173 Jackson JL, O’Malley PG, Kroenke K. Evaluation of acute knee pain in primary care. Annals of Internal Medicine. Oct. 7. 2003;139(7):575-88. [pmid: 14530229].
174 Jacobs CA, Christensen CP. Correlations between knee society function scores and functional force measures. Clinical Orthopaedics & Related Research. Sep. 2009;467(9):2414-9. [pmid: 19343460].
175 Jaglal S, Lakhani Z, Schatzker J. Reliability, validity, and responsiveness of the lower extremity measure for patients with a hip fracture. J Bone Joint Surg Am. Jul. 2000;82-A(7):955-62. [pmid: 10901310].
176 Jitpraphai C, Cheamvaraporn K. Conservative management of degenerative knee: an experience with 508 cases at Ramathibodi Hospital. Journal of the Medical Association of Thailand. Jan. 1992;75(1):35-8. [pmid: 1602261].
177 Johanson NA, Liang MH, Daltroy L, et al. American Academy of Orthopaedic Surgeons lower limb outcomes assessment instruments. Reliability, validity, and sensitivity to change. J Bone Joint Surg Am. May. 2004;86-A(5):902-9. [pmid: 15118030].
178 Jones G, Glisson M, Hynes K, et al. Sex and site differences in cartilage development: a possible explanation for variations in knee osteoarthritis in later life. Arthritis & Rheumatism. Nov. 2000;43(11):2543-9. [pmid: 11083279].
179 Jung YB, Lee YS, Lee EY, et al. Comparison of the modified subvastus and medial parapatellar approaches in total knee arthroplasty. International Orthopaedics. Apr. 2009;33(2):419-23. [pmid: 18196241].
180 Kadikar A, Maurer J, Kesten S. The six-minute walk test: a guide to assessment for lung transplantation. J Heart Lung Transplant. Mar. 1997;16(3):313-9. [pmid: 9087875].
181 Kanekasu K, Kondo M, Kadoya Y. Axial radiography of the distal femur to assess rotational alignment in total knee arthroplasty. Clinical Orthopaedics & Related Research. 2005;(434):193-7. [pmid: 15864052].
182 Karatosun V, Unver B, Gocen Z, et al. Intra-articular hyaluranic acid compared with progressive knee exercises in osteoarthritis of the knee: a prospective randomized trial with long-term follow-up. Rheumatol Int. Feb. 2006;26(4):277-84. [pmid: 15776267].
183 Karlsson J, Sjogren LS, Lohmander LS. Comparison of two hyaluronan drugs and placebo in patients with knee osteoarthritis. A controlled, randomized, double-blind, parallel-design multicentre study. Rheumatology. 2002;41(11):1240-8. [pmid: 12421996].
184 Kawasaki T, Kurosawa H, Ikeda H, et al. Therapeutic home exercise versus intraarticular hyaluronate injection for osteoarthritis of the knee: 6-month prospective randomized open-labeled trial. J Orthop Sci. Mar. 2009;14(2):182-91. [pmid: 19337810].
185 Kean CO, Birmingham TB, Garland SJ, et al. Preoperative strength training for patients undergoing high tibial osteotomy: a prospective cohort study with historical controls. Journal of Orthopaedic & Sports Physical Therapy. Feb. 2011;41(2):52-9. [pmid: 21212500].
186 Keiser H, Sandson JI. Immunodiffusion and gel-electrophoretic studies of human articular cartilage proteoglycan. Arthritis Rheum. May–Jun. 1974;17(3):219-28. [pmid: 4133061].
187 Keller SD, Ware JE Jr, Hatoum HT, et al. The SF-36 Arthritis-Specific Health Index (ASHI): II. Tests of validity in four clinical trials. Med Care. May. 1999;37(5 Suppl):MS51-60. [pmid: 10335743].
188 Kerrigan DC, Riley PO, Nieto TJ, et al. Knee joint torques: a comparison between women and men during barefoot walking. Archives of Physical Medicine and Rehabilitation. Sep. 2000;81(9):5.
189 Kerrigan DC, Todd MK, O Riley P. Knee osteoarthritis and high-heeled shoes. Lancet. May. 1998;351(9113):401.
190 King MB, Judge JO, Whipple R, et al. Reliability and responsiveness of two physical performance measures examined in the context of a functional training intervention. Phys Ther. Jan. 2000;80(1):8-16. [pmid: 10623956].
191 King S, Wessel J, Bhambhani Y, et al. Validity and reliability of the 6 minute walk in persons with fibromyalgia. J Rheumatol. Oct. 1999;26(10):2233-7. [pmid: 10529146].
192 Kobayashi M. A study of polyvinyl alcohol-hydrogel (PVA-H) artificial meniscus in vivo. Bio-Medical Materials & Engineering. 2004;14(4):505-15. [pmid: 15472397].
193 Kosinski M, Keller SD, Hatoum HT, et al. The SF-36 Health Survey as a generic outcome measure in clinical trials of patients with osteoarthritis and rheumatoid arthritis: tests of data quality, scaling assumptions and score reliability. Med Care. May. 1999;37(5 Suppl):MS10-22. [pmid: 10335740].
194 Kouri-Flores JB, Abbud-Lozoya KA, Roja-Morales L. Kinetics of the ultrastructural changes in apoptotic chondrocytes from an osteoarthrosis rat model: a window of comparison to the cellular mechanism of apoptosis in human chondrocytes. Ultrastruct Pathol. Jan–Feb. 2002;26(1):33-40. [pmid: 12028657].
195 Koybasi M, Borman P, Kocaoglu S, et al. The effect of additional therapeutic ultrasound in patients with primary hip osteoarthritis: a randomized placebo-controlled study. Clin Rheumatol. Dec. 2010;29(12):1387-94. [pmid: 20499122].
196 Koyonos L, Yanke AB, McNickle AG, et al. A randomized, prospective, double-blind study to investigate the effectiveness of adding DepoMedrol to a local anesthetic injection in postmeniscectomy patients with osteoarthritis of the knee. American Journal of Sports Medicine. Jun. 2009;37(6):1077-82. [pmid: 19279226].
197 Kumar PJ, McPherson EJ, Dorr LD, et al. Rehabilitation after total knee arthroplasty: a comparison of 2 rehabilitation techniques. Clin Orthop Relat Res. Oct. 1996;(331):93-101. [pmid: 8895624].
198 Lane NE, Nevitt MC, Lui L-Y, et al. Wnt signaling antagonists are potential prognostic biomarkers for the progression of radiographic hip osteoarthritis in elderly Caucasian women. Arthritis & Rheumatism. Oct. 2007;56(10):3319-25. [pmid: 17907185].
199 Laprade JA, Culham EG. A self-administered pain severity scale for patellofemoral pain syndrome. Clin Rehabil. Nov. 2002;16(7):780-8. [pmid: 12428827].
200 Larsson S, Englund M, Struglics A, et al. Association between synovial fluid levels of aggrecan ARGS fragments and radiographic progression in knee osteoarthritis. Arthritis Research & Therapy. 2010;12(6):R230. [pmid: 21194461].
201 Leopold SS, Redd BB, Warme WJ, et al. Corticosteroid compared with hyaluronic acid injections for the treatment of osteoarthritis of the knee. A prospective, randomized trial. Journal of Bone & Joint Surgery - American Volume. 2003;85-A(7):1197-203. [pmid: 12851342].
202 Lesher JD, Sutlive TG, Miller GA, et al. Development of a clinical prediction rule for classifying patients with patellofemoral pain syndrome who respond to patellar taping. Journal of Orthopaedic & Sports Physical Therapy. Nov. 2006;36(11):854-66. [pmid: 17154139].
203 Lievense AM, Koes BW, Verhaar JAN, et al. Prognosis of hip pain in general practice: a prospective followup study. Arthritis & Rheumatism. Dec. 15. 2007;57(8):1368-74. [pmid: 18050175].
204 Lipkin DP, Scriven AJ, Crake T, et al. Six minute walking test for assessing exercise capacity in chronic heart failure. Br Med J (Clin Res Ed). Mar. 8. 1986;292(6521):653-5. [pmid: 3081210].
205 Long MJ, McQueen DA, Bangalore VG, et al. Using self-assessed health to predict patient outcomes after total knee replacement. Clinical Orthopaedics & Related Research. 2005;(434):189-92. [pmid: 15864051].
206 Losina E, Barrett J, Baron JA, et al. Accuracy of Medicare claims data for rheumatologic diagnoses in total hip replacement recipients. Journal of Clinical Epidemiology. Jun. 2003;56(6):515-9. [pmid: 12873645].
207 Lowe CJ, Wilson MS, Sackley CM, et al. Blind outcome assessment: the development and use of procedures to maintain and describe blinding in a pragmatic physiotherapy rehabilitation trial. Clin Rehabil. Mar. 2011;25(3):264-74. [pmid: 20971749].
208 Lundin-Olsson L, Nyberg L, Gustafson Y. Attention, frailty, and falls: the effect of a manual task on basic mobility. J Am Geriatr Soc. Jun. 1998;46(6):758-61. [pmid: 9625194].
209 Maheu E, Altman RD, Bloch DA, et al. Design and conduct of clinical trials in patients with osteoarthritis of the hand: recommendations from a task force of the Osteoarthritis Research Society International. Osteoarthritis Cartilage. Apr. 2006;14(4):303-22. [pmid: 16697937].
210 Maheu E, Cadet C, Marty M, et al. Reproducibility and sensitivity to change of various methods to measure joint space width in osteoarthritis of the hip: a double reading of three different radiographic views taken with a three-year interval. Arthritis Research & Therapy. 2005;7(6):R1375-85. [pmid: 16277690].
211 Mahler DA, Mackowiak JI. Evaluation of the short-form 36-item questionnaire to measure health-related quality of life in patients with COPD. Chest. Jun. 1995;107(6):1585-9. [pmid: 7781351].
212 Maillefert JF, Gueguen A, Nguyen M, et al. Relevant change in radiological progression in patients with hip osteoarthritis. I. Determination using predictive validity for total hip arthroplasty. Rheumatology. Feb. 2002;41(2):142-7. [pmid: 11886961].
213 Maillefert JF, Nguyen M, Gueguen A, et al. Relevant change in radiological progression in patients with hip osteoarthritis. II. Determination using an expert opinion approach. Rheumatology. Feb. 2002;41(2):148-52. [pmid: 11886962].
214 Malchau H, Garellick G, et al. Presidential guest address: the Swedish Hip Registry: increasing the sensitivity by patient outcome data. Clinical Orthopaedics & Related Research. Dec. 2005;441:19-29. [pmid: 16330981].
215 Malviya A, Lingard EA, Weir DJ, et al. Predicting range of movement after knee replacement: the importance of posterior condylar offset and tibial slope. Knee Surgery, Sports Traumatology, Arthroscopy. May. 2009;17(5):491-8. [pmid: 19139846].
216 Mandelin J, Li T-F, Hukkanen MVJ, et al. Increased expression of a novel osteoclast-stimulating factor, ADAM8, in interface tissue around loosened hip prostheses. Journal of Rheumatology. Sep. 2003;30(9):2033-8. [pmid: 12966612].
217 Marks R, Quinney AH. Reliability and validity of the measurement of position sense in women with osteoarthritis of the knee. J Rheumatol. Nov. 1993;20(11):1919-24. [pmid: 8308779].
218 Marshall D, Pericak D, Grootendorst P, et al. Validation of a prediction model to estimate health utilities index Mark 3 utility scores from WOMAC index scores in patients with osteoarthritis of the hip. Value Health. May–Jun. 2008;11(3):470-7. [pmid: 18489670].
219 Marumo K, Sato Y, Suzuki H, et al. MRI study of bioabsorbable poly-L-lactic acid devices used for fixation of fracture and osteotomies. Journal of Orthopaedic Science. Mar. 2006;11(2):154-8. [pmid: 16568387].
220 Marx RG, Stump TJ, Jones EC, et al. Development and evaluation of an activity rating scale for disorders of the knee. American Journal of Sports Medicine. Mar–Apr. 2001;29(2):213-8. [pmid: 11292048].
221 Masuhara K, Nakai T, Yamaguchi K, et al. Significant increases in serum and plasma concentrations of matrix metalloproteinases 3 and 9 in patients with rapidly destructive osteoarthritis of the hip. Arthritis & Rheumatism. Oct. 2002;46(10):2625-31. [pmid: 12384920].
222 Matsumoto T, Muratsu H, Tsumura N, et al. Joint gap kinematics in posterior-stabilized total knee arthroplasty measured by a new tensor with the navigation system. Journal of Biomechanical Engineering. Dec. 2006;128(6):867-71. [pmid: 17154688].
223 Mazières B, et al. Molecular markers of cartilage breakdown and synovitis at baseline as predictors of structural progression of hip osteoarthritis. The ECHODIAH Cohort. Annals of the Rheumatic Diseases. Mar. 2006;65(3):354-9. [pmid: 16322084].
224 Mazzuca SA, Brandt KD, Buckwalter KA. Detection of radiographic joint space narrowing in subjects with knee osteoarthritis: longitudinal comparison of the metatarsophalangeal and semiflexed anteroposterior views. Arthritis Rheum. Feb. 2003;48(2):385-90. [pmid: 12571847].
225 McGrory BJ, Harris WH. Can the western Ontario and McMaster Universities (WOMAC) osteoarthritis index be used to evaluate different hip joints in the same patient?. J Arthroplasty. Oct. 1996;11(7):841-4. [pmid: 8934324].
226 McKean KA, Landry SC, HubleyKozey CL, et al. Gender differences exist in osteoarthritic gait. Clinical Biomechanics. 2007;22(4):400-9. [pmid: 17239509].
227 Menetrey J, Siegrist O, Fritschy D. Medial meniscectomy in patients over the age of fifty: a six year follow-up study. Swiss Surgery. 2002;8(3):113-9. [pmid: 12125334].
228 Micera S, Vannozzi G, Sabatini AM, et al. Improving detection of muscle activation intervals. IEEE Engineering in Medicine & Biology Magazine. Nov–Dec. 2001;20(6):38-46. [pmid: 11838257].
229 Miklowitz DJ, Axelson DA, Birnnaher B, et al. Family-focused treatment for adolescents with bipolar disorder: Results of a 2-year randomized trial. Archives of General Psychiatry. Sep. 2008;65(9):61.
230 Miyamoto S, Nagaya N, Satoh T, et al. Clinical correlates and prognostic significance of six-minute walk test in patients with primary pulmonary hypertension. Comparison with cardiopulmonary exercise testing. Am J Respir Crit Care Med. Feb. 2000;161(2 Pt 1):487-92. [pmid: 10673190].
231 Moffet H, Collet JP, Shapiro SH, et al. Effectiveness of intensive rehabilitation on functional ability and quality of life after first total knee arthroplasty: A single-blind randomized controlled trial. Archives of Physical Medicine and Rehabilitation. 2004;85(4):546-56. [pmid: 15083429].
232 Molsberger AF, Streitberger K, Kraemer J, et al. Designing an acupuncture study: II. The nationwide, randomized, controlled German acupuncture trials on low-back pain and gonarthrosis. Journal of Alternative & Complementary Medicine. 2006;12(8):733-42. [pmid: 17034279].
233 Montgomery PS, Gardner AW. The clinical utility of a six-minute walk test in peripheral arterial occlusive disease patients. J Am Geriatr Soc. Jun. 1998;46(6):706-11. [pmid: 9625185].
234 Moore SR, Shurman J. Combined neuromuscular electrical stimulation and transcutaneous electrical nerve stimulation for treatment of chronic back pain: a double-blind, repeated measures comparison. Arch Phys Med Rehabil. Jan. 1997;78(1):55-60. [pmid: 9014958].
235 Murphy S, Deshmukh R. Periacetabular osteotomy: preoperative radiographic predictors of outcome. Clinical Orthopaedics & Related Research. Dec. 2002;(405):168-74. [pmid: 12461370].
236 Naal FD, Sieverding M, Impellizzeri FM, et al. Reliability and validity of the cross-culturally adapted German Oxford hip score. Clinical Orthopaedics & Related Research. Apr. 2009;467(4):952-7. [pmid: 18726655].
237 Nagasawa F, Miyake Y, Akazawa H, et al. Predictability of the progress of secondary osteoarthritis after developmental dislocation of the hip, utilizing inferior edge (of the teardrop)--center (of the femoral head) distance. Journal of Orthopaedic Science. 2000;5(1):10-7. [pmid: 10664434].
238 Nakajima K, Kakihana W, Nakagawa T, et al. Addition of an arch support improves the biomechanical effect of a laterally wedged insole. Gait & Posture. Feb. 2009;29(2):208-13. [pmid: 18824355].
239 Nebel MB, Sims EL, Keefe FJ, et al. The degree to which 2 commonly used measures of pain and disability, the Arthritis Impact Measurement Scales (AIMS) and the Western Ontario and McMaster Universities Osteoarthritis Index (WOMAC), relate to objective gait measurements. Archives of Physical Medicine and Rehabilitation. 2009. 2009;90(11):1874-9. [pmid: 19887211].
240 Neptune RR, Kautz SA. Knee joint loading in forward versus backward pedaling: implications for rehabilitation strategies. Clin Biomech (Bristol, Avon). Aug. 2000;15(7):528-35. [pmid: 10831813].
241 Nilsdotter AK, Lohmander LS. Age and waiting time as predictors of outcome after total hip replacement for osteoarthritis. Rheumatology. Nov. 2002;41(11):1261-7. [pmid: 12421998].
242 Nishii T, Sugano N, Sakai T, et al. Osteoblastic response to osteoarthrosis of the hip does not predict outcome of cementless cup fixation: 79 patients followed for 5–11 years. Acta Orthopaedica Scandinavica. Aug. 2001;72(4):343-7. [pmid: 11580121].
243 Nixon PA, Joswiak ML, Fricker FJ. A six-minute walk test for assessing exercise tolerance in severely ill children. J Pediatr. Sep. 1996;129(3):362-6. [pmid: 8804324].
244 Noguchi Y, Miura H, Takasugi S, et al. Cartilage and labrum degeneration in the dysplastic hip generally originates in the anterosuperior weight-bearing area: an arthroscopic observation. Arthroscopy. Jul–Aug. 1999;15(5):496-506. [pmid: 10424553].
245 O’Keeffe ST, Lye M, Donnellan C, et al. Reproducibility and responsiveness of quality of life assessment and six minute walk test in elderly heart failure patients. Heart. Oct. 1998;80(4):377-82. [pmid: 9875117].
246 Ozturk C, Atamaz F, Hepguler S, et al. The safety and efficacy of intraarticular hyaluronan with/without corticosteroid in knee osteoarthritis: 1-year, single-blind, randomized study. Rheumatol Int. Feb. 2006;26(4):314-9. [pmid: 15703953].
247 Paker N, Tekdos D, Kesiktas N, et al. Comparison of the therapeutic efficacy of TENS versus intra-articular hyaluronic acid injection in patients with knee osteoarthritis: a prospective randomized study. Advances in Therapy. Mar–Apr. 2006;23(2):342-53. [pmid: 16751166].
248 Pankoff B, Overend T, Lucy D, et al. Validity and responsiveness of the 6 minute walk test for people with fibromyalgia. J Rheumatol. Nov. 2000;27(11):2666-70. [pmid: 11093451].
249 Pavlovich RI, Vazquez-Vela G, Garcia PG, et al. Synovial impingement syndrome and dysphoria articularis syndrome of the knee. The Journal of Knee Surgery. Winter. 2002;15(1):49-52. [pmid: 11829335].
250 Pisoni C, Giardini A, Majani G, et al. International Classification of Functioning, Disability and Health (ICF) core sets for osteoarthritis. A useful tool in the follow-up of patients after joint arthroplasty. European journal of physical & rehabilitation medicine. 2008;44(4):377-85. [pmid: 18469736].
251 Physical activity and exercise adherence in physical therapy exercise treatment in patients with osteoarthritis of hip or knee. Arthritis and Rheumatism. 2008. 2008 Annual Scientific Meeting of the American College of Rheumatology and Association of Rheumatology Health Professionals. Moscone Cneter, San Francisco, California (USA). 24–29 Oct 2008.
252 Piva SR, Gil AB, Almeida GJ, et al. A balance exercise program appears to improve function for patients with total knee arthroplasty: a randomized clinical trial. Phys Ther. Jun. 2010;90(6):880-94. [pmid: 20378678].
253 Powers CM, Heino JG, Rao S, et al. The influence of patellofemoral pain on lower limb loading during gait. Clin Biomech (Bristol, Avon). Dec. 1999;14(10):722-8. [pmid: 10545627].
254 Proctor M, Farquhar C, Stones W, et al. Transcutaneous electrical nerve stimulation for primary dysmenorrhoea, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2002.
255 Proctor M, Hing W, Johnson Trina C, et al. Spinal manipulation for dysmenorrhoea, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2006.
256 Pruitt AL. Orthotic and brace use in the athlete with degenerative joint disease with angular deformity. Clinics in Sports Medicine. Jan. 2005;24(1):93-9. [pmid: 15636780].
257 Pua YH, Cowan SM, Wrigley TV, et al. The Lower Extremity Functional Scale could be an alternative to the Western Ontario and McMaster Universities Osteoarthritis Index physical function scale. J Clin Epidemiol. Oct. 2009;62(10):1103-11. [pmid: 19282145].
258 Pua YH, Wrigley TV, Collins M, et al. Association of physical performance with muscle strength and hip range of motion in hip osteoarthritis. Arthritis Rheum. Apr. 15. 2009;61(4):442-50. [pmid: 19333975].
259 Pua Y-H, Wrigley TV, Cowan SM, et al. Hip flexion range of motion and physical function in hip osteoarthritis: mediating effects of hip extensor strength and pain. Arthritis & Rheumatism. May. 15. 2009;61(5):633-40. [pmid: 19405017].
260 Quintana J, Escobar A, et al. Predictors of health-related quality-of-life change after total hip arthroplasty. Clinical Orthopaedics & Related Research. Nov. 2009;467(11):2886-94. [pmid: 19412646].
261 Rat AC, Baumann C, Klein S, et al. Effect of order of presentation of a generic and a specific health-related quality of life instrument in knee and hip osteoarthritis: a randomized study. Osteoarthritis and Cartilage. 2008;16(4):429-35. [pmid: 17920302].
262 Raynauld JP, Goldsmith CH, Bellamy N, et al. Effectiveness and safety of repeat courses of hylan G-F 20 in patients with knee osteoarthritis. Osteoarthritis and Cartilage. 2005;13(2):111-9. [pmid: 15694572].
263 Redelmeier DA, Bayoumi AM, Goldstein RS, et al. Interpreting small differences in functional status: the Six Minute Walk test in chronic lung disease patients. Am J Respir Crit Care Med. Apr. 1997;155(4):1278-82. [pmid: 9105067].
264 Reijman M, Hazes JM, Koes BW, et al. Validity, reliability, and applicability of seven definitions of hip osteoarthritis used in epidemiological studies: a systematic appraisal. Ann Rheum Dis. Mar. 2004;63(3):226-32. [pmid: 14962953].
265 Reijman M, Hazes JMW, Pols HAP, et al. Acetabular dysplasia predicts incident osteoarthritis of the hip: the Rotterdam study. Arthritis & Rheumatism. Mar. 2005;52(3):787-93. [pmid: 15751071].
266 Repicci JA. Total knee or uni? Benefits and limitations of the unicondylar knee prosthesis. Orthopedics. Mar. 2003;26(3):274. [pmid: 12650318].
267 Reynolds NL, Worrell TW, Perrin DH. Effect of a Lateral Step-up Exercise Protocol on Quadriceps Isokinetic Peak Torque Values and Thigh Girth. Journal of Orthopaedic & Sports Physical Therapy. 1992;15(3):151-5. [pmid: 18796787].
268 Richolt JA, Effenberger H, Rittmeister ME. How does soft tissue distribution affect anteversion accuracy of the palpation procedure in image-free acetabular cup navigation? An ultrasonographic assessment. Computer Aided Surgery. Mar. 2005;10(2):87-92. [pmid: 16298919].
269 Riley M, McParland J, Stanford CF, et al. Oxygen consumption during corridor walk testing in chronic cardiac failure. Eur Heart J. Jun. 1992;13(6):789-93. [pmid: 1623869].
270 Rockwood K, Awalt E, Carver D, et al. Feasibility and measurement properties of the functional reach and the timed up and go tests in the Canadian study of health and aging. J Gerontol A Biol Sci Med Sci. Feb. 2000;55(2):M70-3. [pmid: 10737688].
271 Rodgers JA, Garvin KL, Walker CW, et al. Preoperative physical therapy in primary total knee arthroplasty. J Arthroplasty. Jun. 1998;13(4):414-21. [pmid: 9645522].
272 Rogers LQ, Macera CA, Hootman JM, et al. The association between joint stress from physical activity and self-reported osteoarthritis: an analysis of the Cooper Clinic data. Osteoarthritis and Cartilage. 2002;10(8):617-22. [pmid: 12479383].
273 Roos EM, Toksvig-Larsen S. Knee injury and Osteoarthritis Outcome Score (KOOS) - validation and comparison to the WOMAC in total knee replacement. Health Qual Life Outcomes. 2003;1:17. [pmid: 12801417].
274 Rose Kristy J, Burns J, Wheeler Danielle M, et al. Interventions for increasing ankle range of motion in patients with neuromuscular disease, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
275 Rowlands B. The efficacy of patella mobilisation in patients suffering from patellofemoral pain syndrome. JNMS: Journal of the neuromusculoskeletal system: a journal of the American Chiropractic Association. 1999;7(4):142-49.
276 Rozendaal RM, Koes BW, van Osch GJVM, et al. Effect of glucosamine sulfate on hip osteoarthritis: a randomized trial. [Summary for patients in Ann Intern Med. 2008 Feb 19;148(4):I49; PMID: 18283200]. Annals of Internal Medicine. Feb. 19. 2008;148(4):268-77. [pmid: 18283204].
277 Russell TG, Buttrum P, Wootton R, et al. Internet-based outpatient telerehabilitation for patients following total knee arthroplasty: a randomized controlled trial. J Bone Joint Surg Am. Jan. 2011;93(2):113-20. [pmid: 21248209].
278 Ryd L, Karrholm J, Ahlvin P. Knee scoring systems in gonarthrosis. Evaluation of interobserver variability and the envelope of bias. Score Assessment Group. Acta Orthop Scand. Feb. 1997;68(1):41-5. [pmid: 9057566].
279 Sakai T, Sugano N, Nishii T, et al. Extent of osteonecrosis on MRI predicts humeral head collapse. Clinical Orthopaedics & Related Research. May. 2008;466(5):1074-80. [pmid: 18350349].
280 Salavati M, Akhbari B, Mohammadi F, et al. Knee injury and Osteoarthritis Outcome Score (KOOS); reliability and validity in competitive athletes after anterior cruciate ligament reconstruction. Osteoarthritis Cartilage. Apr. 2011;19(4):406-10. [pmid: 21255667].
281 Samojlow R, Bojarska-Szmygin A, Asarabowski J, et al. Application of scintigraphy MDP 99 mTc in the diagnosis of osteoarticular pains of obscure etiology. Ann Univ Mariae Curie Sklodowska Med. 2002;57(1):364-9. [pmid: 12898945].
282 Sashika H, Matsuba Y, Watanabe Y. Home program of physical therapy: effect on disabilities of patients with total hip arthroplasty. Arch Phys Med Rehabil. Mar. 1996;77(3):273-7. [pmid: 8600871].
283 Schmalz T, Blumentritt S, Drewitz H, et al. The influence of sole wedges on frontal plane knee kinetics, in isolation and in combination with representative rigid and semi-rigid ankle-foot-orthoses. Clinical Biomechanics. 2006;21(6):631-9. [pmid: 16567026].
284 Schmitt LC, Fitzgerald GK, Reisman AS, et al. Instability, laxity, and physical function in patients with medial knee osteoarthritis. Phys Ther. Dec. 2008;88(12):1506-16. [pmid: 18820096].
285 Schoppen T, Boonstra A, Groothoff JW, et al. The Timed “up and go” test: reliability and validity in persons with unilateral lower limb amputation. Arch Phys Med Rehabil. Jul. 1999;80(7):825-8. [pmid: 10414769].
286 Segal NA, Yack HJ, Khole P. Weight, rather than obesity distribution, explains peak external knee adduction moment during level gait. American Journal of Physical Medicine & Rehabilitation. Mar. 2009;88(3):180-8. quiz 9–91. [pmid: 19847127].
287 Shi Q, Lajeunesse D, Reboul P, et al. Metabolic activity of osteoblasts from periprosthetic trabecular bone in failed total hip arthroplasties and osteoarthritis as markers of osteolysis and loosening. Journal of Rheumatology. Jul. 2002;29(7):1437-45. [pmid: 12136903].
288 Shields RK, Enloe LJ, Leo KC. Health related quality of life in patients with total hip or knee replacement. Arch Phys Med Rehabil. May. 1999;80(5):572-9. [pmid: 10326924].
289 Silva Kelson NG, Mizusaki Imoto A, Almeida Gustavo JM, et al. Balance training (proprioceptive training) for patients with rheumatoid arthritis, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
290 Singh BB, Mishra LC, Vinjamury SP, et al. The effectiveness of Commiphora mukul for osteoarthritis of the knee: an outcomes study. Alternative Therapies in Health & Medicine. May–Jun. 2003;9(3):74-9. [pmid: 12776478].
291 Slappendel R, Weber EW, Bugter ML, et al. The intensity of preoperative pain is directly correlated with the amount of morphine needed for postoperative analgesia. Anesthesia & Analgesia. Jan. 1999;88(1):146-8. [pmid: 9895082].
292 Sloan FA, Ruiz D Jr, Platt A. Changes in functional status among persons over age sixty-five undergoing total knee arthroplasty. Medical care. 2009;47(7):742-8. [pmid: 19536027].
293 Soderman P, Malchau H. Validity and reliability of Swedish WOMAC osteoarthritis index: a self-administered disease-specific questionnaire (WOMAC) versus generic instruments (SF-36 and NHP). Acta Orthop Scand. Feb. 2000;71(1):39-46. [pmid: 10743991].
294 Soohoo NF, Vyas RM, Samimi DB, et al. Comparison of the responsiveness of the SF-36 and WOMAC in patients undergoing total hip arthroplasty. Journal of Arthroplasty. Dec. 2007;22(8):1168-73. [pmid: 18078886].
295 Stamm TA, Machold KP, Smolen JS, et al. Joint protection and home hand exercises improve hand function in patients with hand osteoarthritis: a randomized controlled trial. Arthritis Rheum. Feb. 2002;47(1):44-9. [pmid: 11932877].
296 Stelian J, Gil I, Habot B, et al. Improvement of pain and disability in elderly patients with degenerative osteoarthritis of the knee treated with narrow-band light therapy. J Am Geriatr Soc. Jan. 1992;40(1):23-6. [pmid: 1727843].
297 Stener-Victorin E, Kruse-Smidje C, Jung K. Comparison between electro-acupuncture and hydrotherapy, both in combination with patient education and patient education alone, on the symptomatic treatment of osteoarthritis of the hip. Clin J Pain. May–Jun. 2004;20(3):179-85. [pmid: 15100594].
298 Stewart AL, Hays RD, Ware JE Jr. The MOS short-form general health survey. Reliability and validity in a patient population. Med Care. Jul. 1988;26(7):724-35. [pmid: 3393032].
299 Stitik TP, Blacksin MF, Stiskal DM, et al. Efficacy and safety of hyaluronan treatment in combination therapy with home exercise for knee osteoarthritis pain. Arch Phys Med Rehabil. Feb. 2007;88(2):135-41. [pmid: 17270509].
300 Stitik TP, Foye PM. The prevalence of knee pain and symptomatic knee osteoarthritis among veteran traumatic amputees and nonamputees. Archives of Physical Medicine and Rehabilitation. Jun. 2005;86(6).
301 Stratford PW, Kennedy DM, Hanna SE. Condition-specific Western Ontario McMaster Osteoarthritis Index was not superior to region-specific Lower Extremity Functional Scale at detecting change. Journal of Clinical Epidemiology. Oct. 2004;57(10):1025-32. [pmid: 15528053].
302 Stratford PW, Kennedy DM, Maly MR, et al. Quantifying self-report measures’ overestimation of mobility scores postarthroplasty. Phys Ther. Sep. 2010;90(9):1288-96. [pmid: 20592271].
303 Sun J-l, Fan J-z, Song G-z, et al. Infrared radiation and magnetic field therapy ameliorates cartilage damage in rabbits with knee osteoarthritis. Nan Fang Yi Ke Da Xue Xue Bao = Journal of Southern Medical University. Dec. 2007;27(12):1851-5. [pmid: 18159001].
304 Suter LG, Fraenkel L, Losina E, et al. Medical decision making in patients with knee pain, meniscal tear, and osteoarthritis. Arthritis & Rheumatism. Nov. 15. 2009;61(11):1531-8. [pmid: 19877094].
305 Sutlive TG, Lopez HP, Schnitker DE, et al. Development of a clinical prediction rule for diagnosing hip osteoarthritis in individuals with unilateral hip pain. Journal of Orthopaedic & Sports Physical Therapy. Sep. 2008;38(9):542-50. [pmid: 18758047].
306 Sylvester KL. Investigation of the effect of hydrotherapy in the treatment of osteoarthritic hips. Clinical Rehabilitation. 1990;4:223-8.
307 Tanavalee A, Yuktanandana P, Ngarmukos C. Surgical epicondylar axis vs anatomical epicondylar axis for rotational alignment of the femoral component in total knee arthroplasty. Journal of the Medical Association of Thailand. Jun. Suppl 1. 2001;84:S401-8. [pmid: 11529366].
308 Tappen RM, Roach KE, Buchner D, et al. Reliability of physical performance measures in nursing home residents with Alzheimer’s disease. J Gerontol A Biol Sci Med Sci. Jan. 1997;52(1):M52-5. [pmid: 9008669].
309 Tasciotaoglu F, Oner C. Efficacy of intra-articular sodium hyaluronate in the treatment of knee osteoarthritis. Clin Rheumatol. May. 2003;22(2):112-7. [pmid: 12740675].
310 Taylor KE. An investigation into the effect of exercise combined with patella mobilization/manipulation in the treatment of patellofemoral pain syndrome: a randomized, assessor-blinded, controlled clinical pilot trial. European Journal of Chiropractic. 2003;51(1):5-17.
311 Thiele J, Nimmo R, Rowell W, et al. A randomized single blind crossover trial comparing leather and commercial wrist splints for treating chronic wrist pain in adults. BMC Musculoskelet Disord. 2009;10:129. [pmid: 19843345].
312 Thomee P, Wahrborg P, Borjesson M, et al. A randomized, controlled study of a rehabilitation model to improve knee-function self-efficacy with ACL injury. J Sport Rehabil. May. 2010;19(2):200-13. [pmid: 20543220].
313 Thorp LE, Sumner DR, Block JA, et al. Knee joint loading differs in individuals with mild compared with moderate medial knee osteoarthritis. Arthritis & Rheumatism. Dec. 2006;54(12):3842-9. [pmid: 17133592].
314 Tigani D, Del Baldo A, Trentani P, et al. Closed-wedge tibial osteotomy: conventional technique versus a new system of compression-dynamic fixation. Orthopedics. Nov. 2002;25(11):1265-8. [pmid: 12452344].
315 Tousignant M, Moffet H, Boissy P, et al. A randomized controlled trial of home telerehabilitation for post-knee arthroplasty. J Telemed Telecare. 2011;17(4):195-8. [pmid: 21398389].
316 Tsai PF, Kuo YF, Beck C, et al. Non-verbal cues to osteoarthritic knee and/or hip pain in elders. Res Nurs Health. Jun. 2011;34(3):218-27. [pmid: 21425277].
317 Tulgar M, McGlone F, Bowsher D, et al. Comparative effectiveness of different stimulation modes in relieving pain. Part II. A double-blind controlled long-term clinical trial. Pain. Nov. 1991;47(2):157-62. [pmid: 1762810].
318 Uchio Y, Ochi M, Adachi N, et al. Arthroscopic assessment of human cartilage stiffness of the femoral condyles and the patella with a new tactile sensor. Medical Engineering & Physics. Jul. 2002;24(6):431-5. [pmid: 12135651].
319 Valat JP, Accardo S, Reginster JY, et al. A comparison of the efficacy and tolerability of meloxicam and diclofenac in the treatment of patients with osteoarthritis of the lumbar spine. Inflamm Res. Mar. Suppl 1. 2001;50:S30-4. [pmid: 11339519].
320 Valtonen A, Poyhonen T, Sipila S, et al. Effects of aquatic resistance training on mobility limitation and lower-limb impairments after knee replacement. Arch Phys Med Rehabil. Jun. 2010;91(6):833-9. [pmid: 20510971].
321 van Arkel ER, Goei R, de Ploeg I, et al. Meniscal allografts: evaluation with magnetic resonance imaging and correlation with arthroscopy. Arthroscopy. Jul–Aug. 2000;16(5):517-21. [pmid: 10882448].
322 Vossinakis IC, Georgiades G, Kafidas D, et al. Unilateral hip osteoarthritis: can we predict the outcome of the other hip?. Skeletal Radiology. Oct. 2008;37(10):911-6. [pmid: 18649078].
323 Waddell J, Pritzker KP, Boynton EL. Increased cytokine secretion in patients with failed implants compared with patients with primary implants. Clinical Orthopaedics & Related Research. May. 2005;(434):170-6. [pmid: 15864048].
324 Walters SJ, Morrell CJ, Dixon S. Measuring health-related quality of life in patients with venous leg ulcers. Qual Life Res. Jun. 1999;8(4):327-36. [pmid: 10472165].
325 Wang TM, Yen HC, Lu TW, et al. Bilateral knee osteoarthritis does not affect inter-joint coordination in older, adults with gait deviations during obstacle-crossing. Journal of Biomechanics. Oct. 16. 2009;42(14):2349-56. [pmid: 19679309].
326 Wang YC, Hart DL, Stratford PW, et al. Clinical interpretation of a lower-extremity functional scale-derived computerized adaptive test. Phys Ther. Sep. 2009;89(9):957-68. [pmid: 19628577].
327 Warden SJ, Metcalf BR, Kiss ZS, et al. Low-intensity pulsed ultrasound for chronic patellar tendinopathy: a randomized, double-blind, placebo-controlled trial. Rheumatology (Oxford). Apr. 2008;47(4):467-71. [pmid: 18270224].
328 Wei L, de Bri E, Lundberg A, et al. Mechanical load and primary guinea pig osteoarthritis. Acta Orthopaedica Scandinavica. 1998;69(4):351-7. [pmid: 9798441].
329 Weidenhielm L, Mattsson E, Brostrom LA, et al. Effect of preoperative physiotherapy in unicompartmental prosthetic knee replacement. Scand J Rehabil Med. Mar. 1993;25(1):33-9. [pmid: 8465163].
330 Weidow J, Tranberg R, Saari T, et al. Hip and knee joint rotations differ between patients with medial and lateral knee osteoarthritis: gait analysis of 30 patients and 15 controls. Journal of Orthopaedic Research. Sep. 2006;24(9):1890-9. [pmid: 16838360].
331 Williams NH, Amoakwa E, Burton K, et al. Activity Increase Despite Arthritis (AIDA): design of a Phase II randomised controlled trial evaluating an active management booklet for hip and knee osteoarthritis. [ISRCTN24554946]. BMC Family Practice. 2009;10(Journal Article):62. [pmid: 19732415].
332 Williams SB, Brand CA, Hill KD, et al. Feasibility and outcomes of a home-based exercise program on improving balance and gait stability in women with lower-limb osteoarthritis or rheumatoid arthritis: a pilot study. Arch Phys Med Rehabil. Jan. 2010;91(1):106-14. [pmid: 20103404].
333 Wislowska M, Jakubicz D, Stepien K, et al. Serum concentrations of formation (PINP) and resorption (Ctx) bone turnover markers in rheumatoid arthritis. Rheumatology International. Oct. 2009;29(12):1403-9. [pmid: 19219607].
334 Wolfe F, Hawley DJ, Goldenberg DL, et al. The assessment of functional impairment in fibromyalgia (FM): Rasch analyses of 5 functional scales and the development of the FM Health Assessment Questionnaire. J Rheumatol. Aug. 2000;27(8):1989-99. [pmid: 10955343].
335 Woo MA, Moser DK, Stevenson LW, et al. Six-minute walk test and heart rate variability: lack of association in advanced stages of heart failure. Am J Crit Care. Sep. 1997;6(5):348-54. [pmid: 9283671].
336 Yakhdani HRF, Bafghi HA, Meijer OG, et al. Stability and variability of knee kinematics during gait in knee osteoarthritis before and after replacement surgery. Clinical Biomechanics. Mar. 2010;25(3):230-6. [pmid: 20060628].
337 Yamada H, Miyauchi S, Hotta H, et al. Levels of chondroitin sulfate isomers in synovial fluid of patients with hip osteoarthritis. Journal of Orthopaedic Science. 1999;4(4):250-4. [pmid: 10436271].
338 Yamamoto T, Nagira K, Akisue T, et al. Osteoarthropathy associated with Weber-Christian disease. J Rheumatol. Sep. 2001;28(9):2136-8. [pmid: 11550989].
339 Yrjönen T. Prognosis in Perthes’ disease after noncontainment treatment. 106 hips followed for 28–47 years. Acta Orthopaedica Scandinavica. Oct. 1992;63(5):523-6. [pmid: 1441948].
340 Zorman D, Etuin P, Jennart H, et al. Computer-assisted total knee arthroplasty: comparative results in a preliminary series of 72 cases. Acta Orthopaedica Belgica. Dec. 2005;71(6):696-702. [pmid: 16459860].
341 Zwinderman AH, Cleophas TJ, van der Sluijs H, et al. Comparison of 50-mg and 100-mg sustained-release isosorbide mononitrate in the treatment of stable angina pectoris: effects on quality-of-life indices. Dutch Mononitrate Quality of Life (DUMQOL) Study Group. Angiology. Dec. 1999;50(12):963-9. [pmid: 10609762].

## Not Eligible Exposure

1 Carvalho NA, Bittar ST, Pinto FR, et al. Manual for guided home exercises for osteoarthritis of the knee. Clinics (Sao Paulo). Jun. 2010;65(8):775-80. [pmid: 20835554].
2 Crema MD, Roemer FW, Guermazi A. Magnetic resonance imaging in knee osteoarthritis research: semiquantitative and compositional assessment. Magn Reson Imaging Clin N Am. May. 2011;19(2):295-321. [pmid: 21665092].
3 NCT00061490. The Effect of Weight Loss and Exercise on Knee Osteoarthritis. 2006.
4 NCT00197977. Addressing Patients’ Expectations of Total Knee Arthroplasty in a Randomized Trial. 2004.
5 NCT00305890. Weight Management and Coping Skills Training For Patients With Knee Osteoarthritis. 2009.
6 NCT00655941. Influence of Weight Loss or Exercise on Cartilage in Obese Knee Osteoarthritis Patients. 2010.
7 NCT00763386. A Study to Compare the NexGen LPS and LPS-Flex Knee Implants. 2010.
8 NCT00938808. Long-term Intervention With Weight Loss in Patients With Concomitant Obesity and Knee Osteoarthritis. The LIGHT Study. 2013.
9 NCT00951990. Ergometer Cycling After Replacement of the Hip or Knee Joint. 2008.
10 Petersen SG, Beyer N, Hansen M, et al. Nonsteroidal anti-inflammatory drug or glucosamine reduced pain and improved muscle strength with resistance training in a randomized controlled trial of knee osteoarthritis patients. Arch Phys Med Rehabil. Aug. 2011;92(8):1185-93. [pmid: 21807137].
11 12th Congress of the European Society of Sports Traumatology, Knee Surgery and Arthroscopy (ESSKA 2000). 12th Congress of the European Society of Sports Traumatology, Knee Surgery and Arthroscopy (ESSKA 2000). Congress Innsbruck, Innsbruck (Austria). 24–27 May 2006.
12 2008 Asia Pacific Geriatric Conference (APGC 2008). 2008 Asia Pacific Geriatric Conference (APGC 2008). Discovery Kartika Plaza Hotel, Bali (Indonesia). 13–16 Nov 2008.
13 Get-Up and Go Test. Annals of the Rheumatic Diseases. 1997;56(Journal Article):641-8. [pmid: 9462165].
14 Clinical Assessment of Osteoarthritis of the Knee Measure. Annals of the Rheumatic Diseases. 1997;56(Journal Article):641-8. [pmid: 9462165].
15 Fifty Feet Timed Walk Measure. Annals of the Rheumatic Diseases. 1997;56(Journal Article):641-8. [pmid: 9462165].
16 Aggregate Functional Performance Time Measure. Annals of the Rheumatic Diseases. 1997;56(Journal Article):641-8. [pmid: 9462165].
17 Lequesne Index for Knee Osteoarthritis. Annals of the Rheumatic Diseases. 1997;56(Journal Article):641-8. [pmid: 9462165].
18 Lequesne Index. Scandinavian journal of rheumatology. 2001;30(Journal Article):242-7. [pmid: 11578021].
19 Anxiety and Depression Scales. Journal of Rheumatology. 2002;29(Journal Article):139-46. [pmid: 11824950].
20 Body Satisfaction Measure. Health Psychology. 2002;21(Journal Article):419-26. [pmid: 12211508].
21 Health Assessment Questionnaire. Journal of Rheumatology. 2002;29(Journal Article):139-46. [pmid: 11824950].
22 American College of Rheumatology Criteria for Knee Osteoarthritis. Archives of Physical and Medical Rehabilitation. 2002;83(Journal Article):1432-6.
23 Arthritis Impact Measurement Scales. Journal of Rheumatology. 2002;29(Journal Article):139-46. [pmid: 11824950].
24 Western Ontario McMaster Universities Osteoarthritis Index. Journal of Rheumatology. 2003;30(Journal Article):2452-9. [pmid: 14677192].
25 Osteoarthritis Health Outcome Interview Schedule. Journal of Rheumatology. 2003;30(Journal Article):2452-9. [pmid: 14677192].
26 Knee arthritis: flawed therapies. Johns Hopkins Medical Letter, Health After 50. Aug. 2003;15(6):1-2. [pmid: 12889454].
27 Summaries for patients. Acupuncture for treating knee osteoarthritis. Annals of Internal Medicine. 2004;141(12):20. [pmid: 15611482].
28 Hyaluronic acid minimally effective for knee degenerative joint disease. Cleveland Clinic Journal of Medicine. Apr. 2004;71(4):272. [pmid: 15117164].
29 At 76 years old, I’m very proud that I don’t take any medicines. But I have arthritis in both knees that is getting pretty painful. I refused painkillers but did go to physical therapy, and the exercises have helped. Now the therapist wants to tape my knee. I’m willing, but only if it will help. What do you suggest?. Harvard Mens Health Watch. Jul. 2005;9(12):8. [pmid: 16163782].
30 Difficult knees get modest benefit from acupuncture. Harvard Women’s Health Watch. 2005;12(7):3. [pmid: 16532559].
31 Acupuncture helps ease knee osteoarthritis pain. Health News. 2005;11(12):11. [pmid: 16416551].
32 Acupuncture points to pain relief, Johns Hopkins Medical Letter. Health After 50. 7. 2005;17(5):1-2. Jul. 2005;17(5):1–2, 7. [pmid: 16138404].
33 Acupuncture helpful for knee pain. Health News. 2005;11(2):5. [pmid: 15732147].
34 Summaries for patients. Adding acupuncture to physical therapy and anti-inflammatory drugs in the treatment of knee osteoarthritis. Annals of Internal Medicine. 2006;145(1):17. [pmid: 16818921].
35 Is acupuncture more effective than conventional therapy in improving pain and functionality for osteoarthritis of the knee?. Managed Care Interface. Dec. 2006;19(12):69. [pmid: 17274484].
36 Supplements may not relieve osteoarthritis-related knee pain. Mayo Clinic Women’s Healthsource. Aug. 2006;10(8):3. [pmid: 16829841].
37 Acupuncture for osteoarthritis of the knee. Drug & Therapeutics Bulletin. 2007;45(10):76-9. [pmid: 17928285].
38 Help for hurting knees. Advances in knee replacement. Mayo Clinic Women’s Healthsource. Nov. 2008;12(11):4-5. [pmid: 18836397].
39 Summaries for patients. Glucosamine sulfate to treat hip osteoarthritis. [Original report in Ann Intern Med. 2008 Feb 19;148(4):268–77; PMID: 18283204]. Annals of Internal Medicine. Feb. 19. 2008;148(4):I49. [pmid: 18283200].
40 Arthroscopic surgery may not be best treatment for knee osteoarthritis. Mayo Clinic Women’s Healthsource. 2009;13(2):3. [pmid: 19112339].
41 Value of common knee surgery questioned. Johns Hopkins Medical Letter, Health After 50. Mar. 2009;21(1):3. [pmid: 19370798].
42 A negative verdict for glucosamine and chondroitin supplements. Johns Hopkins Medical Letter, Health After 50. Feb. 2009;20(12):1-2. [pmid: 19241608].
43 Leg-length inequality: a risk factor for OA. Simple shoe modification may correct knee osteoarthritis and other conditions that result from a shorter leg. Duke Medicine Health News. Jun. 2010;16(6):1-2. [pmid: 20568337].
44 Aaron RK, Skolnick AH, Reinert SE, et al. Arthroscopic debridement for osteoarthritis of the knee. Journal of Bone & Joint Surgery - American Volume. May. 2006;88(5):936-43. [pmid: 16651566].
45 Abdeen AR, Collen SB, Vince KG. Fifteen-year to 19-year follow-up of the Insall-Burstein-1 total knee arthroplasty. Journal of Arthroplasty. Feb. 2010;25(2):173-8. [pmid: 19195825].
46 Abdel Megied WS, Mahran MA, Thakeb MF, et al. The new “dual osteotomy”: combined open wedge and tibial tuberosity anteriorisation osteotomies. International Orthopaedics. Feb. 2010;34(2):231-7. [pmid: 19998035].
47 Abd-el Wahab M, Szepesi K, Szucs G, et al. Functional improvement after knee arthroplasty without resurfacing of patella. Acta Chirurgica Hungarica. 1998;37(1–2):59-66. [pmid: 10196612].
48 Abramson SB. Do nonsteroidal anti-inflammatory drugs accelerate disease progression in osteoarthritis?. Nature Clinical Practice Rheumatology. Jun. 2006;2(6):302-3. [pmid: 16932708].
49 Acebes C, Roman-Blas JA, Delgado-Baeza E, et al. Correlation between arthroscopic and histopathological grading systems of articular cartilage lesions in knee osteoarthritis. Osteoarthritis Cartilage. Feb. 2009;17(2):205-12. [pmid: 18676161].
50 Acebes JC, Sanchez-Pernaute O, Diaz-Oca A, et al. Ultrasonographic assessment of Baker’s cysts after intra-articular corticosteroid injection in knee osteoarthritis. Journal of Clinical Ultrasound. Mar–Apr. 2006;34(3):113-7. [pmid: 16547992].
51 Ackerman D, Lett P, Galat DD Jr, et al. Results of total hip and total knee arthroplasties in patients with synovial chondromatosis. Journal of Arthroplasty. Apr. 2008;23(3):395-400. [pmid: 18358378].
52 Ackroyd CE, Chir B. Development and early results of a new patellofemoral arthroplasty. Clinical Orthopaedics & Related Research. 2005;(436):7-13. [pmid: 15995414].
53 Ackroyd CE, Newman JH, Evans R, et al. The Avon patellofemoral arthroplasty: five-year survivorship and functional results. Journal of Bone & Joint Surgery - British Volume. Mar. 2007;89(3):310-5. [pmid: 17356140].
54 Ackroyd CE, Whitehouse SL, Newman JH, et al. A comparative study of the medial St Georg sled and kinematic total knee arthroplasties. Ten-year survivorship. Journal of Bone & Joint Surgery - British Volume. Jul. 2002;84(5):667-72. [pmid: 12188481].
55 Adachi N, Ochi M, Deie M, et al. Transplant of mesenchymal stem cells and hydroxyapatite ceramics to treat severe osteochondral damage after septic arthritis of the knee. Journal of Rheumatology. Aug. 2005;32(8):1615-8. [pmid: 16078345].
56 Adili A, Bhandari M, Giffin R, et al. Valgus high tibial osteotomy. Comparison between an Ilizarov and a Coventry wedge technique for the treatment of medial compartment osteoarthritis of the knee. Knee Surgery, Sports Traumatology, Arthroscopy. May. 2002;10(3):169-76. [pmid: 12012035].
57 Agarwal V, Kumar M, Singh JK, et al. Diffusion tensor anisotropy magnetic resonance imaging: a new tool to assess synovial inflammation. Rheumatology (Oxford). Apr. 2009;48(4):378-82. [pmid: 19174567].
58 Agarwala S, Shah SB. Staple versus locking compression plate fixation after lateral closing wedge high tibial osteotomy. Journal of Orthopaedic Surgery. Dec. 2008;16(3):303-7. [pmid: 19126895].
59 Aglietti P, Buzzi R, Vena LM, et al. High tibial valgus osteotomy for medial gonarthrosis: a 10- to 21-year study. The Journal of Knee Surgery. Jan. 2003;16(1):21-6. [pmid: 12568262].
60 Aglietti P, Lup D, Cuomo P, et al. Total knee arthroplasty using a pie-crusting technique for valgus deformity. Clinical Orthopaedics & Related Research. Nov. 2007;464:73-7. [pmid: 17975373].
61 Aglietti P, Sensi L, Cuomo P, et al. Rotational position of femoral and tibial components in TKA using the femoral transepicondylar axis. Clinical Orthopaedics & Related Research. 2008;466(11):2751-5. [pmid: 18825470].
62 Agnesi F, Amrami KK, Frigo CA, et al. Comparison of cartilage thickness with radiologic grade of knee osteoarthritis. Skeletal Radiology. Jul. 2008;37(7):639-43. [pmid: 18461323].
63 Ahsin S, Saleem S, Bhatti AM, et al. Clinical and endocrinological changes after electro-acupuncture treatment in patients with osteoarthritis of the knee. Pain. Dec. 15. 2009;147(1–3):60-6. [pmid: 19766392].
64 Aiyejusunle CB, Kola-Korolo TA, Ajiboye OA. Comparison of the effects of tens and sodium salicylate iontophoresis in the management of osteoarthritis of the knee. Nig Q J Hosp Med. Jan–Mar. 2007;17(1):30-4. [pmid: 17688170].
65 Akai M, Doi T, Fujino K, et al. An outcome measure for Japanese people with knee osteoarthritis. Journal of Rheumatology. 2005;32(8):1524-32. [pmid: 16078330].
66 Akamizu T, Iwakura H, Ariyasu H, et al. Effects of ghrelin treatment on patients undergoing total hip replacement for osteoarthritis: different outcomes from studies in patients with cardiac and pulmonary cachexia. J Am Geriatr Soc. Dec. 2008;56(12):2363-5. [pmid: 19093947].
67 Akgun U, Nuran R, Karahan M. Modified Fulkerson osteotomy in recurrent patellofemoral dislocations. Acta Orthopaedica et Traumatologica Turcica. 2010;44(1):27-35. [pmid: 20513988].
68 Akhtar NM, Naseer R, Farooqi AZ, et al. Oral enzyme combination versus diclofenac in the treatment of osteoarthritis of the knee--a double-blind prospective randomized study. Clinical Rheumatology. Oct. 2004;23(5):410-5. [pmid: 15278753].
69 Akinbo SR, Aiyejusunle CB, Akinyemi OA, et al. Comparison of the therapeutic efficacy of phonophoresis and iontophoresis using dexamethasone sodium phosphate in the management of patients with knee osteoarthritis. Nigerian Postgraduate Medical Journal. 2007;14(3):190-4. [pmid: 17767200].
70 Akinbo SR, Sokunbi O, Ogunbameru T. Factors contributing to possession of walking aids among persons with osteoarthritis of the knee. Nig Q J Hosp Med. Apr–Jun. 2008;18(2):64-8. [pmid: 19068554].
71 Akinpelu A, Odole AC, Adegoke BO, et al. Development and Initial Validation of the Ibadan Knee/Hip Osteoarthritis, Outcome Measure. South African Journal of Physiotherapy. 2007;63(2):3-8.
72 Akizuki S, Shibakawa A, Takizawa T, et al. The long-term outcome of high tibial osteotomy: a ten- to 20-year follow-up. Journal of Bone & Joint Surgery - British Volume. May. 2008;90(5):592-6. [pmid: 18450624].
73 Alambert Paulo, Augusto PAA, Atallah Álvaro N, Soares Bernardo Garcia de O, et al. Chloroquines for the treatment of osteoarthritis, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2002.
74 AlArfaj A, AlBoukai AA. Prevalence of radiographic knee osteoarthritis in Saudi Arabia. Clinical rheumatology. 2002;21(2):142-5. [pmid: 12086165].
75 Albert A, Forthomme JP, Vandenhooft A, et al. Are lesions of the posterior cruciate ligament predictable before knee arthroplasty? A histological study of 434 ligaments in osteoarthritic knees. Acta Orthopaedica Belgica. Oct. 2008;74(5):652-8. [pmid: 19058700].
76 Alden KJ, Duncan WH, Trousdale RT, et al. Intraoperative fracture during primary total knee arthroplasty. Clinical Orthopaedics & Related Research. Jan. 2010;468(1):90-5. [pmid: 19430855].
77 Alemparte J, Johnson GV-V, Worland RL, et al. Results of simultaneous bilateral total knee replacement: a study of 1208 knees in 604 patients. Journal of the Southern Orthopaedic Association. 2002;11(3):153-6. [pmid: 12539940].
78 Alentorn-Geli E, Lajara F, Samitier G, et al. The transtibial versus the anteromedial portal technique in the arthroscopic bone-patellar tendon-bone anterior cruciate ligament reconstruction. Knee Surgery, Sports Traumatology, Arthroscopy. Aug. 2010;18(8):1013-37. [pmid: 19902178].
79 Alkire MR, Swank ML. Use of inpatient continuous passive motion versus no CPM in computer-assisted total knee arthroplasty. Orthop Nurs. Jan–Feb. 2010;29(1):36-40. [pmid: 20142693].
80 Al-Kurdi D, Bell-Syer Sally EM, Flemming K. Therapeutic ultrasound for venous leg ulcers, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2008.
81 Almekinders LC, Pandarinath R, Rahusen FT. Knee stability following anterior cruciate ligament rupture and surgery. The contribution of irreducible tibial subluxation. Journal of Bone & Joint Surgery - American Volume. May. 2004;86-A(5):983-7. [pmid: 15118041].
82 AlOmran AS. Osteoarthritis of knee: correlation between radiographic and arthroscopic findings. Int Surg. Jul–Sep. 2009;94(3):269-72. [pmid: 20187524].
83 Al-Omran AS, Sadat-Ali M. Arthroscopic joint lavage in osteoarthritis of the knee. Is it effective?. Saudi Medical Journal. 2009;30(6):809-12. [pmid: 19526165].
84 The Educational Needs of Women With Knee Osteoarthritis in Saudi Arabia. 6th Annual European Congress of Rheumatology (EULAR 2005). Vienna (Austria). 8–11 Jun 2005.
85 Altman RD, Akermark C, Beaulieu AD, et al. Efficacy and safety of a single intra-articular injection of non-animal stabilized hyaluronic acid (NASHA) in patients with osteoarthritis of the knee. Osteoarthritis & Cartilage. Aug. 2004;12(8):642-9. [pmid: 15262244].
86 Altman RD, Marcussen KC. Effects of a ginger extract on knee pain in patients with osteoarthritis. Arthritis & Rheumatism. Nov. 2001;44(11):2531-8. [pmid: 11710709].
87 Altman RD, Moskowitz R. A randomized clinical trial of intra-articular sodium hyaluronate in patients with osteoarthritis of the knee: a summary. American Journal of Orthopedics (Chatham, Nj). Nov. 1999;28(11 Suppl):3-4. [pmid: 10587244].
88 Altman RD, Rosen JE, Bloch DA, et al. A double-blind, randomized, saline-controlled study of the efficacy and safety of EUFLEXXA for treatment of painful osteoarthritis of the knee, with an open-label safety extension (the FLEXX trial). Seminars in Arthritis & Rheumatism. Aug. 2009;39(1):1-9. [pmid: 19539353].
89 Amendola L, Fosco M, Cenni E, et al. Knee joint arthroplasty after tibial osteotomy. International Orthopaedics. Feb. 2010;34(2):289-95. [pmid: 19882155].
90 Amin A, Watson A, Mangwani J, et al. A prospective randomised controlled trial of autologous retransfusion in total knee replacement. Journal of Bone & Joint Surgery - British Volume. Apr. 2008;90(4):451-4. [pmid: 18378918].
91 Amin AK, Patton JT, Cook RE, et al. Does obesity influence the clinical outcome at five years following total knee replacement for osteoarthritis?. Journal of Bone and Joint Surgery (British). 2006;88(3):335-40. [pmid: 16498007].
92 Amin AK, Patton JT, Cook RE, et al. Unicompartmental or total knee arthroplasty?: Results from a matched study. Clinical Orthopaedics & Related Research. 2006;451(Journal Article):101-6. [pmid: 16760806].
93 Amin S, LaValley MP, Guermazi A, et al. The relationship between cartilage loss on magnetic resonance imaging and radiographic progression in men and women with knee osteoarthritis. Arthritis Rheum. Oct. 2005;52(10):3152-9. [pmid: 16200595].
94 Amin S, Niu J, Guermazi A, et al. Cigarette smoking and the risk for cartilage loss and knee pain in men with knee osteoarthritis. Annals of the Rheumatic Diseases. Jan. 2007;66(1):18-22. [pmid: 17158140].
95 Anandacoomarasamy A, Bagga H, Ding C, et al. Predictors of clinical response to intraarticular Hylan injections -- a prospective study using synovial fluid measures, clinical outcomes, and magnetic resonance imaging. Journal of Rheumatology. Apr. 2008;35(4):685-90. [pmid: 18278831].
96 Anandacoomarasamy A, Caterson ID, Leibman S, et al. Influence of BMI on health-related quality of life: comparison between an obese adult cohort and age-matched population norms. Obesity (Silver Spring). Nov. 2009;17(11):2114-8. [pmid: 19390522].
97 Anandacoomarasamy A, Giuffre BM, Leibman S, et al. Delayed gadolinium-enhanced magnetic resonance imaging of cartilage: clinical associations in obese adults. J Rheumatol. May. 2009;36(5):1056-62. [pmid: 19369468].
98 Anandacoomarasamy A, Smith G, Leibman S, et al. Cartilage defects are associated with physical disability in obese adults. Rheumatology (Oxford). Oct. 2009;48(10):1290-3. [pmid: 19690127].
99 Anchuela J, Gomez-Pellico L, Ferrer-Blanco M, et al. Muscular function and bone mass after knee arthroplasty. International Orthopaedics. 2001;25(4):253-6. [pmid: 11561503].
100 Andereya S, Stanzel S, Maus U, et al. Assessment of leech therapy for knee osteoarthritis: a randomized study. Acta Orthopaedica. 2008;79(2):235-43. [pmid: 18484250].
101 Andersson GBJ, Bouchard J, Bozic KJ, et al. Arthritis and related conditions. The Burden of Musculoskeletal Diseases. Rosemont, IL. Bone and Joint Decade. 2008:71-96.
102 Andersson GBJ, Bouchard J, Bozic KJ, et al. Health care utilization and economic cost of musculoskeletal diseases. The Burden of Musculoskeletal Diseases. Rosemont, IL. Bone and Joint Decade. 2008:195-225.
103 Andersson MLE, Thorstensson CA, Roos EM, et al. Serum levels of cartilage oligomeric matrix protein (COMP) increase temporarily after physical exercise in patients with knee osteoarthritis. BMC Musculoskeletal Disorders. 2006;7:98. [pmid: 17156423].
104 Andres BM, Mears SC, Somel DS, et al. Treatment of osteoarthritic cartilage lesions with osteochondral autograft transplantation. Orthopedics. Nov. 2003;26(11):1121-6. [pmid: 14627109].
105 Andriacchi T, Koo S, Scanlan SF. Gait mechanics influence healthy cartilage morphology and osteoarthritis of the knee. J Bone Joint Surg Am. 2009;91(SUPPL 1):95-100. [pmid: 19182033].
106 Ang DC, Ibrahim SA, Burant CJ, et al. Is there a difference in the perception of symptoms between african americans and whites with osteoarthritis?. J Rheumatol. Jun. 2003;30(6):1305-10. [pmid: 12784407].
107 Angelini ED, Ciaccio EJ. Optimized region finding and edge detection of knee cartilage surfaces from magnetic resonance images. Annals of Biomedical Engineering. Mar. 2003;31(3):336-45. [pmid: 12680731].
108 Angermann P, Riegels-Nielsen P, Pedersen H. Osteochondritis dissecans of the femoral condyle treated with periosteal transplantation. Poor outcome in 14 patients followed for 6–9 years. Acta Orthopaedica Scandinavica. Dec. 1998;69(6):595-7. [pmid: 9930104].
109 Angin S, Karatosun V, Unver B, et al. Gait assessment in patients with thrust plate prosthesis and intramedullary stemmed prosthesis implanted to each hip. Archives of Orthopaedic & Trauma Surgery. Feb. 2007;127(2):91-6. [pmid: 17216169].
110 Aoki Y, Yasuda K, Mikami S, et al. Inverted V-shaped high tibial osteotomy compared with closing-wedge high tibial osteotomy for osteoarthritis of the knee. Ten-year follow-up result. Journal of Bone & Joint Surgery - British Volume. Oct. 2006;88(10):1336-40. [pmid: 17012424].
111 Appelboom T, Schuermans J, Verbruggen G, et al. Symptoms modifying effect of avocado/soybean unsaponifiables (ASU) in knee osteoarthritis: A double blind, prospective, placebo-controlled study. Scandinavian journal of rheumatology. 2001;30(4):242-7. [pmid: 11578021].
112 Ara Y, Koshino T, Takagi T, et al. Modified Loeffler’s medial capsulotomy for osteoarthritis of the knee: 20 years’ follow-up. International Orthopaedics. 2001;24(6):327-30. [pmid: 11294423].
113 Arabori M, Matsui N, Kuroda R, et al. Posterior condylar offset and flexion in posterior cruciate-retaining and posterior stabilized TKA. Journal of Orthopaedic Science. Jan. 2008;13(1):46-50. [pmid: 18274855].
114 Arbes S, Resinger C, Vecsei V, et al. The functional outcome of total tears of the anterior cruciate ligament (ACL) in the skeletally immature patient. Int Orthop. Aug. 2007;31(4):471-5. [pmid: 16947051].
115 Archibeck MJ, White RE Jr. Council of Musculoskeletal Specialty Societies AAoOS. What’s new in adult reconstructive knee surgery. Journal of Bone & Joint Surgery - American Volume. Aug. 2004;86-A(8):1839-49. [pmid: 15292446].
116 Arden NK, Reading IC, Jordan KM, et al. A randomised controlled trial of tidal irrigation vs corticosteroid injection in knee osteoarthritis: the KIVIS Study. Osteoarthritis & Cartilage. 2008;16(6):733-9. [pmid: 18077189].
117 Impact of an Integrated Health Education, Patient-Consultation, and Exercise Program on Functional Performance among Women with Knee Osteoarthritis. 19th IAGG World Congress of Gerontology and Geriatrics. Paris (France). 5–9 Jul 2009.
118 Argenson JN, Flecher X, Parratte S, et al. Patellofemoral arthroplasty: an update. Clinical Orthopaedics & Related Research. 2005;440(Journal Article):50-3. [pmid: 16239783].
119 Argenson JN, Parratte S, Ashour A, et al. Patient-reported outcome correlates with knee function after a single-design mobile-bearing TKA. Clinical Orthopaedics & Related Research. 2008;466(11):2669-76. [pmid: 18709432].
120 Argenson JN, Parratte S, Bertani A, et al. Long-term results with a lateral unicondylar replacement. Clinical Orthopaedics & Related Research. 2008;466(11):2686-93. [pmid: 18574650].
121 Arokoski JP, Leinonen V, Arokoski MH, et al. Postural control in male patients with hip osteoarthritis. Gait and Posture. 2006;23(1):45-50. [pmid: 16311194].
122 Asai H, Nakamura R. Effect of non-steroidal anti-inflammatory drugs on osteoarthritis of the knee. With special reference to PSP clearance as an indicator. Acta Rheumatol Scand. 1970;16(3):231-9. [pmid: 5488868].
123 Asano H, Muneta T, Sekiya I. Soft tissue tension in extension in total knee arthroplasty affects postoperative knee extension and stability. [Erratum appears in Knee Surg Sports Traumatol Arthrosc. 2009 Apr;17(4):431]. Knee Surgery, Sports Traumatology, Arthroscopy. Nov. 2008;16(11):999-1003. [pmid: 18758749].
124 Asay JL, Mundermann A, Andriacchi TP. Adaptive patterns of movement during stair climbing in patients with knee osteoarthritis. Journal of Orthopaedic Research. 2009;27(3):325-9. [pmid: 18853434].
125 Ashraf T, Beard DJ, Newman JH. Symmetrical vs asymmetrical total knee replacement--a medium term comparative analysis. Knee. Mar. 2003;10(1):61-6. [pmid: 12649029].
126 Ashraf T, Newman JH, Evans RL, et al. Lateral unicompartmental knee replacement survivorship and clinical experience over 21 years. Journal of Bone & Joint Surgery - British Volume. Nov. 2002;84(8):1126-30. [pmid: 12463656].
127 Asik M, Sen C, Kilic B, et al. High tibial osteotomy with Puddu plate for the treatment of varus gonarthrosis. Knee Surgery, Sports Traumatology, Arthroscopy. Oct. 2006;14(10):948-54. [pmid: 16607564].
128 Ask S, Lindmark B, Johansson A. Utvtirdering av Continuous Passive Motion (CPM) vid rehabilitering efter knaprotesoperation. Nordisk Fysioterapi. 2003;7(2):29-39.
129 Askary-Ashtiani AR, Mousavi SJ, Montazeri A, et al. Cultural adaptation and validation of the Persian version of the Arthritis Impact Measurement Scales 2-Short Form in patients with osteoarthritis of the knee. Disabil Rehabil. 2009;31(25):2081-7. [pmid: 19888838].
130 Astephen JL, Deluzio KJ. Changes in frontal plane dynamics and the loading response phase of the gait cycle are characteristic of severe knee osteoarthritis application of a multidimensional analysis technique. Clinical Biomechanics. 2005;20(2):209-17. [pmid: 15621327].
131 Astephen JL, Deluzio KJ, Caldwell G, et al. Biomechanical Changes At the Hip, Knee, and Ankle Joints During Gait Are Associated with Knee Osteoarthritis Severity. Journal of Orthopaedic Research. 2008;26(3):332-41. [pmid: 17960658].
132 Astephen JL, Deluzio KJ, Caldwell GE, et al. Gait and neuromuscular pattern changes are associated with, differences in knee osteoarthritis severity levels. Journal of Biomechanics. 2008;41(4):868-76. [pmid: 18078943].
133 Astephen Wilson JL, Wilson DA, Dunbar MJ, et al. Preoperative gait patterns and BMI are associated with tibial component migration. Acta Orthop. Aug. 2010;81(4):478-86. [pmid: 20809746].
134 Atamaz F, Hepguler S, Oncu J. Translation and validation of the Turkish version of the arthritis impact measurement scales 2 in patients with knee osteoarthritis. J Rheumatol. Jul. 2005;32(7):1331-6. [pmid: 15996073].
135 Atamaz F, Kirazli Y, Akkoc Y. A comparison of two different intra-articular hyaluronan drugs and physical therapy in the management of knee osteoarthritis. Rheumatol Int. Aug. 2006;26(10):873-8. [pmid: 16416102].
136 Attur MG, Patel R, DiCesare PE, et al. Regulation of nitric oxide production by salicylates and tenidap in human OA-affected cartilage, rat chondrosarcomas and bovine chondrocytes. Osteoarthritis Cartilage. Jul. 1998;6(4):269-77. [pmid: 9876396].
137 Auvinet B, Chaleil D, Barrey E. Accelerometric gait analysis for use in hospital outpatients. Rev Rhum Engl Ed. Jul–Sep. 1999;66(7–9):389-97. [pmid: 10526379].
138 Avramidis K, Strike PW, Taylor PN, et al. Effectiveness of electric stimulation of the vastus medialis muscle in the rehabilitation of patients after total knee arthroplasty. Arch Phys Med Rehabil. Dec. 2003;84(12):1850-3. [pmid: 14669193].
139 Evaluation of Dynamic Balance in Knee Osteoarthritis Patients With Varus Deformity. 6th Annual European Congress of Rheumatology (EULAR 2005). Vienna (Austria). 8–11 Jun 2005.
140 Aydogan NH, Baydar ML, Atay T, et al. The effect of arthroscopic surgery and intraarticular drug injection to the antioxidation system and lipid peroxidation at osteoarthritis of knee. Saudi Medical Journal. Mar. 2008;29(3):397-402. [pmid: 18327367].
141 Ayers DC, Franklin PD, Ploutz-Snyder R, et al. Total knee replacement outcome and coexisting physical and emotional illness. Clinical Orthopaedics & Related Research. 2005;440(Journal Article):157-61. [pmid: 16239800].
142 Ayral X, Dougados M, Listrat V, et al. Arthroscopic evaluation of chondropathy in osteoarthritis of the knee. J Rheumatol. Apr. 1996;23(4):698-706. [pmid: 8730130].
143 Ayral X, Gicquere C, Duhalde A, et al. Effects of video information on preoperative anxiety level and tolerability of joint lavage in knee osteoarthritis. Arthritis & Rheumatism. Aug. 2002;47(4):380-2. [pmid: 12209483].
144 Ayral X, Mackillop N, Genant HK, et al. Arthroscopic evaluation of potential structure-modifying drug in osteoarthritis of the knee. A multicenter, randomized, double-blind comparison of tenidap sodium vs piroxicam. Osteoarthritis & Cartilage. Mar. 2003;11(3):198-207. [pmid: 12623291].
145 Babul N, Noveck R, Chipman H, et al. Efficacy and safety of extended-release, once-daily tramadol in chronic pain: a randomized 12-week clinical trial in osteoarthritis of the knee. Journal of Pain & Symptom Management. Jul. 2004;28(1):59-71. [pmid: 15223085].
146 Bach CM, Nogler M, Steingruber IE, et al. Scoring systems in total knee arthroplasty. Clinical Orthopaedics & Related Research. 2002;(399):184-96. [pmid: 12011708].
147 Bachmeier CJ, March LM, Cross MJ, et al. A comparison of outcomes in osteoarthritis patients undergoing total hip and knee replacement surgery. Osteoarthritis & Cartilage. Feb. 2001;9(2):137-46. [pmid: 11330253].
148 Backstein D, Morag G, Hanna S, et al. Long-term follow-up of distal femoral varus osteotomy of the knee. Journal of Arthroplasty. Jun. 2007;22(4 Suppl 1):2-6. [pmid: 17570268].
149 Badria FA, ElFarahaty T, Shabana AA, et al. Boswellia-curcumin preparation for treating knee osteoarthritis: a clinical evaluation. Alternative and Complementary Therapies. 2002;8(6):341-8.
150 Bae DK, Song SJ, Yoon KH. Closed-wedge high tibial osteotomy using computer-assisted surgery compared to the conventional technique. Journal of Bone & Joint Surgery - British Volume. Sep. 2009;91(9):1164-71. [pmid: 19721041].
151 Bae DK, Song SJ, Yoon KH. Total knee arthroplasty following closed wedge high tibial osteotomy. International Orthopaedics. Feb. 2010;34(2):283-7. [pmid: 19367405].
152 Baer PA, Thomas LM, Shainhouse Z. Treatment of osteoarthritis of the knee with a topical diclofenac solution: a randomised controlled, 6-week trial. [ISRCTN53366886]. BMC Musculoskeletal Disorders. 2005;6(Journal Article):44. [pmid: 16086839].
153 Bailie AG, Lewis PL, Brumby SA, et al. The Unispacer knee implant: early clinical results. Journal of Bone & Joint Surgery - British Volume. Apr. 2008;90(4):446-50. [pmid: 18378917].
154 Baker PN, Khaw FM, Kirk LMG, et al. A randomised controlled trial of cemented versus cementless press-fit condylar total knee replacement: 15-year survival analysis. Journal of Bone & Joint Surgery - British Volume. Dec. 2007;89(12):1608-14. [pmid: 18057361].
155 Bal BS, Greenberg DD, Buhrmester L, et al. Primary TKA with a zirconia ceramic femoral component. The Journal of Knee Surgery. Apr. 2006;19(2):89-93. [pmid: 16642883].
156 Baldini A, Adravanti P. Less invasive TKA: extramedullary femoral reference without navigation. Clinical Orthopaedics & Related Research. 2008;466(11):2694-700. [pmid: 18712455].
157 Baliunas AJ, Hurwitz DE, Ryals AB, et al. Increased knee joint loads during walking are present in subjects with knee osteoarthritis. Osteoarthritis and Cartilage. 2002;10(7):573-9. [pmid: 12127838].
158 Baltzer AW, Moser C, Jansen SA, et al. Autologous conditioned serum (Orthokine) is an effective treatment for knee osteoarthritis. Osteoarthritis & Cartilage. 2009;17(2):152-60. [pmid: 18674932].
159 Band PA. Comparing different therapeutic classes for the treatment of osteoarthritis of the knee: data from the OMERACT-OARSI responder criteria analysis. Osteoarthritis & Cartilage. May. 2005;13(5):449. author reply 50. [pmid: 15882568].
160 Bankes MJK, Back DL, Cannon SR, et al. The effect of component malalignment on the clinical and radiological outcome of the Kinemax total knee replacement. Knee. Mar. 2003;10(1):55-60. [pmid: 12649028].
161 Bannuru RR, Natov NS, Obadan IE, et al. Therapeutic trajectory of hyaluronic acid versus corticosteroids in the treatment of knee osteoarthritis: a systematic review and meta-analysis. Arthritis & Rheumatism. Dec. 15. 2009;61(12):1704-11. [pmid: 19950318].
162 Bao F, Wu Z. Observation on Therapeutic Effect of Knee Osteoarthritis Treated by Electroacupuncture. International Journal of Clinical Acupuncture. 2007;16(3):191-5.
163 Baraf HS, Gloth FM, Barthel HR, et al. Safety and efficacy of topical diclofenac sodium gel for knee osteoarthritis in elderly and younger patients: pooled data from three randomized, double-blind, parallel-group, placebo-controlled, multicentre trials. Drugs & Aging. Jan. 1. 2011;28(1):27-40. [pmid: 21174485].
164 Bare J, MacDonald SJ, Bourne RB. Preoperative evaluations in revision total knee arthroplasty. Clin Orthop Relat Res. May. 2006;446:40-4. [pmid: 16672870].
165 Bare JV, Gill HS, Beard DJ, et al. A convex lateral tibial plateau for knee replacement. Knee. Mar. 2006;13(2):122-6. [pmid: 16403637].
166 Barrack RL, Bertot AJ, Wolfe MW, et al. Patellar resurfacing in total knee arthroplasty. A prospective, randomized, double-blind study with five to seven years of follow-up. Journal of Bone & Joint Surgery - American Volume. Sep. 2001;83-A(9):1376-81. [pmid: 11568201].
167 Barrack RL, Nakamura SJ, Hopkins SG, et al. Winner of the 2003 James A. Rand Young Investigator’s Award. Early failure of cementless mobile-bearing total knee arthroplasty. Journal of Arthroplasty. Oct. 2004;19(7 Suppl 2):101-6. [pmid: 15457427].
168 Barrett DS, Cobb AG, Bentley G. Joint proprioception in normal, osteoarthritic and replaced knees. J Bone Joint Surg Br. Jan. 1991;73(1):53-6. [pmid: 1991775].
169 Progression of dynamic knee loading at one year in medial knee osteoarthritis: the influence of baseline load. 2008. 2008 Combined Sections Meeting of the American Physical Therapy Association (CSM 2008). Nashville, Tennessee (USA). 6–10 Feb 2008.
170 Barrios JA, Higginson JS, Royer TD, et al. Static and dynamic correlates of the knee adduction moment in healthy knees ranging from normal to varus-aligned. Clinical Biomechanics. Dec. 2009;24(10):850-4. [pmid: 19703728].
171 Bartels EM, Bliddal H, Schondorff PK, et al. Symptomatic efficacy and safety of diacerein in the treatment of osteoarthritis: a meta-analysis of randomized placebo-controlled trials. Osteoarthritis & Cartilage. Mar. 2010;18(3):289-96. [pmid: 19857509].
172 Barthel HR, Haselwood D, Longley S 3rd, et al. Randomized controlled trial of diclofenac sodium gel in knee osteoarthritis. Seminars in Arthritis & Rheumatism. Dec. 2009;39(3):203-12. [pmid: 19932833].
173 Relationship among weight loss, body composition, and symptom improvement in overweight persons with Knee OA. Arthritis and Rheumatism. 2005. 69Th Annual Meeting of the American College of Rheumatology and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
174 Bassiouni M, Bassiouni H, el-Feki M. Sensitivity versus specificity of phonoarthrography as an indicator for cartilage degeneration. Clin Rheumatol. Mar. 1995;14(2):135-42. [pmid: 7789052].
175 Basskin L. Comparison of a scheduled narcotic for chronic pain with a similar medication for breakthrough pain only is not a clinically relevant comparison. American Journal of Managed Care. Jul. 2006;12(7):412. author reply -5. [pmid: 16834528].
176 Bastable R, Rann S, Barker V. Top tips in 2 minutes: osteoarthritis in the knee. British Journal of General Practice. May. 2008;58(550):376-7. [pmid: 18482504].
177 Bathis H, Perlick L, Tingart M, et al. CT-free computer-assisted total knee arthroplasty versus the conventional technique: radiographic results of 100 cases. Orthopedics. May. 2004;27(5):476-80. [pmid: 15181942].
178 Batlle-Gualda E, Roman Ivorra J, Martin-Mola E, et al. Aceclofenac vs paracetamol in the management of symptomatic osteoarthritis of the knee: a double-blind 6-week randomized controlled trial. Osteoarthritis & Cartilage. Aug. 2007;15(8):900-8. [pmid: 17387026].
179 Battisti WP, Katz NP, Weaver AL, et al. Pain management in osteoarthritis: a focus on onset of efficacy--a comparison of rofecoxib, celecoxib, acetaminophen, and nabumetone across four clinical trials. Journal of Pain. Nov. 2004;5(9):511-20. [pmid: 15556830].
180 Bauer HW, Klasser M, von Hanstein KL, et al. Oxaceprol is as effective as diclofenac in the therapy of osteoarthritis of the knee and hip. Clinical Rheumatology. 1999;18(1):4-9. [pmid: 10088941].
181 Bauer T, Hardy P, Lemoine J, et al. Drop foot after high tibial osteotomy: a prospective study of aetiological factors. Knee Surgery, Sports Traumatology, Arthroscopy. Jan. 2005;13(1):23-33. [pmid: 15103455].
182 Baumann C, Rat AC, Osnowycz G, et al. Do clinical presentation and pre-operative quality of life predict satisfaction with care after total hip or knee replacement?. Journal of Bone & Joint Surgery - British Volume. Mar. 2006;88(3):366-73. [pmid: 16498013].
183 Bayramoglu M, Karatas M, Cetin N, et al. Comparison of two different viscosupplements in knee osteoarthritis -- a pilot study. Clin Rheumatol. May. 2003;22(2):118-22. [pmid: 12740676].
184 Bayramoglu M, Toprak R, Sozay S. Effects of Osteoarthritis and Fatigue on Proprioception of the Knee Joint. Archives of Physical Medicine and Rehabilitation. 2007;88(3):346-50. [pmid: 17321828].
185 Baysal O, Baysal T, Alkan A, et al. Comparison of MRI graded cartilage and MRI based volume measurement in knee osteoarthritis. Swiss Medical Weekly. May. 15. 2004;134(19–20):283-8. [pmid: 15243849].
186 Beard DJ, Murray DW, Rees JL, et al. Accelerated recovery for unicompartmental knee replacement--a feasibility study. Knee. Sep. 2002;9(3):221-4. [pmid: 12126681].
187 Beard DJ, Pandit H, Gill HS, et al. The influence of the presence and severity of pre-existing patellofemoral degenerative changes on the outcome of the Oxford medial unicompartmental knee replacement. Journal of Bone & Joint Surgery - British Volume. Dec. 2007;89(12):1597-601. [pmid: 18057359].
188 Beard DJ, Pandit H, Ostlere S, et al. Pre-operative clinical and radiological assessment of the patellofemoral joint in unicompartmental knee replacement and its influence on outcome. Journal of Bone & Joint Surgery - British Volume. Dec. 2007;89(12):1602-7. [pmid: 18057360].
189 Beaupre LA, al-Yamani M, Huckell JR, et al. Hydroxyapatite-coated tibial implants compared with cemented tibial fixation in primary total knee arthroplasty. A randomized trial of outcomes at five years. Journal of Bone & Joint Surgery - American Volume. Oct. 2007;89(10):2204-11. [pmid: 17908897].
190 Beaupre LA, Davies DM, Jones CA, et al. Exercise combined with continuous passive motion or slider board therapy compared with exercise only: a randomized controlled trial of patients following total knee arthroplasty. Physical Therapy. 2001;81(4):1029-37. [pmid: 11296803].
191 Beaupre LA, Lier D, Davies DM, et al. The effect of a preoperative exercise and education program on functional recovery, health related quality of life, and health service utilization following primary total knee arthroplasty. Journal of Rheumatology. 2004;31(6):1166-73. [pmid: 15170931].
192 Becker R, Ropke M, Krull A, et al. Surgical treatment of isolated patellofemoral osteoarthritis. Clinical Orthopaedics & Related Research. 2008;466(2):443-9. [pmid: 18196430].
193 Becvar R, Urbanova Z, Vlasakova V, et al. Nabumetone induces less gastrointestinal mucosal changes than diclofenac retard. Clinical Rheumatology. 1999;18(4):273-8. [pmid: 10468165].
194 Bedson J, Jordan K, Croft P. How do GPs use x rays to manage chronic knee pain in the elderly? A case study. Annals of the Rheumatic Diseases. 2003;62(5):450-4. [pmid: 12695159].
195 Bedson J, Mottram S, Thomas E, et al. Knee pain and osteoarthritis in the general population: what influences patients to consult?. Family practice. 2007;24(5):443-53. [pmid: 17675657].
196 Comparative Efficacy of Three and Five Intra-Articular Injections of Sodium Hyaluronate in the Treatment of Knee Osteoarthritis - A 12-Month Study. 2006 Annual European Congress of Rheumatology (EULAR 2006). Amsterdam (Netherlands (The)). 21–24 Jun 2006.
197 Bellamy N, Bell MJ, Goldsmith CH, et al. BLISS index using WOMAC index detects between-group differences at low-intensity symptom states in osteoarthritis. Journal of Clinical Epidemiology. May. 2010;63(5):566-74. [pmid: 19896801].
198 Bellamy N, Bell MJ, Goldsmith CH, et al. Evaluation of WOMAC 20, 50, 70 response criteria in patients treated with hylan G-F 20 for knee osteoarthritis. Annals of the Rheumatic Diseases. 2005;64(6):881-5. [pmid: 15564311].
199 Bellamy N, Bell MJ, Goldsmith CH, et al. The effectiveness of hylan G-F 20 in patients with knee osteoarthritis: an application of two sets of response criteria developed by the OARSI and one set developed by OMERACT-OARSI. Osteoarthritis and Cartilage. 2005;13(2):104-10. [pmid: 15694571].
200 Bellamy N, Buchanan WW, Goldsmith CH, et al. Validation study of WOMAC: a health status instrument for measuring clinically important patient relevant outcomes to antirheumatic drug therapy in patients with osteoarthritis of the hip or knee. J Rheumatol. Dec. 1988;15(12):1833-40. [pmid: 3068365].
201 Bellamy N, Campbell J, Robinson V, et al. Intraarticular corticosteroid for treatment of osteoarthritis of the knee. Cochrane Database Syst Rev. 2005;(2):CD005328. [pmid: 15846755].
202 Bellamy N, Campbell J, Robinson V, et al. Viscosupplementation for the treatment of osteoarthritis of the knee. Cochrane Database Syst Rev. 2005;(2):CD005321. [pmid: 15846754].
203 Bellamy N, Campbell J, Stevens J, et al. Validation study of a computerized version of the Western Ontario and McMaster Universities VA3.0 Osteoarthritis Index. J Rheumatol. Dec. 1997;24(12):2413-5. [pmid: 9415651].
204 Bellamy N, Goldstein LD, Tekanoff RA. Continuing medical education-driven skills acquisition and impact on improved patient outcomes in family practice setting. J Contin Educ Health Prof. Winter. 2000;20(1):52-61. [pmid: 11232072].
205 Bellamy N, Klestov A, Muirden K, et al. Perceptual variation in categorizing individuals according to American College of Rheumatology classification criteria for hand, knee, and hip osteoarthritis (OA): observations based on an Australian Twin Registry study of OA. J Rheumatol. Dec. 1999;26(12):2654-8. [pmid: 10606378].
206 Bellamy N, Wilson C, Hendrikz J, et al. Electronic data capture (EDC) using cellular technology: implications for clinical trials and practice, and preliminary experience with the m-Womac Index in hip and knee OA patients. Inflammopharmacology. Apr. 2009;17(2):93-9. [pmid: 19139830].
207 Bellemans J, Banks S, Victor J, et al. Fluoroscopic analysis of the kinematics of deep flexion in total knee arthroplasty. Influence of posterior condylar offset. Journal of Bone & Joint Surgery - British Volume. Jan. 2002;84(1):50-3. [pmid: 11837832].
208 Bellemans J, Vandenneucker H, Vanlauwe J, et al. The influence of coronal plane deformity on mediolateral ligament status: an observational study in varus knees. Knee Surgery, Sports Traumatology, Arthroscopy. Feb. 2010;18(2):152-6. [pmid: 19730815].
209 Beltran J, Martin-Mola E, Figueroa M, et al. Comparison of dexketoprofen trometamol and ketoprofen in the treatment of osteoarthritis of the knee. Journal of Clinical Pharmacology. Dec. 1998;38(12 Suppl):74S-80S. [pmid: 9882085].
210 Bennell K, Crossley K, Jayarajan J, et al. Ground reaction forces and bone parameters in females with tibial stress fracture. Med Sci Sports Exerc. Mar. 2004;36(3):397-404. [pmid: 15076780].
211 Bennell K, Duncan M, Cowan S, et al. Effects of vastus medialis oblique retraining versus general quadriceps strengthening on vasti onset. Med Sci Sports Exerc. May. 2010;42(5):856-64. [pmid: 19997004].
212 Bennell K, Wee E, Crossley K, et al. Effects of experimentally-induced anterior knee pain on knee joint position sense in healthy individuals. J Orthop Res. Jan. 2005;23(1):46-53. [pmid: 15607874].
213 Bennell K, White S, Crossley K. The oral contraceptive pill: a revolution for sportswomen?. Br J Sports Med. Aug. 1999;33(4):231-8. [pmid: 10450476].
214 Bennell KL, Creaby MW, Wrigley TV, et al. Bone marrow lesions are related to dynamic knee loading in medial knee osteoarthritis. Annals of the Rheumatic Diseases. Jun. 2010;69(6):1151-4. [pmid: 19910299].
215 Bennell KL, Crossley K. Musculoskeletal injuries in track and field: incidence, distribution and risk factors. Aust J Sci Med Sport. Sep. 1996;28(3):69-75. [pmid: 8937661].
216 Bennell KL, Hinman RS, Metcalf BR. Association of sensorimotor function with knee joint kinematics during locomotion in knee osteoarthritis. American Journal of Physical Medicine and Rehabilitation. 2004;83(6):455-63. [pmid: 15166690].
217 Bennell KL, Hinman RS, Metcalf BR, et al. Relationship of knee joint proprioception to pain and disability in individuals with knee osteoarthritis. Journal of Orthopaedic Research. 2003;21(5):792-7. [pmid: 12919865].
218 Bennell KL, Hunt MA, Wrigley TV, et al. Role of muscle in the genesis and management of knee osteoarthritis. Rheum Dis Clin North Am. Aug. 2008;34(3):731-54. [pmid: 18687280].
219 Bennett AN, Crossley KM, Brukner PD, et al. Predictors of symptomatic response to glucosamine in knee osteoarthritis: an exploratory study. British Journal of Sports Medicine. Jul. 2007;41(7):415-9. [pmid: 17261554].
220 Bennett D, Hanratty B, Thompson N, et al. The influence of pain on knee motion in patients with osteoarthritis undergoing total knee arthroplasty. Orthopedics. 2009;32(4). [pmid: 19388620].
221 Bennett Michael H, Best Thomas M, Babul-Wellar S, et al. Hyperbaric oxygen therapy for delayed onset muscle soreness and closed soft tissue injury, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2005.
222 Berend KR, Lombardi AV Jr, Adams JB. Obesity, young age, patellofemoral disease, and anterior knee pain: identifying the unicondylar arthroplasty patient in the United States. Orthopedics. May. 2007;30(5 Suppl):19-23. [pmid: 17549861].
223 Berend KR, Lombardi AV Jr, Mallory TH, et al. Early failure of minimally invasive unicompartmental knee arthroplasty is associated with obesity. Clinical Orthopaedics & Related Research. 2005;440(Journal Article):60-6. [pmid: 16239785].
224 Bergami E, Gildone A, Zanoli G, et al. Static and dynamic baropodometry to evaluate patients treated by total knee replacement with a mobile meniscus. Chirurgia Degli Organi di Movimento. Oct–Dec. 2005;90(4):387-96. [pmid: 16878774].
225 Berger MJ, Doherty TJ. The Role of the Neuromuscular System in the Development, Progression, and Rehabilitation of Osteoarthritis of the Knee. Critical Reviews in Physical and Rehabilitation Medicine. 2007;19(3):227-49.
226 Berger RA, Meneghini RM, Sheinkop MB, et al. The progression of patellofemoral arthrosis after medial unicompartmental replacement: results at 11 to 15 years. Clinical Orthopaedics & Related Research. Nov. 2004;(428):92-9. [pmid: 15534526].
227 Berkovitz S, Cummings M, Perrin C, et al. High volume acupuncture clinic (HVAC) for chronic knee pain--audit of a possible model for delivery of acupuncture in the National Health Service. Acupuncture in Medicine. 2008;26(1):46-50. [pmid: 18356798].
228 Berman B. A 60-year-old woman considering acupuncture for knee pain. JAMA. Apr. 18. 2007;297(15):1697-707. [pmid: 17440146].
229 Berman BM, Lao L, Langenberg P, et al. Effectiveness of acupuncture as adjunctive therapy in osteoarthritis of the knee: a randomized, controlled trial. [Reprint of Acupunct Med. 2006 Dec;24 Suppl:S7–14; PMID: 17308513]. Annals of Internal Medicine. 2004;141(12):901-10. [pmid: 15611487].
230 Berman BM, Singh BB, Lao L, et al. A randomized trial of acupuncture as an adjunctive therapy in osteoarthritis of the knee. Rheumatology. 1999;38(4):346-54. [pmid: 10378713].
231 Berth A, Urbach D, Awiszus F. Improvement of voluntary quadriceps muscle activation after total knee arthroplasty. Arch Phys Med Rehabil. Oct. 2002;83(10):1432-6. [pmid: 12370881].
232 Berth A, Urbach D, Neumann W, et al. Strength and voluntary activation of quadriceps femoris muscle in total knee arthroplasty with midvastus and subvastus approaches. Journal of Arthroplasty. Jan. 2007;22(1):83-8. [pmid: 17197313].
233 Bertin KC. Cruciate-retaining total knee arthroplasty at 5 to 7 years followup. Clinical Orthopaedics & Related Research. 2005;(436):177-83. [pmid: 15995438].
234 Bertin KC. Tibial component fixation in total knee arthroplasty: a comparison of pegged and stemmed designs. Journal of Arthroplasty. Aug. 2007;22(5):670-8. [pmid: 17689774].
235 Betancourt MCC, Linden JCVd, et al. Dual energy x-ray absorptiometry analysis contributes to the prediction of hip osteoarthritis progression. Arthritis Research & Therapy. 2009;11(6):R162. [pmid: 19883507].
236 Bezwada HP, Nazarian DG, Booth RE Jr. Simultaneous revision and contralateral primary total knee arthroplasty. Journal of Bone & Joint Surgery - American Volume. 2003;85-A(10):1993-8. [pmid: 14563810].
237 Bhan S, Malhotra R. Results of rotating-platform, low-contact-stress knee prosthesis. Journal of Arthroplasty. Dec. 2003;18(8):1016-22. [pmid: 14658106].
238 Bhan S, Malhotra R, Kiran EK, et al. A comparison of fixed-bearing and mobile-bearing total knee arthroplasty at a minimum follow-up of 4.5 years. Journal of Bone & Joint Surgery - American Volume. Oct. 2005;87(10):2290-6. [pmid: 16203896].
239 Bhosale AM, Myint P, Roberts S, et al. Combined autologous chondrocyte implantation and allogenic meniscus transplantation: a biological knee replacement. Knee. Oct. 2007;14(5):361-8. [pmid: 17689085].
240 Bianchi M, Broggini M, Balzarini P, et al. Effects of nimesulide on pain and on synovial fluid concentrations of substance P, interleukin-6 and interleukin-8 in patients with knee osteoarthritis: comparison with celecoxib. International Journal of Clinical Practice. Aug. 2007;61(8):1270-7. [pmid: 17590218].
241 Biau D, Mullins MM, Judet T, et al. Mobile versus fixed-bearing total knee arthroplasty: mid-term comparative clinical results of 216 prostheses. Knee Surgery, Sports Traumatology, Arthroscopy. Oct. 2006;14(10):927-33. [pmid: 16565879].
242 Bijl D, Dekker J, van Baar ME, et al. Validity of Cyriax’s concept capsular pattern for the diagnosis of osteoarthritis of hip and/or knee. Scandinavian Journal of Rheumatology. 1998;27(5):347-51. [pmid: 9808397].
243 Bilgen MS, Atici T, Bilgen OF. High tibial osteotomy for medial compartment osteoarthritis: a comparison of clinical and radiological results from closed wedge and focal dome osteotomies. Journal of International Medical Research. Nov–Dec. 2007;35(6):733-41. [pmid: 18034986].
244 Bin SI, Nam TS. Early results of high-flex total knee arthroplasty: comparison study at 1 year after surgery. Knee Surgery, Sports Traumatology, Arthroscopy. Apr. 2007;15(4):350-5. [pmid: 17072657].
245 Bin S-I, Lee S-H, Kim C-W, et al. Results of arthroscopic medial meniscectomy in patients with grade IV osteoarthritis of the medial compartment. Arthroscopy. Mar. 2008;24(3):264-8. [pmid: 18308176].
246 Bingham CO 3rd, Bird SR, Smugar SS, et al. Responder analysis and correlation of outcome measures: pooled results from two identical studies comparing etoricoxib, celecoxib, and placebo in osteoarthritis. Osteoarthritis & Cartilage. Nov. 2008;16(11):1289-93. [pmid: 18514551].
247 Bingham CO 3rd, Buckland-Wright JC, Garnero P, et al. Risedronate decreases biochemical markers of cartilage degradation but does not decrease symptoms or slow radiographic progression in patients with medial compartment osteoarthritis of the knee: results of the two-year multinational knee osteoarthritis structural arthritis study. Arthritis & Rheumatism. Nov. 2006;54(11):3494-507. [pmid: 17075851].
248 Bingham CO 3rd, Sebba AI, Rubin BR, et al. Efficacy and safety of etoricoxib 30 mg and celecoxib 200 mg in the treatment of osteoarthritis in two identically designed, randomized, placebo-controlled, non-inferiority studies. Rheumatology. 2007;46(3):496-507. [pmid: 16936327].
249 Bingham CO 3rd, Smugar SS, Wang H, et al. Early response to COX-2 inhibitors as a predictor of overall response in osteoarthritis: pooled results from two identical trials comparing etoricoxib, celecoxib and placebo. Rheumatology. Sep. 2009;48(9):1122-7. [pmid: 19589894].
250 Birchall D, Ismail AM, Peat G. Clinical outcomes from a physiotherapist-led intra-articular hyaluronic acid injection clinic. Musculoskeletal Care. Sep. 2008;6(3):135-49. [pmid: 18729065].
251 Birmingham TB, Giffin JR, Chesworth BM, et al. Medial opening wedge high tibial osteotomy: a prospective cohort study of gait, radiographic, and patient-reported outcomes. Arthritis & Rheumatism. May. 15. 2009;61(5):648-57. [pmid: 19405016].
252 Biscevic M, Ljuca F, Biscevic A, et al. Morphometric alteration of femoral condyles due to knee osteoarthritis. Collegium Antropologicum. Sep. 2008;32(3):875-9. [pmid: 18982764].
253 Biswal S, Medhi B, Pandhi P. Longterm efficacy of topical nonsteroidal antiinflammatory drugs in knee osteoarthritis: metaanalysis of randomized placebo controlled clinical trials. Journal of Rheumatology. Sep. 2006;33(9):1841-4. [pmid: 16960944].
254 Bito H, Takeuchi R, Kumagai K, et al. A predictive factor for acquiring an ideal lower limb realignment after opening-wedge high tibial osteotomy. Knee Surgery, Sports Traumatology, Arthroscopy. Apr. 2009;17(4):382-9. [pmid: 19183959].
255 Bjordal J. NSAIDs in osteoarthritis: irreplaceable or troublesome guidelines?. British Journal of Sports Medicine. Apr. 2006;40(4):285-6. discussion 6. [pmid: 16556779].
256 Blacher RS. Arthroscopic surgery for osteoarthritis of the knee. New England Journal of Medicine. Nov. 21. 2002;347(21):1717-9. author reply -9. [pmid: 12448432].
257 Blin O, Pailhous J, Lafforgue P, et al. Quantitative analysis of walking in patients with knee osteoarthritis: a method of assessing the effectiveness of non-steroidal anti-inflammatory treatment. Annals of the Rheumatic Diseases. 1990;49(12):990-3. [pmid: 2270972].
258 Board TN, Javed A. Patellar resurfacing in total knee arthroplasty. Journal of Bone & Joint Surgery - American Volume. Dec. 2003;85-A(12):2483-4. author reply 4. [pmid: 14668527].
259 Board TN, Mahmood A, Ryan WG, et al. The Lubinus patellofemoral arthroplasty: a series of 17 cases. Archives of Orthopaedic & Trauma Surgery. Jun. 2004;124(5):285-7. [pmid: 15024580].
260 Bocanegra TS, Weaver AL, Tindall EA, et al. Diclofenac/misoprostol compared with diclofenac in the treatment of osteoarthritis of the knee or hip: a randomized, placebo controlled trial. Arthrotec Osteoarthritis Study Group. Journal of Rheumatology. Aug. 1998;25(8):1602-11. [pmid: 9712107].
261 Boegard T, Rudling O, Dahlstrom J, et al. Bone scintigraphy in chronic knee pain: comparison with magnetic resonance imaging. Annals of the Rheumatic Diseases. 1999;58(1):20-6. [pmid: 10343536].
262 Boegard T, Rudling O, Petersson IF, et al. Correlation between radiographically diagnosed osteophytes and magnetic resonance detected cartilage defects in the tibiofemoral joint. Ann Rheum Dis. Jul. 1998;57(7):401-7. [pmid: 9797566].
263 Boegard T, Rudling O, Petersson IF, et al. Correlation between radiographically diagnosed osteophytes and magnetic resonance detected cartilage defects in the patellofemoral joint. Ann Rheum Dis. Jul. 1998;57(7):395-400. [pmid: 9797565].
264 Bohnsack M, Lipka W, Ruhmann O, et al. The value of knee arthroscopy in patients with severe radiological osteoarthritis. Archives of Orthopaedic & Trauma Surgery. Nov. 2002;122(8):451-3. [pmid: 12442182].
265 Bolbos RI, Zuo J, Banerjee S, et al. Relationship between trabecular bone structure and articular cartilage morphology and relaxation times in early OA of the knee joint using parallel MRI at 3 T. Osteoarthritis Cartilage. Oct. 2008;16(10):1150-9. [pmid: 18387828].
266 Boldt JG, Stiehl JB, Hodler J, et al. Femoral component rotation and arthrofibrosis following mobile-bearing total knee arthroplasty. International Orthopaedics. Oct. 2006;30(5):420-5. [pmid: 16521009].
267 Bonin N, Ait Si, Selmi T, Donell ST, et al. Anterior cruciate reconstruction combined with valgus upper tibial osteotomy: 12 years follow-up. Knee. Dec. 2004;11(6):431-7. [pmid: 15581760].
268 Bonutti PM, Dethmers D, Ulrich SD, et al. Computer navigation-assisted versus minimally invasive TKA: benefits and drawbacks. Clinical Orthopaedics & Related Research. Nov. 2008;466(11):2756-62. [pmid: 18815850].
269 Bonutti PM, Dethmers DA, McGrath MS, et al. Navigation did not improve the precision of minimally invasive knee arthroplasty. Clinical Orthopaedics & Related Research. 2008;466(11):2730-5. [pmid: 18618213].
270 Bonutti PM, Zywiel MG, Ulrich SD, et al. A comparison of subvastus and midvastus approaches in minimally invasive total knee arthroplasty. Journal of Bone & Joint Surgery - American Volume. Mar. 2010;92(3):575-82. [pmid: 20194315].
271 Boocock M, McNair P, Cicuttini F, et al. The short-term effects of running on the deformation of knee articular cartilage and its relationship to biomechanical loads at the knee. Osteoarthritis and Cartilage. 2009;17(7):883-90. [pmid: 19246217].
272 Boon AJ, Smith J, Dahm DL, et al. Efficacy of intra-articular botulinum toxin type A in painful knee osteoarthritis: a pilot study. Pm & R. Apr. 2010;2(4):268-76. [pmid: 20430328].
273 Boonstra MC, De Waal Malefijt MC, Verdonschot N. How to quantify knee function after total knee arthroplasty?. Knee. Oct. 2008;15(5):390-5. [pmid: 18620863].
274 Boonstra MC, Jenniskens AT, Barink M, et al. Functional evaluation of the TKA patient using the coordination and variability of rising. Journal of Electromyography and Kinesiology. 2007;17(1):49-56. [pmid: 16455268].
275 Boonstra MC, Schwering PJ, De Waal Malefijt MC, et al. Sit-to-stand movement as a performance-based measure for patients with total knee arthroplasty. Phys Ther. Feb. 2010;90(2):149-56. [pmid: 20007664].
276 Boquet J, Goffin E, Poilvache P. Outcome of total knee arthroplasties after renal transplantation. Archives of Orthopaedic & Trauma Surgery. Dec. 2008;128(12):1345-8. [pmid: 18758791].
277 Borjesson M, Weidenhielm L, Mattsson E, et al. Gait and clinical measurements in patients with knee osteoarthritis after surgery: a prospective 5-year follow-up study. Knee. Apr. 2005;12(2):121-7. [pmid: 15749447].
278 Boswell DJ, Ostergaard K, Philipson RS, et al. Evaluation of GW406381 for treatment of osteoarthritis of the knee: two randomized, controlled studies. Medscape journal of medicine. 2008;10(11):259. [pmid: 19099009].
279 Botha-Scheepers S, Dougados M, Ravaud P, et al. Effect of medial tibial plateau alignment on serial radiographs on the capacity to predict progression of knee osteoarthritis. Osteoarthritis Cartilage. Feb. 2008;16(2):272-6. [pmid: 18262805].
280 Botha-Scheepers S, Kloppenburg M, Kroon HM, et al. Fixed-flexion knee radiography: the sensitivity to detect knee joint space narrowing in osteoarthritis. Osteoarthritis Cartilage. Mar. 2007;15(3):350-3. [pmid: 17074511].
281 Botha-Scheepers S, Watt I, Rosendaal FR, et al. Changes in outcome measures for impairment, activity limitation, and participation restriction over two years in osteoarthritis of the lower extremities. Arthritis Rheum. Dec. 15. 2008;59(12):1750-5. [pmid: 19035428].
282 Botha-Scheepers S, Watt I, Slagboom E, et al. Innate production of tumour necrosis factor alpha and interleukin 10 is associated with radiological progression of knee osteoarthritis. Annals of the Rheumatic Diseases. Aug. 2008;67(8):1165-9. [pmid: 18029383].
283 Bothra V, Lemon G, Lang D, et al. Reliability of templating in estimating the size of uni-condylar knee arthroplasty. J Arthroplasty. Sep. 2003;18(6):780-3. [pmid: 14513454].
284 Bottros J, Gad B, Krebs V, et al. Gap balancing in total knee arthroplasty. Journal of Arthroplasty. Jun. 2006;21(4 Suppl 1):11-5. [pmid: 16781420].
285 Boureau F, Schneid H, Zeghari N, et al. The IPSO study: ibuprofen, paracetamol study in osteoarthritis. A randomised comparative clinical study comparing the efficacy and safety of ibuprofen and paracetamol analgesic treatment of osteoarthritis of the knee or hip. Annals of the Rheumatic Diseases. 2004;63(9):1028-34. [pmid: 15308513].
286 Self-Reported Fatigue in Individuals with Knee Osteoarthritis. 69th Annual Meeting of the American College of Rheumatology and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
287 Boyd SK, Muller R, Matyas JR, et al. Early morphometric and anisotropic change in periarticular cancellous bone in a model of experimental knee osteoarthritis quantified using microcomputed tomography. Clinical Biomechanics. 2000;15(8):624-31. [pmid: 10936436].
288 Boyer P, Boublil D, Magrino B, et al. Total knee replacement in the fixed valgus deformity using a lateral approach: role of the automatic iliotibial band release for a successful balancing. International Orthopaedics. Dec. 2009;33(6):1577-83. [pmid: 19066890].
289 Boylan M. Acupuncture with Voltaren is superior than Voltaren alone in knee osteoarthritis. Journal - Australian Traditional-Medicine Society. 2005;11(2):65.
290 Brach JS, Perera S, Studenski S, et al. The reliability and validity of measures of gait variability in community-dwelling older adults. Arch Phys Med Rehabil. Dec. 2008;89(12):2293-6. [pmid: 19061741].
291 Bradley JD, Brandt KD, Katz BP, et al. Treatment of knee osteoarthritis: relationship of clinical features of joint inflammation to the response to a nonsteroidal antiinflammatory drug or pure analgesic. J Rheumatol. Dec. 1992;19(12):1950-4. [pmid: 1294745].
292 Bradley JD, Flusser D, Katz BP, et al. A randomized, double blind, placebo controlled trial of intravenous loading with S-adenosylmethionine (SAM) followed by oral SAM therapy in patients with knee osteoarthritis. J Rheumatol. May. 1994;21(5):905-11. [pmid: 8064733].
293 Bradley JD, Heilman DK, Katz BP, et al. Tidal irrigation as treatment for knee osteoarthritis: a sham-controlled, randomized, double-blinded evaluation. Arthritis & Rheumatism. 2002;46(1):100-8. [pmid: 11817581].
294 Bradley JD, Katz BP, Brandt KD. Severity of knee pain does not predict a better response to an antiinflammatory dose of ibuprofen than to analgesic therapy in patients with osteoarthritis. Journal of Rheumatology. May. 2001;28(5):1073-6. [pmid: 11361192].
295 Bradley JD, Rudy AC, Katz BP, et al. Correlation of serum concentrations of ibuprofen stereoisomers with clinical response in the treatment of hip and knee osteoarthritis. J Rheumatol. Jan. 1992;19(1):130-4. [pmid: 1556674].
296 Brahmachari B, Chatterjee S, Ghosh A. Efficacy and safety of diacerein in early knee osteoarthritis: a randomized placebo-controlled trial. Clin Rheumatol. Oct. 2009;28(10):1193-8. [pmid: 19597913].
297 Brand C, Snaddon J, Bailey M, et al. Vitamin E is ineffective for symptomatic relief of knee osteoarthritis: a six month double blind, randomised, placebo controlled study. Annals of the Rheumatic Diseases. 2001;60(10):946-9. [pmid: 11557651].
298 Brander VA, Stulberg SD, Adams AD, et al. Predicting total knee replacement pain: a prospective, observational study. Clin Orthop Relat Res. Nov. 2003;(416):27-36. [pmid: 14646737].
299 Brandt KD. The role of analgesics in the management of osteoarthritis pain. American Journal of Therapeutics. Mar. 2000;7(2):75-90. [pmid: 11319576].
300 Brandt KD, Block JA, Michalski JP, et al. Efficacy and safety of intraarticular sodium hyaluronate in knee osteoarthritis. ORTHOVISC Study Group. Clinical Orthopaedics & Related Research. 2001;(385):130-43. [pmid: 11302304].
301 Brandt KD, Mazzuca SA. Experience with a placebo-controlled randomized clinical trial of a disease-modifying drug for osteoarthritis: the doxycycline trial. Rheumatic Diseases Clinics of North America. Feb. 2006;32(1):217-34. [pmid: 16504832].
302 Brandt KD, Mazzuca SA, Buckwalter KA. Acetaminophen, like conventional NSAIDs, may reduce synovitis in osteoarthritic knees. Rheumatology. 2006;45(11):1389-94. [pmid: 16606655].
303 Brandt KD, Mazzuca SA, Katz BP. Methodology and statistical analysis in the Glucosamine/Chondroitin Arthritis Intervention Trial: comment on the article by Sawitzke et al. Arthritis & Rheumatism. Nov. 2009;60(11):3514-5. author reply 5–6. [pmid: 19877051].
304 Brandt KD, Mazzuca SA, Katz BP, et al. Effects of doxycycline on progression of osteoarthritis: results of a randomized, placebo-controlled, double-blind trial. Arthritis & Rheumatism. Jul. 2005;52(7):2015-25. [pmid: 15986343].
305 Brantingham JW, Globe G, Pollard H, et al. Manipulative therapy for lower extremity conditions: expansion of literature review. J Manipulative Physiol Ther. 2009;32(1):53-71. [pmid: 19121464].
306 Brassard MF, Insall JN, Scuderi GR, et al. Does modularity affect clinical success? A comparison with a minimum 10-year followup. Clinical Orthopaedics & Related Research. 2001;(388):26-32. [pmid: 11451128].
307 Braverman DL, Kern HB, Nagler W. Recurrent spontaneous hemarthrosis associated with reflex sympathetic dystrophy. Arch Phys Med Rehabil. Mar. 1998;79(3):339-42. [pmid: 9523789].
308 Bremander AB, Dahl LL, Roos EM. Validity and reliability of functional performance tests in meniscectomized patients with or without knee osteoarthritis. Scandinavian Journal of Medicine and Science in Sports. 2007;17(2):120-7. [pmid: 17394472].
309 Symptoms, not radiographic features, predict functional decline over 4–10 years in patients with knee injury and knee osteoarthritis. 2005. 69th Annual Meeting of the American College of Rheumatology and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
310 Bridgman SA, Walley G, MacKenzie G, et al. Sub-vastus approach is more effective than a medial parapatellar approach in primary total knee arthroplasty: a randomized controlled trial. Knee. Jun. 2009;16(3):216-22. [pmid: 19135375].
311 Differences in Self Report and Performance Responsiveness to Intra-Articular Hyaluronan Injection for Knee Osteoarthritis. 2008 Combined Sections Meeting of the American Physical Therapy Association (CSM 2008). Nashville, Tennessee (USA). 6–10 Feb 2008.
312 Briem K, Axe MJ, Snyder-Mackler L. Functional and perceived response to intra-articular hyaluronan injection in patients with knee osteoarthritis: persistence of treatment effects over 5 months. Knee Surgery, Sports Traumatology, Arthroscopy. 2009;17(7):763-9. [pmid: 19296086].
313 Brien S, Lewith G, Walker AF, et al. Bromelain as an adjunctive treatment for moderate-to-severe osteoarthritis of the knee: a randomized placebo-controlled pilot study. Qjm. 2006;99(12):841-50. [pmid: 17121765].
314 Brilhault J, Lautman S, Favard L, et al. Lateral femoral sliding osteotomy lateral release in total knee arthroplasty for a fixed valgus deformity. Journal of Bone & Joint Surgery - British Volume. Nov. 2002;84(8):1131-7. [pmid: 12463657].
315 Brinkhaus B, Witt CM, Jena S, et al. Physician and treatment characteristics in a randomised multicentre trial of acupuncture in patients with osteoarthritis of the knee. Complementary Therapies in Medicine. 2007;15(3):180-9. [pmid: 17709063].
316 Brinkman JM, Lobenhoffer P, Agneskirchner JD, et al. Osteotomies around the knee: patient selection, stability of fixation and bone healing in high tibial osteotomies. Journal of Bone & Joint Surgery - British Volume. Dec. 2008;90(12):1548-57. [pmid: 19043123].
317 Brinkman J-M, Luites JWH, Wymenga AB, et al. Early full weight bearing is safe in open-wedge high tibial osteotomy. Acta Orthopaedica. Apr. 2010;81(2):193-8. [pmid: 20175658].
318 Brinkmann JR, Perry J. Rate and range of knee motion during ambulation in healthy and arthritic subjects. Phys Ther. Jul. 1985;65(7):1055-60. [pmid: 4011684].
319 Brosseau L, Welch V, Wells G, et al. Low level laser therapy (Classes I, II and III) for treating osteoarthritis. Cochrane Database of Systematic Reviews. 2003;(2):CD002046. [pmid: 12804422].
320 Brouwer RW, Bierma-Zeinstra SMA, van Raaij TM, et al. Osteotomy for medial compartment arthritis of the knee using a closing wedge or an opening wedge controlled by a Puddu plate. A one-year randomised, controlled study. Journal of Bone & Joint Surgery - British Volume. Nov. 2006;88(11):1454-9. [pmid: 17075089].
321 Brown C, Jones A. A response to O’Connell, et al. letter ‘A failure of the review process? Comment on Ahsin et al. Clinical and endocrinological changes after electro-acupuncture treatment in patients with osteoarthritis of the knee. Pain 2009;147:60–6’. Pain. 2010;149(1):161. [pmid: 20172655].
322 Brown CA, Jones AKP. Physiological mechanisms of acupuncture: beyond placebo?. Pain. Dec. 15. 2009;147(1–3):11-2. [pmid: 19796877].
323 Brown K, Kachelman J, Topp R, et al. Predictors of functional task performance among patients scheduled for total knee arthroplasty. Journal of Strength & Conditioning Research. 2009;23(2):436-43. [pmid: 19197199].
324 Brown TE, Diduch DR, Moskal JT. Component size asymmetry in bilateral total knee arthroplasty. American Journal of Knee Surgery. 2001;14(2):81-4. [pmid: 11401174].
325 Bruhlmann P, Michel BA. Topical diclofenac patch in patients with knee osteoarthritis: a randomized, double-blind, controlled clinical trial. Clinical & Experimental Rheumatology. Mar–Apr. 2003;21(2):193-8. [pmid: 12747273].
326 Brunner F. zur Studie von Kirkley et al. “A randomized trial of arthroscopic surgery for osteoarthritis of the knee”. Praxis. Dec. 17. 2008;97(25):1347. [pmid: 19085846].
327 Bruns J, Rayf M, Steinhagen J. Longitudinal long-term results of surgical treatment in patients with osteochondritis dissecans of the femoral condyles. Knee Surgery, Sports Traumatology, Arthroscopy. May. 2008;16(5):436-41. [pmid: 18305925].
328 Bruun JV. Arthroscopic treatment of knee osteoarthritis is not better than conservative treatment. Ugeskrift for Laeger. Oct. 20. 2008;170(43):3446. [pmid: 18979671].
329 Bruyere O, Collette J, Kothari M, et al. Osteoarthritis, magnetic resonance imaging, and biochemical markers: a one year prospective study. Annals of the Rheumatic Diseases. Aug. 2006;65(8):1050-4. [pmid: 16396978].
330 Bruyere O, Collette JH, Ethgen O, et al. Biochemical markers of bone and cartilage remodeling in prediction of longterm progression of knee osteoarthritis. J Rheumatol. May. 2003;30(5):1043-50. [pmid: 12734904].
331 Bruyere O, Dardenne C, Lejeune E, et al. Subchondral tibial bone mineral density predicts future joint space narrowing at the medial femoro-tibial compartment in patients with knee osteoarthritis. Bone. May. 2003;32(5):541-5. [pmid: 12753870].
332 Bruyere O, Reginster JY. Glucosamine and chondroitin sulfate as therapeutic agents for knee and hip osteoarthritis. Drugs & Aging. 2007;24(7):573-80. [pmid: 17658908].
333 Bruyere O, Richy F, Reginster JY. Three year joint space narrowing predicts long term incidence of knee surgery in patients with osteoarthritis: an eight year prospective follow up study. Ann Rheum Dis. Dec. 2005;64(12):1727-30. [pmid: 15843444].
334 Bryant AL, Clark RA, Bartold S, et al. Effects of estrogen on the mechanical behavior of the human Achilles tendon in vivo. J Appl Physiol. Oct. 2008;105(4):1035-43. [pmid: 18566188].
335 Brys DA. Corticosteroid compared with hyaluronic acid injections for the treatment of osteoarthritis of the knee. Journal of Bone & Joint Surgery - American Volume. Apr. 2004;86-A(4):874. author reply -5. [pmid: 15069162].
336 Buck RJ, Wyman BT, Le Graverand MP, et al. Does the use of ordered values of subregional change in cartilage thickness improve the detection of disease progression in longitudinal studies of osteoarthritis?. Arthritis Rheum. Jul. 15. 2009;61(7):917-24. [pmid: 19565557].
337 Buck RJ, Wyman BT, Le Graverand MP, et al. An efficient subset of morphological measures for articular cartilage in the healthy and diseased human knee. Magn Reson Med. Mar. 2010;63(3):680-90. [pmid: 20187178].
338 BucklandWright C. Subchondral bone changes in hand and knee osteoarthritis detected by radiography. Osteoarthritis and Cartilage. 2004;12(Suppl A):S10-9. [pmid: 14698636].
339 Buckland-Wright C. Evaluation of disease progression during nonsteroidal antiinflammatory drug treatment: imaging X-rays. Osteoarthritis & Cartilage. May. 1999;7(3):343-4. [pmid: 10329325].
340 Risedronate Protects against Subchondral Bone Loss in OA Knee Patients with Progressive Joint Space Narrowing. 69th Annual Meeting of the American College of Rheumatology and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
341 Buckland-Wright JC, Macfarlane DG, Williams SA, et al. Accuracy and precision of joint space width measurements in standard and macroradiographs of osteoarthritic knees. Ann Rheum Dis. Nov. 1995;54(11):872-80. [pmid: 7492235].
342 Buckwalter JA, Saltzman C, Brown T. The impact of osteoarthritis: Implications for research. Clinical Orthopaedics and Related Research. 2004;(427 SUPPL).
343 Home-Based Exercise and Weight Control in Overweight Elderly Individuals with Knee Osteoarthritis. 69th Annual Meeting of the American College of Rheumatology and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
344 Budsberg SC, Bergh MS, Reynolds LR, et al. Evaluation of pentosan polysulfate sodium in the postoperative recovery from cranial cruciate injury in dogs: a randomized, placebo-controlled clinical trial. Veterinary Surgery. Apr. 2007;36(3):234-44. [pmid: 17461948].
345 Buechel FF Sr., Buechel FF Jr, Pappas MJ, et al. Twenty-year evaluation of meniscal bearing and rotating platform knee replacements. Clinical Orthopaedics & Related Research. 2001;(388):41-50. [pmid: 11451131].
346 Bulow HH, Christensen BV, Wilbek H, et al. Predictive value of subjective and objective evaluation before acupuncture treatment. American Journal of Chinese Medicine. 1992;20(1):17-23. [pmid: 1605127].
347 Bulthuis Y, Mohammad S, Braakman-Jansen LM, et al. Cost-effectiveness of intensive exercise therapy directly following hospital discharge in patients with arthritis: results of a randomized controlled clinical trial. Arthritis Rheum. Feb. 15. 2008;59(2):247-54. [pmid: 18240191].
348 Burch F, Codding C, Patel N, et al. Lidocaine patch 5% improves pain, stiffness, and physical function in osteoarthritis pain patients. A prospective, multicenter, open-label effectiveness trial. Osteoarthritis & Cartilage. Mar. 2004;12(3):253-5. [pmid: 14972343].
349 Burch F, Fishman R, Messina N, et al. A comparison of the analgesic efficacy of Tramadol Contramid OAD versus placebo in patients with pain due to osteoarthritis. Journal of Pain & Symptom Management. Sep. 2007;34(3):328-38. [pmid: 17583466].
350 Burnett RS, Haydon CM, Rorabeck CH, et al. Patella resurfacing versus nonresurfacing in total knee arthroplasty: results of a randomized controlled clinical trial at a minimum of 10 years’ followup. Clinical Orthopaedics & Related Research. 2004;(428):12-25. [pmid: 15534514].
351 Burns R, Graney MJ, Lummus AC, et al. Differences of self-reported osteoarthritis disability and race. J Natl Med Assoc. Sep. 2007;99(9):1046-51. [pmid: 17913116].
352 Busija L, Osborne RH, Nilsdotter A, et al. Magnitude and meaningfulness of change in SF-36 scores in four types of orthopedic surgery. Health & Quality of Life Outcomes. 2008;6(Journal Article):55. [pmid: 18667085].
353 Butler RJ, Minick KI, Ferber R, et al. Gait mechanics after ACL reconstruction implications for the early onset of knee osteoarthritis. British Journal of Sports Medicine. 2009;43(5):366-70. [pmid: 19042923].
354 Caborn D, Rush J, Lanzer W, et al. A randomized, single-blind comparison of the efficacy and tolerability of hylan G-F 20 and triamcinolone hexacetonide in patients with osteoarthritis of the knee. Journal of Rheumatology. Feb. 2004;31(2):333-43. [pmid: 14760806].
355 Functioning over time in persons with severe knee osteoarthritis (OA). 2005. 69th Annual Meeting of the American College of Rheumatology and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
356 Cahue S, Sharma L, Dunlop D, et al. The ratio of type II collagen breakdown to synthesis and its relationship with the progression of knee osteoarthritis. Osteoarthritis & Cartilage. Jul. 2007;15(7):819-23. [pmid: 17344068].
357 Cai L, Okumu FW, Cleland JL, et al. A slow release formulation of insulin as a treatment for osteoarthritis. Osteoarthritis Cartilage. Sep. 2002;10(9):692-706. [pmid: 12202122].
358 Calder JD, Ashwood N, Hollingdale JP. Survivorship analysis of the “Performance” total knee replacement--7-year follow-up. International Orthopaedics. 1999;23(2):100-3. [pmid: 10422025].
359 Pulsed Electrical Stimulation in Patients with Osteoarthritis of the Knee: Follow-Up in 288 Patients who had Failed Non-Operative Therapy. 70th Annual Meeting of the American College of Rheumatology and the 41st Annual Meeting of the Association of Rheumatology Health Professionals (ACR/ARHP 2006). Washington Convention Center, Washington DC (USA). 10–15 Nov 2006.
360 Callaghan JJ, O’Rourke MR, Johnston RC. The uni experience: history tells it all. Orthopedics. Sep. 2005;28(9):988. [pmid: 16190080].
361 Campbell D, Schuster AJ, Pfluger D, et al. Unicondylar knee replacement with a new tensioner device: clinical results of a multicentre study on 168 cases. Archives of Orthopaedic & Trauma Surgery. Jun. 2010;130(6):727-32. [pmid: 20306198].
362 Campbell DG, Duncan WW, Ashworth M, et al. Patellar resurfacing in total knee replacement: a ten-year randomised prospective trial. Journal of Bone & Joint Surgery - British Volume. Jun. 2006;88(6):734-9. [pmid: 16720765].
363 Capeci CM, Brown EC 3rd, Scuderi GR, et al. Component asymmetry in simultaneous bilateral total knee arthroplasty. Journal of Arthroplasty. Aug. 2006;21(5):749-53. [pmid: 16877164].
364 Carames B, Lopez-Armada MJ, Cillero-Pastor B, et al. Differential effects of tumor necrosis factor-alpha and interleukin-1beta on cell death in human articular chondrocytes. Osteoarthritis Cartilage. Jun. 2008;16(6):715-22. [pmid: 18054255].
365 Carballido-Gamio J, Blumenkrantz G, Lynch JA, et al. Longitudinal analysis of MRI T(2) knee cartilage laminar organization in a subset of patients from the osteoarthritis initiative. Magn Reson Med. Feb. 2010;63(2):465-72. [pmid: 19918905].
366 Carballido-Gamio J, Stahl R, Blumenkrantz G, et al. Spatial analysis of magnetic resonance T1rho and T2 relaxation times improves classification between subjects with and without osteoarthritis. Med Phys. Sep. 2009;36(9):4059-67. [pmid: 19810478].
367 Carlsson A, Bjorkman A, Besjakov J, et al. Cemented tibial component fixation performs better than cementless fixation: a randomized radiostereometric study comparing porous-coated, hydroxyapatite-coated and cemented tibial components over 5 years. Acta Orthopaedica. Jun. 2005;76(3):362-9. [pmid: 16156464].
368 Carmona L, Ballina J, Gabriel R, et al. The burden of musculoskeletal diseases in the general population of Spain: results from a national survey. Ann Rheum Dis. Nov. 2001;60(11):1040-5. [pmid: 11602475].
369 Carpenter J, Gajewski B, Teel C, et al. Bayesian data analysis: estimating the efficacy of T’ai Chi as a case study. Nursing Research. May–Jun. 2008;57(3):214-9. [pmid: 18496107].
370 Cartier P, Sanouiller J-L, Khefacha A. Long-term results with the first patellofemoral prosthesis. Clinical Orthopaedics & Related Research. Jul. 2005;(436):47-54. [pmid: 15995419].
371 Case JP, Baliunas AJ, Block JA. Lack of efficacy of acetaminophen in treating symptomatic knee osteoarthritis: a randomized, double-blind, placebo-controlled comparison trial with diclofenac sodium. Archives of Internal Medicine. Jan. 27. 2003;163(2):169-78. [pmid: 12546607].
372 Caspi D, Anouk M, Golan I, et al. Synovial fluid levels of anti-cyclic citrullinated peptide antibodies and IgA rheumatoid factor in rheumatoid arthritis, psoriatic arthritis, and osteoarthritis. Arthritis Rheum. Feb. 15. 2006;55(1):53-6. [pmid: 16463412].
373 Castagna A, Rinaldi S, Fontani V, et al. Does osteoarthritis of the knee also have a psychogenic component? Psycho-emotional treatment with a radio-electric device vs. intra-articular injection of sodium hyaluronate: an open-label, naturalistic study. Acupunct Electrother Res. 2010;35(1–2):1-16. [pmid: 20578643].
374 Catani F, Innocenti B, Belvedere C, et al. The Mark Coventry Award: Articular contact estimation in TKA using in vivo kinematics and finite element analysis. Clinical Orthopaedics & Related Research. Jan. 2010;468(1):19-28. [pmid: 19548042].
375 Catani F, Leardini A, Ensini A, et al. The stability of the cemented tibial component of total knee arthroplasty: posterior cruciate-retaining versus posterior-stabilized design. Journal of Arthroplasty. Sep. 2004;19(6):775-82. [pmid: 15343540].
376 Catterall JB, Stabler TV, Flannery CR, et al. Changes in serum and synovial fluid biomarkers after acute injury (NCT00332254). Arthritis Research & Therapy. Dec. 31. 2010;12(6):R229. [pmid: 21194441].
377 Causero A, Tcherkes-Zade T, Tcherkes-Zade D, et al. The Ilizarov technique in the treatment of osteoarthritic genu varum. Chirurgia Degli Organi di Movimento. Oct–Dec. 2002;87(4):235-40. [pmid: 12847792].
378 Centeno CJ, Busse D, Kisiday J, et al. Increased knee cartilage volume in degenerative joint disease using percutaneously implanted, autologous mesenchymal stem cells. Pain Physician. May–Jun. 2008;11(3):343-53. [pmid: 18523506].
379 Cha HS, Koh JH, Jeon CH, et al. Comparison of the efficacy and safety of naproxen CR and nabumetone in the treatment of patients with osteoarthritis of the knee. International Journal of Clinical Pharmacology & Therapeutics. Dec. 2001;39(12):539-45. [pmid: 11770835].
380 Chaiyakit P, Hongku N, Meknavin S. A comparison of early clinical outcome in computer assisted surgery and conventional technique in minimally invasive total knee arthroplasty. Journal of the Medical Association of Thailand. Dec. Suppl 6. 2009;92:S91-6. [pmid: 20120669].
381 Chakravarty EF, Hubert HB, Lingala VB, et al. Long distance running and knee osteoarthritis. A prospective study. Am J Prev Med. Aug. 2008;35(2):133-8. [pmid: 18550323].
382 Chambers K, Schulzer M, Sobolev B. A controlled trial of arthroscopic surgery for osteoarthritis of the knee. Arthroscopy. Sep. 2002;18(7):683-7. [pmid: 12240636].
383 Chan WP, Hsu SM, Huang GS, et al. Creation of a reflecting formula to determine a patient’s indication for undergoing total knee arthroplasty. J Orthop Sci. Jan. 2010;15(1):44-50. [pmid: 20151250].
384 Flexion contracture and progression of knee osteoarthritis (OA). 2006. 2006 Combined Section Meeting of the Specialty Sections of the American Physical Therapy Association (CSM 2006). San Diego Convention Center, San Diego, California (USA). 1–5 Feb 2006.
385 Chang A, Hayes K, Dunlop D, et al. Thrust during ambulation and the progression of knee osteoarthritis. Arthritis Rheum. Dec. 2004;50(12):3897-903. [pmid: 15593195].
386 Chang CB, Seong SC, Kim TK. Evaluations of radiographic joint space--do they adequately predict cartilage conditions in the patellofemoral joint of the patients undergoing total knee arthroplasty for advanced knee osteoarthritis?. Osteoarthritis Cartilage. Oct. 2008;16(10):1160-6. [pmid: 18387318].
387 Chantarapanich N, Nanakorn P, Chernchujit B, et al. A finite element study of stress distributions in normal and osteoarthritic knee joints. Journal of the Medical Association of Thailand. Dec. Suppl 6. 2009;92:S97-103. [pmid: 20120670].
388 Chantre P, Cappelaere A, Leblan D, et al. Efficacy and tolerance of Harpagophytum procumbens versus diacerhein in treatment of osteoarthritis. Phytomedicine. Jun. 2000;7(3):177-83. [pmid: 11185727].
389 Chao EYS. Coventry’s classic. Journal of Bone & Joint Surgery - American Volume. Jun. 2002;84-A(6):1081-2. [pmid: 12063350].
390 Chao J, Wu C, Sun B, et al. Inflammatory characteristics on ultrasound predict poorer longterm response to intraarticular corticosteroid injections in knee osteoarthritis. Journal of Rheumatology. Mar. 2010;37(3):650-5. [pmid: 20080918].
391 Using Ultrasound to Predict Response to Intraarticular Steroid Injections in Knee Osteoarthritis. 2008 Annual Scientific Meeting of the American College of Rheumatology and Association of Rheumatology Health Professionals. Moscone Center, San Francisco, California (USA). 24–29 Oct 2008.
392 Chapman AB, Feller JA. Therapeutic arthroscopy for knee osteoarthritis: time to reconsider?. Medical Journal of Australia. 2003;179(4):179-80. [pmid: 12914503].
393 Chard JA, Tallon D, Dieppe PA. Epidemiology of research into interventions for the treatment of osteoarthritis of the knee joint. Ann Rheum Dis. Jun. 2000;59(6):414-8. [pmid: 10834855].
394 Charni-Ben Tabassi N, Desmarais S, Bay-Jensen AC, et al. The type II collagen fragments Helix-II and CTX-II reveal different enzymatic pathways of human cartilage collagen degradation. Osteoarthritis Cartilage. Oct. 2008;16(10):1183-91. [pmid: 18403221].
395 Short Term Results at 6 Months Follow Up of Yttrium-90 Silicate Radiosynovectomy Treatment in Knee Osteoarthritis. 20th Annual Congress of the European Association of Nuclear Medicine (EANM 2007). Copenhagen Congress Center, Copenhagen (Denmark). 13–17 Oct 2007.
396 Chatzopoulos D, Moralidis E, Markou P, et al. Yttrium-90 radiation synovectomy in knee osteoarthritis: a prospective assessment at 6 and 12 months. Nuclear Medicine Communications. 2009;30(6):472-9. [pmid: 19357547].
397 Chaudhary R, Beaupre LA, Johnston DWC. Knee range of motion during the first two years after use of posterior cruciate-stabilizing or posterior cruciate-retaining total knee prostheses. A randomized clinical trial. Journal of Bone & Joint Surgery - American Volume. Dec. 2008;90(12):2579-86. [pmid: 19047702].
398 Chayanupatkul M, Honsawek S. Soluble receptor for advanced glycation end products (sRAGE) in plasma and synovial fluid is inversely associated with disease severity of knee osteoarthritis. Clin Biochem. Sep. 2010;43(13–14):1133-7. [pmid: 20627100].
399 Checa S, Taylor M, New A. Influence of an interpositional spacer on the behaviour of the tibiofemoral joint: a finite element study. Clin Biomech (Bristol, Avon). Oct. 2008;23(8):1044-52. [pmid: 18499317].
400 Chen A, Rich V, Bain E, et al. Variability of single-leg versus double-leg stance radiographs in the varus knee. The Journal of Knee Surgery. Jul. 2009;22(3):213-7. [pmid: 19634724].
401 Chen AF, Alan RK, Redziniak DE, et al. Quadriceps sparing total knee replacement. The initial experience with results at two to four years. Journal of Bone & Joint Surgery - British Volume. Nov. 2006;88(11):1448-53. [pmid: 17075088].
402 Chen AL, Desai P, Adler EM, et al. Granulomatous inflammation after Hylan G-F 20 viscosupplementation of the knee : a report of six cases. Journal of Bone & Joint Surgery - American Volume. Jul. 2002;84-A(7):1142-7. [pmid: 12107313].
403 Chen AL, Mujtaba M, Zuckerman JD, et al. Midterm clinical and radiographic results with the genesis I total knee prosthesis. Journal of Arthroplasty. Dec. 2001;16(8):1055-62. [pmid: 11740763].
404 Chen CA, Lu W, John CT, et al. Multiecho IDEAL gradient-echo water-fat separation for rapid assessment of cartilage volume at 1.5 T: initial experience. Radiology. Aug. 2009;252(2):561-7. [pmid: 19528355].
405 Chen CF, Chen WM, Lee KS, et al. Advanced osteoarthritic knee with neglected patellar tendon rupture treated with total patellectomy and total knee arthroplasty. J Arthroplasty. Sep. 2004;19(6):793-6. [pmid: 15343543].
406 Chen CP, Chen MJ, Pei YC, et al. Sagittal plane loading response during gait in different age groups and in people with knee osteoarthritis. American Journal of Physical Medicine and Rehabilitation. 2003;82(4):307-12. [pmid: 12649658].
407 The correlation between ultrasonographic findings and Lequesne’s Index in patients with knee osteoarthritis. 2006. 11th Congree of the World Federation for Ultrasound in Medicine and Biology. COEX Convention Center, Seoul (Korea (South)). 28 May 1 Jun 2006.
408 Chen KW, Perlman A, Liao JG, et al. Effects of external qigong therapy on osteoarthritis of the knee. A randomized controlled trial. Clin Rheumatol. 2008;27(12):1497-505. [pmid: 18654733].
409 Chen Z, Wang S, Zhang J, et al. A combined TCM treatment for 72 cases of bony gonitis. Journal of Traditional Chinese Medicine. Jun. 2004;24(2):108-11. [pmid: 15270260].
410 Cheng CK, Lung CY, Lee YM, et al. A new approach of designing the tibial baseplate of total knee prostheses. Clin Biomech (Bristol, Avon). Feb. 1999;14(2):112-7. [pmid: 10619098].
411 Cheng K, Dashti H, McLeod G. Does flexion contracture continue to improve up to five years after total knee arthroplasty?. Journal of Orthopaedic Surgery. Dec. 2007;15(3):303-5. [pmid: 18162675].
412 Cheng SC, Hung TSL, Tse PYT. Investigation of the use of drained blood reinfusion after total knee arthroplasty: a prospective randomised controlled study. Journal of Orthopaedic Surgery. Aug. 2005;13(2):120-4. [pmid: 16131672].
413 Cheng T, Li FF, Zhao S, et al. Soluble P selectin in synovial fluid level is correlated with the radiographic severity of knee osteoarthritis. Clin Chim Acta. Oct. 9. 2010;411(19–20):1529-31. [pmid: 20580699].
414 Cherkin DC, Sherman KJ. Acupuncture and knee osteoarthritis. Annals of Internal Medicine. May. 17. 2005;142(10):872. author reply -3. [pmid: 15897543].
415 Chesworth BM, Mahomed NN, Bourne RB, et al. Willingness to go through surgery again validated the WOMAC clinically important difference from THR/TKR surgery. J Clin Epidemiol. Sep. 2008;61(9):907-18. [pmid: 18687289].
416 Chevalier X, Goupille P, Beaulieu AD, et al. Intraarticular injection of anakinra in osteoarthritis of the knee: a multicenter, randomized, double-blind, placebo-controlled study. Arthritis Rheum. Mar. 15. 2009;61(3):344-52. [pmid: 19248129].
417 Results from a Double Blind, Placebo-Controlled, Multicenter Trial of a Single Intra-Articular Injection of Anakinra (KineretRG) in Patients with Osteoarthritis of the Knee. 69th Annual Meeting of the American College of Rheumatology and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
418 Chevalier X, Jerosch J, Goupille P, et al. Single, intra-articular treatment with 6 ml hylan G-F 20 in patients with symptomatic primary osteoarthritis of the knee: a randomised, multicentre, double-blind, placebo controlled trial. Annals of the Rheumatic Diseases. Jan. 2010;69(1):113-9. [pmid: 19304567].
419 Chiang H, Hsu H-C, Jiang CC. Dome-shaped high tibial osteotomy: a long-term follow-up study. Journal of the Formosan Medical Association. Mar. 2006;105(3):214-9. [pmid: 16520837].
420 Childs JD, Sparto PJ, Fitzgerald GK, et al. Alterations in lower extremity movement and muscle activation patterns in individuals with knee osteoarthritis. Clin Biomech (Bristol, Avon). Jan. 2004;19(1):44-9. [pmid: 14659929].
421 Chitnavis J, Sinsheimer JS, Suchard MA, et al. End-stage coxarthrosis and gonarthrosis Aetiology, clinical patterns and radiological features of idiopathic osteoarthritis. Rheumatology (Oxford). Jun. 2000;39(6):612-9. [pmid: 10888705].
422 Chiu FY, Lin CF, Chen CM, et al. Cefuroxime-impregnated cement at primary total knee arthroplasty in diabetes mellitus. A prospective, randomised study. Journal of Bone & Joint Surgery - British Volume. Jul. 2001;83(5):691-5. [pmid: 11476307].
423 Cho YR, Hong BY, Lim SH, et al. Effects of joint effusion on proprioception in patients with knee osteoarthritis: a single-blind, randomized controlled clinical trial. Osteoarthritis Cartilage. Jan. 2011;19(1):22-8. [pmid: 21034839].
424 Chodosh J, Morton SC, Mojica W, et al. Meta-analysis: chronic disease self-management programs for older adults. Annals of Internal Medicine. Sep. 20. 2005;143(6):427-38. [pmid: 16172441].
425 Choi Brian KL, Verbeek Jos H, Tam Wilson W-S, et al. Exercises for prevention of recurrences of low-back pain, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
426 Choi HR, Hasegawa Y, Kondo S, et al. High tibial osteotomy for varus gonarthrosis: a 10- to 24-year follow-up study. Journal of Orthopaedic Science. 2001;6(6):493-7. [pmid: 11793170].
427 Choquette D, McCarthy TG, Rodrigues JFN, et al. Transdermal fentanyl improves pain control and functionality in patients with osteoarthritis: an open-label Canadian trial. Clinical Rheumatology. May. 2008;27(5):587-95. [pmid: 18038178].
428 Chotanaphuti T, Ongnamthip P, Karnchanalerk K, et al. Comparative study between 2 cm limited quadriceps exposure minimal invasive surgery and conventional total knee arthroplasty in quadriceps function: prospective randomized controlled trial. Journal of the Medical Association of Thailand. Feb. 2008;91(2):203-7. [pmid: 18389985].
429 Chouteau J, Lerat JL, Testa R, et al. Kinematics of a cementless mobile bearing posterior cruciate ligament-retaining total knee arthroplasty. Knee. Jun. 2009;16(3):223-7. [pmid: 19073365].
430 Christensen BV, Iuhl IU, Vilbek H, et al. Acupuncture treatment of severe knee osteoarthrosis. A long-term study. Acta Anaesthesiologica Scandinavica. Aug. 1992;36(6):519-25. [pmid: 1514335].
431 Christensen R, Astrup A, Bliddal H. Weight loss: the treatment of choice for knee osteoarthritis? A randomized trial. Osteoarthritis and Cartilage. 2005;13(1):20-7. [pmid: 15639633].
432 Christmas C, Moncada L. Interpretation of therapies for knee arthritis. Archives of Internal Medicine. Aug. 11–25. 2003;163(15):1862. [pmid: 12912728].
433 Christodoulou NA, Tsaknis RN, Sdrenias CV, et al. Improvement of proximal tibial osteotomy results by lateral retinacular release. Clinical Orthopaedics & Related Research. 2005;441(Journal Article):340-5. [pmid: 16331024].
434 Chrubasik S, Black A. Difference in treatment response of osteoarthritic pain in the hip and knee. Clinical Rheumatology. Jun. 2004;23(3):274. [pmid: 15168163].
435 Chrubasik S, Thanner J, Kunzel O, et al. Comparison of outcome measures during treatment with the proprietary Harpagophytum extract doloteffin in patients with pain in the lower back, knee or hip. Phytomedicine. Apr. 2002;9(3):181-94. [pmid: 12046857].
436 Chung CY, Park MS, Lee KM, et al. Hip osteoarthritis and risk factors in elderly Korean population. Osteoarthritis Cartilage. Mar. 2010;18(3):312-6. [pmid: 19914196].
437 Cibere J, Kopec JA, Thorne A, et al. Randomized, double-blind, placebo-controlled glucosamine discontinuation trial in knee osteoarthritis. Arthritis Care and Research. 2004;51(5):738-45. [pmid: 15478160].
438 Pre-Radiographic Knee Osteoarthritis is Common in People with Knee Pain: Results from a Population-Based Study. 69th Annual Meeting of the American College of Rheumatology and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
439 Cibulka MT, Threlkeld-Watkins J. Patellofemoral pain and asymmetrical hip rotation. Phys Ther. Nov. 2005;85(11):1201-7. [pmid: 16253048].
440 Cicuttini F, Hankin J, Jones G, et al. Comparison of conventional standing knee radiographs and magnetic resonance imaging in assessing progression of tibiofemoral joint osteoarthritis. Osteoarthritis & Cartilage. Aug. 2005;13(8):722-7. [pmid: 15922634].
441 Cicuttini FM, Baker J, Hart DJ, et al. Association of pain with radiological changes in different compartments and views of the knee joint. Osteoarthritis Cartilage. Jun. 1996;4(2):143-7. [pmid: 8806116].
442 Cicuttini FM, Baker J, Hart DJ, et al. Choosing the best method for radiological assessment of patellofemoral osteoarthritis. Ann Rheum Dis. Feb. 1996;55(2):134-6. [pmid: 8712864].
443 Cicuttini FM, Baker J, Hart DJ, et al. Relation between Heberden’s nodes and distal interphalangeal joint osteophytes and their role as markers of generalised disease. Ann Rheum Dis. Apr. 1998;57(4):246-8. [pmid: 9709182].
444 Cicuttini FM, Wang YY, Forbes A, et al. Comparison between patella cartilage volume and radiological assessment of the patellofemoral joint. Clinical & Experimental Rheumatology. May–Jun. 2003;21(3):321-6. [pmid: 12846050].
445 Cisar P, Jany R, Waczulikova I, et al. Effect of pine bark extract (Pycnogenol) on symptoms of knee osteoarthritis. Phytotherapy Research. Aug. 2008;22(8):1087-92. [pmid: 18570266].
446 Clarius M, Hauck C, Seeger JB, et al. Pulsed lavage reduces the incidence of radiolucent lines under the tibial tray of Oxford unicompartmental knee arthroplasty: pulsed lavage versus syringe lavage. International Orthopaedics. Dec. 2009;33(6):1585-90. [pmid: 19219432].
447 Clark BM. Rheumatology: 9. Physical and occupational therapy in the management of arthritis. CMAJ Canadian Medical Association Journal. Oct. 17. 2000;163(8):999-1005. [pmid: 11068573].
448 Clark M, Campbell DG, Kiss G, et al. Reintervention after mobile-bearing Oxford unicompartmental knee arthroplasty. Clinical Orthopaedics & Related Research. 2010;468(2):576-80. [pmid: 19768516].
449 Clarke GR, Willis LA, Fish WW, et al. A radiological assessment of osteoarthrosis of the knee: experiments in observer error. Rheumatol Rehabil. May. 1975;14(2):81-6. [pmid: 1145013].
450 Clarke HD, Hentz JG. Restoration of femoral anatomy in TKA with unisex and gender-specific components. Clinical Orthopaedics & Related Research. 2008;466(11):2711-6. [pmid: 18719972].
451 Clarke S, Lock V, Duddy J, et al. Intra-articular hylan G-F 20 (Synvisc) in the management of patellofemoral osteoarthritis of the knee (POAK). Knee. Jan. 2005;12(1):57-62. [pmid: 15664879].
452 Cleary M, Keating C, Poynton AR. Viscosupplementation in lumbar facet joint arthropathy: a pilot study. Journal of Spinal Disorders & Techniques. 2008;21(1):29-32. [pmid: 18418133].
453 Clegg DO, Reda DJ, Harris CL, et al. Glucosamine, chondroitin sulfate, and the two in combination for painful knee osteoarthritis. New England Journal of Medicine. Feb. 23. 2006;354(8):795-808. [pmid: 16495392].
454 Clemens D, Lereim P, Holm I, et al. Conversion of knee fusion to total arthroplasty: complications in 8 patients. Acta Orthopaedica. Jun. 2005;76(3):370-4. [pmid: 16156465].
455 Clements WJ, Miller L, Whitehouse SL, et al. Early outcomes of patella resurfacing in total knee arthroplasty. Acta Orthopaedica. Feb. 2010;81(1):108-13. [pmid: 19968604].
456 Clifford A, O’Connell M, Gabriel S, et al. The KineSpring load absorber implant: rationale, design and biomechanical characterization. J Med Eng Technol. Jan. 2011;35(1):65-71. [pmid: 21142591].
457 Cloutier JM, Sabouret P, Deghrar A. Total knee arthroplasty with retention of both cruciate ligaments. A nine to eleven-year follow-up study. Journal of Bone & Joint Surgery - American Volume. May. 1999;81(5):697-702. [pmid: 10360698].
458 Coan P, Bamberg F, Diemoz PC, et al. Characterization of osteoarthritic and normal human patella cartilage by computed tomography X-ray phase-contrast imaging: a feasibility study. Invest Radiol. Jul. 2010;45(7):437-44. [pmid: 20479648].
459 Cohen ZA, Henry JH, McCarthy DM, et al. Computer simulations of patellofemoral joint surgery. Patient-specific models for tuberosity transfer. American Journal of Sports Medicine. Jan–Feb. 2003;31(1):87-98. [pmid: 12531764].
460 Effects of Self-Management, Education, and Specific Exercises, Delivered By Health Professionals, Using Behaviour Modification in Patients With Osteoarthritis of the Knee. 6th Annual European Congress of Rheumatology (EULAR 2005). Vienna (Austria). 8–11 Jun 2005.
461 Coleridge S. The Lubinus patellofemoral arthroplasty: a five- to ten-year prospective study. Journal of Bone & Joint Surgery - British Volume. Mar. 2002;84(2):306. author reply -7. [pmid: 11922379].
462 Colker CM, Swain M, Lynch L, et al. Effects of a milk-based bioactive micronutrient beverage on pain symptoms and activity of adults with osteoarthritis: a double-blind, placebo-controlled clinical evaluation. Nutrition. May. 2002;18(5):388-92. [pmid: 11985942].
463 Collier MB, Eickmann TH, Anbari KK, et al. Lateral tibiofemoral compartment narrowing after medial unicondylar arthroplasty. Clin Orthop Relat Res. Nov. 2007;464:43-52. [pmid: 17876288].
464 Collier MB, McAuley JP, Szuszczewicz ES, et al. Proprioceptive deficits are comparable before unicondylar and total knee arthroplasties, but greater in the more symptomatic knee of the patient. Clinical Orthopaedics & Related Research. Jun. 2004;(423):138-43. [pmid: 15232439].
465 Electrical Stimulation to Improve Proprioception in Knee Osteoarthritis. 56th Annual Meeting of the Orthopaedic Research Society, Ernest N. Morial Convention Center. New Orleans, Louisiana. 6–9 Mar 2010.
466 Conaghan P, D’Agostino MA, Ravaud P, et al. EULAR report on the use of ultrasonography in painful knee osteoarthritis. Part 2: exploring decision rules for clinical utility. Ann Rheum Dis. Dec. 2005;64(12):1710-4. [pmid: 15878902].
467 Confalonieri N, Manzotti A, Cerveri P, et al. Bi-unicompartmental versus total knee arthroplasty: a matched paired study with early clinical results. Archives of Orthopaedic & Trauma Surgery. Sep. 2009;129(9):1157-63. [pmid: 18696093].
468 Confalonieri N, Manzotti A, Pullen C. Navigated shorter incision or smaller implant in knee arthritis?. Clinical Orthopaedics & Related Research. 2007;463(Journal Article):63-7. [pmid: 17589366].
469 Conner-Spady BL, Arnett G, McGurran JJ, et al. Prioritization of patients on scheduled waiting lists: validation of a scoring system for hip and knee arthroplasty. Can J Surg. Feb. 2004;47(1):39-46. [pmid: 14997924].
470 Conrozier T, Favret H, Mathieu P, et al. Influence of the quality of tibial plateau alignment on the reproducibility of computer joint space measurement from Lyon schuss radiographic views of the knee in patients with knee osteoarthritis. Osteoarthritis and Cartilage. 2004;12(10):765-70. [pmid: 15450525].
471 Conrozier T, Jerosch J, Beks P, et al. Prospective, multi-centre, randomised evaluation of the safety and efficacy of five dosing regimens of viscosupplementation with hylan G-F 20 in patients with symptomatic tibio-femoral osteoarthritis: a pilot study. Archives of Orthopaedic & Trauma Surgery. Mar. 2009;129(3):417-23. [pmid: 18365224].
472 Conrozier T, Mathieu P, Schott A-M, et al. Factors predicting long-term efficacy of Hylan GF-20 viscosupplementation in knee osteoarthritis. Joint, Bone, Spine: Revue du Rhumatisme. Mar. 2003;70(2):128-33. [pmid: 12713857].
473 Cooke TDV, Harrison L, Khan B, et al. Analysis of limb alignment in the pathogenesis of osteoarthritis: a comparison of Saudi Arabian and Canadian cases. Rheumatology International. Aug. 2002;22(4):160-4. [pmid: 12172956].
474 Cordero-Ampuero J, Esteban J, Garcia-Rey E. Results after late polymicrobial, gram-negative, and methicillin-resistant infections in knee arthroplasty. Clinical Orthopaedics & Related Research. May. 2010;468(5):1229-36. [pmid: 20087702].
475 Enhanced flexor withdrawal in response to osteroarthritic knee pain. 2006. 2006 Annual Conference and Exposition of the American Physical Therapy Association (PT 2006). Orlando, Florida (USA). 21–24 Jun 2006.
476 Cowan SM, Crossley KM, Bennell KL. Altered hip and trunk muscle function in individuals with patellofemoral pain. Br J Sports Med. Aug. 2009;43(8):584-8. [pmid: 18838402].
477 Cowan SM, Schache AG, Brukner P, et al. Delayed onset of transversus abdominus in long-standing groin pain. Med Sci Sports Exerc. Dec. 2004;36(12):2040-5. [pmid: 15570137].
478 Creamer P, Sharif M, George E, et al. Intra-articular hyaluronic acid in osteoarthritis of the knee: an investigation into mechanisms of action. Osteoarthritis & Cartilage. Jun. 1994;2(2):133-40. [pmid: 11548229].
479 Creamer P, Singh BB, Hochberg MC, et al. Are psychosocial factors related to response to acupuncture among patients with knee osteoarthritis?. Alternative Therapies in Health and Medicine. 1999;5(4):72-6. [pmid: 10394677].
480 Creel AH, Losina E, Mandl LA, et al. An assessment of willingness to participate in a randomized trial of arthroscopic knee surgery in patients with osteoarthritis. Contemporary Clinical Trials. Apr. 2005;26(2):169-78. [pmid: 15837439].
481 MRI-detected Bone Marrow Edema-like Lesions are Strongly Associated with Subchondral Cysts in Patients with or at Risk for Knee Osteoarthritis: The MOST Study. 94th Scientific Assembly and Annual Meeting of the Radiological Society of North America (RSNA 2008). McCormick Place, Chicago, Illinois (USA). 30 Nov–5 Dec 2008.
482 Criscione LG, Elliott AL, Stabler T, et al. Variation of serum hyaluronan with activity in individuals with knee osteoarthritis. Osteoarthritis & Cartilage. Sep. 2005;13(9):837-40. [pmid: 16153551].
483 Cromie MJ, Siston RA, Giori NJ, et al. Posterior cruciate ligament removal contributes to abnormal knee motion during posterior stabilized total knee arthroplasty. Journal of Orthopaedic Research. Nov. 2008;26(11):1494-9. [pmid: 18464260].
484 Crosbie J, Naylor J, Harmer A, et al. Predictors of functional ambulation and patient perception following total knee replacement and short-term rehabilitation. Disabil Rehabil. 2010;32(13):1088-98. [pmid: 19860602].
485 Cross MJ, March LM, Lapsley HM, et al. Determinants of willingness to pay for hip and knee joint replacement surgery for osteoarthritis. Rheumatology. 2000;39(11):1242-8. [pmid: 11085804].
486 Crossley K, Bennell KL, Wrigley T, et al. Ground reaction forces, bone characteristics, and tibial stress fracture in male runners. Med Sci Sports Exerc. Aug. 1999;31(8):1088-93. [pmid: 10449008].
487 Crossley KM, Bennell KL, Cowan SM, et al. Analysis of outcome measures for persons with patellofemoral pain: which are reliable and valid?. Arch Phys Med Rehabil. May. 2004;85(5):815-22. [pmid: 15129407].
488 Crossley KM, Cowan SM, Bennell KL, et al. Knee flexion during stair ambulation is altered in individuals with patellofemoral pain. J Orthop Res. Mar. 2004;22(2):267-74. [pmid: 15013084].
489 Crossley KM, Marino GP, Macilquham MD, et al. Can patellar tape reduce the patellar malalignment and pain associated with patellofemoral osteoarthritis? Arthritis &. Rheumatism. 2009;61(12):1719-25. [pmid: 19950307].
490 Crotty M, Prendergast J, Battersby MW, et al. Self-management and peer support among people with arthritis on a hospital joint replacement waiting list: a randomised controlled trial. Osteoarthritis Cartilage. Nov. 2009;17(11):1428-33. [pmid: 19486959].
491 Cubukcu D, Ardic F, Karabulut N, et al. Hylan G-F 20 efficacy on articular cartilage quality in patients with knee osteoarthritis: clinical and MRI assessment. Clinical Rheumatology. Aug. 2005;24(4):336-41. [pmid: 15599642].
492 Cuckler JM. Alternative therapies for arthritis of the knee: a triumph of hope over reason?. Orthopedics. Sep. 2000;23(9):975-6. [pmid: 11003104].
493 Cullu E, Aydogdu S, Sur H. Does patellar ligament length change after dome-type high tibial osteotomy?. Bulletin of the Hospital for Joint Diseases. 2000;59(3):140-3. [pmid: 11126715].
494 Currier LL, Froehlich PJ, Carow SD, et al. Development of a clinical prediction rule to identify patients with knee pain and clinical evidence of knee osteoarthritis who demonstrate a favorable short-term response to hip mobilization. Physical Therapy. 2007;87(9):1106-19. [pmid: 17609333].
495 Curtis SP, Bockow B, Fisher C, et al. Etoricoxib in the treatment of osteoarthritis over 52-weeks: a double-blind, active-comparator controlled trial. [NCT00242489]. BMC Musculoskelet Disord. 2005;6:58. [pmid: 16321158].
496 Knee Osteoarthritis: A Randomized Controlled Trial Comparing Hydrotherapy and Continuous Short-Wave Diathermy. 69th Annual Meeting of the American College of Rheumatology and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
497 Cushnaghan J, Bennett J, Reading I, et al. Long-term outcome following total knee arthroplasty: a controlled longitudinal study. Annals of the Rheumatic Diseases. May. 2009;68(5):642-7. [pmid: 18664545].
498 Dahlberg L. Treatment after anterior cruciate ligament injury: comment on the article by Ageberg et al. Arthritis & Rheumatism. Jun. 15. 2009;61(6):853. author reply 4. [pmid: 19479695].
499 Dahlberg LE, Holme I, Hoye K, et al. A randomized, multicentre, double-blind, parallel-group study to assess the adverse event-related discontinuation rate with celecoxib and diclofenac in elderly patients with osteoarthritis. Scandinavian Journal of Rheumatology. Mar–Apr. 2009;38(2):133-43. [pmid: 19165648].
500 Dailiana ZH, Malizos KN, Varitimidis S, et al. Low-molecular-weight heparin for prevention of thrombosis: inverted role. Journal of Trauma-Injury Infection & Critical Care. 2007;63(5):E111-5.
501 Daluga D, Lombardi AV Jr, Mallory TH, et al. Knee manipulation following total knee arthroplasty. Analysis of prognostic variables. J Arthroplasty. Jun. 1991;6(2):119-28. [pmid: 1875202].
502 Dalury DF. Total knee replacement for patellofemoral disease. The Journal of Knee Surgery. Oct. 2005;18(4):274-7. [pmid: 16262008].
503 Dalury DF, Barrett WP, Mason JB, et al. Midterm survival of a contemporary modular total knee replacement: a multicentre study of 1970 knees. Journal of Bone & Joint Surgery - British Volume. Dec. 2008;90(12):1594-6. [pmid: 19043130].
504 Dalury DF, Fisher DA, Adams MJ, et al. Unicompartmental knee arthroplasty compares favorably to total knee arthroplasty in the same patient. Orthopedics. 2009;32(4). [pmid: 19388619].
505 Dalury DF, Jiranek WA. A comparison of the midvastus and paramedian approaches for total knee arthroplasty. Journal of Arthroplasty. Jan. 1999;14(1):33-7. [pmid: 9926950].
506 Dalury DF, Mason JB, Murphy JA, et al. Analysis of the outcome in male and female patients using a unisex total knee replacement system. Journal of Bone & Joint Surgery - British Volume. Mar. 2009;91(3):357-60. [pmid: 19258612].
507 Dalury DF, Mulliken BD, Adams MJ, et al. Early recovery after total knee arthroplasty performed with and without patellar eversion and tibial translation. A prospective randomized study. Journal of Bone & Joint Surgery - American Volume. Jun. 2009;91(6):1339-43. [pmid: 19487510].
508 Dam EB, Byrjalsen I, Karsdal MA, et al. Increased urinary excretion of C-telopeptides of type II collagen (CTX-II) predicts cartilage loss over 21 months by MRI. Osteoarthritis Cartilage. Mar. 2009;17(3):384-9. [pmid: 18768336].
509 Dam EB, Loog M, Christiansen C, et al. Identification of progressors in osteoarthritis by combining biochemical and MRI-based markers. Arthritis Research & Therapy. 2009;11(4):R115. [pmid: 19630944].
510 Darmanis S, Toms A, Durman R, et al. A technical innovation for improving identification of the trackers by the LED cameras in navigation-assisted total knee arthroplasty. Computer Aided Surgery. Jul. 2007;12(4):247-51. [pmid: 17786601].
511 Das A Jr, Hammad TA. Efficacy of a combination of FCHG49 glucosamine hydrochloride, TRH122 low molecular weight sodium chondroitin sulfate and manganese ascorbate in the management of knee osteoarthritis. Osteoarthritis & Cartilage. Sep. 2000;8(5):343-50. [pmid: 10966840].
512 Das SK, Ramakrishnan S, Mishra K, et al. A randomized controlled trial to evaluate the slow-acting symptom-modifying effects of colchicine in osteoarthritis of the knee: a preliminary report. Arthritis & Rheumatism. Jun. 15. 2002;47(3):280-4. [pmid: 12115158].
513 Dashti M, Wluka AE, Geso M, et al. Relationship between the area of cartilage shown on the magnetic resonance imaging middle-slice image of the medial and lateral tibial cartilages with cartilage volume and grade of osteoarthritis over time. Scand J Rheumatol. 2004;33(2):87-93. [pmid: 15163109].
514 Daubresse F, Vajeu C, Loquet J. Total knee arthroplasty with conventional or navigated technique: comparison of the learning curves in a community hospital. Acta Orthopaedica Belgica. Dec. 2005;71(6):710-3. [pmid: 16459862].
515 Dauty M, Smitt X, Menu P, et al. Which factors affect the duration of inpatient rehabilitation after total knee arthroplasty in the absence of complications?. Ann Phys Rehabil Med. Apr. 2009;52(3):234-45. [pmid: 19522038].
516 Davidson PA, Rivenburgh DW, Dawson PE, et al. Clinical, histologic, and radiographic outcomes of distal femoral resurfacing with hypothermically stored osteoarticular allografts. American Journal of Sports Medicine. Jul. 2007;35(7):1082-90. [pmid: 17351122].
517 Davidson PL, Sanderson DJ, Loomer RL. Kinematics of valgus bracing for medial gonarthrosis: technical report. Clin Biomech (Bristol, Avon). Sep. 1998;13(6):414-9. [pmid: 11415816].
518 Davies-Tuck ML, Wluka AE, Teichtahl AJ, et al. Association between meniscal tears and the peak external knee adduction moment and foot rotation during level walking in postmenopausal women without knee osteoarthritis: a cross-sectional study. Arthritis Research & Therapy. 2008;10(3):R58. [pmid: 18492234].
519 Davies-Tuck ML, Wluka AE, Wang Y, et al. The natural history of cartilage defects in people with knee osteoarthritis. Osteoarthritis & Cartilage. Mar. 2008;16(3):337-42. [pmid: 17698376].
520 Davis CR, Karl J, Granell R, et al. Can biochemical markers serve as surrogates for imaging in knee osteoarthritis?. Arthritis Rheum. Dec. 2007;56(12):4038-47. [pmid: 18050200].
521 Day R, Brooks P, Conaghan PG, et al. A double blind, randomized, multicenter, parallel group study of the effectiveness and tolerance of intraarticular hyaluronan in osteoarthritis of the knee. Journal of Rheumatology. Apr. 2004;31(4):775-82. [pmid: 15088306].
522 de Bois MH, Tak PP, Arndt JW, et al. Joint scintigraphy for quantification of synovitis with 99mTc-labelled human immunoglobulin G compared to histological examination. Clin Exp Rheumatol. Mar–Apr. 1995;13(2):155-9. [pmid: 7656461].
523 De Filippis LG, Gulli S, Caliri A, et al. Factors influencing pain, physical function and social functioning in patients with osteoarthritis in southern Italy. International Journal of Clinical Pharmacology Research. 2004;24(4):103-9. [pmid: 15754914].
524 de Groot IB, Bussmann HJ, Stam HJ, et al. Small increase of actual physical activity 6 months after total hip or knee arthroplasty. Clinical Orthopaedics & Related Research. Sep. 2008;466(9):2201-8. [pmid: 18506555].
525 de Groot IB, Favejee MM, Reijman M, et al. The Dutch version of the Knee Injury and Osteoarthritis Outcome Score: a validation study. Health Qual Life Outcomes. 2008;6:16. [pmid: 18302729].
526 De Rycke L, Vandooren B, Kruithof E, et al. Tumor necrosis factor alpha blockade treatment down-modulates the increased systemic and local expression of Toll-like receptor 2 and Toll-like receptor 4 in spondylarthropathy. Arthritis & Rheumatism. Jul. 2005;52(7):2146-58. [pmid: 15986373].
527 de Seny D, Fillet M, Meuwis MA, et al. Discovery of new rheumatoid arthritis biomarkers using the surface-enhanced laser desorption/ionization time-of-flight mass spectrometry ProteinChip approach. Arthritis Rheum. Dec. 2005;52(12):3801-12. [pmid: 16320331].
528 Deacon A, Bennell K, Kiss ZS, et al. Osteoarthritis of the knee in retired, elite Australian Rules footballers. Med J Aust. Feb. 17. 1997;166(4):187-90. [pmid: 9066547].
529 Deberg MA, Labasse AH, Collette J, et al. One-year increase of Coll 2–1 a new marker of type II collagen degradation, in urine is highly predictive of radiological OA progression. Osteoarthritis Cartilage. Dec. 2005;13(12):1059-65. [pmid: 16154771].
530 Debi R, Mor A, Segal O, et al. Differences in gait patterns, pain, function and quality of life between males and females with knee osteoarthritis: a clinical trial. BMC Musculoskelet Disord. 2009;10:127. [pmid: 19825163].
531 Decking R, Markmann Y, Fuchs J, et al. Leg axis after computer-navigated total knee arthroplasty: a prospective randomized trial comparing computer-navigated and manual implantation. Journal of Arthroplasty. Apr. 2005;20(3):282-8. [pmid: 15809943].
532 Deie M, Ochi M, Adachi N, et al. A new articulated distraction arthroplasty device for treatment of the osteoarthritic knee joint: a preliminary report. Arthroscopy. 2007;23(8):833-8. [pmid: 17681204].
533 Dejour D, Deschamps G, Garotta L, et al. Laxity in posterior cruciate sparing and posterior stabilized total knee prostheses. Clinical Orthopaedics & Related Research. 1999;(364):182-93. [pmid: 10416408].
534 Deluzio KJ, Astephen JL. Biomechanical features of gait waveform data associated with knee osteoarthritis: an application of principal component analysis. Gait and Posture. 2007;25(1):86-93. [pmid: 16567093].
535 Demir B, Gursu S, Oke R, et al. Proximal tibia stress fracture caused by severe arthrosis of the knee with varus deformity. American Journal of Orthopedics (Chatham, Nj). Sep. 2009;38(9):457-9. [pmid: 19911100].
536 Denis M, Moffet H, Caron F, et al. Effectiveness of continuous passive motion and conventional physical therapy after total knee arthroplasty: a randomized clinical trial. Physical Therapy. 2006;86(2):174-85. [pmid: 16445331].
537 Deniz S, Atalay NS, Sarsan A, et al. Comparison of the effectiveness of pulsed and continuous diclofenac phonophoresis in treatment of knee osteoarthritis. Journal of Physical Therapy Science. 2009;21(4):331-6.
538 Dennis DA, Komistek RD, Kim RH, et al. Gap balancing versus measured resection technique for total knee arthroplasty. Clinical Orthopaedics & Related Research. Jan. 2010;468(1):102-7. [pmid: 19789934].
539 Denoeud L, Mazieres B, Payen-Champenois C, et al. First line treatment of knee osteoarthritis in outpatients in France: adherence to the EULAR 2000 recommendations and factors influencing adherence. Annals of the Rheumatic Diseases. 2005;64(1):70-4. [pmid: 15608302].
540 Dervin GF, Conway AF, Thurston P. Combined anterior cruciate ligament reconstruction and unicompartmental knee arthroplasty: surgical technique. Orthopedics. May. 2007;30(5 Suppl):39-41. [pmid: 17549866].
541 Dervin GF, Stiell IG, Rody K, et al. Effect of arthroscopic debridement for osteoarthritis of the knee on health-related quality of life. Journal of Bone & Joint Surgery - American Volume. 2003;85-A(1):10-9. [pmid: 12533566].
542 Deshmukh RG, Hayes JH, Pinder IM. Does body weight influence outcome after total knee arthroplasty? A 1-year analysis. Journal of Arthroplasty. Apr. 2002;17(3):315-9. [pmid: 11938508].
543 Desmeules F, Dionne CE, Belzile E, et al. Waiting for total knee replacement surgery: factors associated with pain, stiffness, function and quality of life. BMC Musculoskelet Disord. 2009;10:52. [pmid: 19457252].
544 Detrembleur C, Nayer J, van den Hecke A. Celecoxib improves the efficiency of the locomotor mechanism in patients with knee osteoarthritis. A randomised, placebo, double-blind and cross-over trial. Osteoarthritis and Cartilage. 2005;13(3):206-10. [pmid: 15727886].
545 Dierick F, Aveniere T, Cossement M, et al. Outcome assessment in osteoarthritic patients undergoing total knee arthroplasty. Acta Orthopaedica Belgica. Feb. 2004;70(1):38-45. [pmid: 15055316].
546 Ding C, Cicuttini F, Scott F, et al. Association of prevalent and incident knee cartilage defects with loss of tibial and patellar cartilage: a longitudinal study. Arthritis Rheum. Dec. 2005;52(12):3918-27. [pmid: 16320339].
547 Ding M-h, Zhang H, Li Y. A randomized controlled study on warming needle moxibustion for treatment of knee osteoarthritis. Zhongguo Zhenjiu. Aug. 2009;29(8):603-7. [pmid: 19947259].
548 Diracoglu D, Alptekin K, Teksoz B, et al. Knee vs hip single-joint intra-articular hyaluronic acid injection in patients with both hip and knee osteoarthritis: a pilot study. Clinical Rheumatology. Sep. 2009;28(9):1021-4. [pmid: 19455363].
549 Diracoglu D, Vural M, Baskent A, et al. The effect of viscosupplementation on neuromuscular control of the knee in patients with osteoarthritis. Journal of Back and Musculoskeletal Rehabilitation. 2009;22(1):1-9. [pmid: 20023357].
550 Divine JG, Hewett TE. Valgus Bracing for Degenerative Knee Osteoarthritis: Relieving Pain, Improving Gait, and Increasing Activity. Physician and Sports Medicine. 2005;33(2):40-7.
551 Dixon P, Parish EN, Chan B, et al. Hydroxyapatite-coated, cementless total knee replacement in patients aged 75 years and over. Journal of Bone & Joint Surgery - British Volume. Mar. 2004;86(2):200-4. [pmid: 15046433].
552 D’Lima DD, Colwell CW Jr, Morris BA, et al. The effect of preoperative exercise on total knee replacement outcomes. Clin Orthop Relat Res. May. 1996;(326):174-82. [pmid: 8620638].
553 D’Lima DD, Steklov N, Patil S, et al. The Mark Coventry Award: in vivo knee forces during recreation and exercise after knee arthroplasty. Clinical Orthopaedics & Related Research. 2008;466(11):2605-11. [pmid: 18563502].
554 Doherty M, Belcher C, Regan M, et al. Association between synovial fluid levels of inorganic pyrophosphate and short term radiographic outcome of knee osteoarthritis. Ann Rheum Dis. Jul. 1996;55(7):432-6. [pmid: 8774160].
555 Doi T, Akai M, Fujino K, et al. Effect of nonsteroidal anti-inflammatory drug plasters for knee osteoarthritis in Japanese: a randomized controlled trial. Mod Rheumatol. Feb. 2010;20(1):24-33. [pmid: 19806426].
556 Impact of an Aquatic Physical Therapy Protocol in Elderly Womem with Osteoarthritis of the Knee. 19th IAGG World Congress of Gerontology and Geriatrics. Paris (France). 5–9 Jul 2009.
557 Donell ST, Glasgow MMS. Isolated patellofemoral osteoarthritis. Knee. Jun. 2007;14(3):169-76. [pmid: 17222557].
558 Dorsey WOP, Miller BS, Tadje JP, et al. The stability of three commercially available implants used in medial opening wedge high tibial osteotomy. The Journal of Knee Surgery. Apr. 2006;19(2):95-8. [pmid: 16642884].
559 Predictive Factors of Articular Replacement Due to Primary Knee Osteoarthritis: A Prospective Two Year Study of 530 Patients. 69th Annual Meeting of the American College of Rheumatology and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
560 Dougados M, Moore A, Yu S, et al. Evaluation of the patient acceptable symptom state in a pooled analysis of two multicentre, randomised, double-blind, placebo-controlled studies evaluating lumiracoxib and celecoxib in patients with osteoarthritis. Arthritis Research & Therapy. 2007;9(1):R11. [pmid: 17266764].
561 Dougados M, Ravaud P. Exercise therapy in patients with osteoarthritis of the hip or knee. Current Rheumatology Reports. Oct. 2001;3(5):353-4. [pmid: 11564364].
562 Dowsey MM, Liew D, Stoney JD, et al. The impact of pre-operative obesity on weight change and outcome in total knee replacement: a prospective study of 529 consecutive patients. Journal of Bone & Joint Surgery - British Volume. Apr. 2010;92(4):513-20. [pmid: 20357327].
563 Drake BG, Callahan CM, Dittus RS, et al. Global rating systems used in assessing knee arthroplasty outcomes. J Arthroplasty. Aug. 1994;9(4):409-17. [pmid: 7964773].
564 Du H, Masuko-Hongo K, Nakamura H, et al. The prevalence of autoantibodies against cartilage intermediate layer protein, YKL-39, osteopontin, and cyclic citrullinated peptide in patients with early-stage knee osteoarthritis: evidence of a variety of autoimmune processes. Rheumatol Int. Nov. 2005;26(1):35-41. [pmid: 15378262].
565 Dugan SA. Sports-related knee injuries in female athletes: what gives?. American Journal of Physical Medicine and Rehabilitation. 2005;84(2):122-30. [pmid: 15668560].
566 Dumurgier J, Elbaz A, Ducimetiere P, et al. Slow walking speed and cardiovascular death in well functioning older adults: prospective cohort study. BMJ. 2009;339:b4460. [pmid: 19903980].
567 Dunbar MJ, Robertsson O, Ryd L. What’s all that noise? The effect of co-morbidity on health outcome questionnaire results after knee arthroplasty. Acta Orthopaedica Scandinavica. Apr. 2004;75(2):119-26. [pmid: 15180225].
568 Prevalence of Radiographic Knee Osteoarthritis - It all Depends on Your Point of View. 69th Annual Meeting of the American College of Rheumatology and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
569 Duncan R, Peat G, Thomas E, et al. Symptoms and radiographic osteoarthritis: not as discordant as they are made out to be?. Ann Rheum Dis. Jan. 2007;66(1):86-91. [pmid: 16877532].
570 Duncan RC, Hay EM, Saklatvala J, et al. Prevalence of radiographic osteoarthritis--it all depends on your point of view. Rheumatology (Oxford). Jun. 2006;45(6):757-60. [pmid: 16418199].
571 Dunn TC, Lu Y, Jin H, et al. T2 relaxation time of cartilage at MR imaging: comparison with severity of knee osteoarthritis. Radiology. Aug. 2004;232(2):592-8. [pmid: 15215540].
572 Dupuis DE, Beynnon BD, Richard MJ, et al. Precision and accuracy of joint space width measurements of the medial compartment of the knee using standardized MTP semi-flexed radiographs. Osteoarthritis and Cartilage. 2003;11(10):716-24. [pmid: 13129690].
573 Duryea J, Zaim S, Genant HK. New radiographic-based surrogate outcome measures for osteoarthritis of the knee. Osteoarthritis & Cartilage. Feb. 2003;11(2):102-10. [pmid: 12554126].
574 Dutt Sharma V, Sharma A, Kushwah HK. An Indigenous Approach to Manage The Osteoarthritis of Knee Joint with Lakshadi Guggulu, Kalka-Patra Bandhan And Knee Traction. Ancient Science of Life. 2007;26(3–4):23-9. [pmid: 22557237].
575 Dutton AQ, Yeo S-J, Yang K-Y, et al. Computer-assisted minimally invasive total knee arthroplasty compared with standard total knee arthroplasty. A prospective, randomized study. Journal of Bone & Joint Surgery - American Volume. Jan. 2008;90(1):2-9. [pmid: 18171951].
576 Eberhardt C, Kurth AH, Hailer N, et al. Revision ACL reconstruction using autogenous patellar tendon graft. Knee Surgery, Sports Traumatology, Arthroscopy. 2000;8(5):290-5. [pmid: 11061298].
577 Eberhardt C, Wentz S, Leonhard T, et al. Effects of revisional ACL surgery in semi-professional athletes in “high-risk pivoting sports” with chronic anterior instability of the knee. Journal of Orthopaedic Science. 2000;5(3):205-9. [pmid: 10982658].
578 Ebinesan AD, Sarai BS, Walley G, et al. Total knee arthroplasty: good agreement of clinical severity scores between patients and consultants. BMC Musculoskeletal Disorders. 2006;7(Journal Article):61. [pmid: 16879741].
579 Eckstein F, Benichou O, Wirth W, et al. Magnetic resonance imaging-based cartilage loss in painful contralateral knees with and without radiographic joint space narrowing: Data from the Osteoarthritis Initiative. Arthritis Rheum. Sep. 15. 2009;61(9):1218-25. [pmid: 19714595].
580 Eder U, Hukkanen M, Leitner B, et al. The presence of secretoneurin in human synovium and synovial fluid. Neurosci Lett. Mar. 14. 1997;224(2):139-41. [pmid: 9086476].
581 Edworthy SM, Devins GM. Improving medication adherence through patient education distinguishing between appropriate and inappropriate utilization. Patient Education Study Group. J Rheumatol. Aug. 1999;26(8):1793-801. [pmid: 10451079].
582 Ehrich EW, Schnitzer TJ, McIlwain H, et al. Effect of specific COX-2 inhibition in osteoarthritis of the knee: a 6 week double blind, placebo controlled pilot study of rofecoxib. Rofecoxib Osteoarthritis Pilot Study Group. Journal of Rheumatology. Nov. 1999;26(11):2438-47. [pmid: 10555907].
583 El-Azab H, Halawa A, Anetzberger H, et al. The effect of closed- and open-wedge high tibial osteotomy on tibial slope: a retrospective radiological review of 120 cases. Journal of Bone & Joint Surgery - British Volume. Sep. 2008;90(9):1193-7. [pmid: 18757959].
584 Association of symptoms and signs of hand osteoarthritis with hip and knee osteoarthritis in African Americans and Caucasians. 2005. 69th Annual Meeting of the American College of Rheumatolgoy and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
585 Ellis TJ, Beshires E, Brindley GW, et al. Knee manipulation after total knee arthroplasty. J South Orthop Assoc. Summer. 1999;8(2):73-9. [pmid: 10472823].
586 Emerson RH Jr. Preoperative and postoperative limb alignment after Oxford unicompartmental knee arthroplasty. Orthopedics. May. 2007;30(5 Suppl):32-4. [pmid: 17549864].
587 Emerson RH Jr, Ayers C, Head WC, et al. Surgical closing in primary total knee arthroplasties: flexion versus extension. Clin Orthop Relat Res. Oct. 1996;(331):74-80. [pmid: 8895621].
588 Emerson RH Jr, Ayers C, Higgins LL. Surgical closing in total knee arthroplasty. A series followup. Clinical Orthopaedics & Related Research. 1999;(368):176-81. [pmid: 10613166].
589 Emerson RH Jr, Higgins LL. Unicompartmental knee arthroplasty with the oxford prosthesis in patients with medial compartment arthritis. Journal of Bone & Joint Surgery - American Volume. Jan. 2008;90(1):118-22. [pmid: 18171965].
590 Emerson RH Jr, Martinez J. Men versus women: does size matter in total knee arthroplasty? Clinical Orthopaedics &. Related Research. 2008;466(11):2706-10. [pmid: 18709428].
591 Engh GA. A bi-compartmental solution: what the Deuce?. Orthopedics. Sep. 2007;30(9):770-1. [pmid: 17899932].
592 Englund M, Lohmander LS. Patellofemoral osteoarthritis coexistent with tibiofemoral osteoarthritis in a meniscectomy population. Annals of the Rheumatic Diseases. 2005;64(12):1721-6. [pmid: 15843446].
593 Englund M, Roos EM, Lohmander LS. Impact of type of meniscal tear on radiographic and symptomatic knee osteoarthritis: a sixteen-year followup of meniscectomy with matched controls. Arthritis & Rheumatism. Aug. 2003;48(8):2178-87. [pmid: 12905471].
594 The Effect of Demographic Characteristics on Clinical Deterioration Over 6–9 Years in a Meniscectomy Population with or without Radiographic Knee Osteoarthritis. 69th Annual Meeting of the American College of Rheumatology and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
595 Clinical Progression Over 6–9 Years in a Meniscectomy Population with or without Radiographic Knee Osteoarthritis. 69th Annual Meeting of the American College of Rheumatology and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
596 Englund M, Roos EM, Roos HP, et al. Patient-relevant outcomes fourteen years after meniscectomy: influence of type of meniscal tear and size of resection. Rheumatology. 2001;40(6):631-9. [pmid: 11426019].
597 Epinette J-A, Manley MT. Is hydroxyapatite a reliable fixation option in unicompartmental knee arthroplasty? A 5- to 13-year experience with the hydroxyapatite-coated unix prosthesis. The Journal of Knee Surgery. Oct. 2008;21(4):299-306. [pmid: 18979933].
598 Ergun H, Kulcu D, Kutlay S, et al. Efficacy and safety of topical nimesulide in the treatment of knee osteoarthritis. JCR: Journal of Clinical Rheumatology. 2007;13(5):251-5. [pmid: 17921791].
599 Ericsson YB, Roos EM, Dahlberg L. Muscle strength, functional performance, and self-reported outcomes four years after arthroscopic partial meniscectomy in middle-aged patients. Arthritis Rheum. Dec. 15. 2006;55(6):946-52. [pmid: 17139641].
600 Ericsson YB, Tjornstrand J, Tiderius CJ, et al. Relationship between cartilage glycosaminoglycan content (assessed with dGEMRIC) and OA risk factors in meniscectomized patients. Osteoarthritis & Cartilage. May. 2009;17(5):565-70. [pmid: 19058980].
601 Eriksen J, Christensen J, Solgaard S, et al. The cementless AGC 2000 knee prosthesis: 20-year results in a consecutive series. Acta Orthopaedica Belgica. Apr. 2009;75(2):225-33. [pmid: 19492562].
602 Ersoz M, Ergun S. Relationship between knee range of motion and Kellgren-Lawrence radiographic scores in knee osteoarthritis. Am J Phys Med Rehabil. Feb. 2003;82(2):110-5. [pmid: 12544756].
603 Escobar A, Quintana JM, Bilbao A, et al. Validation of the Spanish version of the WOMAC questionnaire for patients with hip or knee osteoarthritis. Western Ontario and McMaster Universities Osteoarthritis Index. Clinical Rheumatology. Nov. 2002;21(6):466-71. [pmid: 12447629].
604 Escobar A, Quintana JM, Bilbao A, et al. Effect of patient characteristics on reported outcomes after total knee replacement. Rheumatology. 2007;46(1):112-9. [pmid: 16735451].
605 Esenkaya I, Elmali N. Proximal tibia medial open-wedge osteotomy using plates with wedges: early results in 58 cases. Knee Surgery, Sports Traumatology, Arthroscopy. Oct. 2006;14(10):955-61. [pmid: 16568341].
606 EstevedeMiguel C. The arthroscopic treatment of knee osteoarthritis. Current Orthopaedics. 2003;17(1):63-9.
607 Ethgen M, Boutron I, Baron G, et al. Reporting of harm in randomized, controlled trials of nonpharmacologic treatment for rheumatic disease. Annals of Internal Medicine. Jul. 5. 2005;143(1):20-5. [pmid: 15998751].
608 Ethgen O, Tancredi A, Lejeune E, et al. Do utility values and willingness to pay suitably reflect health outcome in hip and knee osteoarthritis? A comparative analysis with the WOMAC Index. J Rheumatol. Nov. 2003;30(11):2452-9. [pmid: 14677192].
609 Ethgen O, Vanparijs P, Delhalle S, et al. Social support and health-related quality of life in hip and knee osteoarthritis. Quality of Life Research. 2004;13(2):321-30. [pmid: 15085904].
610 Evanich JD, Evanich CJ, Wright MB, et al. Efficacy of intraarticular hyaluronic acid injections in knee osteoarthritis. Clin Orthop Relat Res. Sep. 2001;(390):173-81. [pmid: 11550864].
611 Evcik D, Maralcan G, Kuru I. The efficacy of intra-articular tenoxicam in the treatment of knee osteoarthritis. Pain Clinic. 2003;15(4):405-8.
612 Everts PAM, Devilee RJJ, Oosterbos CJM, et al. Autologous platelet gel and fibrin sealant enhance the efficacy of total knee arthroplasty: improved range of motion, decreased length of stay and a reduced incidence of arthrofibrosis. Knee Surgery, Sports Traumatology, Arthroscopy. Jul. 2007;15(7):888-94. [pmid: 17323096].
613 Evgeniadis G, Beneka A, Malliou P, et al. Effects of pre- or postoperative therapeutic exercise on the quality of life, before and after total knee arthroplasty for osteoarthritis. Journal of Back and Musculoskeletal Rehabilitation. 2008;21(3):161-9.
614 Fabricant PD, Rosenberger PH, Jokl P, et al. Predictors of short-term recovery differ from those of long-term outcome after arthroscopic partial meniscectomy. Arthroscopy. Jul. 2008;24(7):769-78. [pmid: 18589265].
615 Fairweather J, Jawad ASM. Arthroscopic surgery and osteoarthritis of knee. Saudi Medical Journal. Sep. 2008;29(9):1361. author reply. [pmid: 18813434].
616 Falahee MH, Matthews LS, Kaufer H. Resection arthroplasty as a salvage procedure for a knee with infection after a total arthroplasty. J Bone Joint Surg Am. Sep. 1987;69(7):1013-21. [pmid: 3654692].
617 Falconer J, Hayes KW. A simple method to measure gait for use in arthritis clinical research. Arthritis Care Res. Mar. 1991;4(1):52-7. [pmid: 11188588].
618 Fan C-Y, Hsieh JT-S, Hsieh M-S, et al. Primitive results after medial-pivot knee arthroplasties: a minimum 5-year follow-up study. Journal of Arthroplasty. Apr. 2010;25(3):492-6. [pmid: 19577880].
619 Fantini Pagani CH, Potthast W, Bruggemann GP. The effect of valgus bracing on the knee adduction moment during gait and running in male subjects with varus alignment. Clin Biomech (Bristol, Avon). Jan. 2010;25(1):70-6. [pmid: 19758735].
620 Faraj AA, Boda P. Is a femoral component applicator useful in total knee replacement?. Knee Surgery, Sports Traumatology, Arthroscopy. Feb. 2009;17(2):125-7. [pmid: 18779948].
621 Faraj AA, Nevelos AB, Nair A. A 4- to 10-year follow-up study of the Tricon-M noncemented total knee replacement. Orthopedics. Dec. 2001;24(12):1151-4. [pmid: 11770092].
622 Fargas-Babjak AM, Pomeranz B, Rooney PJ. Acupuncture-like stimulation with codetron for rehabilitation of patients with chronic pain syndrome and osteoarthritis. Acupunct Electrother Res. 1992;17(2):95-105. [pmid: 1353654].
623 Farquhar S, Snyder-Mackler L. The Chitranjan Ranawat Award: The nonoperated knee predicts function 3 years after unilateral total knee arthroplasty. Clin Orthop Relat Res. Jan. 2010;468(1):37-44. [pmid: 19472024].
624 Farquhar SJ, Kaufman KR, Snyder-Mackler L. Sit-to-stand 3 months after unilateral total knee arthroplasty: comparison of self-selected and constrained conditions. Gait Posture. Aug. 2009;30(2):187-91. [pmid: 19473843].
625 Effects of an Education and Exercise Intervention on Physical Activity in Early Knee Osteoarthritis Patients. 55th Annual Meeting on American College of Sports Medicine. Indianapolis, Indiana (USA). 28–31 May 2008.
626 Fawzy E, Pandit H, Jenkins C, et al. Determination of femoral component size in unicompartmental knee replacement. Knee. Oct. 2008;15(5):403-6. [pmid: 18675547].
627 Fayfman M, Niu J, Zhang YQ, et al. The relation of plasma homocysteine to radiographic knee osteoarthritis. Osteoarthritis Cartilage. Jun. 2009;17(6):766-71. [pmid: 19073367].
628 Fehring TK, Odum SM, Masonis JL, et al. Early failures in unicondylar arthroplasty. Orthopedics. Jan. 1. 2010;33(1):11. [pmid: 20055339].
629 Felson DT. The epidemiology of knee osteoarthritis: results from the Framingham Osteoarthritis Study. Semin Arthritis Rheum. Dec. 1990;20(3 Suppl 1):42-50. [pmid: 2287948].
630 Felson DT. Glucosamine and chondroitin sulfate in knee osteoarthritis: where now?. Nature Clinical Practice Rheumatology. Jul. 2006;2(7):356-7. [pmid: 16932718].
631 Felson DT, Cooke TD, Niu J, et al. Can anatomic alignment measured from a knee radiograph substitute for mechanical alignment from full limb films?. Osteoarthritis Cartilage. Nov. 2009;17(11):1448-52. [pmid: 19505430].
632 Felson DT, McAlindon TE, Anderson JJ, et al. Defining radiographic osteoarthritis for the whole knee. Osteoarthritis Cartilage. Jul. 1997;5(4):241-50. [pmid: 9404469].
633 Felson DT, Niu J, Clancy M, et al. Effect of Recreational Physical Activities on the Development of Knee Osteoarthritis in Older Adults of Different Weights: The Framingham Study. Arthritis Care and Research. 2007;57(1):6-12. [pmid: 17266077].
634 Fernandez-Fairen M, Querales V, Jakowlew A, et al. Tantalum is a good bone graft substitute in tibial tubercle advancement. Clinical Orthopaedics & Related Research. May. 2010;468(5):1284-95. [pmid: 19806411].
635 Ferrara PE, Rabini A, Maggi L, et al. Effect of pre-operative physiotherapy in patients with end-stage osteoarthritis undergoing hip arthroplasty. [Erratum appears in Clin Rehabil. 2008 Dec;22(12):1137 Note: Lombi, G Magliocchetti [corrected to Magliocchetti, G]]. Clinical Rehabilitation. Oct–Nov. 2008;22(10–11):977-86. [pmid: 18955429].
636 Fife RS, Brandt KD, Braunstein EM, et al. Relationship between arthroscopic evidence of cartilage damage and radiographic evidence of joint space narrowing in early osteoarthritis of the knee. Arthritis Rheum. Apr. 1991;34(4):377-82. [pmid: 2012624].
637 Figaro MK, Russo PW, Allegrante JP. Preferences for arthritis care among urban African Americans: “I don’t want to be cut”. Health Psychol. May. 2004;23(3):324-9. [pmid: 15099175].
638 Osteoarthritic Lesion Progression in the Knee of the Aging Guinea Pig and Chondroprotective Effect of Pulsed Electromagnetic Field Stimulation. 6th Symposium of the International Cartilage Repair Society (ICRS 2006). San Diego Marriott Hotel & Marina, San Diego, California (USA). 8–11 Jan 2006.
639 Fisher NM, Pendergast DR. Reduced muscle function in patients with osteoarthritis. Scand J Rehabil Med. 1997;29(4):213-21. [pmid: 9428055].
640 Fisher NM, White SC, Yack HJ, et al. Muscle function and gait in patients with knee osteoarthritis before and after muscle rehabilitation. Disability and rehabilitation. 1997;19(2):47-55. [pmid: 9058029].
641 Fitzgerald GK, Lephart SM, Hwang JH, et al. Hop tests as predictors of dynamic knee stability. Journal of Orthopaedic & Sports Physical Therapy. Oct. 2001;31(10):588-97. [pmid: 11665746].
642 Flamme CH, Ruhmann O, Schmolke S, et al. Long-term outcome following high tibial osteotomy with tension bend principle. Archives of Orthopaedic & Trauma Surgery. Feb. 2003;123(1):12-6. [pmid: 12582790].
643 Fleischmann R, Sheldon E, Maldonado-Cocco J, et al. Lumiracoxib is effective in the treatment of osteoarthritis of the knee: a prospective randomized 13-week study versus placebo and celecoxib. Clinical Rheumatology. Feb. 2006;25(1):42-53. [pmid: 16132165].
644 Fleischmann R, Tannenbaum H, Patel NP, et al. Long-term retention on treatment with lumiracoxib 100 mg once or twice daily compared with celecoxib 200 mg once daily: a randomised controlled trial in patients with osteoarthritis. BMC Musculoskelet Disord. 2008;9:32. [pmid: 18328090].
645 Floren M, Reichel H, Davis J, et al. The mini-incision mid-vastus approach for total knee arthroplasty. Oper Orthop Traumatol. Dec. 2008;20(6):534-43. [pmid: 19137400].
646 Focht BC, Gauvin L, Rejeski WJ. The contribution of daily experiences and acute exercise to fluctuations in daily feeling states among older, obese adults with knee osteoarthritis. Journal of Behavioral Medicine. Apr. 2004;27(2):101-21. [pmid: 15171102].
647 Folkesson J, Dam E, Olsen OF, et al. Automatic segmentation of the articular cartilage in knee MRI using a hierarchical multi-class classification scheme. Med Image Comput Comput Assist Interv. 2005;8(Pt 1):327-34. [pmid: 16685862].
648 Fond J, Rodin D, Ahmad S, et al. Arthroscopic debridement for the treatment of osteoarthritis of the knee: 2- and 5-year results. Arthroscopy. Oct. 2002;18(8):829-34. [pmid: 12368778].
649 Foote JA, Smith HK, Jonas SC, et al. Return to work following knee arthroplasty. Knee. Jan. 2010;17(1):19-22. [pmid: 19632120].
650 Foran JRH, Mont MA, Etienne G, et al. The outcome of total knee arthroplasty in obese patients. Journal of Bone & Joint Surgery - American Volume. Aug. 2004;86-A(8):1609-15. [pmid: 15292406].
651 Foroughi N, Smith RM, Lange AK, et al. Lower limb muscle strengthening does not change frontal plane moments in women with knee osteoarthritis: A randomized controlled trial. Clin Biomech (Bristol, Avon). Feb. 2011;26(2):167-74. [pmid: 20888096].
652 Forrest KY, Zmuda JM, Cauley JA. Correlates of decline in lower extremity performance in older women: A 10-year follow-up study. J Gerontol A Biol Sci Med Sci. Nov. 2006;61(11):1194-200. [pmid: 17167162].
653 Forster M. Long-term results of retention of the posterior cruciate ligament in total knee replacement. Journal of Bone & Joint Surgery - British Volume. Jan. 2002;84(1):147. [pmid: 11837821].
654 Forster MC, Bauze AJ, Bailie AG, et al. A retrospective comparative study of bilateral total knee replacement staged at a one-week interval. Journal of Bone & Joint Surgery - British Volume. Aug. 2006;88(8):1006-10. [pmid: 16877597].
655 Forster MC, Bauze AJ, Keene GCR. Lateral unicompartmental knee replacement: fixed or mobile bearing?. Knee Surgery, Sports Traumatology, Arthroscopy. Sep. 2007;15(9):1107-11. [pmid: 17551711].
656 Forster MC, Straw R. A prospective randomised trial comparing intra-articular Hyalgan injection and arthroscopic washout for knee osteoarthritis. Knee. 2003;10(3):291-3. [pmid: 12893153].
657 Forsythe ME, Dunbar MJ, Hennigar AW, et al. Prospective relation between catastrophizing and residual pain following knee arthroplasty: two-year follow-up. Pain Res Manag. Jul–Aug. 2008;13(4):335-41. [pmid: 18719716].
658 Forsythe ME, Englund RE, Leighton RK. Unicondylar knee arthroplasty: a cementless perspective. Canadian Journal of Surgery. Dec. 2000;43(6):417-24. [pmid: 11129829].
659 Foster NA, Segal NA, Clearfield JS, et al. Central versus lower body obesity distribution and the association with lower limb physical function and disability. Pm & R. Dec. 2010;2(12):1119-26. [pmid: 21145524].
660 Foster NE, Thomas E, Barlas P, et al. Acupuncture as an adjunct to exercise based physiotherapy for osteoarthritis of the knee: randomised controlled trial. BMJ. Sep. 1. 2007;335(7617):436. [pmid: 17699546].
661 Effects of Shock Absorbing Insoles on Knee Pain and Functional Mobility in Persons with Symptomatic Knee Osteoarthritis. 2008 Combined Sections Meeting of the American Physical Therapy Association (CSM 2008). Nashville, Tennessee (USA). 6–10 Feb 2008.
662 Fraenkel L, Bogardus ST Jr, Concato J, et al. Treatment options in knee osteoarthritis: the patient’s perspective. Archives of Internal Medicine. Jun. 28. 2004;164(12):1299-304. [pmid: 15226163].
663 Patients with Knee Osteoarthritis (OA) Prefer Exercise over NSAIDs. 70th Annual Meeting of the American College of Rheumatology and the 41st Annual Meeting of the Association of Rheumatology Health Professionals (ACR/ARHP 2006). Washington Convention Center, Washington DC (USA). 10–15 Nov 2006.
664 Fraenkel L, Wittink DR, Concato J, et al. Informed choice and the Widespread Use of Antiinflammatory Drugs. Arthritis Care and Research. 2004;51(2):210-4. [pmid: 15077261].
665 Fraenkel L, Wittink DR, Concato J, et al. Are preferences for cyclooxygenase-2 inhibitors influenced by the certainty effect?. J Rheumatol. Mar. 2004;31(3):591-3. [pmid: 14994409].
666 Franklin PD, Li W, Ayers DC. The Chitranjan Ranawat Award: functional outcome after total knee replacement varies with patient attributes. Clinical Orthopaedics & Related Research. 2008;466(11):2597-604. [pmid: 18810570].
667 Fransen M, Crosbie J, Edmonds J. Reliability of gait measurements in people with osteoarthritis of the knee. Phys Ther. Sep. 1997;77(9):944-53. [pmid: 9291951].
668 Freedman J. An audit of 500 acupuncture patients in general practice. Acupuncture in Medicine. 2002;20(1):30-4. [pmid: 11926603].
669 Freedman J, Richardson M. Setting up an acupuncture knee clinic under Practice Based Commissioning. Acupuncture in Medicine. Sep. 2008;26(3):183-7. [pmid: 18818564].
670 Fregly BJ. Computational assessment of combinations of gait modifications for knee osteoarthritis rehabilitation. IEEE Transactions on Biomedical Engineering. Aug. 2008;55(8):2104-6. [pmid: 18632374].
671 Fregly BJ, D’Lima DD, Colwell CW Jr. Effective gait patterns for offloading the medial compartment of the knee. Journal of Orthopaedic Research. 2009;27(8):1016-21. [pmid: 19148939].
672 Fregly BJ, Reinbolt JA, Rooney KL, et al. Design of patient-specific gait modifications for knee osteoarthritis rehabilitation. IEEE Transactions on Biomedical Engineering. Sep. 2007;54(9):1687-95. [pmid: 17867361].
673 Frestedt JL, Kuskowski MA, Zenk JL. A natural seaweed derived mineral supplement (Aquamin F) for knee osteoarthritis: a randomised, placebo controlled pilot study. Nutrition Journal. 2009;8:7. [pmid: 19187557].
674 Frestedt JL, Walsh M, Kuskowski MA, et al. A natural mineral supplement provides relief from knee osteoarthritis symptoms: a randomized controlled pilot trial. Nutrition Journal. 2008;7:9. [pmid: 18279523].
675 Frias G, Caracuel MA, Escudero A, et al. Assessment of the efficacy of joint lavage versus joint lavage plus corticoids in patients with osteoarthritis of the knee. Current Medical Research & Opinion. 2004;20(6):861-7. [pmid: 15200744].
676 Friedrich KM, Shepard T, Chang G, et al. Does joint alignment affect the T2 values of cartilage in patients with knee osteoarthritis?. Eur Radiol. Jun. 2010;20(6):1532-8. [pmid: 20013272].
677 Fritz J, Janssen P, Gaissmaier C, et al. Articular cartilage defects in the knee--basics, therapies and results. Injury. Apr. Suppl 1. 2008;39:S50-7. [pmid: 18313472].
678 Frosch P, Decking J, Theis C, et al. Complications after total knee arthroplasty: a comprehensive report. Acta Orthopaedica Belgica. Dec. 2004;70(6):565-9. [pmid: 15669457].
679 Fu P, Wu Y, Wu H, et al. Efficacy of intra-articular cocktail analgesic injection in total knee arthroplasty - a randomized controlled trial. Knee. Aug. 2009;16(4):280-4. [pmid: 19299145].
680 Fuchs S, Rolauffs B, Plaumann T, et al. Clinical and functional results after the rehabilitation period in minimally-invasive unicondylar knee arthroplasty patients. Knee Surgery, Sports Traumatology, Arthroscopy. 2005;13(3):179-86. [pmid: 15175850].
681 Fuchs S, Skwara A, Rosenbaum D. Preliminary results after total knee arthroplasty without femoral trochlea: evaluation of clinical results, quality of life and gait function. Knee Surgery, Sports Traumatology, Arthroscopy. Nov. 2005;13(8):664-9. [pmid: 15918065].
682 Fuchs S, Strosche H, Tinius W, et al. Preliminary remarks on a prospective multicenter study of the Repicci minimally invasive unicondylar knee replacement. Knee Surgery, Sports Traumatology, Arthroscopy. Nov. 2005;13(8):670-6. [pmid: 15877217].
683 Fuchs S, Tibesku CO, Frisse D, et al. Clinical and functional comparison of uni- and bicondylar sledge prostheses. Knee Surgery, Sports Traumatology, Arthroscopy. Apr. 2005;13(3):197-202. [pmid: 15619131].
684 Fuchs S, Tibesku CO, Frisse D, et al. Quality of life and gait after unicondylar knee prosthesis are inferior to age-matched control subjects. American Journal of Physical Medicine & Rehabilitation. Jun. 2003;82(6):441-6. [pmid: 12820786].
685 Fuchs S, Tibesku CO, Genkinger M, et al. Proprioception with bicondylar sledge prostheses retaining cruciate ligaments. Clinical Orthopaedics & Related Research. Jan. 2003;(406):148-54. [pmid: 12579014].
686 Fujita T, Ohue M, Fujii Y, et al. Analgesic and chondroprotective effects of risedronate in osteoarthritis assessed by electroalgometry and measurement of collagen type II fragments in urine. Journal of International Medical Research. Sep–Oct. 2008;36(5):932-41. [pmid: 18831886].
687 Polymerized-type I Collagen: A Disease Modifier Drug for the Treatment of Patients with Knee Osteoarthritis. 13th International Congress of Immunology (ICI 2007). Rio de Janeiro (Brazil). 21–25 Aug 2007.
688 Furuzawa-Carballeda J, Munoz-Chable OA, Macias-Hernandez SI, et al. Effect of polymerized-type I collagen in knee osteoarthritis. II. In vivo study. European Journal of Clinical Investigation. Jul. 2009;39(7):598-606. [pmid: 19397687].
689 Gaasbeek RDA, Sonneveld H, van Heerwaarden RJ, et al. Distal tuberosity osteotomy in open wedge high tibial osteotomy can prevent patella infera: a new technique. Knee. Dec. 2004;11(6):457-61. [pmid: 15581764].
690 Gajre SS, Anand S, Singh U, et al. Novel method of using dynamic electrical impedance signals for noninvasive diagnosis of knee osteoarthritis. Conf Proc IEEE Eng Med Biol Soc. 2006;1:2207-10. [pmid: 17946097].
691 Gajre SS, Singh U, Saxena RK, et al. Electrical impedance signal analysis in assessing the possibility of non-invasive diagnosis of knee osteoarthritis. J Med Eng Technol. Jul–Aug. 2007;31(4):288-99. [pmid: 17566932].
692 Galea A, Giuffre B, Dimmick S, et al. The accuracy of magnetic resonance imaging scanning and its influence on management decisions in knee surgery. Arthroscopy. May. 2009;25(5):473-80. [pmid: 19409304].
693 Galli M, Santis V, Tafuro L. Reliability of the Ahlback classification of knee osteoarthritis. Osteoarthritis and Cartilage. 2003;11(8):580-4. [pmid: 12880580].
694 Gamo R, Aguilar A, Cuetara M, et al. Sporotrichosis following mesotherapy for arthrosis. Acta Dermato-Venereologica. 2007;87(5):430-1. [pmid: 17721653].
695 Gandhi R, de Beer J, Leone J, et al. Predictive risk factors for stiff knees in total knee arthroplasty. Journal of Arthroplasty. Jan. 2006;21(1):46-52. [pmid: 16446184].
696 Gandhi R, Dhotar H, Razak F, et al. Predicting the longer term outcomes of total knee arthroplasty. Knee. Jan. 2010;17(1):15-8. [pmid: 19589683].
697 Gandhi R, Razak F, Davey JR, et al. Ethnicity and patient’s perception of risk in joint replacement surgery. J Rheumatol. Aug. 2008;35(8):1664-7. [pmid: 18597402].
698 Gandhi R, Razak F, Davey JR, et al. Effect of sex and living arrangement on the timing and outcome of joint replacement surgery. Canadian Journal of Surgery. 2010;53(1):37-41. [pmid: 20100411].
699 Gandhi R, Razak F, Pathy R, et al. Antibiotic bone cement and the incidence of deep infection after total knee arthroplasty. Journal of Arthroplasty. Oct. 2009;24(7):1015-8. [pmid: 18823748].
700 Gandhi R, Razak F, Tso P, et al. Greater perceived helplessness in osteoarthritis predicts outcome of joint replacement surgery. J Rheumatol. Jul. 2009;36(7):1507-11. [pmid: 19487268].
701 Gandhi R, Tsvetkov D, Davey JR, et al. Relationship between self-reported and performance-based tests in a hip and knee joint replacement population. Clin Rheumatol. Mar. 2009;28(3):253-7. [pmid: 18853222].
702 Gandy SJ, Dieppe PA, Keen MC, et al. No loss of cartilage volume over three years in patients with knee osteoarthritis as assessed by magnetic resonance imaging. Osteoarthritis and Cartilage. 2002;10(12):929-37. [pmid: 12464553].
703 Gapeyeva H, Buht N, Peterson K, et al. Quadriceps femoris muscle voluntary isometric force production and relaxation characteristics before and 6 months after unilateral total knee arthroplasty in women. Knee Surgery, Sports Traumatology, Arthroscopy. Feb. 2007;15(2):202-11. [pmid: 17006663].
704 Garcia JA, Bewley B, Redden JF. The St. Leger total knee replacement--a 7-year clinical assessment and survivorship analysis. Knee. Jun. 2003;10(2):173-7. [pmid: 12788002].
705 Garcia RM, Kraay MJ, Goldberg VM. Isolated all-polyethylene patellar revisions for metal-backed patellar failure. Clinical Orthopaedics & Related Research. 2008;466(11):2784-9. [pmid: 18688690].
706 Garcia RM, Kraay MJ, Goldberg VM. Retention of superficially damaged femoral components after metal-backed patella component failure. Journal of Arthroplasty. Sep. 2008;23(6):850-8. [pmid: 18534531].
707 Garnero P, Aronstein WS, Cohen SB, et al. Relationships between biochemical markers of bone and cartilage degradation with radiological progression in patients with knee osteoarthritis receiving risedronate: the Knee Osteoarthritis Structural Arthritis randomized clinical trial. Osteoarthritis & Cartilage. Jun. 2008;16(6):660-6. [pmid: 17993283].
708 Garnero P, Ayral X, Rousseau JC, et al. Uncoupling of type II collagen synthesis and degradation predicts progression of joint damage in patients with knee osteoarthritis. Arthritis Rheum. Oct. 2002;46(10):2613-24. [pmid: 12384919].
709 Garneti N, Mahadeva D, Khalil A, et al. Patellar resurfacing versus no resurfacing in Scorpio total knee arthroplasty. The Journal of Knee Surgery. Apr. 2008;21(2):97-100. [pmid: 18500059].
710 Garo-Falides B. Acupuncture for osteoarthritis of the knee. Acupuncture in Medicine. Jun. 2004;22(2):100. author reply -1. [pmid: 15253588].
711 Garvin KL, Scuderi G, Insall JN. Evolution of the quadriceps snip. Clin Orthop Relat Res. Dec. 1995;(321):131-7. [pmid: 7497658].
712 Gatha NM, Clarke HD, Fuchs R, et al. Factors affecting postoperative range of motion after total knee arthroplasty. The Journal of Knee Surgery. Oct. 2004;17(4):196-202. [pmid: 15553586].
713 Gaudet MC, Ehrmann Feldman D, Rossignol M, et al. The wait for total hip replacement in patients with osteoarthritis. Can J Surg. Apr. 2007;50(2):101-9. [pmid: 17550712].
714 Gavenis K, Andereya S, Schmidt-Rohlfing B, et al. Millicurrent stimulation of human articular chondrocytes cultivated in a collagen type-I gel and of human osteochondral explants. BMC Complement Altern Med. 2010;10:43. [pmid: 20691044].
715 Gazi MB, Sakata RK, Issy AM. Intra-articular morphine versus bupivacaine for knee motion among patients with osteoarthritis: randomized double-blind clinical trial. Sao Paulo Med J. Nov. 2008;126(6):309-13. [pmid: 19274316].
716 Geier KA. The UniSpacer for knee osteoarthritis. Orthopaedic Nursing. Sep–Oct. 2003;22(5):369-70. [pmid: 14595998].
717 Gejo R, Akizuki S, Takizawa T. Fixation of the NexGen HA-TCP-coated cementless, screwless total knee arthroplasty: comparison with conventional cementless total knee arthroplasty of the same type. Journal of Arthroplasty. Jun. 2002;17(4):449-56. [pmid: 12066275].
718 Gejo R, Morita Y, Matsushita I, et al. Joint gap changes with patellar tendon strain and patellar position during TKA. Clinical Orthopaedics & Related Research. 2008;466(4):946-51. [pmid: 18264741].
719 Gemmell HA, Jacobson BH, Hayes BM. Effect of a topical herbal cream on osteoarthritis of the hand and knee: a pilot study. Journal of manipulative and physiological therapeutics. 2003;26(5):322. [pmid: 12819631].
720 Genet F, Schnitzler A, Lapeyre E, et al. Change of impairment, disability and patient satisfaction after total knee arthroplasty in secondary care practice. Annales de Readaptation et de Medecine Physique. 2008;51(8):671-6. [pmid: 18801590].
721 George LK, Ruiz D Jr, Sloan FA. The effects of total knee arthroplasty on physical functioning in the older population. Arthritis Rheum. Oct. 2008;58(10):3166-71. [pmid: 18821689].
722 Germanou E, Beneka A, Malliou P, et al. Reproducibility of concentric isokinetic strength of the knee extensors and flexors in individuals with mild and moderate osteoarthritis of the knee. Isokinetics and Exercise Science. 2007;15(3):151-64.
723 Ghanem E, Restrepo C, Joshi A, et al. Periprosthetic infection does not preclude good outcome for revision arthroplasty. Clinical Orthopaedics & Related Research. 2007;461(Journal Article):54-9. [pmid: 17572638].
724 Ghomrawi HMK, Kane RL, Eberly LE, et al. Patterns of functional improvement after revision knee arthroplasty. Journal of Bone & Joint Surgery - American Volume. Dec. 2009;91(12):2838-45. [pmid: 19952245].
725 Ghosh S, Paul S, Das N, et al. A study on the effects of diclofenac sodium and etoricoxib in the treatment of osteoarthritis. Journal of the Indian Medical Association. May. 2007;105(5):260-2. [pmid: 17915794].
726 Giannoni MF, Ciatti R, Capoccia L, et al. Total knee replacement: prevention of deep-vein thrombosis using pharmacological (low-molecular-weight heparin) and mechanical (intermittent foot sole pump system) combined prophylaxis. Preliminary results. International Angiology. Sep. 2006;25(3):316-21. [pmid: 16878083].
727 Giaquinto S, Ciotola E, Dall’Armi V, et al. Hydrotherapy after total knee arthroplasty. A follow-up study. Archives of Gerontology & Geriatrics. Jul–Aug. 2010;51(1):59-63. [pmid: 19735951].
728 Gibson K, Sayers SP, Minor MA. Accuracy of a non-radiographic method of measuring varus/valgus alignment in knees with osteoarthritis. Missouri Medicine. Mar–Apr. 2009;106(2):132-5. [pmid: 19397113].
729 Gibson T, Winter PJ, Grahame R. Radiotherapy in the treatment of osteoarthrosis of the knee. Rheumatol Rehabil. Feb. 1973;12(1):42-6. [pmid: 4200381].
730 Gibson TJ, Winter PJ, Grahame R. Radiotherapy in the treatment of osteoarthrosis of the knee. Ann Rheum Dis. Sep. 1972;31(5):423-4. [pmid: 5071640].
731 Gidwani S, Tauro B, Whitehouse S, et al. Do patients need to earn total knee arthroplasty?. Journal of Arthroplasty. Feb. 2003;18(2):199-203. [pmid: 12629611].
732 Gill GS, Joshi AB. Long-term results of cemented, posterior cruciate ligament-retaining total knee arthroplasty in osteoarthritis. American Journal of Knee Surgery. 2001;14(4):209-14. [pmid: 11703032].
733 Gill GS, Joshi AB. Long-term results of Kinematic Condylar knee replacement. An analysis of 404 knees. Journal of Bone & Joint Surgery - British Volume. Apr. 2001;83(3):355-8. [pmid: 11341419].
734 Gill S, McBurney H. Reliability of performance-based measures in people awaiting joint replacement surgery of the hip or knee. Physiother Res Int. Sep. 2008;13(3):141-52. [pmid: 18697226].
735 Gillette JC, Stevermer CA. Optimization of foot placement for individuals with total knee replacements during sit-to-stand transfers. Biomed Sci Instrum. 2006;42:524-9. [pmid: 16817662].
736 Gillingham SJ, Alvi F, Lovell ME. The effect of increasing age on nocturnal joint pain in patients about to undergo hip or knee joint arthroplasty. Archives of Gerontology & Geriatrics. Jan–Feb. 2010;50(1):34-5. [pmid: 19233489].
737 Gioe TJ, Bowman KR. A randomized comparison of all-polyethylene and metal-backed tibial components. Clinical Orthopaedics & Related Research. 2000;(380):108-15. [pmid: 11064980].
738 Gioe TJ, Novak C, Sinner P, et al. Knee arthroplasty in the young patient: survival in a community registry. Clinical Orthopaedics & Related Research. 2007;464(Journal Article):83-7. [pmid: 17589362].
739 Gioe TJ, Pomeroy D, Suthers K, et al. Can patients help with long-term total knee arthroplasty surveillance? Comparison of the American Knee Society Score self-report and surgeon assessment. Rheumatology. 2009;48(2):160-4. [pmid: 19106165].
740 Gobbi A, Bathan L. Biological approaches for cartilage repair. The Journal of Knee Surgery. Jan. 2009;22(1):36-44. [pmid: 19216352].
741 Gobbi A, Kon E, Berruto M, et al. Patellofemoral full-thickness chondral defects treated with Hyalograft-C: a clinical, arthroscopic, and histologic review. American Journal of Sports Medicine. 2006;34(11):1763-73. [pmid: 16832129].
742 Intraarticular Injection of Triamcinolone Acetonide and Hyaluronic Acid for Knee Osteoarthritis: Role of Ultrasound in Therapy Selection and Monitoring of Response. 2008 Annual Scientific Meeting of the American College of Rheumatology and Association of Rheumatology Health Professionals. Moscone Center, San Francisco, California (USA). 24–29 Oct 2008.
743 Lateral Wedge Orthotics Delay Progression of Joint Space Narrowing in Patients with Medial Knee Osteoarthritis. 2008 Annual Scientific Meeting of the American College of Rheumatology and Association of Rheumatology Health Professionals, Moscone Center. San Francisco, California (USA). 24–29 Oct 2008.
744 Gomez-Barrena E, Fernandez-Garcia C, Fernandez-Bravo A, et al. Functional performance with a single-radius femoral design total knee arthroplasty. Clinical Orthopaedics & Related Research. May. 2010;468(5):1214-20. [pmid: 20012237].
745 Gomoll AH, Kang RW, Chen AL, et al. Triad of cartilage restoration for unicompartmental arthritis treatment in young patients: meniscus allograft transplantation, cartilage repair and osteotomy. The Journal of Knee Surgery. Apr. 2009;22(2):137-41. [pmid: 19476178].
746 Goncalves RS, Cabri J, Pinheiro JP. Cross-cultural adaptation and validation of the Portuguese version of the Knee Outcome Survey-Activities of Daily Living Scale (KOS-ADLS). Clin Rheumatol. Nov. 2008;27(11):1445-9. [pmid: 18773253].
747 Goncalves RS, Cabri J, Pinheiro JP, et al. Cross-cultural adaptation and validation of the Portuguese version of the Knee injury and Osteoarthritis Outcome Score (KOOS). Osteoarthritis Cartilage. Sep. 2009;17(9):1156-62. [pmid: 19303082].
748 Goncalves RS, Cabri J, PinHeiro JP, et al. Reliability, validity and responsiveness of the Portuguese version of the Knee injury and Osteoarthritis Outcome Score - Physical Function Short-form. Osteoarthritis and Cartilage. 2010;18(3):372-6. [pmid: 19912982].
749 Gonzalez-Fuentes AM, Green DM, Rossen RD, et al. Intra-articular hyaluronic acid increases cartilage breakdown biomarker in patients with knee osteoarthritis. Clinical Rheumatology. Jun. 2010;29(6):619-24. [pmid: 20101426].
750 Goodfellow J, O’Connor J, Murray DW. The Oxford meniscal unicompartmental knee. The Journal of Knee Surgery. 2002;15(4):240-6. [pmid: 12416907].
751 Goorman SD, Watanabe TK, Miller EH, et al. Functional outcome in knee osteoarthritis after treatment with hylan G-F 20: a prospective study. Archives of Physical Medicine and Rehabilitation. 2000;81(4):479-83. [pmid: 10768539].
752 Goradia VK, Van Allen J. Chronic lateral knee instability treated with a high tibial osteotomy. Arthroscopy. 2002;18(7):807-11. [pmid: 12209441].
753 Gottesdiener K, Schnitzer T, Fisher C, et al. Results of a randomized, dose-ranging trial of etoricoxib in patients with osteoarthritis. Rheumatology. 2002;41(9):1052-61. [pmid: 12209041].
754 Goutallier D, Van Driessche S, Manicom O, et al. Influence of lower-limb torsion on long-term outcomes of tibial valgus osteotomy for medial compartment knee osteoarthritis. [Erratum appears in J Bone Joint Surg Am. 2007 Feb;89(2):388 Note: Ali, Edy Sari [corrected to Sariali, E]]. Journal of Bone & Joint Surgery - American Volume. Nov. 2006;88(11):2439-47. [pmid: 17079402].
755 MDCT arthrography of the knee: morphological assessment of articular cartilage in osteoarthritis. 2008. 94th Scientific Assembly and Annual Meeting of the Radiological Socity of North America (RSNA 2008). McCormick Place, Chicago, Illinois (USA). 30 Nov–5 Dec 2008.
756 Grace D, Rogers J, Skeith K, et al. Topical diclofenac versus placebo: a double blind, randomized clinical trial in patients with osteoarthritis of the knee. Journal of Rheumatology. Dec. 1999;26(12):2659-63. [pmid: 10606379].
757 Gravlee JR, Van Durme DJ. Braces and splints for musculoskeletal conditions. American Family Physician. Feb. 1. 2007;75(3):342-8. [pmid: 17304865].
758 Grecomoro G, La Sala F, Francavilla G. Rheologic changes in the synovial fluid of patients with gonarthritis induced by intraarticular infiltration of hyaluronic acid. International Journal of Tissue Reactions. 2001;23(2):67-71. [pmid: 11447776].
759 Griffin FM, Insall JN, Scuderi GR. The posterior condylar angle in osteoarthritic knees. Journal of Arthroplasty. Oct. 1998;13(7):812-5. [pmid: 9802670].
760 Grindrod KA, Marra CA, Colley L, et al. After patients are diagnosed with knee osteoarthritis, what do they do?. Arthritis Care Res (Hoboken). Apr. 2010;62(4):510-5. [pmid: 20391506].
761 Gristina AG, Green DL. Arthritic joints. American Family Physician. Nov. 1974;10(5):131-8. [pmid: 4423837].
762 Groeneboer S, Pastoureau P, Vignon E, et al. Cyclodextrin polysulphate protects articular cartilage in experimental lapine knee osteoarthritis. Osteoarthritis & Cartilage. Sep. 2008;16(9):986-93. [pmid: 18308591].
763 Grotle M, Garratt AM, Klokkerud M, et al. What’s in team rehabilitation care after arthroplasty for osteoarthritis? Results from a multicenter, longitudinal study assessing structure, process, and outcome. Phys Ther. Jan. 2010;90(1):121-31. [pmid: 20045807].
764 Grotle M, Hagen KB, Natvig B, et al. Prevalence and burden of osteoarthritis: results from a population survey in Norway. J Rheumatol. Apr. 2008;35(4):677-84. [pmid: 18278832].
765 Grube B, Grunwald J, Krug L, et al. Efficacy of a comfrey root (Symphyti offic. radix) extract ointment in the treatment of patients with painful osteoarthritis of the knee: results of a double-blind, randomised, bicenter, placebo-controlled trial. Phytomedicine. Jan. 2007;14(1):2-10. [pmid: 17169543].
766 Gstottner M, Pedross F, Liebensteiner M, et al. Long-term outcome after high tibial osteotomy. [Erratum appears in Arch Orthop Trauma Surg. 2008 Mar;128(3):345 Note: Michaela, Gstottner [corrected to Gstottner, Michaela]; Florian, Pedross [corrected to Pedross, Florian]; Michael, Liebensteiner [corrected to Liebensteiner, Michael]; Christian, Bach [corrected to Bach, Christian]]. Archives of Orthopaedic & Trauma Surgery. Jan. 2008;128(1):111-5. [pmid: 17828411].
767 Guccione AA, Felson DT, Anderson JJ. Defining arthritis and measuring functional status in elders: methodological issues in the study of disease and physical disability. Am J Public Health. Aug. 1990;80(8):945-9. [pmid: 2368855].
768 Guccione AA, Felson DT, Anderson JJ, et al. The effects of specific medical conditions on the functional limitations of elders in the Framingham Study. Am J Public Health. Mar. 1994;84(3):351-8. [pmid: 8129049].
769 Gudbergsen H, Boesen M, Christensen R, et al. Radiographs and low field MRI (0.2T) as predictors of efficacy in a weight loss trial in obese women with knee osteoarthritis. BMC Musculoskelet Disord. 2011;12:56. [pmid: 21356061].
770 Semiquantitative whole-knee scoring for the assessment of synovitis in knee osteoarthritis (OA) on contrast enhanced (CE) MRI: the multicenter osteoarthritis study (MOST). 2008. 94th Scientific Assembly and Annual Meeting of the Radiological Society of North America (RSNA 2008). McCormick Place, Chicago, Illinois (USA). 30 Nov–5 Dec 2008.
771 Guermazi M, Poiraudeau S, Yahia M, et al. Translation, adaptation and validation of the Western Ontario and McMaster Universities osteoarthritis index (WOMAC) for an Arab population: the Sfax modified WOMAC. Osteoarthritis Cartilage. Jun. 2004;12(6):459-68. [pmid: 15135142].
772 Gugenheim JJ Jr, Brinker MR. Bone realignment with use of temporary external fixation for distal femoral valgus and varus deformities. Journal of Bone & Joint Surgery - American Volume. 2003;85-A(7):1229-37. [pmid: 12851347].
773 Gulati A, Chau R, Beard DJ, et al. Localization of the full-thickness cartilage lesions in medial and lateral unicompartmental knee osteoarthritis. Journal of Orthopaedic Research. Oct. 2009;27(10):1339-46. [pmid: 19396859].
774 Gulati A, Chau R, Simpson DJ, et al. Influence of component alignment on outcome for unicompartmental knee replacement. Knee. Jun. 2009;16(3):196-9. [pmid: 19042132].
775 Guler H, Karazincir S, Turhanoglu AD, et al. Effect of coexisting foot deformity on disability in women with knee osteoarthritis. Journal - American Podiatric Medical Association. 2009;99(1):23-7.
776 Gunther KP. Surgical approaches for osteoarthritis. Best Pract Res Clin Rheumatol. Oct. 2001;15(4):627-43. [pmid: 11567544].
777 Gunther KP, Sun Y. Reliability of radiographic assessment in hip and knee osteoarthritis. Osteoarthritis Cartilage. Mar. 1999;7(2):239-46. [pmid: 10222223].
778 Guo R, Canter PH, Ernst E. A systematic review of randomised clinical trials of individualised herbal medicine in any indication. Postgraduate Medical Journal. Oct. 2007;83(984):633-7. [pmid: 17916871].
779 Gur A, Cosut A, Sarac AJ, et al. Efficacy of different therapy regimes of low-power laser in painful osteoarthritis of the knee: a double-blind and randomized-controlled trial. Lasers in Surgery & Medicine. 2003;33(5):330-8. [pmid: 14677160].
780 Gur H, Cakin N. Muscle mass, isokinetic torque, and functional capacity in women with osteoarthritis of the knee. Arch Phys Med Rehabil. Oct. 2003;84(10):1534-41. [pmid: 14586923].
781 Habata T, Uematsu K, Hattori K, et al. High tibial osteotomy that does not cause recurrence of varus deformity for medial gonarthrosis. Knee Surgery, Sports Traumatology, Arthroscopy. Oct. 2006;14(10):962-7. [pmid: 16639630].
782 Habib G, Safia A. The effect of intra-articular injection of betamethasone acetate/betamethasone sodium phosphate on blood glucose levels in controlled diabetic patients with symptomatic osteoarthritis of the knee. Clin Rheumatol. Jan. 2009;28(1):85-7. [pmid: 18853221].
783 Hadjianastassiou VG, Virich G, Lennox IA. Use of the blood transfusion service in total knee replacement arthroplasty. The cost implications. Knee. May. 2002;9(2):145-8. [pmid: 11950579].
784 Haflah NHM, Jaarin K, Abdullah S, et al. Palm vitamin E and glucosamine sulphate in the treatment of osteoarthritis of the knee. Saudi Medical Journal. Nov. 2009;30(11):1432-8. [pmid: 19882056].
785 Hale M, Upmalis D, Okamoto A, et al. Tolerability of tapentadol immediate release in patients with lower back pain or osteoarthritis of the hip or knee over 90 days: a randomized, double-blind study. Current Medical Research & Opinion. May. 2009;25(5):1095-104. [pmid: 19301989].
786 Halket A, Stratford PW, Kennedy DM, et al. Using hierarchical linear modeling to explore predictors of pain after total hip and knee arthroplasty as a consequence of osteoarthritis. J Arthroplasty. Feb. 2010;25(2):254-62. [pmid: 19625162].
787 Hall M, Migay AM, Persad T, et al. Individuals’ experience of living with osteoarthritis of the knee and perceptions of total knee arthroplasty. Physiother Theory Pract. May–Jun. 2008;24(3):167-81. [pmid: 18569854].
788 Hamai S, Miura H, Higaki H, et al. Three-dimensional knee joint kinematics during golf swing and stationary cycling after total knee arthroplasty. Journal of Orthopaedic Research. Dec. 2008;26(12):1556-61. [pmid: 18524002].
789 Hamel MB, Toth M, Legedza A, et al. Joint replacement surgery in elderly patients with severe osteoarthritis of the hip or knee: decision making, postoperative recovery, and clinical outcomes. Archives of Internal Medicine. 2008;168(13):1430-40. [pmid: 18625924].
790 Hammad TA. Structure modification in knee osteoarthritis: methodology and outcome parameters. Osteoarthritis & Cartilage. Jul. 2001;9(5):488-98. [pmid: 11467898].
791 Han I, Seong SC, Lee S, et al. Simultaneous bilateral MIS-TKA results in faster functional recovery. Clinical Orthopaedics & Related Research. 2008;466(6):1449-53. [pmid: 18351423].
792 Han SB, Nha KW, Yoon JR, et al. The reliability of navigation-guided gap technique in total knee arthroplasty. Orthopedics. Oct. 2008;31(10 Suppl 1). [pmid: 19298036].
793 Hanby CK. Total knee arthroplasty for the patellofemoral joint. Journal of Bone & Joint Surgery - American Volume. 2003;85-A(7):1391-2. [pmid: 12851369].
794 Handl M, Filova E, Kubala M, et al. Fluorescent advanced glycation end products in the detection of factual stages of cartilage degeneration. Physiol Res. 2007;56(2):235-42. [pmid: 16555949].
795 Handoll Helen HG, Hanchard Nigel CA, Goodchild Lorna M, et al. Conservative management following closed reduction of traumatic anterior dislocation of the shoulder, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2006.
796 Hanna F, Teichtahl AJ, Bell R, et al. The cross-sectional relationship between fortnightly exercise and knee cartilage properties in healthy adult women in midlife. Menopause. Sep–Oct. 2007;14(5):830-4. [pmid: 17413649].
797 Hanson EC. Sodium hyaluronate--application in a community practice. American Journal of Orthopedics (Chatham, Nj). Nov. 1999;28(11 Suppl):11-2. [pmid: 10587247].
798 Hanson GR, Suggs JF, Kwon Y-M, et al. In vivo anterior tibial post contact after posterior stabilizing total knee arthroplasty. Journal of Orthopaedic Research. Nov. 2007;25(11):1447-53. [pmid: 17557322].
799 Hanssen AD. Orthopaedic crossfire--All patellae should be resurfaced during primary total knee arthroplasty: in the affirmative. Journal of Arthroplasty. Apr. 2003;18(3 Suppl 1):31-4. [pmid: 12730925].
800 Hansson U, Toksvig-Larsen S, Jorn LP, et al. Mobile vs. fixed meniscal bearing in total knee replacement: a randomised radiostereometric study. Knee. Dec. 2005;12(6):414-8. [pmid: 16125941].
801 Harato K, Nagura T, Matsumoto H, et al. Extension limitation in standing affects weight-bearing asymmetry after unilateral total knee arthroplasty. Journal of Arthroplasty. Feb. 2010;25(2):225-9. [pmid: 19264442].
802 Hardeman F, Vandenneucker H, Van Lauwe J, et al. Cementless total knee arthroplasty with Profix: a 8- to 10-year follow-up study. Knee. Dec. 2006;13(6):419-21. [pmid: 17064905].
803 Harding AK, Toksvig-Larsen S, et al. A single dose zoledronic acid enhances pin fixation in high tibial osteotomy using the hemicallotasis technique. A double-blind placebo controlled randomized study in 46 patients. Bone. Mar. 2010;46(3):649-54. [pmid: 19913119].
804 Hardwick ME, Pulido PA, D’Lima DD, et al. e-Knee: the electronic knee prosthesis. Orthopaedic Nursing. 2006;25(5):326-9. [pmid: 17035919].
805 Harrington KD. Long-term results for the McKeever patellar resurfacing prosthesis used as a salvage procedure for severe chondromalacia patellae. Clin Orthop Relat Res. Jun. 1992;(279):201-13. [pmid: 1600657].
806 Harrington MA, Hopkinson WJ, Hsu P, et al. Fixed- vs mobile-bearing total knee arthroplasty: does it make a difference?--a prospective randomized study. Journal of Arthroplasty. Sep. 2009;24(6 Suppl):24-7. [pmid: 19553072].
807 Harrison MM, Waddell JP. A comparison of plate versus staple-and-cast fixation in maintaining femoral tibial alignment after valgus tibial osteotomy. Canadian Journal of Surgery. Feb. 2005;48(1):33-8. [pmid: 15757034].
808 Hart DJ, Spector TD, Brown P, et al. Clinical signs of early osteoarthritis: reproducibility and relation to x ray changes in 541 women in the general population. Ann Rheum Dis. Jul. 1991;50(7):467-70. [pmid: 1877852].
809 Hart L. Supervised exercise versus usual care for patellofemoral pain syndrome. Clin J Sport Med. 20(2):133. [pmid: 20215901].
810 Hart R, Janecek M, Chaker A, et al. Total knee arthroplasty implanted with and without kinematic navigation. International Orthopaedics. 2003;27(6):366-9. [pmid: 12942197].
811 Hartford JM, Hunt T, Kaufer H. Low contact stress mobile bearing total knee arthroplasty: results at 5 to 13 years. Journal of Arthroplasty. Dec. 2001;16(8):977-83. [pmid: 11740751].
812 Hartley RC, Barton-Hanson NG, Finley R, et al. Early patient outcomes after primary and revision total knee arthroplasty. A prospective study. [Erratum appears in J Bone Joint Surg Br 2003 Jan;85(1):153.]. Journal of Bone & Joint Surgery - British Volume. Sep. 2002;84(7):994-9. [pmid: 12358393].
813 Hasegawa M, Nakoshi Y, Tsujii M, et al. Changes in biochemical markers and prediction of effectiveness of intra-articular hyaluronan in patients with knee osteoarthritis. Osteoarthritis Cartilage. Apr. 2008;16(4):526-9. [pmid: 17951079].
814 Hasegawa M, Sudo A, Uchida A. Staged bilateral mobile-bearing and fixed-bearing total knee arthroplasty in the same patients: a prospective comparison of a posterior-stabilized prosthesis. Knee Surgery, Sports Traumatology, Arthroscopy. Mar. 2009;17(3):237-43. [pmid: 19020863].
815 Hashmi FR, Barlas K, Mann CF, et al. Staged bilateral hip or knee arthroplasties. Journal of Orthopaedic Surgery. Aug. 2007;15(2):159-62. [pmid: 17709852].
816 Hassaballa MA, Porteous AJ, Newman JH. Observed kneeling ability after total, unicompartmental and patellofemoral knee arthroplasty: perception versus reality. Knee Surgery, Sports Traumatology, Arthroscopy. Mar. 2004;12(2):136-9. [pmid: 12897983].
817 Hassaballa MA, Porteous AJ, Newman JH, et al. Can knees kneel? Kneeling ability after total, unicompartmental and patellofemoral knee arthroplasty. Knee. Jun. 2003;10(2):155-60. [pmid: 12787999].
818 Hassan BS, Doherty SA, Mockett S, et al. Effect of pain reduction on postural sway, proprioception, and quadriceps strength in subjects with knee osteoarthritis. Annals of the Rheumatic Diseases. May. 2002;61(5):422-8. [pmid: 11959766].
819 Hau RCY, Newman JH. Knee replacement for osteoarthritis secondary to chronic patellar dislocation and trochlear dysplasia. Knee. Dec. 2008;15(6):447-50. [pmid: 18692396].
820 Haverkamp D, de Jong PT, Marti RK. Intertrochanteric osteotomies do not impair long-term outcome of subsequent cemented total hip arthroplasties. Clinical Orthopaedics & Related Research. 2006;444(Journal Article):154-60. [pmid: 16523138].
821 Haverkamp D, Sierevelt IN, Breugem SJ, et al. Translation and validation of the Dutch version of the International Knee Documentation Committee Subjective Knee Form. American Journal of Sports Medicine. 2006;34(10):1680-4. [pmid: 16816150].
822 Hawker GA, Badley EM, Croxford R, et al. A population-based nested case-control study of the costs of hip and knee replacement surgery. Medical care. 2009;47(7):732-41. [pmid: 19536034].
823 Hawker GA, Katz JN, Solomon DH. The patient’s perspective on the recall of Vioxx. Journal of Rheumatology. Jun. 2006;33(6):1082-8. [pmid: 16755654].
824 Hawker GA, Wright JG, Badley EM, et al. Perceptions of, and willingness to consider, total joint arthroplasty in a population-based cohort of individuals with disabling hip and knee arthritis. Arthritis Rheum. Aug. 15. 2004;51(4):635-41. [pmid: 15334438].
825 Hawkey CJ, Laine L, Harper SE, et al. Influence of risk factors on endoscopic and clinical ulcers in patients taking rofecoxib or ibuprofen in two randomized controlled trials. Aliment Pharmacol Ther. Oct. 2001;15(10):1593-601. [pmid: 11563999].
826 Hazaki S, Yokoyama Y, Inoue H. A radiographic analysis of anterior-posterior translation in total knee arthroplasty. Journal of Orthopaedic Science. 2001;6(5):390-6. [pmid: 11845347].
827 Heck DA, Robinson RL, Partridge CM, et al. Patient outcomes after knee replacement. Clinical Orthopaedics & Related Research. 1998;(356):93-110. [pmid: 9917673].
828 Heiberg KE, Bruun-Olsen V, Mengshoel AM. Pain and recovery of physical functioning nine months after total knee arthroplasty. Journal of Rehabilitation Medicine. Jul. 2010;42(7):614-9. [pmid: 20603690].
829 Heiden TL, Lloyd DG, Ackland TR. Knee joint kinematics, kinetics and muscle co-contraction in knee osteoarthritis patient gait. Clin Biomech (Bristol, Avon). Dec. 2009;24(10):833-41. [pmid: 19765867].
830 Heintjes Edith M, Berger M, Bierma-Zeinstra Sita MA, et al. Pharmacotherapy for patellofemoral pain syndrome, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2004.
831 Heir S, Nerhus TK, Rotterud JH, et al. Focal cartilage defects in the knee impair quality of life as much as severe osteoarthritis: A comparison of knee injury and osteoarthritis outcome score in 4 patient categories scheduled for knee surgery. American Journal of Sports Medicine. Feb. 2010;38(2;):231-7. (Journal Article). [pmid: 20042546].
832 Hellio Le, Graverand MP, Brandt KD, Mazzuca SA, et al. Association between concentrations of urinary type II collagen neoepitope (uTIINE) and joint space narrowing in patients with knee osteoarthritis. Osteoarthritis Cartilage. Nov. 2006;14(11):1189-95. [pmid: 16753310].
833 Helm AT, Kerin C, Ghalayini SRA, et al. Preliminary results of an uncemented trabecular metal tibial component in total knee arthroplasty. Journal of Arthroplasty. Sep. 2009;24(6):941-4. [pmid: 18672343].
834 Helmy N, Anglin C, Greidanus NV, et al. To resurface or not to resurface the patella in total knee arthroplasty. Clinical Orthopaedics & Related Research. 2008;466(11):2775-83. [pmid: 18726657].
835 Hempfling H. Intra-articular hyaluronic acid after knee arthroscopy: a two-year study. Knee Surgery, Sports Traumatology, Arthroscopy. 2007;15(5):537-46. [pmid: 17187274].
836 Hendel D, Beloosesky Y, Garti A, et al. Medial unicompartmental replacement for tricompartmental disease in the elderly. Knee. Dec. 2003;10(4):363-5. [pmid: 14629941].
837 Hendry M, Williams NH, Markland D, et al. Why should we exercise when our knees hurt? A qualitative study of primary care patients with osteoarthritis of the knee. Fam Pract. Oct. 2006;23(5):558-67. [pmid: 16731544].
838 Hennig AC, Incavo SJ, Beynnon BD, et al. The safety and efficacy of a new adjustable plate used for proximal tibial opening wedge osteotomy in the treatment of unicompartmental knee osteoarthrosis. The Journal of Knee Surgery. Jan. 2007;20(1):6-14. [pmid: 17288082].
839 Henricson A, Dalen T, Nilsson KG. Mobile bearings do not improve fixation in cemented total knee arthroplasty. Clinical Orthopaedics & Related Research. 2006;448(Journal Article):114-21. [pmid: 16826105].
840 Henricson A, Linder L, Nilsson KG. A trabecular metal tibial component in total knee replacement in patients younger than 60 years: a two-year radiostereophotogrammetric analysis. Journal of Bone & Joint Surgery - British Volume. Dec. 2008;90(12):1585-93. [pmid: 19043129].
841 Henriksen M, Christensen R, Alkjaer T, et al. Influence of pain and gender on impact loading during walking: A randomised trial. Clinical Biomechanics. 2008;23(2):221-30. [pmid: 17980941].
842 Henriksen M, Graven-Nielsen T, Aaboe J, et al. Gait changes in patients with knee osteoarthritis are replicated by experimental knee pain. Arthritis Care & Research. Apr. 2010;62(4):501-9. [pmid: 20391505].
843 Henriksen M, Simonsen EB, Graven-Nielsen T, et al. Impulse-forces during walking are not increased in patients with knee osteoarthritis. Acta Orthopaedica. Aug. 2006;77(4):650-6. [pmid: 16929444].
844 Hernandez-Vaquero D, Noriega-Fernandez A, Suarez-Vazquez A. Total knee arthroplasties performed with a mini-incision or a standard incision. Similar results at six months follow-up. BMC Musculoskeletal Disorders. 2010;11:27. [pmid: 20137094].
845 Hernandez-Vaquero D, Suarez-Vazquez A. Knee arthrodesis with navigation: a new indication for computer-assisted surgery? A case report. Knee. Mar. 2007;14(2):162-3. [pmid: 17196821].
846 Hernborg JS, Nilsson BE. The natural course of untreated osteoarthritis of the knee. Clin Orthop Relat Res. Mar–Apr. 1977;(123):130-7. [pmid: 856513].
847 Hernigou P, Deschamps G. Posterior slope of the tibial implant and the outcome of unicompartmental knee arthroplasty. Journal of Bone & Joint Surgery - American Volume. Mar. 2004;86-A(3):506-11. [pmid: 14996875].
848 Hernigou P, Garabedian JM. Intercondylar notch width and the risk for anterior cruciate ligament rupture in the osteoarthritic knee: evaluation by plain radiography and CT scan. Knee. Dec. 2002;9(4):313-6. [pmid: 12424040].
849 Hernigou P, Ma W. Open wedge tibial osteotomy with acrylic bone cement as bone substitute. Knee. Jun. 2001;8(2):103-10. [pmid: 11337236].
850 Hernigou P, Medevielle D, Debeyre J, et al. Proximal tibial osteotomy for osteoarthritis with varus deformity. A ten to thirteen-year follow-up study. J Bone Joint Surg Am. Mar. 1987;69(3):332-54. [pmid: 3818700].
851 Hernigou P, Roussignol X, Flouzat-Lachaniette CH, et al. Opening wedge tibial osteotomy for large varus deformity with Ceraver resorbable beta tricalcium phosphate wedges. International Orthopaedics. Feb. 2010;34(2):191-9. [pmid: 19795122].
852 Herrera JA, Gonzalez M. Comparative evaluation of the effectiveness and tolerability of nimesulide versus rofecoxib taken once a day in the treatment of patients with knee osteoarthritis. American Journal of Therapeutics. 2003;10(6):468-72. [pmid: 14624289].
853 Herrero-Beaumont G, Ivorra JAR, Del Carmen Trabado M, et al. Glucosamine sulfate in the treatment of knee osteoarthritis symptoms: a randomized, double-blind, placebo-controlled study using acetaminophen as a side comparator. Arthritis & Rheumatism. Feb. 2007;56(2):555-67. [pmid: 17265490].
854 Effects of Glucosamine Sulfate on 6-Month Control of Knee Osteoarthritis Symptoms vs Placebo and Acetaminophen: Results from the Glucosamine Unum in Die Efficacy (GUIDE) Trial. 69th Annual Meeting of the American College of Rheumatology and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
855 Herrmann JM, Pitris C, Bouma BE, et al. High resolution imaging of normal and osteoarthritic cartilage with optical coherence tomography. J Rheumatol. Mar. 1999;26(3):627-35. [pmid: 10090174].
856 Hesslink R Jr, Armstrong D 3rd, Nagendran MV, et al. Cetylated fatty acids improve knee function in patients with osteoarthritis. Journal of Rheumatology. Aug. 2002;29(8):1708-12. [pmid: 12180734].
857 Hewett TE. Predisposition to ACL injuries in female athletes versus male athletes. Orthopedics. Jan. 2008;31(1):26-8. [pmid: 18269164].
858 Higuchi H, Hatayama K, Shimizu M, et al. Relationship between joint gap difference and range of motion in total knee arthroplasty: a prospective randomised study between different platforms. International Orthopaedics. Aug. 2009;33(4):997-1000. [pmid: 19399499].
859 Hill CL, Hunter DJ, Niu J, et al. Synovitis detected on magnetic resonance imaging and its relation to pain and cartilage loss in knee osteoarthritis. Ann Rheum Dis. Dec. 2007;66(12):1599-603. [pmid: 17491096].
860 Hill J, Lewis M, Bird H. Do OA patients gain additional benefit from care from a clinical nurse specialist?--a randomized clinical trial. Rheumatology. 2009;48(6):658-64. [pmid: 19321512].
861 Knee Braces and Foot Orthosis for Knee Osteoarthritis. 2008 Annual Scientific Meeting of the American College of Rheumatology and Association of Rheumatology Health Professionals. Moscone Center, San Francisco, California (USA). 24–29 Oct 2008.
862 Himanen A-K, Belt E, Nevalainen J, et al. Survival of the AGC total knee arthroplasty is similar for arthrosis and rheumatoid arthritis. Finnish Arthroplasty Register report on 8,467 operations carried out between 1985 and 1999. Acta Orthopaedica. Feb. 2005;76(1):85-8. [pmid: 15788313].
863 Hinman RS, Bennell KL, Metcalf BR, et al. Balance impairments in individuals with symptomatic knee osteoarthritis: a comparison with matched controls using clinical tests. Rheumatology. Dec. 2002;41(12):94. [pmid: 12468818].
864 Hirohata K, Yao S, Imura S, et al. Treatment of osteoarthritis of the knee joint at the stage of hydroarthrosis. (Especially from the viewpoint of its histological findings). Kobe J Med Sci. Dec. Suppl. 1965;11:65-7. [pmid: 5874747].
865 Hitzeman N, Masley C. Arthroscopic surgery for knee osteoarthritis. American Family Physician. Aug. 1. 2008;78(3):331-2. [pmid: 18711946].
866 Ho DM, Huo MH. Are critical pathways and implant standardization programs effective in reducing costs in total knee replacement operations?. Journal of the American College of Surgeons. Jul. 2007;205(1):97-100. [pmid: 17617338].
867 Hochberg MC, Clegg DO. Potential effects of chondroitin sulfate on joint swelling: a GAIT report. Osteoarthritis & Cartilage. Suppl 3. 2008;16:S22-4. [pmid: 18768335].
868 Hodge WA, Harman MK, Banks SA. Patterns of knee osteoarthritis in Arabian and American knees. Journal of Arthroplasty. Apr. 2009;24(3):448-53. [pmid: 18534414].
869 Hodges PW, Mellor R, Crossley K, et al. Pain induced by injection of hypertonic saline into the infrapatellar fat pad and effect on coordination of the quadriceps muscles. Arthritis Rheum. Jan. 15. 2009;61(1):70-7. [pmid: 19116977].
870 Hodrick JT, Severson EP, McAlister DS, et al. Highly crosslinked polyethylene is safe for use in total knee arthroplasty. Clinical Orthopaedics & Related Research. 2008;466(11):2806-12. [pmid: 18781371].
871 Hoenig H, Pieper C, Branch LG, et al. Effect of motorized scooters on physical performance and mobility: a randomized clinical trial. Archives of Physical Medicine & Rehabilitation. 2007;88(3):279-86. [pmid: 17321817].
872 Hofmann AA, Evanich JD, Ferguson RP, et al. Ten- to 14-year clinical followup of the cementless Natural Knee system. Clinical Orthopaedics & Related Research. 2001;(388):85-94. [pmid: 11451137].
873 Hofmann AA, Heithoff SM, Camargo M. Cementless total knee arthroplasty in patients 50 years or younger. Clinical Orthopaedics & Related Research. Nov. 2002;(404):102-7. [pmid: 12439246].
874 Persons with patellofemoral osteoarthritis exhibit altered knee kinematics during a sit-to-stand task. 2008. 2008 Combined Sections Meeting of the American Physical Therapy Association (CSM 2008). Nashville, Tennessee (USA). 6–10 Feb 2008.
875 Hollander AP, Dickinson SC, Sims TJ, et al. Maturation of tissue engineered cartilage implanted in injured and osteoarthritic human knees. Tissue Engineering. Jul. 2006;12(7):1787-98. [pmid: 16889509].
876 Hollinghurst D, Stoney J, Ward T, et al. In vivo sagittal plane kinematics of the Avon patellofemoral arthroplasty. Journal of Arthroplasty. Jan. 2007;22(1):117-23. [pmid: 17197318].
877 Holm B, Kristensen MT, Bencke J, et al. Loss of knee-extension strength is related to knee swelling after total knee arthroplasty. Arch Phys Med Rehabil. Nov. 2010;91(11):1770-6. [pmid: 21044725].
878 Holm I, Oiestad BE, Risberg MA, et al. No difference in knee function or prevalence of osteoarthritis after reconstruction of the anterior cruciate ligament with 4-strand hamstring autograft versus patellar tendon-bone autograft: a randomized study with 10-year follow-up. American Journal of Sports Medicine. Mar. 2010;38(3):448-54. [pmid: 20097928].
879 Holmstrom A, Hardin BC. Cryo/Cuff compared to epidural anesthesia after knee unicompartmental arthroplasty: a prospective, randomized and controlled study of 60 patients with a 6-week follow-up. Journal of Arthroplasty. 2005;20(3):316-21. [pmid: 15809948].
880 Hooper G, Leslie H, Burn J, et al. Oblique upper tibial opening wedge osteotomy for genu varum. Operative Orthopadie und Traumatologie. Dec. 2005;17(6):662-73. [pmid: 16369759].
881 Hooper G, Rothwell A, Frampton C. The low contact stress mobile-bearing total knee replacement: a prospective study with a minimum follow-up of ten years. Journal of Bone & Joint Surgery - British Volume. Jan. 2009;91(1):58-63. [pmid: 19092005].
882 Hopkins AR, New AM, Rodriguez-y-Baena F, et al. Finite element analysis of unicompartmental knee arthroplasty. Medical Engineering & Physics. 2010;32(1):14-21. [pmid: 19897397].
883 Hopkins AR, Taylor M. Minimal-resection arthroplasty to treat meniscal tears with associated condyle lesions: finite element analysis. Proceedings of the Institution of Mechanical Engineers Part H - Journal of Engineering in Medicine. Apr. 2009;223(3):329-38. [pmid: 19405438].
884 Hopman-Rock M, Kraaimaat FW, Bijlsma JW. Quality of life in elderly subjects with pain in the hip or knee. Qual Life Res. Jan. 1997;6(1):67-76. [pmid: 9062444].
885 Hopman-Rock M, Kraaimaat FW, Odding E, et al. Coping with pain in the hip or knee in relation to physical disability in community-living elderly people. Arthritis Care Res. Aug. 1998;11(4):243-52. [pmid: 9791323].
886 Hortobagyi T, Garry J, Holbert D, et al. Aberrations in the control of quadriceps muscle force in patients with knee osteoarthritis. Arthritis & Rheumatism. Aug. 15. 2004;51(4):562-9. [pmid: 15334428].
887 Hortobagyi T, Westerkamp L, Beam S, et al. Altered hamstring-quadriceps muscle balance in patients with knee osteoarthritis. Clinical Biomechanics. 2005;20(1):97-104. [pmid: 15567543].
888 Horton TC, Jackson R, Mohan N, et al. Is routine splintage following primary total knee replacement necessary? A prospective randomised trial. Knee. Sep. 2002;9(3):229-31. [pmid: 12126683].
889 Horwitz MD, Awan S, Chatoo MB, et al. An 8- to 10-year review of the Rotaglide total knee replacement. International Orthopaedics. Feb. 2009;33(1):111-5. [pmid: 18084758].
890 Hossain F, Patel S, Haddad FS. Midterm assessment of causes and results of revision total knee arthroplasty. Clinical Orthopaedics & Related Research. May. 2010;468(5):1221-8. [pmid: 20058112].
891 Houpt JB, McMillan R, Wein C, et al. Effect of glucosamine hydrochloride in the treatment of pain of osteoarthritis of the knee. J Rheumatol. Nov. 1999;26(11):2423-30. [pmid: 10555905].
892 Hoxie SC, Dobbs RE, Dahm DL, et al. Total knee arthroplasty after anterior cruciate ligament reconstruction. Journal of Arthroplasty. Oct. 2008;23(7):1005-8. [pmid: 18534505].
893 Hsu YC, Cheng HC, Ng TP, et al. Antibiotic-loaded cement articulating spacer for 2-stage reimplantation in infected total knee arthroplasty: a simple and economic method. Journal of Arthroplasty. Oct. 2007;22(7):1060-6. [pmid: 17920482].
894 Huang H-T, Su JY, Wang GJ. The early results of high-flex total knee arthroplasty: a minimum of 2 years of follow-up. Journal of Arthroplasty. Aug. 2005;20(5):674-9. [pmid: 16310007].
895 Huang T-L, Hsu H-C, Yang K-C, et al. Effect of different molecular weight hyaluronans on osteoarthritis-related protein production in fibroblast-like synoviocytes from patients with tibia plateau fracture. Journal of Trauma-Injury Infection & Critical Care. Jan. 2010;68(1):146-52. [pmid: 20065770].
896 Huang YM, Wang CM, Wang CT, et al. Perioperative celecoxib administration for pain management after total knee arthroplasty - a randomized, controlled study. BMC Musculoskelet Disord. 2008;9:77. [pmid: 18519002].
897 Hubley-Kozey C, Deluzio K, Dunbar M. Muscle co-activation patterns during walking in those with severe knee osteoarthritis. Clinical Biomechanics. 2008;23(1):71-80. [pmid: 17935845].
898 HubleyKozey CL, Deluzio KJ, Landry SC, et al. Neuromuscular alterations during walking in persons with moderate knee osteoarthritis. Journal of Electromyography and Kinesiology. 2006;16(4):365-78. [pmid: 16213159].
899 Hudd A, Kunasingam K, Ricketts D, et al. A 5 to 8 year follow-up study of the Rotaglide mobile bearing total knee arthroplasty. International Orthopaedics. Jun. 2009;33(3):675-8. [pmid: 18594822].
900 Huddleston JI, Scarborough DM, Goldvasser D, et al. Marshall Urist Young Investigator Award: how often do patients with high-flex total knee arthroplasty use high flexion?. Clinical Orthopaedics & Related Research. 2009. Jul. 2009;467(7):1898-906. [pmid: 19421828].
901 Huetink K, Nelissen RG, Watt I, et al. Localized development of knee osteoarthritis can be predicted from MR imaging findings a decade earlier. Radiology. Aug. 2010;256(2):536-46. [pmid: 20587644].
902 Huff TW, Sculco TP. The tri-compartment fixed plateau: why bother with less?. Orthopedics. Sep. 2007;30(9):772-3. [pmid: 17899933].
903 Hughes R, Carr A. A randomized, double-blind, placebo-controlled trial of glucosamine sulphate as an analgesic in osteoarthritis of the knee. Rheumatology. 2002;41(3):279-84. [pmid: 11934964].
904 Hunt MA, Birmingham TB, Bryant D, et al. Lateral trunk lean explains variation in dynamic knee joint load in patients with medial compartment knee osteoarthritis. Osteoarthritis & Cartilage. May. 2008;16(5):591-9. [pmid: 18206395].
905 Hunt MA, Birmingham TB, Jones IC, et al. Effect of tibial re-alignment surgery on single leg standing balance in patients with knee osteoarthritis. Clinical Biomechanics. Oct. 2009;24(8):693-6. [pmid: 19527918].
906 Hunt MA, Wrigley TV, Hinman RS, et al. Individuals with severe knee osteoarthritis (OA) exhibit altered proximal walking mechanics compared with individuals with less severe OA and those without knee pain. Arthritis Care & Research. Oct. 2010;62(10):1426-32. [pmid: 20506534].
907 Hunter DJ, Lavalley M, Li J, et al. Urinary pentosidine does not predict cartilage loss among subjects with symptomatic knee OA: the BOKS Study. Osteoarthritis Cartilage. Jan. 2007;15(1):93-7. [pmid: 16857393].
908 Hunter DJ, Sharma L, Skaife T. Alignment and osteoarthritis of the knee. Journal of Bone & Joint Surgery - American Volume. Feb. Suppl 1. 2009;91:85-9. [pmid: 19182031].
909 Hunter DJ, Zhang YQ, Niu JB, et al. Patella malalignment, pain and patellofemoral progression: the Health ABC Study. Osteoarthritis Cartilage. Oct. 2007;15(10):1120-7. [pmid: 17502158].
910 Huotari K, Lyytikainen O, Ollgren J, et al. Disease burden of prosthetic joint infections after hip and knee joint replacement in Finland during 1999–2004 capture-recapture estimation. J Hosp Infect. Jul. 2010;75(3):205-8. [pmid: 20227137].
911 Hurley MV. The effects of joint damage on muscle function, proprioception and rehabilitation. Manual Therapy. 1997;2(1):11-7. [pmid: 11440520].
912 Hurley MV, Scott DL, Rees J, et al. Sensorimotor changes and functional performance in patients with knee osteoarthritis. Ann Rheum Dis. Nov. 1997;56(11):641-8. [pmid: 9462165].
913 Hurwitz DE, Ryals AB, Case JP, et al. The knee adduction moment during gait in subjects with knee osteoarthritis is more closely correlated with static alignment than radiographic disease severity, toe out angle and pain. Journal of Orthopaedic Research. 2002;20(1):101-7. [pmid: 11853076].
914 Huskin JP, Vandekerckhove B, Delince P, et al. Multicentre, prospective, open study to evaluate the safety and efficacy of hylan G-F 20 in knee osteoarthritis subjects presenting with pain following arthroscopic meniscectomy. Knee Surgery, Sports Traumatology, Arthroscopy. 2008;16(8):747-52. [pmid: 18536906].
915 Huskisson E, Donnelly S. Is hyaluronic acid effective in patients with osteoarthritis of the knee?. Western Journal of Medicine. Oct. 2000;173(4):252. [pmid: 11017989].
916 Huskisson EC. Measurement of pain. Lancet. Nov. 9. 1974;2(7889):1127-31. [pmid: 4139420].
917 Hutchinson JRM, Parish EN, Cross MJ. A comparison of bilateral uncemented total knee arthroplasty: simultaneous or staged?. Journal of Bone & Joint Surgery - British Volume. Jan. 2006;88(1):40-3. [pmid: 16365118].
918 Hyldahl H, Regner L, Carlsson L, et al. All-polyethylene vs. metal-backed tibial component in total knee arthroplasty-a randomized RSA study comparing early fixation of horizontally and completely cemented tibial components: part 1. Horizontally cemented components: AP better fixated than MB. Acta Orthopaedica. Dec. 2005;76(6):769-77. [pmid: 16470428].
919 Hyldahl H, Regner L, Carlsson L, et al. All-polyethylene vs. metal-backed tibial component in total knee arthroplasty-a randomized RSA study comparing early fixation of horizontally and completely cemented tibial components: part 2. Completely cemented components: MB not superior to AP components. Acta Orthopaedica. Dec. 2005;76(6):778-84. [pmid: 16470429].
920 Ibrahim SA, Stone RA, Han X, et al. Racial/ethnic differences in surgical outcomes in veterans following knee or hip arthroplasty. Arthritis & Rheumatism. Oct. 2005;52(10):3143-51. [pmid: 16200594].
921 Ike R, O’Rourke KS. Compartment-directed physical examination of the knee can predict articular cartilage abnormalities disclosed by needle arthroscopy. Arthritis Rheum. Jul. 1995;38(7):917-25. [pmid: 7612041].
922 Ike RW, Somers EC, Arnold EL, et al. Ultrasound of the knee during voluntary quadriceps contraction: a technique for detecting otherwise occult effusions. Arthritis Care & Research. May. 2010;62(5):725-9. [pmid: 20461790].
923 Ikejiani CE, Leighton R, Petrie DP. Comparison of patellar resurfacing versus nonresurfacing in total knee arthroplasty. Canadian Journal of Surgery. Feb. 2000;43(1):35-8. [pmid: 10714255].
924 Ikeuchi M, Takahashi T, Tani T. Localized synovial hypertrophy in the anteromedial compartment of the osteoarthritic knee. Arthroscopy. Dec. 2005;21(12):1457-61. [pmid: 16376235].
925 Ilfeld BM, Le LT, Meyer RS, et al. Ambulatory continuous femoral nerve blocks decrease time to discharge readiness after tricompartment total knee arthroplasty: a randomized, triple-masked, placebo-controlled study. Anesthesiology. Apr. 2008;108(4):703-13. [pmid: 18362603].
926 Ilfeld BM, Meyer RS, Le LT, et al. Health-related quality of life after tricompartment knee arthroplasty with and without an extended-duration continuous femoral nerve block: a prospective, 1-year follow-up of a randomized, triple-masked, placebo-controlled study. Anesthesia & Analgesia. 2009;108(4):1320-5. [pmid: 19299806].
927 Im SH, Lee SC, Park YB, et al. Feasibility of sonography for intra-articular injections in the knee through a medial patellar portal. J Ultrasound Med. Nov. 2009;28(11):1465-70. [pmid: 19854960].
928 Imamura M, Imamura ST, Kaziyama HH, et al. Impact of nervous system hyperalgesia on pain, disability, and quality of life in patients with knee osteoarthritis: a controlled analysis. Arthritis Rheum. Oct. 15. 2008;59(10):1424-31. [pmid: 18821657].
929 In Y, Kim J-M, Woo Y-K, et al. Factors affecting flexion gap tightness in cruciate-retaining total knee arthroplasty. Journal of Arthroplasty. Feb. 2009;24(2):317-21. [pmid: 18951761].
930 Inaba Y, Numazaki S, Koshino T, et al. Provoked anterior knee pain in medial osteoarthritis of the knee. Knee. Dec. 2003;10(4):351-5. [pmid: 14629939].
931 Incavo SJ, Coughlin KM, Beynnon BD. Femoral component sizing in total knee arthroplasty: size matched resection versus flexion space balancing. Journal of Arthroplasty. Jun. 2004;19(4):493-7. [pmid: 15188110].
932 Indelli PF, Aglietti P, Buzzi R, et al. The Insall-Burstein II prosthesis: a 5- to 9-year follow-up study in osteoarthritic knees. Journal of Arthroplasty. Aug. 2002;17(5):544-9. [pmid: 12168167].
933 The Therapeutic Effects of Gelatin Hydrogel-Basic Fibroblast Growth Factor System on Experimental Osteoarthritis in the Rabbit Knee. 52nd Annual Meeting of the Orthopaedic Research Society. Lakeside Center, McCormick Place, Chicago, Illinois (USA). 19–22 Mar 2006.
934 The Therapeutic Effects of Gelatin Hydrogel-Basic Fibroblast Growth Factor System on Experimental Osteoarthritis in the Rabbit Knee. 69th Annual Meeting of the American College of Rheumatology and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
935 Inoue S, Nagamine R, Miura H, et al. Anteroposterior weight-bearing radiography of the knee with both knees in semiflexion, using new equipment. J Orthop Sci. 2001;6(6):475-80. [pmid: 11793167].
936 Ip D, Wu WC, Tsang WL. Early results of posterior-stabilised NexGen Legacy total knee arthroplasty. Journal of Orthopaedic Surgery. 2003;11(1):38-42. [pmid: 12810970].
937 Irie K, Uchiyama E, Iwaso H. Intraarticular inflammatory cytokines in acute anterior cruciate ligament injured knee. Knee. Mar. 2003;10(1):93-6. [pmid: 12649034].
938 Irwin KE, Wening JD, Bhatt T, et al. Does knee osteoarthritis alter the neuromuscular responses to a perturbation during single lower limb stance?. Journal of Geriatric Physical Therapy. 2005;28(3):93-101. [pmid: 16386171].
939 Ishii Y, Matsuda Y, Ishii R, et al. Coronal laxity in extension in vivo after total knee arthroplasty. Journal of Orthopaedic Science. 2003;8(4):538-42. [pmid: 12898307].
940 Ishii Y, Noguchi H, Matsuda Y, et al. Preoperative laxity in osteoarthritis patients undergoing total knee arthroplasty. International Orthopaedics. Feb. 2009;33(1):105-9. [pmid: 17938923].
941 Ishii Y, Terajima K, Koga Y, et al. Gait analysis after total knee arthroplasty. Comparison of posterior cruciate retention and substitution. Journal of Orthopaedic Science. 1998;3(6):310-7. [pmid: 9811982].
942 Ismail AI, Al-Abdulwahab AH, Al-Mulhim AS. Osteoarthritis of knees and obesity in Eastern Saudi Arabia. Saudi Medical Journal. Nov. 2006;27(11):1742-4. [pmid: 17106554].
943 Issa SN, Dunlop D, Chang A, et al. Full-limb and knee radiography assessments of varus-valgus alignment and their relationship to osteoarthritis disease features by magnetic resonance imaging. Arthritis Rheum. Apr. 15. 2007;57(3):398-406. [pmid: 17394225].
944 Issack PS, Cottrell JM, Delgado S, et al. Failure at the taper lock of a modular stemmed femoral implant in revision knee arthroplasty. A report of two cases and a retrieval analysis. Journal of Bone & Joint Surgery - American Volume. Oct. 2007;89(10):2271-4. [pmid: 17908906].
945 Ito H, Matsuno T, Minami A. Fixation with poly-L-lactide screws in hip osteotomies. Clinical Orthopaedics & Related Research. 2006;444(Journal Article):169-75. [pmid: 16449915].
946 Itoh K, Hirota S, Katsumi Y, et al. Trigger point acupuncture for treatment of knee osteoarthritis - a preliminary RCT for a pragmatic trial. Acupuncture in Medicine. 2008;26(1):17-26. [pmid: 18356795].
947 Jackson MP, Sexton SA, Walter WL, et al. The impact of obesity on the mid-term outcome of cementless total knee replacement. Journal of Bone & Joint Surgery - British Volume. Aug. 2009;91(8):1044-8. [pmid: 19651831].
948 Jackson WFM, van der Tempel WM, Salmon LJ, et al. Endoscopically-assisted single-bundle posterior cruciate ligament reconstruction: results at minimum ten-year follow-up. Journal of Bone & Joint Surgery - British Volume. Oct. 2008;90(10):1328-33. [pmid: 18827243].
949 Jacobi M, Wahl P, Jakob RP. Avoiding intraoperative complications in open-wedge high tibial valgus osteotomy: technical advancement. Knee Surgery, Sports Traumatology, Arthroscopy. Feb. 2010;18(2):200-3. [pmid: 19784624].
950 Jacobs WCH, Clement DJ, Wymenga AB. Retention versus removal of the posterior cruciate ligament in total knee replacement: a systematic literature review within the Cochrane framework. Acta Orthopaedica. Dec. 2005;76(6):757-68. [pmid: 16470427].
951 Jacquet A, Girodet PO, Pariente A, et al. Phytalgic, a food supplement, vs placebo in patients with osteoarthritis of the knee or hip: a randomised double-blind placebo-controlled clinical trial. Arthritis Research & Therapy. 2009;11(6):R192. [pmid: 20015358].
952 Jaggers JR, Simpson CD, Frost KL, et al. Prehabilitation before knee arthroplasty increases postsurgical function: a case study. Journal of Strength & Conditioning Research. 2007;21(2):632-4. [pmid: 17530958].
953 Jahromi I, Walton NP, Dobson PJ, et al. Patient-perceived outcome measures following unicompartmental knee arthroplasty with mini-incision. International Orthopaedics. Oct. 2004;28(5):286-9. [pmid: 15480659].
954 Jamal OS, Conaghan PG, Cunningham AM, et al. Increased expression of human type IIa secretory phospholipase A2 antigen in arthritic synovium. Ann Rheum Dis. Sep. 1998;57(9):550-8. [pmid: 9849315].
955 Jamali AA, Emmerson BC, Chung C, et al. Fresh osteochondral allografts: results in the patellofemoral joint. Clinical Orthopaedics & Related Research. 2005;(437):176-85. [pmid: 16056047].
956 Effects of a 6-week Tai Chi Exercise Intervention on Gait Kinematics in Knee Osteoarthritic Individuals. 53rd Annual Meeting of the American College of Sports Medicine (ACSM 2006). Denver, Colorado (USA). 31 May–3 Jun 2006.
957 Jamsen E, Nevalainen P, Kalliovalkama J, et al. Preoperative hyperglycemia predicts infected total knee replacement. Eur J Intern Med. Jun. 2010;21(3):196-201. [pmid: 20493422].
958 Jamtvedt G, Dahm KT, Holm I, et al. Measuring physiotherapy performance in patients with osteoarthritis of the knee: a prospective study. BMC Health Serv Res. 2008;8:145. [pmid: 18611250].
959 Jang I, Park J. Can carbon dioxide laser substitute moxibustion?. Lasers in Medical Science. 2009;24(2):290-2. [pmid: 18600289].
960 Jansen CM, Windau JE, Bonutti PM, et al. Treatment of a knee contracture using a knee orthosis incorporating stress-relaxation techniques. Phys Ther. Feb. 1996;76(2):182-6. [pmid: 8592722].
961 Janssen I, Mark AE. Separate and combined influence of body mass index and waist circumference on arthritis and knee osteoarthritis. Int J Obes (Lond). Aug. 2006;30(8):1223-8. [pmid: 16520810].
962 Jarvela T, Paakkala T, Jarvela K, et al. Graft placement after the anterior cruciate ligament reconstruction: a new method to evaluate the femoral and tibial placements of the graft. Knee. Oct. 2001;8(3):219-27. [pmid: 11706730].
963 Jarvenpaa J, Kettunen J, Kroger H, et al. Obesity may impair the early outcome of total knee arthroplasty. Scandinavian Journal of Surgery: SJS. 2010;99(1):45-9. [pmid: 20501358].
964 Javaid MK, Lynch JA, Tolstykh I, et al. Pre-radiographic MRI findings are associated with onset of knee symptoms: the most study. Osteoarthritis Cartilage. Mar. 2010;18(3):323-8. [pmid: 19919856].
965 Jay GD, Elsaid KA, Zack J, et al. Lubricating ability of aspirated synovial fluid from emergency department patients with knee joint synovitis. Journal of Rheumatology. Mar. 2004;31(3):557-64. [pmid: 14994405].
966 Jazrawi L, Sherman O, Hunt S. Arthroscopic management of osteoarthritis of the knee. Journal of the American Academy of Orthopaedic Surgeons. Jul–Aug. 2003;11(4):290. [pmid: 12921088].
967 Jenkins C, Barker KL, Pandit H, et al. After partial knee replacement, patients can kneel, but they need to be taught to do so: a single-blind randomized controlled trial. Physical Therapy. 2008;88(9):1012-21. [pmid: 18635671].
968 Jenkyn TR, Hunt Jones IC, et al. Toe-out gait in patients with knee osteoarthritis partially transforms, external knee adduction moment into flexion moment during early instance phase of gait: A tri-planar kinetic mechanism. Journal of Biomechanics. 2008;41(2):276-83. [pmid: 18061197].
969 Jette AM, McDonough CM, Ni P, et al. A functional difficulty and functional pain instrument for hip and knee osteoarthritis. Arthritis Research & Therapy. 2009;11(4):R107. [pmid: 19589168].
970 Jevsevar DS, Riley PO, Hodge WA, et al. Knee kinematics and kinetics during locomotor activities of daily living in subjects with knee arthroplasty and in healthy control subjects. Phys Ther. Apr. 1993;73(4):229-39. discussion 40–2. [pmid: 8456142].
971 Jiang A, Zhang L, Zhao C, et al. Clinical effect of acupuncture treatment in 109 cases of knee osteoarthritis. Journal of Traditional Chinese Medicine. 2001;21(4):282-5. [pmid: 12014131].
972 Jiang CC, Liu YJ, Yip KM, et al. Physiological patellofemoral crepitus in knee joint disorders. Bulletin of the Hospital for Joint Diseases. 1993;53(4):22-6. [pmid: 8829591].
973 Jinks C, Jordan K, Croft P. Measuring the population impact of knee pain and disability with the Western Ontario and McMaster Universities Osteoarthritis Index (WOMAC). Pain. Nov. 2002;100(1–2):55-64. [pmid: 12435459].
974 Jinks C, Jordan K, Croft P. Disabling knee pain--another consequence of obesity: results from a prospective cohort study. BMC Public Health. 2006;6:258. [pmid: 17052337].
975 Jinks C, Jordan K, Croft P. Osteoarthritis as a public health problem: the impact of developing knee pain on physical function in adults living in the community: (KNEST 3). Rheumatology. 2007;46(5):877-81. [pmid: 17308312].
976 Jinks C, Lewis M, Croft P. Health status after hip or knee arthroplasty. Annals of the Rheumatic Diseases. Aug. 2003;62(8):700-1. [pmid: 12860721].
977 Jinks C, Ong BN, Richardson J. A mixed methods study to investigate needs assessment for knee pain and disability: population and individual perspectives. BMC Musculoskeletal Disorders. 2007;8(Journal Article):59. [pmid: 17610732].
978 Johnson JE. Patient education and self-advocacy. Managing pain in osteoarthritis. J Pain Palliat Care Pharmacother. 2009;23(2):171-3. [pmid: 19492221].
979 Jokhio IA, Siddiqui KA, Waraich T, et al. Study of efficacy and tolerance of ketoprofen and diclofenac sodium in the treatment of acute rheumatic and traumatic conditions. JPMA - Journal of the Pakistan Medical Association. Dec. 1998;48(12):373-6. [pmid: 10531772].
980 Jones AC, Kwoh CK, Groeneveld PW, et al. Investigating racial differences in coping with chronic osteoarthritis pain. J Cross Cult Gerontol. Dec. 2008;23(4):339-47. [pmid: 18561011].
981 Jones AC, Ledingham J, McAlindon T, et al. Radiographic assessment of patellofemoral osteoarthritis. Ann Rheum Dis. Sep. 1993;52(9):655-8. [pmid: 8239760].
982 Jones CA, Voaklander DC, Suarez-Alma ME. Determinants of function after total knee arthroplasty. Physical Therapy. 2003;83(8):696-706. [pmid: 12882610].
983 Jones DPG, Locke C, Pennington J, et al. The effect of sagittal laxity on function after posterior cruciate-retaining total knee replacement. Journal of Arthroplasty. Aug. 2006;21(5):719-23. [pmid: 16877159].
984 Jones JP, Bae YK. Ultrasonia imaging, characterization, and stimluation of acupuncture points. Journal of Alternative & Complementary Medicine. 2004;10(1):202-3.
985 Jonsson H, Riklund-Ahlstrom K, Lind J. Positive pivot shift after ACL reconstruction predicts later osteoarthrosis: 63 patients followed 5–9 years after surgery. Acta Orthopaedica Scandinavica. Oct. 2004;75(5):594-9. [pmid: 15513493].
986 Jordan LR, Dowd JE, Olivo JL, et al. The clinical history of mobile-bearing patella components in total knee arthroplasty. Orthopedics. Feb. 2002;25(2 Suppl):s247-50. [pmid: 11866161].
987 Jorgensen A, Stengaard-Pedersen K, Simonsen O, et al. Intra-articular hyaluronan is without clinical effect in knee osteoarthritis: a multicentre, randomised, placebo-controlled, double-blind study of 337 patients followed for 1 year. Annals of the Rheumatic Diseases. Jun. 2010;69(6):1097-102. [pmid: 20447955].
988 Joshi AB, Gill G. Total knee arthroplasty in nonagenarians. Journal of Arthroplasty. Sep. 2002;17(6):681-4. [pmid: 12216019].
989 Joshy S, Datta A, Perera A, et al. Ethnic differences in preoperative function of patients undergoing total knee arthroplasty. International Orthopaedics. Oct. 2006;30(5):426-8. [pmid: 16622668].
990 Jubb RW, Piva S, Beinat L, et al. A one-year, randomised, placebo (saline) controlled clinical trial of 500–730 kDa sodium hyaluronate (Hyalgan) on the radiological change in osteoarthritis of the knee. International Journal of Clinical Practice. Jul–Aug. 2003;57(6):467-74. [pmid: 12918884].
991 Jubb RW, Tukmachi ES, Jones PW, et al. A blinded randomised trial of acupuncture (manual and electroacupuncture) compared with a non-penetrating sham for the symptoms of osteoarthritis of the knee. AcupunctMed. 2008;26(2):69-78. [pmid: 18591906].
992 Jung M, Christgau S, Lukoschek M, et al. Increased urinary concentration of collagen type II C-telopeptide fragments in patients with osteoarthritis. Pathobiology. 2004;71(2):70-6. [pmid: 14707441].
993 Jung YB, Roh KJ, Jung JA, et al. Effect of SKI 306X, a new herbal anti-arthritic agent, in patients with osteoarthritis of the knee: a double-blind placebo controlled study. American Journal of Chinese Medicine. 2001;29(3–4):485-91. [pmid: 11789591].
994 Juni P, Reichenbach S, Trelle S, et al. Efficacy and safety of intraarticular hylan or hyaluronic acids for osteoarthritis of the knee: a randomized controlled trial. Arthritis & Rheumatism. Nov. 2007;56(11):3610-9. [pmid: 17968921].
995 Juosponis R, Tarasevicius S, Smailys A, et al. Functional and radiological outcome after total knee replacement performed with mini-midvastus or conventional arthrotomy: controlled randomised trial. International Orthopaedics. Oct. 2009;33(5):1233-7. [pmid: 18654774].
996 Kacar C, Gilgil E, Urhan S, et al. The prevalence of symptomatic knee and distal interphalangeal joint osteoarthritis in the urban population of Antalya, Turkey. Rheumatology International. Apr. 2005;25(3):201-4. [pmid: 14661112].
997 Kadoya Y, Kobayashi A, Komatsu T, et al. Effects of posterior cruciate ligament resection on the tibiofemoral joint gap. Clinical Orthopaedics & Related Research. Oct. 2001;(391):210-7. [pmid: 11603671].
998 Kahan A, Lleu P-L, Salin L. Prospective randomized study comparing the medicoeconomic benefits of Hylan GF-20 vs. conventional treatment in knee osteoarthritis. Joint, Bone, Spine: Revue du Rhumatisme. Aug. 2003;70(4):276-81. [pmid: 12951310].
999 Kahan A, Uebelhart D, De Vathaire F, et al. Long-term effects of chondroitins 4 and 6 sulfate on knee osteoarthritis: the study on osteoarthritis progression prevention, a two-year, randomized, double-blind, placebo-controlled trial. Arthritis & Rheumatism. Feb. 2009;60(2):524-33. [pmid: 19180484].
1000 Kakihana W, Akai M, Nakazawa K, et al. Effects of laterally wedged insoles on knee and subtalar joint moments. Archives of Physical Medicine & Rehabilitation. 2005;86(7):1465-71. [pmid: 16003682].
1001 Kalula SZ, Swingler GH, Sayer AA, et al. Does chair type influence outcome in the timed “Up and Go” test in older persons?. Journal of Nutrition, Health & Aging. 2010;14(4):319-23. [pmid: 20306006].
1002 Kalunian KC, Moreland LW, Klashman DJ, et al. Visually-guided irrigation in patients with early knee osteoarthritis: a multicenter randomized, controlled trial. Osteoarthritis & Cartilage. 2000;8(6):412-8. [pmid: 11069725].
1003 Kantz ME, Harris WJ, Levitsky K, et al. Methods for assessing condition-specific and generic functional status outcomes after total knee replacement. Med Care. May. 1992;30(5 Suppl):MS240-52. [pmid: 1583936].
1004 Kapetanakis S, Drygiannakis I, Kazakos K, et al. Serum TGF-beta2 and TGF-beta3 are increased and positively correlated to pain, functionality, and radiographic staging in osteoarthritis. Orthopedics. Aug. 2010;33(8). [pmid: 20704110].
1005 Kaplan LD, Ionescu D, Ernsthausen JM, et al. Temperature requirements for altering the morphology of osteoarthritic and nonarthritic articular cartilage: in vitro thermal alteration of articular cartilage. American Journal of Sports Medicine. Apr–May. 2004;32(3):688-92. [pmid: 15090386].
1006 Karachalios T, Giotikas D, Roidis N, et al. Total knee replacement performed with either a mini-midvastus or a standard approach: a prospective randomised clinical and radiological trial. Journal of Bone & Joint Surgery - British Volume. May. 2008;90(5):584-91. [pmid: 18450623].
1007 Karamanlioglu B, Alagol A, Turan FN. Preemptive oral rofecoxib plus postoperative intraarticular bupivacaine for pain relief after arthroscopic knee surgery. Agri Dergisi. Apr. 2005;17(2):29-33. [pmid: 15977092].
1008 Karatay S, Kiziltunc A, Yildirim K, et al. Effects of different hyaluronic acid products on synovial fluid levels of intercellular adhesion molecule-1 and vascular cell adhesion molecule-1 in knee osteoarthritis. Annals of Clinical & Laboratory Science. 2004;34(3):330-5. [pmid: 15487709].
1009 Karatay S, Kiziltunc A, Yildirim K, et al. Effects of different hyaluronic acid products on synovial fluid NO levels in knee osteoarthritis. Clin Rheumatol. Sep. 2005;24(5):497-501. [pmid: 15906109].
1010 Karatosun V, Unver B, Gocen Z, et al. Comparison of two hyaluronan drugs in patients with advanced osteoarthritis of the knee. A prospective, randomized, double-blind study with long term follow-up. Clinical & Experimental Rheumatology. Mar–Apr. 2005;23(2):213-8. [pmid: 15895892].
1011 Karbowski A, Schwitalle M, Eckardt A, et al. Periprosthetic bone remodelling after total knee arthroplasty: early assessment by dual energy X-ray absorptiometry. Archives of Orthopaedic & Trauma Surgery. 1999;119(5–6):324-6. [pmid: 10447632].
1012 Karjalainen Kaija A, Malmivaara A, van Tulder Maurits W, et al. Multidisciplinary biopsychosocial rehabilitation for subacute low-back pain among working age adults, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2003.
1013 Karlsson J, Pivodic A, Aguirre D, et al. Efficacy, safety, and tolerability of the cyclooxygenase-inhibiting nitric oxide donator naproxcinod in treating osteoarthritis of the hip or knee. Journal of Rheumatology. Jun. 2009;36(6):1290-7. [pmid: 19411388].
1014 Karlsson M, Berggren AC. Efficacy and safety of low-dose transdermal buprenorphine patches (5, 10, and 20 microg/h) versus prolonged-release tramadol tablets (75, 100, 150, and 200 mg) in patients with chronic osteoarthritis pain: a 12-week, randomized, open-label, controlled, parallel-group noninferiority study. Clinical Therapeutics. Mar. 2009;31(3):503-13. [pmid: 19393841].
1015 Karpman RR, Smith HL. Comparison of the early results of minimally invasive vs standard approaches to total knee arthroplasty: a prospective, randomized study. Journal of Arthroplasty. Aug. 2009;24(5):681-8. [pmid: 18538536].
1016 Kashyap SN, van Ommeren JW. Clinical experience with less invasive surgery techniques in total knee arthroplasty: a comparative study. Knee Surgery, Sports Traumatology, Arthroscopy. Jun. 2008;16(6):544-8. [pmid: 18365178].
1017 Katsnelson Y, Khokhlov A, Tsvetkov V, et al. Temporary pain relief using transcranial electrotherapy stimulation: results of a randomized, double-blind pilot study. Conf Proc IEEE Eng Med Biol Soc. 2004;6:4087-90. [pmid: 17271198].
1018 Katz JN, Barrett J, Liang MH, et al. Sensitivity and positive predictive value of Medicare Part B physician claims for rheumatologic diagnoses and procedures. Arthritis Rheum. Sep. 1997;40(9):1594-600. [pmid: 9324013].
1019 Katz JN, Harris TM, Larson MG, et al. Predictors of functional outcomes after arthroscopic partial meniscectomy. J Rheumatol. Dec. 1992;19(12):1938-42. [pmid: 1294743].
1020 Katz JN, Mahomed NN, Baron JA, et al. Association of hospital and surgeon procedure volume with patient-centered outcomes of total knee replacement in a population-based cohort of patients age 65 years and older. Arthritis Rheum. Feb. 2007;56(2):568-74. [pmid: 17265491].
1021 Katz JN, Meredith DS, Lang P, et al. Associations among preoperative MRI features and functional status following arthroscopic partial meniscectomy. Osteoarthritis & Cartilage. May. 2006;14(5):418-22. [pmid: 16413210].
1022 Katz N, Sun S, Johnson F, et al. ALO-01 (morphine sulfate and naltrexone hydrochloride) extended-release capsules in the treatment of chronic pain of osteoarthritis of the hip or knee: pharmacokinetics, efficacy, and safety. Journal of Pain. Apr. 2010;11(4):303-11. [pmid: 19944650].
1023 Kaufmann KR, Huges C, Morrey BF, et al. Gait characteristics of patients with knee osteoarthritis. Journal of Biomechanics. 2001;34(7):907-15. [pmid: 11410174].
1024 Kavadas V, Newman JH. Resource implications of a knee referral. Knee. 2002;9(4):281-3. [pmid: 12424035].
1025 Kawahara Y, Uetani M, Nakahara N, et al. Fast spin-echo MR of the articular cartilage in the osteoarthrotic knee. Correlation of MR and arthroscopic findings. Acta Radiologica. Mar. 1998;39(2):120-5. [pmid: 9529440].
1026 Kawakami H, Sugano N, Yonenobu K, et al. Gait analysis system for assessment of dynamic loading axis of the knee. Gait and Posture. 2005;21(1):125-30. [pmid: 15536041].
1027 Kawakami H, Sugano N, Yonenobu K, et al. Change in the locus of dynamic loading axis on the knee joint after high tibial osteotomy. Gait & Posture. Apr. 2005;21(3):271-8. [pmid: 15760742].
1028 Kazakos KJ, Chatzipapas C, Verettas D, et al. Mid-term results of total knee arthroplasty after high tibial osteotomy. Archives of Orthopaedic & Trauma Surgery. Feb. 2008;128(2):167-73. [pmid: 18008079].
1029 Resistance Training in Patients with Medial Compartment Knee Osteoarthritis and Malalignment. 55th Annual Meeting on American College of Sports Medicine. Indianapolis, Indiana (USA). 28–31 May 2008.
1030 Kean CO, Birmingham TB, Garland JS, et al. Moments and muscle activity after high tibial osteotomy and anterior cruciate ligament reconstruction. Medicine & Science in Sports & Exercise. Mar. 2009;41(3):612-9. [pmid: 19204589].
1031 Keays SL, Newcombe PA, Bullock-Saxton JE, et al. Factors involved in the development of osteoarthritis after anterior cruciate ligament surgery. American Journal of Sports Medicine. Mar. 2010;38(3):455-63. [pmid: 20051501].
1032 Keefe FJ, Caldwell DS, Baucom D, et al. Spouse-assisted coping skills training in the management of knee pain in osteoarthritis: long-term followup results. Arthritis Care Res. Apr. 1999;12(2):101-11. [pmid: 10513498].
1033 Keefe FJ, Lefebvre JC, Egert JR, et al. The relationship of gender to pain, pain behavior, and disability in osteoarthritis patients: the role of catastrophizing. Pain. Sep. 2000;87(3):325-34. [pmid: 10963912].
1034 Keene G, Simpson D, Kalairajah Y. Limb alignment in computer-assisted minimally-invasive unicompartmental knee replacement. Journal of Bone & Joint Surgery - British Volume. Jan. 2006;88(1):44-8. [pmid: 16365119].
1035 Keene JS, Monson DK, Roberts JM, et al. Evaluation of patients for high tibial osteotomy. Clin Orthop Relat Res. Jun. 1989;(243):157-65. [pmid: 2721055].
1036 Kelley Fitzgerald G, Irrgang JJ, Piva SR. Reports of joint instability in knee osteoarthritis: Its prevalence and relationship to physical function. Arthritis Care and Research. 2004;51(6):941-6. [pmid: 15593258].
1037 Kelly AM. Managing osteoarthritis pain. Nursing. Nov. 2006;36(11):20-1. [pmid: 17079898].
1038 Kelly MA. Role of arthroscopic debridement in the arthritic knee. Journal of Arthroplasty. 2006;21(4 Suppl 1):9-10. [pmid: 16781419].
1039 Kelly MA, Kurzweil PR, Lewallen DG, et al. New therapeutic options for managing the arthritic knee. American Journal of Orthopedics (Chatham, Nj). Feb. 2004;33(2 Suppl):35-9. [pmid: 15005299].
1040 Kendrick BJL, Longino D, Pandit H, et al. Polyethylene wear in Oxford unicompartmental knee replacement: a retrieval study of 47 bearings. Journal of Bone & Joint Surgery - British Volume. Mar. 2010;92(3):367-73. [pmid: 20190307].
1041 Kennedy DM, Hanna SE, Stratford PW, et al. Preoperative function and gender predict pattern of functional recovery after hip and knee arthroplasty. J Arthroplasty. Jun. 2006;21(4):559-66. [pmid: 16781410].
1042 Kennedy DM, Stratford PW, Hanna SE, et al. Modeling early recovery of physical function following hip and knee arthroplasty. BMC Musculoskelet Disord. 2006;7:100. [pmid: 17156487].
1043 Kennedy DM, Stratford PW, Riddle DL, et al. Assessing recovery and establishing prognosis following total knee arthroplasty. Physical Therapy. 2008;88(1):22-32. [pmid: 17986495].
1044 Kenny C. Radial displacement of the medial meniscus and Fairbank’s signs. Clin Orthop Relat Res. Jun. 1997;(339):163-73. [pmid: 9186215].
1045 The Efficacy of Open and Closed Kinetic Chain Exercises on Pain, Function, Strength and Joint Position Sense in Osteoarthritis of the Knee: A Blinded Randomized Controlled Trial. 70th Annual Meeting of the American College of Rheumatology and the 41st Annual Meeting of the Association of Rheumatology Health Professionals (ACR/ARHP 2006). Washington Convention Center, Washington DC (USA). 10–15 Nov 2006.
1046 Kerimoglu U, Hayran M, Ergen FB, et al. Sonographic evaluation of entheseal sites of the lower extremity in patients undergoing hemodialysis. Journal of Clinical Ultrasound. Oct. 2007;35(8):417-23. [pmid: 17663458].
1047 Kerkhoffs Gino MMJ, Struijs Peter AA, Marti Rene K, et al. Different functional treatment strategies for acute lateral ankle ligament injuries in adults, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2002.
1048 Kerrigan DC, Johansson JL, Bryant MG, et al. Moderate-heeled shoes and knee joint torques relevant to the development and progression of knee osteoarthritis. Archives of Physical Medicine and Rehabilitation. 2005;86(5):871-5. [pmid: 15895330].
1049 Kessler MA, Behrend H, Henz S, et al. Function, osteoarthritis and activity after ACL-rupture: 11 years follow-up results of conservative versus reconstructive treatment. Knee Surgery, Sports Traumatology, Arthroscopy. May. 2008;16(5):442-8. [pmid: 18292988].
1050 Kessler S, Guenther KP, Puhl W. Scoring prevalence and severity in gonarthritis: the suitability of the Kellgren & Lawrence scale. Clin Rheumatol. 1998;17(3):205-9. [pmid: 9694053].
1051 Kettunen JA, Kujala UM, Raty H, et al. Jumping height in former elite athletes. Eur J Appl Physiol Occup Physiol. Jan. 1999;79(2):197-201. [pmid: 10029342].
1052 Keysor JJ, Jette AM, LaValley MP, et al. Community environmental factors are associated with disability in older adults with functional limitations: the MOST study. J Gerontol A Biol Sci Med Sci. Apr. 2010;65(4):393-9. [pmid: 19995830].
1053 Khan AM, McLoughlin E, Giannakas K, et al. Hip osteoarthritis: where is the pain?. Annals of the Royal College of Surgeons of England. Mar. 2004;86(2):119-21. [pmid: 15005931].
1054 Khan FA, Koff MF, Noiseux NO, et al. Effect of local alignment on compartmental patterns of knee osteoarthritis. Journal of Bone & Joint Surgery - American Volume. Sep. 2008;90(9):1961-9. [pmid: 18762657].
1055 Khaw FM, Kirk LMG, Morris RW, et al. A randomised, controlled trial of cemented versus cementless press-fit condylar total knee replacement. Ten-year survival analysis. Journal of Bone & Joint Surgery - British Volume. Jul. 2002;84(5):658-66. [pmid: 12188480].
1056 Kijowski R, Blankenbaker D, Stanton P, et al. Correlation between radiographic findings of osteoarthritis and arthroscopic findings of articular cartilage degeneration within the patellofemoral joint. Skeletal Radiology. Dec. 2006;35(12):895-902. [pmid: 16680465].
1057 Kijowski R, Blankenbaker DG, Davis KW, et al. Comparison of 1.5- and 3.0-T MR imaging for evaluating the articular cartilage of the knee joint. Radiology. Mar. 2009;250(3):839-48. [pmid: 19164121].
1058 Kijowski R, Blankenbaker DG, Stanton PT, et al. Radiographic findings of osteoarthritis versus arthroscopic findings of articular cartilage degeneration in the tibiofemoral joint. Radiology. Jun. 2006;239(3):818-24. [pmid: 16641340].
1059 Kim H-J, Lee H-M, Kim H-S, et al. Bone metabolism in postmenopausal women with lumbar spinal stenosis: analysis of bone mineral density and bone turnover markers. Spine. Oct. 15. 2008;33(22):2435-9. [pmid: 18923320].
1060 Kim HR, So Y, Moon SG, et al. Clinical value of (99m)Tc-methylene diphosphonate (MDP) bone single photon emission computed tomography (SPECT) in patients with knee osteoarthritis. Osteoarthritis Cartilage. Feb. 2008;16(2):212-8. [pmid: 17662626].
1061 Kim J, Lee EY, Koh E-M, et al. Comparative clinical trial of S-adenosylmethionine versus nabumetone for the treatment of knee osteoarthritis: an 8-week, multicenter, randomized, double-blind, double-dummy, Phase IV study in Korean patients. Clinical Therapeutics. Dec. 2009;31(12):2860-72. [pmid: 20110025].
1062 Kim KJ, Iwase M, Kotake S, et al. Effect of bone marrow grafting on the titanium porous-coated implant in bilateral total knee arthroplasty. Acta Orthopaedica. Feb. 2007;78(1):116-22. [pmid: 17453402].
1063 Kim KT, Lee S, Park HS, et al. A prospective analysis of Oxford phase 3 unicompartmental knee arthroplasty. Orthopedics. May. 2007;30(5 Suppl):15-8. [pmid: 17549860].
1064 Kim LS, Axelrod LJ, Howard P, et al. Efficacy of methylsulfonylmethane (MSM) in osteoarthritis pain of the knee: a pilot clinical trial. Osteoarthritis Cartilage. Mar. 2006;14(3):286-94. [pmid: 16309928].
1065 The Efficacy of Low Power Laser Therapy in Patients with Knee Osteoarthritis. 2006 Annual European Congress of Rheumatology (EULAR 2006). Amsterdam (Netherlands (The)). 21–24 Jun 2006.
1066 Kim S-J, Koh Y-G, Chun Y-M, et al. Medial opening wedge high-tibial osteotomy using a kinematic navigation system versus a conventional method: a 1-year retrospective, comparative study. Knee Surgery, Sports Traumatology, Arthroscopy. Feb. 2009;17(2):128-34. [pmid: 18850089].
1067 Kim TH, Lee DH, Bin SI. The NexGen LPS-flex to the knee prosthesis at a minimum of three years. Journal of Bone & Joint Surgery - British Volume. Oct. 2008;90(10):1304-10. [pmid: 18827239].
1068 Kim TK, Chang CB, Kang YG, et al. Causes and predictors of patient’s dissatisfaction after uncomplicated total knee arthroplasty. Journal of Arthroplasty. Feb. 2009;24(2):263-71. [pmid: 18534422].
1069 Kim TK, Kwon SK, Kang YG, et al. Functional disabilities and satisfaction after total knee arthroplasty in female Asian patients. Journal of Arthroplasty. Apr. 2010;25(3):458-64. e1. 2. [pmid: 19251391].
1070 Kim WY, Jari S. Intra-operative findings in varus osteoarthritis of the knee. Journal of Bone & Joint Surgery - British Volume. Feb. 2005;87(2):277-8. author reply 8. [pmid: 15736758].
1071 Kim YH, Choi Y, Kim JS. Comparison of standard and gender-specific posterior-cruciate-retaining high-flexion total knee replacements: a prospective, randomised study. Journal of Bone & Joint Surgery - British Volume. May. 2010;92(5):639-45. [pmid: 20435999].
1072 Kim YH, Choi YW, Kim JS. Simultaneous bilateral sequential total knee replacement is as safe as unilateral total knee replacement. Journal of Bone & Joint Surgery - British Volume. Jan. 2009;91(1):64-8. [pmid: 19092006].
1073 Kim YH, Kim DY, Kim JS. Simultaneous mobile- and fixed-bearing total knee replacement in the same patients. A prospective comparison of mid-term outcomes using a similar design of prosthesis. Journal of Bone & Joint Surgery - British Volume. Jul. 2007;89(7):904-10. [pmid: 17673583].
1074 Kim YH, Kim JS. Total knee replacement for patients with ankylosed knees. Journal of Bone & Joint Surgery - British Volume. 2008;90(10):1311-6. [pmid: 18827240].
1075 Kim YH, Kim JS. Does TKA improve functional outcome and range of motion in patients with stiff knees? Clinical Orthopaedics &. Related Research. 2009;467(5):1348-54. [pmid: 18712582].
1076 Kim YH, Kook HK, Kim JS. Comparison of fixed-bearing and mobile-bearing total knee arthroplasties. Clinical Orthopaedics & Related Research. 2001;(392):101-15. [pmid: 11716371].
1077 Kim YH, Yoon SH, Kim JS. Early outcome of TKA with a medial pivot fixed-bearing prosthesis is worse than with a PFC mobile-bearing prosthesis. Clinical Orthopaedics & Related Research. 2009;467(2):493-503. [pmid: 18465188].
1078 Kim Y-H, Choi Y, Kim JS. Range of motion of standard and high-flexion posterior cruciate-retaining total knee prostheses a prospective randomized study. Journal of Bone & Joint Surgery - American Volume. Aug. 2009;91(8):1874-81. [pmid: 19651944].
1079 Kim Y-H, Choi Y, Kwon O-R, et al. Functional outcome and range of motion of high-flexion posterior cruciate-retaining and high-flexion posterior cruciate-substituting total knee prostheses. A prospective, randomized study. Journal of Bone & Joint Surgery - American Volume. Apr. 2009;91(4):753-60. [pmid: 19339558].
1080 Kim Y-H, Kim J-S, Hong K-S, et al. Prevalence of fat embolism after total knee arthroplasty performed with or without computer navigation. Journal of Bone & Joint Surgery - American Volume. Jan. 2008;90(1):123-8. [pmid: 18171966].
1081 Kim Y-H, Sohn K-S, Kim JS. Range of motion of standard and high-flexion posterior stabilized total knee prostheses. A prospective, randomized study. Journal of Bone & Joint Surgery - American Volume. Jul. 2005;87(7):1470-5. [pmid: 15995113].
1082 Kinzel V, Shakespeare D, Derbyshire D. The effect of aprotinin on blood loss in bilateral total knee arthroplasty. Knee. Apr. 2005;12(2):107-11. [pmid: 15749445].
1083 Kirchner M, Marshall D. A double-blind randomized controlled trial comparing alternate forms of high molecular weight hyaluronan for the treatment of osteoarthritis of the knee. Osteoarthritis & Cartilage. Feb. 2006;14(2):154-62. [pmid: 16242361].
1084 Kirkhorn S, Greenlee RT, Reeser JC. The epidemiology of agriculture-related osteoarthritis and its impact on occupational disability. WMJ. 2003;102(7):38-44. [pmid: 14711023].
1085 Kirkley A, Birmingham TB, Litchfield RB, et al. A randomized trial of arthroscopic surgery for osteoarthritis of the knee. New England Journal of Medicine. Sep. 11. 2008;359(11):1097-107. [pmid: 18784099].
1086 Kirschner S, Walther M, Bohm D, et al. German short musculoskeletal function assessment questionnaire (SMFA-D): comparison with the SF-36 and WOMAC in a prospective evaluation in patients with primary osteoarthritis undergoing total knee arthroplasty. Rheumatology International. Jan. 2003;23(1):15-20. [pmid: 12548437].
1087 Kirwan JR, Elson CJ. Is the progression of osteoarthritis phasic? Evidence and implications. Journal of Rheumatology. Apr. 2000;27(4):834-6. [pmid: 10782803].
1088 Kito N, Shinkoda K, Yamasaki T, et al. Contribution of knee adduction moment impulse to pain and disability in Japanese women with medial knee osteoarthritis. Clin Biomech (Bristol, Avon). Nov. 2010;25(9):914-9. [pmid: 20650554].
1089 Kiviranta P, Lammentausta E, Toyras J, et al. Indentation diagnostics of cartilage degeneration. Osteoarthritis Cartilage. Jul. 2008;16(7):796-804. [pmid: 18222712].
1090 A Randomized, Open-Label Study Comparing the Efficacy and Safety of Lidocaine Patch 5% with Celecoxib 200 mg in Patients with Pain from Osteoarthritis of the Knee. 69th Annual Meeting of the American College of Rheumatology and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
1091 Kivitz A, Fairfax M, Sheldon EA, et al. Comparison of the effectiveness and tolerability of lidocaine patch 5% versus celecoxib for osteoarthritis-related knee pain: post hoc analysis of a 12 week, prospective, randomized, active-controlled, open-label, parallel-group trial in adults. Clinical Therapeutics. Dec. 2008;30(12):2366-77. [pmid: 19167595].
1092 Kivitz A, Ma C, Ahdieh H, et al. A 2-week, multicenter, randomized, double-blind, placebo-controlled, dose-ranging, phase III trial comparing the efficacy of oxymorphone extended release and placebo in adults with pain associated with osteoarthritis of the hip or knee. Clinical Therapeutics. Mar. 2006;28(3):352-64. [pmid: 16750450].
1093 Janu Basti an Ayurvedic therapy in Osteoarthritis of the Knee. 136th American Public Health Association Annual Meeting and Exposition (APHA 2008). San Diego, California (USA). 25–29 Oct 2008.
1094 Kleiner JB, Thorne RP, Curd JG. The value of bupivicaine hip injection in the differentiation of coxarthrosis from lower extremity neuropathy. J Rheumatol. Mar. 1991;18(3):422-7. [pmid: 1856810].
1095 Klussmann A, Gebhardt H, Liebers F, et al. Individual and occupational risk factors for knee osteoarthritis - study protocol of a case control study. BMC Musculoskeletal Disorders. 2008;9(Journal Article):26. [pmid: 18302740].
1096 Knorth H, Dorfmuller P, Lebert R, et al. Participation of cyclooxygenase-1 in prostaglandin E2 release from synovitis tissue in primary osteoarthritis in vitro. Osteoarthritis Cartilage. Aug. 2004;12(8):658-66. [pmid: 15262246].
1097 Knutsen G, Engebretsen L, Ludvigsen TC, et al. Autologous chondrocyte implantation compared with microfracture in the knee. A randomized trial. Journal of Bone & Joint Surgery - American Volume. Mar. 2004;86-A(3):455-64. [pmid: 14996869].
1098 Ko Y, Lo NN, Yeo SJ, et al. Rasch analysis of the Oxford Knee Score. Osteoarthritis Cartilage. Sep. 2009;17(9):1163-9. [pmid: 19409293].
1099 Kobayashi M, Toguchida J, Oka M. Development of an artificial meniscus using polyvinyl alcohol-hydrogel for early return to, and continuance of, athletic life in sportspersons with severe meniscus injury. II: animal experiments. Knee. Mar. 2003;10(1):53. [pmid: 12649027].
1100 Kocak FU, Unver B, Karatosun V, et al. Associations between radiographic changes and function, pain, range of motion, muscle strength and knee function score in patients with osteoarthritis of the knee. Journal of Physical Therapy Science. 2009;21(1):93-7.
1101 Kodkani PS. Dome osteotomy of the proximal tibia for genu varum treated with a new fixation device. The Journal of Knee Surgery. Apr. 2007;20(2):111-9. [pmid: 17486902].
1102 Koeck FX, Perlick L, Luring C, et al. Leg axis correction with ConforMIS iForma (interpositional device) in unicompartmental arthritis of the knee. International Orthopaedics. Aug. 2009;33(4):955-60. [pmid: 18563412].
1103 Koelling S, Kruegel J, Klinger M, et al. Collagen IX in weight-bearing areas of human articular cartilage in late stages of osteoarthritis. Archives of Orthopaedic & Trauma Surgery. Dec. 2008;128(12):1453-9. [pmid: 18357462].
1104 Koga H, Shimaya M, Muneta T, et al. Local adherent technique for transplanting mesenchymal stem cells as a potential treatment of cartilage defect. Arthritis Research & Therapy. 2008;10(4):R84. [pmid: 18664254].
1105 Kohn D, Aagaard H, Verdonk R, et al. Postoperative follow-up and rehabilitation after meniscus replacement. Scandinavian journal of medicine & science in sports. 1999;9(3):177-80. [pmid: 10380276].
1106 Kolarz G, Kotz R, Hochmayer I. Long-term benefits and repeated treatment cycles of intra-articular sodium hyaluronate (Hyalgan) in patients with osteoarthritis of the knee. Seminars in Arthritis & Rheumatism. Apr. 2003;32(5):310-9. [pmid: 12701041].
1107 Kolasinski SL, Garfinkel M, Tsai AG, et al. Iyengar yoga for treating symptoms of osteoarthritis of the knees: a pilot study. Journal of Alternative & Complementary Medicine. Aug. 2005;11(4):689-93. [pmid: 16131293].
1108 Kolisek FR, Gilmore KJ, Peterson EK. Slide and flex, tighten, extend (SAFTE): a safe, convenient, effective, and no-cost approach to rehabilitation after total knee arthroplasty. J Arthroplasty. Dec. 2000;15(8):1013-6. [pmid: 11112197].
1109 Kolisek FR, Mont MA, Seyler TM, et al. Total knee arthroplasty using cementless keels and cemented tibial trays: 10-year results. International Orthopaedics. Feb. 2009;33(1):117-21. [pmid: 18185931].
1110 Komatsu T, Kim KJ, Kaminai T, et al. Clinical factors as predictors of the risk of falls and subsequent bone fractures due to osteoporosis in postmenopausal women. J Bone Miner Metab. 2006;24(5):419-24. [pmid: 16937276].
1111 Komistek RD, Dennis DA, Northcut EJ, et al. An in vivo analysis of the effectiveness of the osteoarthritic knee brace during heel-strike of gait. Journal of Arthroplasty. 1999;14(6):738-42. [pmid: 10512447].
1112 Kondo K, Hirota Y, Kawamura H, et al. Factors associated with pain and functional limitation in Japanese male patients with knee osteoarthritis. Rheumatol Int. Oct. 2007;27(12):1135-42. [pmid: 17486343].
1113 Kondo K, Tanaka T, Hirota Y, et al. Factors associated with functional limitation in stair climbing in female Japanese patients with knee osteoarthritis. J Epidemiol. Jan. 2006;16(1):21-9. [pmid: 16369105].
1114 Konig A, Walther M, Kirschner S, et al. Balance sheets of knee and functional scores 5 years after total knee arthroplasty for osteoarthritis: a source for patient information. Journal of Arthroplasty. Apr. 2000;15(3):289-94. [pmid: 10794223].
1115 Koo S, Giori NJ, Gold GE, et al. Accuracy of 3D cartilage models generated from MR images is dependent on cartilage thickness: laser scanner based validation of in vivo cartilage. Journal of Biomechanical Engineering. Dec. 2009;131(12):121004. [pmid: 20524727].
1116 Kooijman HJ, Driessen APPM, van Horn JR. Long-term results of patellofemoral arthroplasty. A report of 56 arthroplasties with 17 years of follow-up. Journal of Bone & Joint Surgery - British Volume. Aug. 2003;85(6):836-40. [pmid: 12931801].
1117 Koralewicz LM, Engh GA. Comparison of proprioception in arthritic and age-matched normal knees. Journal of Bone & Joint Surgery - American Volume. Nov. 2000;82-A(11):1582-8. [pmid: 11097448].
1118 Kormelink TG, Tekstra J, Thurlings RM, et al. Decrease in immunoglobulin free light chains in patients with rheumatoid arthritis upon rituximab (anti-CD20) treatment correlates with decrease in disease activity. Ann Rheum Dis. Dec. 2010;69(12):2137-44. [pmid: 20679475].
1119 Kornaat PR, Sharma R, van der Geest RJ, et al. Positive association between increased popliteal artery vessel wall thickness and generalized osteoarthritis: is OA also part of the metabolic syndrome?. Skeletal Radiology. Dec. 2009;38(12):1147-51. [pmid: 19575196].
1120 Korovessis P, Katsoudas G, Salonikides P, et al. Medium- and long-term results of high tibial osteotomy for varus gonarthrosis in an agricultural population. Orthopedics. Aug. 1999;22(8):729-36. [pmid: 10465485].
1121 Korstjens CM, van der Rijt RH, Albers GH, et al. Low-intensity pulsed ultrasound affects human articular chondrocytes in vitro. Medical & Biological Engineering & Computing. Dec. 2008;46(12):1263-70. [pmid: 18853213].
1122 Kort NP, van Raay JJAM, Cheung J, et al. Analysis of Oxford medial unicompartmental knee replacement using the minimally invasive technique in patients aged 60 and above: an independent prospective series. Knee Surgery, Sports Traumatology, Arthroscopy. Nov. 2007;15(11):1331-4. [pmid: 17684726].
1123 Kort NP, van Raay JJAM, van Horn JJ. The Oxford phase III unicompartmental knee replacement in patients less than 60 years of age. Knee Surgery, Sports Traumatology, Arthroscopy. Apr. 2007;15(4):356-60. [pmid: 17028868].
1124 Kosashvili Y, Safir O, Gross A, et al. Distal femoral varus osteotomy for lateral osteoarthritis of the knee: a minimum ten-year follow-up. International Orthopaedics. Feb. 2010;34(2):249-54. [pmid: 19468727].
1125 Koshino T. Osteotomy around young deformed knees: 38-year super-long-term follow-up to detect osteoarthritis. International Orthopaedics. Feb. 2010;34(2):263-9. [pmid: 19777231].
1126 Koshino T, Murase T, Saito T. Medial opening-wedge high tibial osteotomy with use of porous hydroxyapatite to treat medial compartment osteoarthritis of the knee. Journal of Bone & Joint Surgery - American Volume. 2003;85-A(1):78-85. [pmid: 12533576].
1127 Koshino T, Saito T, Orito K, et al. Increase in range of knee motion to obtain floor sitting after high tibial osteotomy for osteoarthritis. Knee. Sep. 2002;9(3):189-96. [pmid: 12126676].
1128 Koshino T, Yoshida T, Ara Y, et al. Fifteen to twenty-eight years’ follow-up results of high tibial valgus osteotomy for osteoarthritic knee. Knee. Dec. 2004;11(6):439-44. [pmid: 15581761].
1129 Kosinski M, Keller SD, Ware JE Jr, et al. The SF-36 Health Survey as a generic outcome measure in clinical trials of patients with osteoarthritis and rheumatoid arthritis: relative validity of scales in relation to clinical measures of arthritis severity. Med Care. May. 1999;37(5 Suppl):MS23-39. [pmid: 10335741].
1130 Koskinen E, Paavolainen P, Eskelinen A, et al. Medial unicompartmental knee arthroplasty with Miller-Galante II prosthesis: mid-term clinical and radiographic results. Archives of Orthopaedic & Trauma Surgery. May. 2009;129(5):617-24. [pmid: 18560850].
1131 Kotevoglu N, Iyibozkurt PC, Hiz O, et al. A prospective randomised controlled clinical trial comparing the efficacy of different molecular weight hyaluronan solutions in the treatment of knee osteoarthritis. Rheumatol Int. Feb. 2006;26(4):325-30. [pmid: 15959784].
1132 Kothari M, Guermazi A, von Ingersleben G, et al. Fixed-flexion radiography of the knee provides reproducible joint space width measurements in osteoarthritis. European Radiology. Sep. 2004;14(9):1568-73. [pmid: 15150666].
1133 Kotz R, Kolarz G. Intra-articular hyaluronic acid: duration of effect and results of repeated treatment cycles. American Journal of Orthopedics (Chatham, Nj). Nov. 1999;28(11 Suppl):5-7. [pmid: 10587245].
1134 Koubaa S, Ksibi I, Lebib S, et al. Total knee arthroplasty in a spinal cord-injured patient: a case report. Annals of Physical & Rehabilitation Medicine. Sep–Oct. 2009;52(7–8):588-93. [pmid: 19720574].
1135 Kozanoglu E, Basaran S, Guzel R, et al. Short term efficacy of ibuprofen phonophoresis versus continuous ultrasound therapy in knee osteoarthritis. Swiss Medical Weekly. Jun. 14. 2003;133(23–24):333-8. [pmid: 12923684].
1136 Krackow KA, Mihalko WM. The effects of severe femoral bone loss on the flexion extension joint space in revision total knee arthroplasty: a cadaveric analysis and clinical consequences. Orthopedics. Feb. 2001;24(2):121-6. [pmid: 11284594].
1137 Kraemer WJ, Ratamess NA, Anderson JM, et al. Effect of a cetylated fatty acid topical cream on functional mobility and quality of life of patients with osteoarthritis. Journal of Rheumatology. 2004;31(4):767-74. [pmid: 15088305].
1138 Kraemer WJ, Ratamess NA, Maresh CM, et al. Effects of treatment with a cetylated fatty acid topical cream on static postural stability and plantar pressure distribution in patients with knee osteoarthritis. [Erratum appears in J Strength Cond Res. 2005 May;19(2):244 Note: Salvestre, Ricardo [corrected to Silvestre, Ricardo]]. Journal of Strength & Conditioning Research. Feb. 2005;19(1):115-21. [pmid: 15705022].
1139 Kramer JF, Speechley M, Bourne R, et al. Comparison of clinic- and home-based rehabilitation programs after total knee arthroplasty. Clin Orthop Relat Res. May. 2003;(410):225-34. [pmid: 12771834].
1140 Kraus VB, Feng S, Wang S, et al. Trabecular morphometry by fractal signature analysis is a novel marker of osteoarthritis progression. Arthritis Rheum. Dec. 2009;60(12):3711-22. [pmid: 19950282].
1141 Autologous Conditioned Serum (ACS) Compared to Hyaluronan and Placebo-Injections for the Treatment of Knee Osteoarthritis: A Prospective, Randomized, Placebo-Controlled, Double-Blind, Parallel-Design Trial. Therapeutic Study, Level I (Randomized Controlle. 2006 Annual European Congress of Rheumatology (EULAR 2006). Amsterdam (Netherlands (The)). 21–24 Jun 2006.
1142 Kreder HJ, Grosso P, Williams JI, et al. Provider volume and other predictors of outcome after total knee arthroplasty: a population study in Ontario. Canadian Journal of Surgery. Feb. 2003;46(1):15-22. [pmid: 12585788].
1143 Kreuz PC, Muller S, Ossendorf C, et al. Treatment of focal degenerative cartilage defects with polymer-based autologous chondrocyte grafts: four-year clinical results. Arthritis Research & Therapy. 2009;11(2):R33. [pmid: 19265548].
1144 Kreuz PC, Steinwachs MR, Erggelet C, et al. Results after microfracture of full-thickness chondral defects in different compartments in the knee. Osteoarthritis & Cartilage. Nov. 2006;14(11):1119-25. [pmid: 16815714].
1145 Krishnan E, Fries JF, Kwoh CK. Primary knee and hip arthroplasty among nonagenarians and centenarians in the United States. Arthritis & Rheumatism. Aug. 15. 2007;57(6):1038-42. [pmid: 17665474].
1146 Kristoffersen H, Torp-Pedersen S, Terslev L, et al. Indications of inflammation visualized by ultrasound in osteoarthritis of the knee. Acta Radiologica. Apr. 2006;47(3):281-6. [pmid: 16613309].
1147 Knee Braces and Foot Orthosis for Knee Osteoarthritis. 2008 Annual Scientific Meeting of the American College of Rheumatology and Association of Rheumatology Health Professionals. Moscone Center, San Francisco, California (USA). 24–29 Oct 2008.
1148 Kroner AH, Berger CE, Kluger R, et al. Influence of high tibial osteotomy on bone marrow edema in the knee. Clinical Orthopaedics & Related Research. 2007;454(Journal Article):155-62. [pmid: 16936577].
1149 Kruger K, Klasser M, Mossinger J, et al. Oxaceprol--a randomised, placebo-controlled clinical study in osteoarthritis with a non-conventional non-steroidal anti-inflammatory drug. Clinical & Experimental Rheumatology. Jan–Feb. 2007;25(1):29-34. [pmid: 17417987].
1150 Krugluger J, Steinwenter A, Knahr K. Uncemented Miller-Galante total knee replacement. The influence of alignment on clinical and radiological outcome in a 5 to 8-year follow-up. International Orthopaedics. 1998;22(4):230-3. [pmid: 9795809].
1151 Krystallis CT, Kirkos JM, Papavasiliou KA, et al. Arthroscopic debridement of the osteoarthritic knee under local anaesthesia. Acta Orthopaedica Belgica. Jun. 2004;70(3):260-7. [pmid: 15287406].
1152 Krzeski P, Buckland-Wright C, Balint G, et al. Development of musculoskeletal toxicity without clear benefit after administration of PG-116800, a matrix metalloproteinase inhibitor, to patients with knee osteoarthritis: a randomized, 12-month, double-blind, placebo-controlled study. Arthritis Research & Therapy. 2007;9(5):R109. [pmid: 17958901].
1153 Ku JH, Lee CK, Joo BS, et al. Correlation of synovial fluid leptin concentrations with the severity of osteoarthritis. Clinical Rheumatology. Dec. 2009;28(12):1431-5. [pmid: 19662330].
1154 Kubo S, Cooper GM, Matsumoto T, et al. Blocking vascular endothelial growth factor with soluble Flt-1 improves the chondrogenic potential of mouse skeletal muscle-derived stem cells. Arthritis & Rheumatism. Jan. 2009;60(1):155-65. [pmid: 19116905].
1155 Kuffner EK, Temple AR, Cooper KM, et al. Retrospective analysis of transient elevations in alanine aminotransferase during long-term treatment with acetaminophen in osteoarthritis clinical trials. Current Medical Research & Opinion. Nov. 2006;22(11):2137-48. [pmid: 17076974].
1156 Kugisaki H, Sonohata M, Komine M, et al. Serum concentrations of interleukin-6 in patients following unilateral versus bilateral total knee arthroplasty. J Orthop Sci. Jul. 2009;14(4):437-42. [pmid: 19662479].
1157 Kuijer PP, van der Molen HF, FringsDresen MH. Occupational diagnostic and preventive measures for shoulder disorders, aspecific low-back pain, and osteoarthritis of the knee. Ned Tijdschr Fysiother. 2007;117(6):192-8.
1158 Kuipers BM, Kollen BJ, Bots PC, et al. Factors associated with reduced early survival in the Oxford phase III medial unicompartment knee replacement. Knee. Jan. 2010;17(1):48-52. [pmid: 19716706].
1159 Kujala UM, Sarna S, Kaprio J, et al. Heart attacks and lower-limb function in master endurance athletes. Medicine & Science in Sports & Exercise. 1999;31(7):1041-6. [pmid: 10416567].
1160 Kulkarni B, Bentley DE, Elliott R, et al. Arthritic pain is processed in brain areas concerned with emotions and fear. Arthritis & Rheumatism. Apr. 2007;56(4):1345-54. [pmid: 17393440].
1161 KulPanza E, Berker N. Pedobarographic findings in patients with knee osteoarthritis. American Journal of Physical Medicine and Rehabilitation. 2006;85(3):228-33. [pmid: 16505639].
1162 Kul-Panza E, Berker N. Is hyaluronate sodium effective in the management of knee osteoarthritis? A placebo-controlled double-blind study. Minerva Medica. Apr. 2010;101(2):63-72. [pmid: 20467406].
1163 Kumar AM, Wen XL. Acupuncture treatment for osteoarthritic pain and inflammation of the knee. Alternative Therapies in Health & Medicine. Nov–Dec. 128. 2002;8(6):6. [pmid: 12440848].
1164 Adaptation to perturbed walking in people with medial knee osteoarthritis. 2008. 38th Annual Meeting of the Society for Neuroscience (Neuroscience 2008). Washington, DC (USA). 15–19 Nov 2008.
1165 Kuptniratsaikul V, Kuptniratsaikul S. Intra-articular injection of deproteinized hemodialysate in osteoarthritis of the knee: a case-series. Journal of the Medical Association of Thailand. Jan. 2004;87(1):100-5. [pmid: 14971542].
1166 Kuraishi J, Akizuki S, Takizawa T, et al. Arthroscopic lateral meniscectomy in knees with lateral compartment osteoarthritis: a case series study. Arthroscopy. Aug. 2006;22(8):878-83. [pmid: 16904587].
1167 Comparison of Allograft with Autograft in Opening-Wedge High Tibial Osteotomy for Medial Knee Joint Osteoarthritis. 2006 Annual Meeting of the American Orthopaedic Society for Sports Medicine (AOSSM 2006). Hershey, Pennsylvania (USA). 29 Jun– 2 Jul 2006.
1168 Kuroki H, Nakagawa Y, Mori K, et al. Ultrasound properties of articular cartilage in the tibio-femoral joint in knee osteoarthritis: relation to clinical assessment (International Cartilage Repair Society grade). Arthritis Research & Therapy. 2008;10(4):R78. [pmid: 18620596].
1169 Kuwano T, Urabe K, Miura H, et al. Importance of the lateral anatomic tibial slope as a guide to the tibial cut in total knee arthroplasty in Japanese patients. Journal of Orthopaedic Science. 2005;10(1):42-7. [pmid: 15666122].
1170 Kuzmanova SI. Treatment of knee osteoarthritis by arthroscopic synovectomy and debridement of cartilage lesions--late results. Folia Medica (Plovdiv). 2003;45(3):66-72. [pmid: 15366669].
1171 Kuzmanova SI, Solakov PT, Atanassov AN, et al. Relevance between arthroscopic pathology and clinical characteristics in knee osteoarthritis. Folia Medica (Plovdiv). 2000;42(4):19-22. [pmid: 15359508].
1172 Kwon YB, Kim JH, Yoon JH, et al. The analgesic efficacy of bee venom acupuncture for knee osteoarthritis: a comparative study with needle acupuncture. American Journal of Chinese Medicine. 2001;29(2):187-99. [pmid: 11527062].
1173 Kwon YD, Pittler MH, Ernst E. Acupuncture for peripheral joint osteoarthritis: a systematic review and meta-analysis. Rheumatology (Oxford). Nov. 2006;45(11):1331-7. [pmid: 16936326].
1174 Laboute E, Savalli L, Puig PL, et al. Validity and reproducibility of the PPLP scoring scale in the follow-up of athletes after anterior cruciate ligament reconstruction. Ann Phys Rehabil Med. Apr. 2010;53(3):162-79. [pmid: 20219437].
1175 Lachiewicz PF, Soileau ES. The rates of osteolysis and loosening associated with a modular posterior stabilized knee replacement. Results at five to fourteen years. Journal of Bone & Joint Surgery - American Volume. Mar. 2004;86-A(3):525-30. [pmid: 14996878].
1176 Ladermann A, Lubbeke A, Stern R, et al. Fixed-bearing versus mobile-bearing total knee arthroplasty: a prospective randomised, clinical and radiological study with mid-term results at 7 years. Knee. Jun. 2008;15(3):206-10. [pmid: 18329883].
1177 Lafeber FPJ, van Roermund PM, Marijnissen CA. No beneficial effects of joint distraction on early microscopical changes in osteoarthrotic knees. Acta Orthopaedica. Dec. 2005;76(6):947. author reply 8. [pmid: 16470459].
1178 Lafuente R, Belda JM, Sanchez-Lacuesta J, et al. Quantitative assessment of gait deviation: contribution to the objective measurement of disability. Gait Posture. Jun. 2000;11(3):191-8. [pmid: 10802431].
1179 Laidlaw MS, Rolston LR, Bozic KJ, et al. Assessment of tibiofemoral position in total knee arthroplasty using the active flexion lateral radiograph. Knee. Jan. 2010;17(1):38-42. [pmid: 19733084].
1180 Lampe F, Bohlen K, Dries SPM, et al. Accuracy of implant alignment and early results after minimally invasive vs conventional OrthoPilot-navigated Columbus TKA. Orthopedics. Oct. 2007;30(10 Suppl):S107-11. [pmid: 17983109].
1181 Lamson L, Tamm A, Gapeyeva H, et al. Quadriceps femoris muscle function characteristics in women with early knee osteoarthritis: A 2-year exercise therapy study. International Journal of Rehabilitation Research. 2009;32(Suppl 1):S97-8.
1182 Landry SC, McKean KA, Hubley-Kozey CL, et al. Knee biomechanics of moderate OA patients measured during gait at a self-selected and fast walking speed. Journal of Biomechanics. 2007;40(8):1754-61. 1754. [pmid: 17084845].
1183 RN624 (Anti-NGF) Improves Pain and Function in Subjects with Moderate Knee Osteoarthritis: A Phase I Study. 69th Annual Meeting of the American College of Rheumatology and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
1184 Lange AK, Fiatarone Singh MA, Smith RM, et al. Degenerative meniscus tears and mobility impairment in women with knee osteoarthritis. Osteoarthritis Cartilage. Jun. 2007;15(6):701-8. [pmid: 17207645].
1185 Langley C, Memel DS, Kirwan JR, et al. Using the Health Assessment Questionnaire and welfare benefits advice to help people disabled through arthritis to access financial support. Rheumatology (Oxford). Jul. 2004;43(7):863-8. [pmid: 15113991].
1186 Lansdown H, Howard K, Brealey S, et al. Acupuncture for pain and osteoarthritis of the knee: a pilot study for an open parallel-arm randomised controlled trial. BMC Musculoskeletal Disorders. 2009;10(Journal Article):130. [pmid: 19852841].
1187 Lanyon P, O’Reilly S, Jones A, et al. Radiographic assessment of symptomatic knee osteoarthritis in the community: definitions and normal joint space. Ann Rheum Dis. Oct. 1998;57(10):595-601. [pmid: 9893570].
1188 Lao L, Berman B. Evaluating the effects of acupuncture on knee osteoarthritis: a stepwise approach to research, University of Maryland experience. Zhong Xi Yi Jie He Xue Bao/Journal of Chinese Integrative Medicine. Nov. 2005;3(6):421-5. [pmid: 16282047].
1189 LaPrade RF, Swiontkowski MF. New horizons in the treatment of osteoarthritis of the knee. JAMA. Mar. 10. 1999;281(10):876-8. [pmid: 10078464].
1190 Larsen K, Sorensen OG, Hansen TB, et al. Accelerated perioperative care and rehabilitation intervention for hip and knee replacement is effective: a randomized clinical trial involving 87 patients with 3 months of follow-up. Acta Orthopaedica. Apr. 2008;79(2):149-59. [pmid: 18478482].
1191 Larsson AC, Petersson I, Ekdahl C. Functional capacity and early radiographic osteoarthritis in middle-aged people with chronic knee pain. Physiotherapy Research International. 1998;3(3):153-63. [pmid: 9782518].
1192 Laskin RS. Total knee replacement in patients older than 85 years. Clinical Orthopaedics & Related Research. 1999;(367):43-9. [pmid: 10546597].
1193 Laskin RS. The Genesis total knee prosthesis: a 10-year followup study. Clinical Orthopaedics & Related Research. 2001;(388):95-102. [pmid: 11451138].
1194 Laskin RS. Minimally invasive total knee replacement using a mini-mid vastus incision technique and results. Surgical Technology International. 2004;13:231-8. [pmid: 15744695].
1195 Laskin RS. Minimally invasive total knee arthroplasty: the results justify its use. Clinical Orthopaedics & Related Research. Nov. 2005;440:54-9. [pmid: 16239784].
1196 Laskin RS, Beksac B, Phongjunakorn A, et al. Minimally invasive total knee replacement through a mini-midvastus incision: an outcome study. Clinical Orthopaedics & Related Research. Nov. 2004;(428):74-81. [pmid: 15534522].
1197 Laskin RS, Davis J. Total knee replacement using the Genesis II prosthesis: a 5-year follow up study of the first 100 consecutive cases. Knee. Jun. 2005;12(3):163-7. [pmid: 15911286].
1198 Laskin RS, Maruyama Y, Villaneuva M, et al. Deep-dish congruent tibial component use in total knee arthroplasty: a randomized prospective study. Clinical Orthopaedics & Related Research. 2000;(380):36-44. [pmid: 11064971].
1199 Laskin RS, van Steijn M. Total knee replacement for patients with patellofemoral arthritis. Clinical Orthopaedics & Related Research. 1999;(367):89-95. [pmid: 10546602].
1200 Latimer N, Lord J, Grant RL, et al. Cost effectiveness of COX 2 selective inhibitors and traditional NSAIDs alone or in combination with a proton pump inhibitor for people with osteoarthritis. BMJ. 2009;339:b2538. [pmid: 19602530].
1201 Laurencin CT, Zelicof SB, Scott RD, et al. Unicompartmental versus total knee arthroplasty in the same patient. A comparative study. Clin Orthop Relat Res. Dec. 1991;(273):151-6. [pmid: 1959264].
1202 LaValley MP, McLaughlin S, Goggins J, et al. The lateral view radiograph for assessment of the tibiofemoral joint space in knee osteoarthritis: its reliability, sensitivity to change, and longitudinal validity. Arthritis Rheum. Nov. 2005;52(11):3542-7. [pmid: 16255043].
1203 Lavernia C, D’Apuzzo M, Rossi MD, et al. Is postoperative function after hip or knee arthroplasty influenced by preoperative functional levels?. J Arthroplasty. Oct. 2009;24(7):1033-43. [pmid: 18963759].
1204 Lavernia CJ, Alcerro JC, Drakeford MK, et al. Resection arthroplasty for failed patellar components. International Orthopaedics. Dec. 2009;33(6):1591-6. [pmid: 18956182].
1205 Lavernia CJ, Alcerro JC, Rossi MD. Fear in arthroplasty surgery: the role of race. Clinical Orthopaedics & Related Research. 2010;468(2):547-54. [pmid: 19763716].
1206 Law A. Diversified chiropractic management in the treatment of osteoarthritis of the knee: a case report. Journal - Canadian Chiropractic Association. 2001;45(4):232-40.
1207 Lawrence T, Moskal JT, Diduch DR. Analysis of routine histological evaluation of tissues removed during primary hip and knee arthroplasty. J Bone Joint Surg Am. Jul. 1999;81(7):926-31. [pmid: 10428123].
1208 Le Loet X, Pavelka K, Richarz U. Transdermal fentanyl for the treatment of pain caused by osteoarthritis of the knee or hip: an open, multicentre study. BMC Musculoskeletal Disorders. 2005;6(Journal Article):31. [pmid: 15958159].
1209 Leardini G, Salaffi F, Caporali R, et al. Direct and indirect costs of osteoarthritis of the knee. Clin Exp Rheumatol. Nov–Dec. 2004;22(6):699-706. [pmid: 15638043].
1210 Leblan D, Chantre P, Fournie B. Harpagophytum procumbens in the treatment of knee and hip osteoarthritis. Four-month results of a prospective, multicenter, double-blind trial versus diacerhein. Joint Bone Spine. 2000;67(5):462-7. [pmid: 11143915].
1211 Lee C, Straus WL, Balshaw R, et al. A comparison of the efficacy and safety of nonsteroidal antiinflammatory agents versus acetaminophen in the treatment of osteoarthritis: a meta-analysis. Arthritis Care and Research. 2004;51(5):746-54. [pmid: 15478167].
1212 Lee DC, Kim DH, Scott RD, et al. Intraoperative flexion against gravity as an indication of ultimate range of motion in individual cases after total knee arthroplasty. Journal of Arthroplasty. Aug. 1998;13(5):500-3. [pmid: 9726313].
1213 Lee D-H, Park J-H, Song D-I, et al. Accuracy of soft tissue balancing in TKA: comparison between navigation-assisted gap balancing and conventional measured resection. Knee Surgery, Sports Traumatology, Arthroscopy. Mar. 2010;18(3):381-7. [pmid: 19924399].
1214 Lee PB, Kim YC, Lim YJ, et al. Comparison between high and low molecular weight hyaluronates in knee osteoarthritis patients: open-label, randomized, multicentre clinical trial. Journal of International Medical Research. Jan–Feb. 2006;34(1):77-87. [pmid: 16604827].
1215 Lee S, Park D, Chmell SJ. Viscosupplementation with hylan G-F 20 (Synvisc): pain and mobility observations from 74 consecutive patients. The Journal of Knee Surgery. Apr. 2004;17(2):73-7. [pmid: 15124659].
1216 Lee TH, Tsuchida T, Kitahara H, et al. Gait analysis before and after unilateral total knee arthroplasty. Study using a linear regression model of normal controls -- women without arthropathy. Journal of Orthopaedic Science. 1999;4(1):13-21. [pmid: 9914424].
1217 Leff RL, Elias I, Ionescu M, et al. Molecular changes in human osteoarthritic cartilage after 3 weeks of oral administration of BAY 12-9566, a matrix metalloproteinase inhibitor. Journal of Rheumatology. Mar. 2003;30(3):544-9. [pmid: 12610815].
1218 Lehmann R, Brzosko M, Kopsa P, et al. Efficacy and tolerability of lumiracoxib 100 mg once daily in knee osteoarthritis: a 13-week, randomized, double-blind study vs. placebo and celecoxib. Current Medical Research & Opinion. Apr. 2005;21(4):517-26. [pmid: 15899100].
1219 Lenssen AF, Crijns YH, Waltje EM, et al. Effectiveness of prolonged use of continuous passive motion (CPM) as an adjunct to physiotherapy following total knee arthroplasty: design of a randomised controlled trial. [ISRCTN85759656]. BMC Musculoskeletal Disorders. 2006;7(Journal Article):15. [pmid: 16504087].
1220 Lenssen AF, Crijns YH, Waltje EM, et al. Efficiency of immediate postoperative inpatient physical therapy following total knee arthroplasty: an RCT. BMC Musculoskeletal Disorders. 2006;7(Journal Article):71. [pmid: 16942627].
1221 Lenssen AF, Koke Aj, Bie RA, Geesink RG. Continuous passive motion following primary total knee arthroplasty:short- and long-term effects on range of motion. Physical Therapy Reviews. 2003;8(3):113-21.
1222 Lenssen AF, van Dam EM, Crijns YH, et al. Reproducibility of goniometric measurement of the knee in the in-hospital phase following total knee arthroplasty. BMC Musculoskelet Disord. 2007;8:83. [pmid: 17705860].
1223 Lenssen TA, van Steyn MJ, Crijns YH, et al. Effectiveness of prolonged use of continuous passive motion (CPM), as an adjunct to physiotherapy, after total knee arthroplasty. BMC Musculoskelet.Disord. 60. 2008;9:60. [pmid: 18442423].
1224 Leo BM, Turner MA, Diduch DR. Split-line pattern and histologic analysis of a human osteochondral plug graft. Arthroscopy. 2004;20(Suppl 2):39-45. [pmid: 15243423].
1225 Leon HO, Blanco CE, Guthrie TB. Arthroscopic decompressive medial release of the varus arthritic knee: Expanding the functional envelope. Arthroscopy. May. 2001;17(5):523-6. [pmid: 11337721].
1226 Leon HO, Blanco CER, Guthrie TB, et al. Intercondylar notch stenosis in degenerative arthritis of the knee. Arthroscopy. Mar. 2005;21(3):294-302. [pmid: 15756182].
1227 Lequesne M, Brandt K, Bellamy N, et al. Guidelines for testing slow acting drugs in osteoarthritis. J Rheumatol Suppl. Sep. 1994;41:65-71. discussion 2–3. [pmid: 7799389].
1228 Lethbridge-Cejku M, Scott WW Jr, Reichle R, et al. Association of radiographic features of osteoarthritis of the knee with knee pain: data from the Baltimore Longitudinal Study of Aging. Arthritis Care Res. Sep. 1995;8(3):182-8. [pmid: 7654803].
1229 Leung AT, Malmstrom K, Gallacher AE, et al. Efficacy and tolerability profile of etoricoxib in patients with osteoarthritis: A randomized, double-blind, placebo and active-comparator controlled 12-week efficacy trial. Current Medical Research & Opinion. 2002;18(2):49-58. [pmid: 12017209].
1230 Leutloff D, Tobian F, Perka C. High tibial osteotomy for valgus and varus deformities of the knee. International Orthopaedics. 2001;25(2):93-6. [pmid: 11409460].
1231 Lev-Ari S, Hasner A, Amir H, et al. Acupuncture as complementary medicine in patients with osteoarthritis of the knee. Harefuah. May. 2007;146(5):354-7. [pmid: 17674552].
1232 Lev-Ari S, Strier L, Kazanov D, et al. Curcumin synergistically potentiates the growth-inhibitory and pro-apoptotic effects of celecoxib in osteoarthritis synovial adherent cells. Rheumatology (Oxford). Feb. 2006;45(2):171-7. [pmid: 16249246].
1233 Leveille SG, Guralnik JM, Ferrucci L, et al. Foot pain and disability in older women. Am J Epidemiol. Oct. 1. 1998;148(7):657-65. [pmid: 9778172].
1234 Levinger P, Lai DT, Begg RK, et al. The application of support vector machines for detecting recovery from knee replacement surgery using spatio-temporal gait parameters. Gait Posture. Jan. 2009;29(1):91-6. [pmid: 18752954].
1235 Levinger P, Lai DT, Webster K, et al. Support Vector Machines for detecting recovery from knee replacement surgery using quantitative gait measures. Conf Proc IEEE Eng Med Biol Soc. 2007;2007:4875-8. [pmid: 18003098].
1236 Levy RM, Saikovsky R, Shmidt E, et al. Flavocoxid is as effective as naproxen for managing the signs and symptoms of osteoarthritis of the knee in humans: a short-term randomized, double-blind pilot study. Nutr Res. May. 2009;29(5):298-304. [pmid: 19555810].
1237 Lewek, Scholz J, Rudolph KS, et al. Stride-to-stride variability of knee motion in patients with knee osteoarthritis. Gait and Posture. 2006;23(4):505-11. [pmid: 16024250].
1238 Lewek MD, Rudolph KS, Snyder-Mackler L. Control of frontal plane knee laxity during gait in patients with medial compartment knee osteoarthritis. Osteoarthritis Cartilage. Sep. 2004;12(9):745-51. [pmid: 15325641].
1239 Lewek MD, Rudolph KS, Snyder-Mackler L. Quadriceps femoris muscle weakness and activation failure in patients with symptomatic knee osteoarthritis. J Orthop Res. Jan. 2004;22(1):110-5. [pmid: 14656668].
1240 Li B, Wen Y, Wu H, et al. The effect of tourniquet use on hidden blood loss in total knee arthroplasty. International Orthopaedics. Oct. 2009;33(5):1263-8. [pmid: 18751703].
1241 Li G, Papannagari R, DeFrate LE, et al. Comparison of the ACL and ACL graft forces before and after ACL reconstruction: an in-vitro robotic investigation. Acta Orthopaedica. Apr. 2006;77(2):267-74. [pmid: 16752289].
1242 Li G, Suggs J, Hanson G, et al. Three-dimensional tibiofemoral articular contact kinematics of a cruciate-retaining total knee arthroplasty. Journal of Bone & Joint Surgery - American Volume. Feb. 2006;88(2):395-402. [pmid: 16452753].
1243 Determinants of Joint Replacement and Joint Failure in Knee Osteoarthritis, and use of Joint Replacement as an Outcome in Knee OA. 69th Annual Meeting of the American College of Rheumatology and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
1244 Li MG, Thorsen K, Nilsson KG. Increased bone turnover as reflected by biochemical markers in patients with potentially unstable fixation of the tibial component. Archives of Orthopaedic & Trauma Surgery. Jul. 2004;124(6):404-9. [pmid: 15156331].
1245 Li MG, Yao F, Joss B, et al. Mobile vs. fixed bearing unicondylar knee arthroplasty: A randomized study on short term clinical outcomes and knee kinematics. Knee. Oct. 2006;13(5):365-70. [pmid: 16797994].
1246 Li PH, Wong YC, Wai YL. Knee flexion after total knee arthroplasty. Journal of Orthopaedic Surgery. Aug. 2007;15(2):149-53. [pmid: 17709850].
1247 Li Q, Zhu J. Observation on therapeutic effect of moxibustion at Shenque (CV 8) combined with electroacupuncture on gonarthritis of type of accumulation of pathogenic cold due to yang deficiency. Zhongguo Zhenjiu. Aug. 2008;28(8):565-8. [pmid: 18767578].
1248 Li W, Du H, Scheidegger R, et al. Value of precontrast T(1) for dGEMRIC of native articular cartilage. J Magn Reson Imaging. Feb. 2009;29(2):494-7. [pmid: 19161210].
1249 Li X, Han ET, Ma CB, et al. In vivo 3T spiral imaging based multi-slice T(1rho) mapping of knee cartilage in osteoarthritis. Magn Reson Med. Oct. 2005;54(4):929-36. [pmid: 16155867].
1250 Li X, Pai A, Blumenkrantz G, et al. Spatial distribution and relationship of T1rho and T2 relaxation times in knee cartilage with osteoarthritis. Magn Reson Med. Jun. 2009;61(6):1310-8. [pmid: 19319904].
1251 Liang MH, Cullen KE, Larson MG, et al. Effects of reducing physical therapy services on outcomes in total joint arthroplasty. Med Care. Apr. 1987;25(4):276-85. [pmid: 3695647].
1252 Licciardone JC, Stoll ST, Cardarelli KM, et al. A randomized controlled trial of osteopathic manipulative treatment following knee or hip arthroplasty. Journal of the American Osteopathic Association. 2004;104(5):193-202. [pmid: 15176518].
1253 Liddle SD. Integrated exercise and self-management programmes in osteoarthritis of the hip and knee. Physical Therapy Reviews. 2007;12(4):285-6.
1254 Liden M, Sernert N, Rostgard-Christensen L, et al. Osteoarthritic changes after anterior cruciate ligament reconstruction using bone-patellar tendon-bone or hamstring tendon autografts: a retrospective, 7-year radiographic and clinical follow-up study. Arthroscopy. Aug. 2008;24(8):899-908. [pmid: 18657738].
1255 Lidtke RH, Muehleman C, Kwasny M, et al. Foot center of pressure and medial knee osteoarthritis. Journal of the American Podiatric Medical Association. May–Jun. 2010;100(3):178-84. [pmid: 20479447].
1256 Liess C, Lusse S, Karger N, et al. Detection of changes in cartilage water content using MRI T2-mapping in vivo. Osteoarthritis & Cartilage. Dec. 2002;10(12):907-13. [pmid: 12464550].
1257 Lievens P, Van de Voorde J. The influence of cycloidal vibrations on the knee joint mobility of osteoarthritic patients. Physiotherapy. Jun. 10. 1984;70(6):241-3. [pmid: 6463141].
1258 Liikavainio T, Isolehto J, Helminen HJ, et al. Loading and gait symmetry during level and stair walking in asymptomatic subjects with knee osteoarthritis: importance of quadriceps femoris in reducing impact force during heel strike?. Knee. Jun. 2007;14(3):231-8. [pmid: 17451958].
1259 Liikavainio T, Lyytinen T, Tyrvainen E, et al. Physical function and properties of quadriceps femoris muscle in men with knee osteoarthritis. Archives of Physical Medicine & Rehabilitation. 2008;89(11):2185-94. [pmid: 18996249].
1260 Lilikakis AK, Gillespie B, Villar RN. The benefit of modified rehabilitation and minimally invasive techniques in total hip replacement. Annals of the Royal College of Surgeons of England. Jul. 2008;90(5):406-11. [pmid: 18634739].
1261 Lim B-W, Hinman RS, Wrigley TV, et al. Varus malalignment and its association with impairments and functional limitations in medial knee osteoarthritis. Arthritis & Rheumatism. Jul. 15. 2008;59(7):935-42. [pmid: 18576296].
1262 Lim B-W, Kemp G, Metcalf B, et al. The association of quadriceps strength with the knee adduction moment in medial knee osteoarthritis. Arthritis & Rheumatism. Apr. 15. 2009;61(4):451-8. [pmid: 19333982].
1263 Lim HC, Bae JH, Hur CR, et al. Arthrodesis of the knee using cannulated screws. Journal of Bone & Joint Surgery - British Volume. Feb. 2009;91(2):180-4. [pmid: 19190050].
1264 Lim JT, Luscombe KL, Jones PW, et al. The effect of preoperative symptom severity on functional outcome of total knee replacement--patients with the lowest preoperative scores achieve the lowest marks. Knee. Jun. 2006;13(3):216-9. [pmid: 16513355].
1265 Lin J, Yang B, Weng XS, et al. Effect of osteoarthritis patients’ gender on rehabilitation after total knee arthroplasty. Chinese Medical Sciences Journal. 2009;24(2):102-6. [pmid: 19618607].
1266 Lin W-P, Lin J, Horng L-C, et al. Quadriceps-sparing, minimal-incision total knee arthroplasty: a comparative study. Journal of Arthroplasty. Oct. 2009;24(7):1024-32. [pmid: 18757172].
1267 Linde K, Weidenhammer W, Streng A, et al. Acupuncture for osteoarthritic pain: an observational study in routine care. Rheumatology. 2006;45(2):222-7. [pmid: 16368731].
1268 Ling SM, Fried LP, Garrett ES, et al. Knee osteoarthritis compromises early mobility function: The Women’s Health and Aging Study II. Journal of Rheumatology. 2003;30(1):114-20. [pmid: 12508399].
1269 Ling SM, Patel DD, Garnero P, et al. Serum protein signatures detect early radiographic osteoarthritis. Osteoarthritis & Cartilage. Jan. 2009;17(1):43-8. [pmid: 18571442].
1270 Lingard EA, Berven S, Katz JN. Management and care of patients undergoing total knee arthroplasty: variations across different health care settings. Arthritis Care Res. Jun. 2000;13(3):129-36. [pmid: 14635286].
1271 Lingard EA, Sledge CB, Learmonth ID, et al. Patient expectations regarding total knee arthroplasty: differences among the United States, United kingdom, and Australia. Journal of Bone & Joint Surgery - American Volume. Jun. 2006;88(6):1201-7. [pmid: 16757751].
1272 Lionberger DR, Weise J, Ho DM, et al. How does electromagnetic navigation stack up against infrared navigation in minimally invasive total knee arthroplasties?. J Arthroplasty. Jun. 2008;23(4):573-80. [pmid: 18514877].
1273 Listrat V, Ayral X, Patarnello F, et al. Arthroscopic evaluation of potential structure modifying activity of hyaluronan (Hyalgan) in osteoarthritis of the knee. Osteoarthritis Cartilage. May. 1997;5(3):153-60. [pmid: 9219678].
1274 Liu K, Lao L, Asami T, et al. Clinical care of osteoarthritic knee with knee orthoses. Fukuoka Igaku Zasshi - Fukuoka Acta Medica. 1998;89(10):298-302. [pmid: 9844273].
1275 Liu T, Liu C. Acupuncture for treating osteoarthritis of the knee and the hip. Arthritis & Rheumatism. Nov. 2006;54(11):3375-7. [pmid: 17075812].
1276 Liu Y, Guo L, Ma S. Treatment of 256 cases of osteoarthritis of knee joint with Guo Jianhua’s four-step therapy. Journal of Traditional Chinese Medicine. Jun. 2008;28(2):114-7. [pmid: 18652118].
1277 Livesley PJ, Doherty M, Needoff M, et al. Arthroscopic lavage of osteoarthritic knees. J Bone Joint Surg Br. Nov. 1991;73(6):922-6. [pmid: 1720118].
1278 Livshits G, Zhai G, Hart DJ, et al. Interleukin-6 is a significant predictor of radiographic knee osteoarthritis: The Chingford Study. Arthritis Rheum. Jul. 2009;60(7):2037-45. [pmid: 19565477].
1279 Lloyd R, Derry S, Moore RA, et al. Intravenous or intramuscular parecoxib for acute postoperative pain in adults, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2009.
1280 Lo WN, Cheung KW, Yung SH, et al. Arthroscopy-assisted computer navigation in high tibial osteotomy for varus knee deformity. Journal of Orthopaedic Surgery. Apr. 2009;17(1):51-5. [pmid: 19398794].
1281 Lobenhoffer P, Agneskirchner JD. Improvements in surgical technique of valgus high tibial osteotomy. Knee Surgery, Sports Traumatology, Arthroscopy. May. 2003;11(3):132-8. [pmid: 12774149].
1282 Lohmander LS, Brandt KD, Mazzuca SA, et al. Use of the plasma stromelysin (matrix metalloproteinase 3) concentration to predict joint space narrowing in knee osteoarthritis. Arthritis Rheum. Oct. 2005;52(10):3160-7. [pmid: 16200596].
1283 Lohmander LS, Dalen N, Englund G, et al. Intra-articular hyaluronan injections in the treatment of osteoarthritis of the knee: a randomised, double blind, placebo controlled multicentre trial. Hyaluronan Multicentre Trial Group. Annals of the Rheumatic Diseases. 1996;55(7):424-31. [pmid: 8774159].
1284 Lohmander LS, Hoerrner LA, Lark MW. Metalloproteinases, tissue inhibitor, and proteoglycan fragments in knee synovial fluid in human osteoarthritis. Arthritis Rheum. Feb. 1993;36(2):181-9. [pmid: 8431206].
1285 Lohmander LS, McKeith D, Svensson O, et al. A randomised, placebo controlled, comparative trial of the gastrointestinal safety and efficacy of AZD3582 versus naproxen in osteoarthritis. Annals of the Rheumatic Diseases. 2005;64(3):449-56. [pmid: 15345500].
1286 Lohmander S. Osteoarthritis is frequent, very frequent. What can we do?. Lakartidningen. Oct. 31. 2002;99(44):4342-4. [pmid: 12469576].
1287 Lombardi AV Jr, Berend KR, Leith JR, et al. Posterior-stabilized constrained total knee arthroplasty for complex primary cases. Journal of Bone & Joint Surgery - American Volume. Oct. Suppl 3. 2007;89:90-102. [pmid: 17908875].
1288 Lombardi AV Jr, Berend KR, Walter CA, et al. Is recovery faster for mobile-bearing unicompartmental than total knee arthroplasty?. Clinical Orthopaedics & Related Research. Jun. 2009;467(6):1450-7. [pmid: 19225852].
1289 Lombardi AV Jr, Dodds KL, Berend KR, et al. An algorithmic approach to total knee arthroplasty in the valgus knee. Journal of Bone & Joint Surgery - American Volume. Suppl 2. 2004;86-A:62-71. [pmid: 15691110].
1290 Long L. Probable benefits of glucosamine and chondroitin preparations for patients with hip and/or knee osteoarthritis. Focus on Alternative and Complementary Therapies. 2000;5(3):211-2.
1291 Lonner JH. A 57-year-old man with osteoarthritis of the knee. JAMA. Feb. 26. 2003;289(8):1016-25. [pmid: 12597755].
1292 Lonner JH, Hershman S, Mont M, et al. Total knee arthroplasty in patients 40 years of age and younger with osteoarthritis. Clinical Orthopaedics & Related Research. 2000;(380):85-90. [pmid: 11064977].
1293 Lonner JH, Mehta S, Booth RE Jr. Ipsilateral patellofemoral arthroplasty and autogenous osteochondral femoral condylar transplantation. Journal of Arthroplasty. Dec. 2007;22(8):1130-6. [pmid: 18078881].
1294 Lopez JPF, Burant CJ, Siminoff LA, et al. Patient perceptions of access to care and referrals to specialists: a comparison of African-American and white older patients with knee and hip osteoarthritis. Journal of the National Medical Association. May. 2005;97(5):667-73. [pmid: 15926643].
1295 Loughnan TE, Taverner MG, Webb A. Randomized, double blinded comparative trial of intradermal injections of lignocaine versus N-saline around the knee to relieve pain in patients awaiting total knee replacement. Clinical Journal of Pain. 2009;25(4):269-72. [pmid: 19590473].
1296 Love B. Incidence and outcomes of knee and hip joint replacements in veterans and civilians. ANZ Journal of Surgery. Dec. 2006;76(12):1133-4. [pmid: 17199711].
1297 Lowe GDO, Sandercock PAG, Rosendaal FR. Prevention of venous thromboembolism after major orthopaedic surgery: is fondaparinux an advance?. Lancet. Aug. 16. 2003;362(9383):504-5. [pmid: 12932379].
1298 Lozano J, Saadat E, Li X, et al. Magnetic resonance T(1 rho) imaging of osteoarthritis: a rabbit ACL transection model. Magn Reson Imaging. Jun. 2009;27(5):611-6. [pmid: 19056196].
1299 Lozano LM, Nunez M, Segur JM, et al. Relationship between knee anthropometry and surgical time in total knee arthroplasty in severely and morbidly obese patients: a new prognostic index of surgical difficulty. Obes Surg. Sep. 2008;18(9):1149-53. [pmid: 18506553].
1300 Lu TW, Chen HL, Wang TM. Obstacle crossing in older adults with medial compartment knee osteoarthritis. Gait and Posture. 2007;26(4):553-9. [pmid: 17240144].
1301 Lu TW, Wei IP, Liu YH, et al. Immediate effects of acupuncture on gait patterns in patients with knee osteoarthritis. Chinese Medical Journal. 2010;123(2):165-72. [pmid: 20137365].
1302 Luciani D, Cadossi M, Tesei F, et al. Viscosupplementation for grade II osteoarthritis of the ankle: a prospective study at 18 months’ follow-up. Chirurgia Degli Organi di Movimento. Dec. 2008;92(3):155-60. [pmid: 19067120].
1303 Ludbrook J. Incidence and outcomes of knee and joint replacement in veterans and civilians. ANZ Journal of Surgery. Dec. 2006;76(12):1134. [pmid: 17199712].
1304 Luites JWH, Brinkman JM, Wymenga AB, et al. Fixation stability of opening- versus closing-wedge high tibial osteotomy: a randomised clinical trial using radiostereometry. Journal of Bone & Joint Surgery - British Volume. Nov. 2009;91(11):1459-65. [pmid: 19880890].
1305 Lundblad H, Kreicbergs A, Jansson KA. Prediction of persistent pain after total knee replacement for osteoarthritis. Journal of Bone & Joint Surgery - British Volume. Feb. 2008;90(2):166-71. [pmid: 18256082].
1306 Lundeberg T. Some of the effects of acupuncture in knee pain may be due to activation of the reward system. Acupuncture in Medicine. 2006;24(Suppl 1):67-70.
1307 Lundsgaard C, Dufour N, Fallentin E, et al. Intra-articular sodium hyaluronate 2 mL versus physiological saline 20 mL versus physiological saline 2 mL for painful knee osteoarthritis: a randomized clinical trial. Scandinavian Journal of Rheumatology. Mar–Apr. 2008;37(2):142-50. [pmid: 18415773].
1308 Luscombe KL, Lim J, Jones PW, et al. Minimally invasive Oxford medial unicompartmental knee arthroplasty. A note of caution!. International Orthopaedics. Jun. 2007;31(3):321-4. [pmid: 16896865].
1309 Lutzner J, Krummenauer F, Gunther KP, et al. Rotational alignment of the tibial component in total knee arthroplasty is better at the medial third of tibial tuberosity than at the medial border. BMC Musculoskelet Disord. 2010;11:57. [pmid: 20338042].
1310 Luyten FP, Geusens P, Malaise M, et al. A prospective randomised multicentre study comparing continuous and intermittent treatment with celecoxib in patients with osteoarthritis of the knee or hip. Annals of the Rheumatic Diseases. Jan. 2007;66(1):99-106. [pmid: 16815864].
1311 Lynch JA, Buckland-Wright JC, Macfarlane DG. Precision of joint space width measurement in knee osteoarthritis from digital image analysis of high definition macroradiographs. Osteoarthritis Cartilage. Oct. 1993;1(4):209-18. [pmid: 15449508].
1312 Lynn SK, Costigan PA. Effect of foot rotation on knee kinetics and hamstring activation in older adults with and without signs of knee osteoarthritis. Clinical Biomechanics. 2008;23(6):779-86. [pmid: 18343001].
1313 Lyu SR. Arthroscopic medial release for medial compartment osteoarthritis of the knee: the result of a single surgeon series with a minimum follow-up of four years. Journal of Bone & Joint Surgery - British Volume. Sep. 2008;90(9):1186-92. [pmid: 18757958].
1314 Ma B, Rudan J, Chakravertty R, et al. Computer-assisted FluoroGuide navigation of unicompartmental knee arthroplasty. Canadian Journal of Surgery. 2009;52(5):379-85. [pmid: 19865572].
1315 Mabuchi A, Ikeda T, Fukuda A, et al. Identification of sequence polymorphisms of the COMP (cartilage oligomeric matrix protein) gene and association study in osteoarthrosis of the knee and hip joints. J Hum Genet. 2001;46(8):456-62. [pmid: 11501943].
1316 Macaulay W, Yoon RS. Fixed-bearing, medial unicondylar knee arthroplasty rapidly improves function and decreases pain: a prospective, single-surgeon outcomes study. The Journal of Knee Surgery. Oct. 2008;21(4):279-84. [pmid: 18979929].
1317 MacAuley D. Managing osteoarthritis of the knee. BMJ. Dec. 4. 2004;329(7478):1300-1. [pmid: 15576717].
1318 MacDonald SJ, Bourne RB, Rorabeck CH, et al. Prospective randomized clinical trial of continuous passive motion after total knee arthroplasty. Clinical Orthopaedics & Related Research. 2000;(380):30-5. [pmid: 11064970].
1319 MacDonald SJ, Charron KD, Bourne RB, et al. The John Insall Award: gender-specific total knee replacement: prospectively collected clinical outcomes. Clinical Orthopaedics & Related Research. 2008;466(11):2612-6. [pmid: 18800216].
1320 Machner A, Pap G, Krohn A, et al. Quadriceps muscle function after high tibial osteotomy for osteoarthritis of the knee. Clinical Orthopaedics & Related Research. 2002;(399):177-83. [pmid: 12011707].
1321 Macule F, Sastre S, Lasurt S, et al. Hoffa’s fat pad resection in total knee arthroplasty. Acta Orthopaedica Belgica. Dec. 2005;71(6):714-7. [pmid: 16459863].
1322 Madan S, Ranjith RK, Fiddian NJ. Intermediate follow-up of high tibial osteotomy: a comparison of two techniques. Bulletin of the Hospital for Joint Diseases. 2002;61(1–2):11-6. [pmid: 12828374].
1323 Madan S, Ranjith RK, Fiddian NJ. Total knee replacement following high tibial osteotomy. Bulletin of the Hospital for Joint Diseases. 2002;61(1–2):5-10. [pmid: 12828373].
1324 Madan S, Rushforth GF. Clinical effectiveness of high tibial osteotomy for osteoarthritis of the knee. Bulletin of the Hospital for Joint Diseases. 2002;61(1–2):45-8. [pmid: 12828379].
1325 Madan-Sharma R, Kloppenburg M, Kornaat PR, et al. Do MRI features at baseline predict radiographic joint space narrowing in the medial compartment of the osteoarthritic knee 2 years later?. Skeletal Radiology. Sep. 2008;37(9):805-11. [pmid: 18566813].
1326 Madsen OR, Schaadt O, Bliddal H, et al. Bone mineral distribution of the proximal tibia in gonarthrosis assessed in vivo by photon absorption. Osteoarthritis Cartilage. Jun. 1994;2(2):141-7. [pmid: 11548230].
1327 Maffiuletti NA, Bizzini M, Widler K, et al. Asymmetry in quadriceps rate of force development as a functional outcome measure in TKA. Clinical Orthopaedics & Related Research. 2010;468(1):191-8. [pmid: 19597897].
1328 Magilavy D, Polisson R, Parenti D. Re: Karlsson, et al. Comparison of two hyaluronan drugs and placebo in patients with knee osteoarthritis. A controlled, randomized, double-blind, parallel-design multicentre study. Rheumatology. Oct. 2003;42(10):1262. author reply -3. [pmid: 14508044].
1329 Magill CD. Non-surgical aid for the degenerated knee. Rocky Mt Med J. Nov. 1968;65(11):45-8. [pmid: 5722939].
1330 Magyar G, Toksvig-Larsen S, Lindstrand A. Changes in osseous correction after proximal tibial osteotomy: radiostereometry of closed- and open-wedge osteotomy in 33 patients. Acta Orthopaedica Scandinavica. Oct. 1999;70(5):473-7. [pmid: 10622480].
1331 Mahboob N, Sousan K, Shirzad A, et al. The efficacy of a topical gel prepared using Lake Urmia mud in patients with knee osteoarthritis. Journal of Alternative & Complementary Medicine. Nov. 2009;15(11):1239-42. [pmid: 19922256].
1332 Mahoney OM, Kinsey T. Overhang of the femoral component in total knee arthroplasty: risk factors and clinical consequences. Journal of Bone & Joint Surgery - American Volume. May. 2010;92(5):1115-21. [pmid: 20439656].
1333 Mahoney OM, Kinsey TL, Banks AZ, et al. Rotational kinematics of a modern fixed-bearing posterior stabilized total knee arthroplasty. Journal of Arthroplasty. Jun. 2009;24(4):641-5. [pmid: 18534538].
1334 Mahoney OM, McClung CD, dela Rosa MA, et al. The effect of total knee arthroplasty design on extensor mechanism function. Journal of Arthroplasty. Jun. 2002;17(4):416-21. [pmid: 12066269].
1335 Majani G, Giardini A, Scotti A. Subjective impact of osteoarthritis flare-ups on patients’ quality of life. Health & Quality of Life Outcomes. 2005;3(Journal Article):14. [pmid: 15771777].
1336 Malonne H, Coffiner M, Fontaine D, et al. Long-term tolerability of tramadol LP, a new once-daily formulation, in patients with osteoarthritis or low back pain. Journal of Clinical Pharmacy & Therapeutics. Apr. 2005;30(2):113-20. [pmid: 15811163].
1337 Maly MR. Linking biomechanics to mobility and disability in people with knee osteoarthritis. Exercise and sport sciences reviews. 2009;37(1):36-42. [pmid: 19098523].
1338 Maly MR, Costigan PA, Olney SJ. Contribution of psychosocial and mechanical variables to physical performance measures in knee osteoarthritis. Phys Ther. Dec. 2005;85(12):1318-28. [pmid: 16305270].
1339 Maly MR, Krupa T. Personal experience of living with knee osteoarthritis among older adults. Disabil Rehabil. Sep. 30. 2007;29(18):1423-33. [pmid: 17729089].
1340 Mambrona L, Catasus ML, Nogales M, et al. Isokinetic Assessment of Scorpio PS Knee Prosthesis. Rehabilitacion. 2007;41(4):161-6.
1341 Mandeville D, Ostenig LR, Chou LS. The effect of total knee replacement surgery on gait stability. Gait and Posture. 2008;27(1):103-9. [pmid: 17419059].
1342 Mandeville D, Osternig LR, Lantz BA, et al. The effect of total knee replacement on the knee varus angle and moment during walking and stair ascent. Clinical Biomechanics. 2008;23(8):1053-8. [pmid: 18534724].
1343 Mandeville DS, Osternig LR, Lantz BA, et al. A multivariate statistical ranking of clinical and gait measures before and after total knee replacement. Gait Posture. Aug. 2009;30(2):197-200. [pmid: 19464893].
1344 Manetta J, Franz LH, Moon C, et al. Comparison of hip and knee muscle moments in subjects with and without knee pain. Gait Posture. Dec. 2002;16(3):249-54. [pmid: 12443949].
1345 Mangaleshkar SR, Bajaj SK, Thomas AP. Denham total knee arthroplasty: a 10-year follow-up study. Journal of Arthroplasty. Aug. 2002;17(5):550-5. [pmid: 12168168].
1346 Mangione KK, Axen K, Haas F. Mechanical unweighting effects on treadmill exercise and pain in elderly people with osteoarthritis of the knee. Phys Ther. Apr. 1996;76(4):387-94. [pmid: 8606901].
1347 Manheimer E, Lim B, Lao L, et al. Acupuncture for knee osteoarthritis - a randomised trial using a novel sham. Acupuncture in Medicine. 2006;24(Suppl 1):7-14. [pmid: 17308513].
1348 Manheimer E, Linde K, Lao L, et al. Meta-analysis: acupuncture for osteoarthritis of the knee. Annals of Internal Medicine. 2007;146(12):868-77. [pmid: 17577006].
1349 Manicourt DH, Azria M, Mindeholm L, et al. Oral salmon calcitonin reduces Lequesne’s algofunctional index scores and decreases urinary and serum levels of biomarkers of joint metabolism in knee osteoarthritis. Arthritis Rheum. Oct. 2006;54(10):3205-11. [pmid: 17009253].
1350 Manicourt DH, Bevilacqua M, Righini V, et al. Comparative effect of nimesulide and ibuprofen on the urinary levels of collagen type II C-telopeptide degradation products and on the serum levels of hyaluronan and matrix metalloproteinases-3 and -13 in patients with flare-up of osteoarthritis. Drugs R D. 2005;6(5):261-71. [pmid: 16128596].
1351 Mannan K, Scott G. The Medial Rotation total knee replacement: a clinical and radiological review at a mean follow-up of six years. Journal of Bone & Joint Surgery - British Volume. Jun. 2009;91(6):750-6. [pmid: 19483227].
1352 Manninen P, Heliovaara M, Riihimaki H, et al. Does psychological distress predict disability?. Int J Epidemiol. Oct. 1997;26(5):1063-70. [pmid: 9363529].
1353 Manninen P, Riihimaki H, Heliovaara M, et al. Overweight, gender and knee osteoarthritis. Int J Obes Relat Metab Disord. Jun. 1996;20(6):595-7. [pmid: 8782738].
1354 Manninen P, Riihimaki H, Heliovaara M, et al. Physical exercise and risk of severe knee osteoarthritis requiring arthroplasty. Rheumatology. 2001;40(4):432-7. [pmid: 11312383].
1355 Mannoni A, Briganti MP, Di Bari M, et al. Epidemiological profile of symptomatic osteoarthritis in older adults: a population based study in Dicomano, Italy. Ann Rheum Dis. Jun. 2003;62(6):576-8. [pmid: 12759299].
1356 Manson JJ, Rahman A. This house believes that we should advise our patients with osteoarthritis of the knee to take glucosamine. Rheumatology. Jan. 2004;43(1):100-1. [pmid: 12867572].
1357 Marcacci M, Soavi R, Loreti I, et al. Micromotion between the half bearings in the interax prosthesis: a roentgen stereophotogrammetric analysis. Journal of Arthroplasty. Dec. 2001;16(8):991-7. [pmid: 11740753].
1358 Marcacci M, Zaffagnini S, Giordano G, et al. Anterior cruciate ligament reconstruction associated with extra-articular tenodesis: A prospective clinical and radiographic evaluation with 10- to 13-year follow-up. American Journal of Sports Medicine. Apr. 2009;37(4):707-14. [pmid: 19193599].
1359 Marcinkowski K, Wong VG, Dignam D. Getting back to the future: a grounded theory study of the patient perspective of total knee joint arthroplasty. Orthopaedic Nursing. May–Jun. 2005;24(3):202-9. [pmid: 15928530].
1360 Marin Morales LA, Gomez Navalon LA, Zorrilla Ribot P, et al. Treatment of osteoarthritis of the knee with valgus deformity by means of varus osteotomy. Acta Orthopaedica Belgica. Jun. 2000;66(3):272-8. [pmid: 11033918].
1361 Marino AA, Waddell DD, Kolomytkin OV, et al. Increased intercellular communication through gap junctions may contribute to progression of osteoarthritis. Clin Orthop Relat Res. May. 2004;(422):224-32. [pmid: 15187861].
1362 Marker DR, Mont MA, Seyler TM, et al. Does functional improvement following TKA correlate to increased sports activity?. Iowa Orthop J. 2009;29:11-6. [pmid: 19742078].
1363 Markou P, Chatzopoulos D. Yttrium-90 silicate radiosynovectomy treatment of painful synovitis in knee osteoarthritis. Results after 6 months. Hellenic Journal of Nuclear Medicine. Jan–Apr. 2009;12(1):33-6. [pmid: 19330180].
1364 Marks R. The effects of 16 months of angle-specific isometric strengthening exercises in midrange on torque of the knee extensor muscles in osteoarthritis of the knee: a case study. Journal of Orthopaedic & Sports Physical Therapy. Aug. 1994;20(2):103-9. [pmid: 7920601].
1365 Marks R. Further evidence of impaired position sense in knee osteoarthritis. Physiother Res Int. 1996;1(2):127-36. [pmid: 9238729].
1366 Marks R. Physical and psychological correlates of disability among a cohort of individuals with knee osteoarthritis. Can J Aging. Winter. 2007;26(4):367-77. [pmid: 18304923].
1367 Marks R. Obesity profiles with knee osteoarthritis: correlation with pain, disability, disease progression. Obesity (Silver Spring). Jul. 2007;15(7):1867-74. [pmid: 17636106].
1368 Marks R, Allegrante JP. Nonoperative management of osteoarthritis. Critical Reviews in Physical and Rehabilitation Medicine. 2001;13(2–3):131-58.
1369 Marks R, Allegrante JP. Chronic osteoarthritis and adherence to exercise: a review of the literature. J Aging Phys Act. Oct. 2005;13(4):434-60. [pmid: 16301755].
1370 Marks R, Cantin D. Symptomatic osteo-arthritis of the knee: the efficacy of physiotherapy. Physiotherapy (London). 1997;83(6):306-12.
1371 Marks R, Ungar M, Ghasemmi M. Electrical muscle stimulation for osteoarthritis of the knee: biological basis and systematic review. New Zealand Journal of Physiotherapy. 2000;28(3):6-20.
1372 Marlovits S, Singer P, Zeller P, et al. Magnetic resonance observation of cartilage repair tissue (MOCART) for the evaluation of autologous chondrocyte transplantation: determination of interobserver variability and correlation to clinical outcome after 2 years. European Journal of Radiology. Jan. 2006;57(1):16-23. [pmid: 16203119].
1373 Marques CJ, Barreiros J, Cabri J, et al. Does the brake response time of the right leg change after left total knee arthroplasty? A prospective study. Knee. Aug. 2008;15(4):295-8. [pmid: 18407504].
1374 Marra CA, Cibere J, Tsuyuki RT, et al. Improving osteoarthritis detection in the community: pharmacist identification of new, diagnostically confirmed osteoarthritis. Arthritis Rheum. Oct. 15. 2007;57(7):1238-44. [pmid: 17907209].
1375 Marsh AP, Rejeski WJ, Lang W, et al. Baseline balance and functional decline in older adults with knee pain: the Observational Arthritis Study in Seniors. J Am Geriatr Soc. Mar. 2003;51(3):331-9. [pmid: 12588576].
1376 Marshall KW, Zhang H, Yager TD, et al. Blood-based biomarkers for detecting mild osteoarthritis in the human knee. Osteoarthritis Cartilage. Oct. 2005;13(10):861-71. [pmid: 16139532].
1377 Martin S, Hernandez L, Romero J, et al. Diagnostic imaging of lipoma arborescens. Skeletal Radiology. Jun. 1998;27(6):325-9. [pmid: 9677649].
1378 Maruyama S, Yoshiya S, Matsui N, et al. Functional comparison of posterior cruciate-retaining versus posterior stabilized total knee arthroplasty. Journal of Arthroplasty. Apr. 2004;19(3):349-53. [pmid: 15067650].
1379 Marx RG. Knee rating scales. Arthroscopy. Dec. 2003;19(10):1103-8. [pmid: 14673453].
1380 Marx RG. Arthroscopic surgery for osteoarthritis of the knee?. [Erratum appears in N Engl J Med. 2008 Oct 9;359(15):1637]. New England Journal of Medicine. Sep. 11. 2008;359(11):1169-70. [pmid: 18784107].
1381 Marx RG, Jones EC, Allen AA, et al. Reliability, validity, and responsiveness of four knee outcome scales for athletic patients. J Bone Joint Surg Am. Oct. 2001;83-A(10):1459-69. [pmid: 11679594].
1382 Masri BA, Bourque J, Patil S. Outcome of unicompartmental knee arthroplasty in patients receiving worker’s compensation. Journal of Arthroplasty. Apr. 2009;24(3):444-7. [pmid: 18534432].
1383 Masui T, Hasegawa Y, Yamaguchi J, et al. Increasing postural sway in rural-community-dwelling elderly persons with knee osteoarthritis. Journal of Orthopaedic Science. Jul. 2006;11(4):353-8. [pmid: 16897198].
1384 Matarazzo Carolina G, Peccin Maria S, Almeida Gustavo JM, et al. Isokinetic exercise for improving knee flexor and extensor muscles, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2006.
1385 Mathieu P, Conrozier T, Vignon E, et al. Rheologic behavior of osteoarthritic synovial fluid after addition of hyaluronic acid: a pilot study. Clinical Orthopaedics & Related Research. Nov. 2009;467(11):3002-9. [pmid: 19418104].
1386 Matsuda S, Miura H, Nagamine R, et al. Effect of femoral and tibial component position on patellar tracking following total knee arthroplasty: 10-year follow-up of Miller-Galante I knees. American Journal of Knee Surgery. 2001;14(3):152-6. [pmid: 11491425].
1387 Matsuda S, Miura H, Nagamine R, et al. Knee stability in posterior cruciate ligament retaining total knee arthroplasty. Clinical Orthopaedics & Related Research. 1999;(366):169-73. [pmid: 10627731].
1388 Matsuda S, Mizu-uchi H, Miura H, et al. Tibial shaft axis does not always serve as a correct coronal landmark in total knee arthroplasty for varus knees. Journal of Arthroplasty. Jan. 2003;18(1):56-62. [pmid: 12555184].
1389 Matsui Y, Kadoya Y, Uehara K, et al. Rotational deformity in varus osteoarthritis of the knee: analysis with computed tomography. Clinical Orthopaedics & Related Research. 2005;(433):147-51. [pmid: 15805950].
1390 Matsumoto T, Kuroda R, Kubo S, et al. The intra-operative joint gap in cruciate-retaining compared with posterior-stabilised total knee replacement. Journal of Bone & Joint Surgery - British Volume. Apr. 2009;91(4):475-80. [pmid: 19336807].
1391 Matsumoto T, Mizuno K, Muratsu H, et al. Influence of intra-operative joint gap on post-operative flexion angle in osteoarthritis patients undergoing posterior-stabilized total knee arthroplasty. Knee Surgery, Sports Traumatology, Arthroscopy. Aug. 2007;15(8):1013-8. [pmid: 17457575].
1392 Matsumoto T, Tsumura N, Kubo S, et al. Influence of hip position on knee flexion angle in patients undergoing total knee arthroplasty. Journal of Arthroplasty. Aug. 2005;20(5):669-73. [pmid: 16310006].
1393 Matsumoto T, Tsumura N, Kurosaka M, et al. Prosthetic alignment and sizing in computer-assisted total knee arthroplasty. International Orthopaedics. Oct. 2004;28(5):282-5. [pmid: 15316675].
1394 Mattsson E, Brostrom LA. The physical and psychosocial effect of moderate osteoarthrosis of the knee. Scand J Rehabil Med. 1991;23(4):215-8. [pmid: 1785032].
1395 Mattsson E, Brostrom LA, Linnarsson D. Changes in walking ability after knee replacement. Int Orthop. 1990;14(3):277-80. [pmid: 2279836].
1396 Mattsson E, Olsson E, Brostrom LA. Assessment of walking before and after unicompartmental knee arthroplasty. A comparison of different methods. Scand J Rehabil Med. 1990;22(1):45-50. [pmid: 2326609].
1397 Mauer AC, Draganich LF, Pandya N, et al. Bilateral total knee arthroplasty increases the propensity to trip on an obstacle. Clinical Orthopaedics & Related Research. Apr. 2005;(433):160-5. [pmid: 15805952].
1398 Maurer F, Wassmer G. High tibial osteotomy: does navigation improve results?. [Erratum appears in Orthopedics. 2007 Apr;30(4):327]. Orthopedics. Oct. 2006;29(10 Suppl):S130-2. [pmid: 17407938].
1399 Mavrodontidis AN, Andrikoula SI, Kontogeorgakos VA, et al. Application of the Endomodel rotating hinge knee prosthesis for knee osteoarthritis. Journal of Surgical Orthopaedic Advances. 2008;17(3):179-84. [pmid: 18851803].
1400 Mazieres B, Combe B, Phan Van A, et al. Chondroitin sulfate in osteoarthritis of the knee: a prospective, double blind, placebo controlled multicenter clinical study. Journal of Rheumatology. Jan. 2001;28(1):173-81. [pmid: 11196521].
1401 Mazieres B, Hucher M, Zaim M, et al. Effect of chondroitin sulphate in symptomatic knee osteoarthritis: a multicentre, randomised, double-blind, placebo-controlled study. Annals of the Rheumatic Diseases. May. 2007;66(5):639-45. [pmid: 17204566].
1402 Mazzuca SA, Brandt KD, Eyre DR, et al. Urinary levels of type II collagen C-telopeptide crosslink are unrelated to joint space narrowing in patients with knee osteoarthritis. Ann Rheum Dis. Aug. 2006;65(8):1055-9. [pmid: 16339292].
1403 Mazzuca SA, Brandt KD, Katz BP, et al. Reduced utilization and cost of primary care clinic visits resulting from self-care education for patients with osteoarthritis of the knee. Arthritis & Rheumatism. Jun. 1999;42(6):1267-73. [pmid: 10366121].
1404 Mazzuca SA, Brandt KD, Katz BP, et al. Subject retention and adherence in a randomized placebo-controlled trial of a disease-modifying osteoarthritis drug. Arthritis & Rheumatism. Dec. 15. 2004;51(6):933-40. [pmid: 15593174].
1405 Mazzuca SA, Brandt KD, Katz BP, et al. Comparison of quantitative and semiquantitative indicators of joint space narrowing in subjects with knee osteoarthritis. Annals of the Rheumatic Diseases. Jan. 2006;65(1):64-8. [pmid: 15919678].
1406 Mazzuca SA, Brandt KD, Schauwecker DS, et al. Bone scintigraphy is not a better predictor of progression of knee osteoarthritis than Kellgren and Lawrence grade. J Rheumatol. Feb. 2004;31(2):329-32. [pmid: 14760805].
1407 Mazzuca SA, Poole AR, Brandt KD, et al. Associations between joint space narrowing and molecular markers of collagen and proteoglycan turnover in patients with knee osteoarthritis. Journal of Rheumatology. Jun. 2006;33(6):1147-51. [pmid: 16652436].
1408 McAlindon T, Formica M, LaValley M, et al. Effectiveness of glucosamine for symptoms of knee osteoarthritis: results from an internet-based randomized double-blind controlled trial. American Journal of Medicine. Nov. 1. 2004;117(9):643-9. [pmid: 15501201].
1409 McAlindon TE, Cooper C, Kirwan JR, et al. Determinants of disability in osteoarthritis of the knee. Ann Rheum Dis. Apr. 1993;52(4):258-62. [pmid: 8484690].
1410 McAlindon TE, Snow S, Cooper C, et al. Radiographic patterns of osteoarthritis of the knee joint in the community: the importance of the patellofemoral joint. Ann Rheum Dis. Jul. 1992;51(7):844-9. [pmid: 1632657].
1411 McAuley JP, Collier MB, Hamilton WG, et al. Posterior cruciate-retaining total knee arthroplasty for valgus osteoarthritis. Clinical Orthopaedics & Related Research. 2008;466(11):2644-9. [pmid: 18712454].
1412 McCalden RW, MacDonald SJ, Charron KDJ, et al. The role of polyethylene design on postoperative TKA flexion: an analysis of 1534 cases. Clinical Orthopaedics & Related Research. Jan. 2010;468(1):108-14. [pmid: 19847581].
1413 McCarthy C, Cushnaghan J, Dieppe P. The predictive role of scintigraphy in radiographic osteoarthritis of the hand. Osteoarthritis Cartilage. Mar. 1994;2(1):25-8. [pmid: 11548221].
1414 McCarthy C, Oldham J. The effectiveness of exercise in the treatment of osteoarthritic knees: a critical review. Physical Therapy Reviews. 1999;4(4):241-50.
1415 McCarthy CJ, Callaghan MJ, Oldham JA. The reliability of isometric strength and fatigue measures in patient with knee osteoarthritis. Manual Therapy. 2008;13(2):159-64. [pmid: 17296324].
1416 McCaslin James E, Macdonald S, Stansby Gerard P. Cryoplasty for peripheral vascular disease, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2007.
1417 McClelland JA, Webster KE, Feller JA. Variability of walking and other daily activities in patients with total knee replacement. Gait & Posture. Oct. 2009;30(3):288-95. [pmid: 19616951].
1418 McGibbon CA, Krebs DE. Compensatory gait mechanics in patients with unilateral knee arthritis. Journal of Rheumatology. Nov. 2002;29(11):2410-9. [pmid: 12415602].
1419 McGinty JB. Understanding the truth: arthroscopic surgery. The Journal of Knee Surgery. 2002;15(4):203. [pmid: 12416900].
1420 McHugh GA, Luker KA, Campbell M, et al. A longitudinal study exploring pain control, treatment and service provision for individuals with end-stage lower limb osteoarthritis. Rheumatology. 2007;46(4):631-7. [pmid: 17043045].
1421 McHugh GA, Silman AJ, Luker KA. Quality of care for people with osteoarthritis: a qualitative study. Journal of Clinical Nursing. Jul. 2007;16(7B):168-76. [pmid: 17584426].
1422 McKenna F, Borenstein D, Wendt H, et al. Celecoxib versus diclofenac in the management of osteoarthritis of the knee. Scandinavian Journal of Rheumatology. 2001;30(1):11-8. [pmid: 11252686].
1423 McMahon M, Block JA. The risk of contralateral total knee arthroplasty after knee replacement for osteoarthritis. J Rheumatol. Aug. 2003;30(8):1822-4. [pmid: 12913941].
1424 McNicholas MJ, Rowley DI, McGurty D, et al. Total meniscectomy in adolescence. A thirty-year follow-up. J Bone Joint Surg Br. Mar. 2000;82(2):217-21. [pmid: 10755429].
1425 McQueen DA, Cooke FW, Hahn DL. Knee arthrodesis with the Wichita Fusion Nail: an outcome comparison. Clinical Orthopaedics & Related Research. 2006;446(Journal Article):132-9. [pmid: 16672882].
1426 McQueen K. An acute care episode of a patient following bilateral total knee arthroplasty. Physiother Theory Pract. Apr. 2006;22(2):97-103. [pmid: 16703819].
1427 Medina JM, Thomas A, Denegar CR. Knee osteoarthritis: should your patient opt for hyaluronic acid injection?. Journal of Family Practice. Aug. 2006;55(8):669-75. [pmid: 16882439].
1428 Meding JB, Anderson AR, Faris PM, et al. Is the preoperative radiograph useful in predicting the outcome of a total hip replacement?. Clin Orthop Relat Res. Jul. 2000;(376):156-60. [pmid: 10906871].
1429 Meding JB, Ritter MA, Faris PM. Total knee arthroplasty with 4.4 mm of tibial polyethylene: 10-year followup. Clinical Orthopaedics & Related Research. 2001;(388):112-7. [pmid: 11451109].
1430 Meding JB, Wing JT, Keating EM, et al. Total knee arthroplasty for isolated patellofemoral arthritis in younger patients. Clinical Orthopaedics & Related Research. 2007;464(Journal Article):78-82. [pmid: 17975374].
1431 Mehta K, Gala J, Bhasale S, et al. Comparison of glucosamine sulfate and a polyherbal supplement for the relief of osteoarthritis of the knee: a randomized controlled trial. [ISRCTN25438351]. BMC Complementary & Alternative Medicine. 2007;7(Journal Article):34. [pmid: 17974032].
1432 Mehta S, Vankleunen JP, Booth RE, et al. Total knee arthroplasty in patients with Parkinson’s disease: impact of early postoperative neurologic intervention. American Journal of Orthopedics (Chatham, Nj). 2008;37(10):513-6. [pmid: 19081879].
1433 MeiDan O, Kish B, Shabat S, et al. Treatment of osteoarthritis of the ankle by intra-articular injections of hyaluronic acid. Journal - American Podiatric Medical Association. 2010;100(2):93-100.
1434 Melzer I, Yekutiel M, Sukenik S. Comparative study of osteoarthritis of the contralateral knee joint of male amputees who do and do not play volleyball. J Rheumatol. Jan. 2001;28(1):169-72. [pmid: 11196520].
1435 Meng CR, Fan L, Fu WB, et al. Clinical research on abdominal acupuncture plus conventional acupuncture for knee osteoarthritis. Journal of Traditional Chinese Medicine. 2009;29(4):249-52. [pmid: 20112481].
1436 Merchant AC. Early results with a total patellofemoral joint replacement arthroplasty prosthesis. Journal of Arthroplasty. Oct. 2004;19(7):829-36. [pmid: 15483797].
1437 Merchant AC. A modular prosthesis for patellofemoral arthroplasty: design and initial results. Clinical Orthopaedics & Related Research. 2005;(436):40-6. [pmid: 15995418].
1438 Merle-Vincent F, Couris CM, Schott AM, et al. Cross-sectional study of pain and disability at knee replacement surgery for osteoarthritis in 299 patients. Joint Bone Spine. Dec. 2007;74(6):612-6. [pmid: 17892964].
1439 Messent EA, Buckland-Wright JC, Blake GM. Fractal analysis of trabecular bone in knee osteoarthritis (OA) is a more sensitive marker of disease status than bone mineral density (BMD). Calcif Tissue Int. Jun. 2005;76(6):419-25. [pmid: 15834503].
1440 Messieh M. Preoperative risk factors associated with symptomatic pulmonary embolism after total knee arthroplasty. Orthopedics. Dec. 1999;22(12):1147-9. [pmid: 10604808].
1441 Messier SP. Physical activity and weight loss interventions in older adults with knee osteoarthritis. North Carolina Medical Journal. Nov–Dec. 2007;68(6):436-8. [pmid: 18236864].
1442 Messier SP. Diet and exercise for obese adults with knee osteoarthritis. Clin Geriatr Med. Aug. 2010;26(3):461-77. [pmid: 20699166].
1443 Messier SP, DeVita P, Cowan RE, et al. Do older adults with knee osteoarthritis place greater loads on the knee during gait? A preliminary study. Archives of Physical Medicine and Rehabilitation. 2005;86(4):703-9. [pmid: 15827921].
1444 Messier SP, Glasser JL, Ettinger WH Jr, et al. Declines in strength and balance in older adults with chronic knee pain: a 30-month longitudinal, observational study. Arthritis Rheum. Apr. 15. 2002;47(2):141-8. [pmid: 11954007].
1445 Messier SP, Gutekunst DJ, Davis C, et al. Weight loss reduces knee-joint loads in overweight and obese older adults with knee osteoarthritis. Arthritis Rheum. Jul. 2005;52(7):2026-32. [pmid: 15986358].
1446 Messier SP, Loeser RF, Mitchell MN, et al. Exercise and weight loss in obese older adults with knee osteoarthritis: a preliminary study. J Am Geriatr Soc. Sep. 2000;48(9):1062-72. [pmid: 10983905].
1447 Messier SP, Mihalko S, Loeser RF, et al. Glucosamine/chondroitin combined with exercise for the treatment of knee osteoarthritis: a preliminary study. Osteoarthritis Cartilage. Nov. 2007;15(11):1256-66. [pmid: 17561418].
1448 Messner K. Indications for meniscal transplantation. Who and how many need a meniscus substitute? A personal view. Scandinavian Journal of Medicine & Science in Sports. Jun. 1999;9(3):184. [pmid: 10380278].
1449 Meuffels DE, Favejee MM, Vissers MM, et al. Ten year follow-up study comparing conservative versus operative treatment of anterior cruciate ligament ruptures. A matched-pair analysis of high level athletes. British Journal of Sports Medicine. May. 2009;43(5):347-51. [pmid: 18603576].
1450 Meunier A, Aspenberg P, Good L. Celecoxib does not appear to affect prosthesis fixation in total knee replacement: A randomized study using radiostereometry in 50 patients. Acta Orthopaedica. Feb. 2009;80(1):46-50. [pmid: 19234885].
1451 Meunier A, Lisander B, Good L. Effects of celecoxib on blood loss, pain, and recovery of function after total knee replacement: a randomized placebo-controlled trial. Acta Orthopaedica. Oct. 2007;78(5):661-7. [pmid: 17966026].
1452 Miceli-Richard C, Le Bars M, Schmidely N, et al. Paracetamol in osteoarthritis of the knee. Annals of the Rheumatic Diseases. 2004;63(8):923-30. [pmid: 15249319].
1453 Michalak KA, Khoo PPC, Yates PJ, et al. Iontophoresed segmental allografts in revision arthroplasty for infection. Journal of Bone & Joint Surgery - British Volume. Nov. 2006;88(11):1430-7. [pmid: 17075085].
1454 Michalsen A, Klotz S, Ludtke R, et al. Effectiveness of leech therapy in osteoarthritis of the knee: a randomized, controlled trial. Annals of Internal Medicine. 2003;139(9):724-30. [pmid: 14597456].
1455 Michalsen A, Moebus S, Spahn G, et al. Leech therapy for symptomatic treatment of knee osteoarthritis: results and implications of a pilot study. Alternative Therapies in Health and Medicine. 2002;8(5):84-8. [pmid: 12233807].
1456 Middleton FR, Boardman DR, Abbassian A, et al. Unicondylar knee arthroplasty in a patient with poliomyelitis. J Surg Orthop Adv. Spring. 2009;18(1):35-8. [pmid: 19327264].
1457 Middleton J, Americh L, Gayon R, et al. A comparative study of endothelial cell markers expressed in chronically inflamed human tissues: MECA-79, Duffy antigen receptor for chemokines, von Willebrand factor, CD31, CD34, CD105 and CD146. J Pathol. Jul. 2005;206(3):260-8. [pmid: 15887283].
1458 Mihalko WM, Ali M, Phillips MJ, et al. Passive knee kinematics before and after total knee arthroplasty: are we correcting pathologic motion?. Journal of Arthroplasty. Jan. 2008;23(1):57-60. [pmid: 18165029].
1459 Miller A, Doll H, David J, et al. Impact of musculoskeletal disease on quality of life in long-standing acromegaly. European Journal of Endocrinology. 2008;158(5):587-93. [pmid: 18426816].
1460 Miller BS, Downie B, McDonough EB, et al. Complications after medial opening wedge high tibial osteotomy. Arthroscopy. Jun. 2009;25(6):639-46. [pmid: 19501295].
1461 Miller BS, Joseph TA, Barry EM, et al. Patient satisfaction after medial opening high tibial osteotomy and microfracture. The Journal of Knee Surgery. Apr. 2007;20(2):129-33. [pmid: 17486904].
1462 Miller GD, Nicklas BJ, Davis C, et al. Intensive weight loss program improves physical function in older obese adults with knee osteoarthritis. Obesity (Silver Spring). Jul. 2006;14(7):1219-30. [pmid: 16899803].
1463 Miller LE, Grifka J, Scholmerich J, et al. Norepinephrine from synovial tyrosine hydroxylase positive cells is a strong indicator of synovial inflammation in rheumatoid arthritis. J Rheumatol. Mar. 2002;29(3):427-35. [pmid: 11908553].
1464 Miller ME, Rejeski WJ, Messier SP, et al. Modifiers of change in physical functioning in older adults with knee pain: The Observational Arthritis Study in Seniors (OASIS). Arthritis Care and Research. 2001;45(4):331-9. [pmid: 11501720].
1465 Milner CE, O’Bryan ME. Bilateral frontal plane mechanics after unilateral total knee arthroplasty. Archives of Physical Medicine & Rehabilitation. Oct. 2008;89(10):1965-9. [pmid: 18929025].
1466 Milner SA, Davis TR, Muir KR, et al. Long-term outcome after tibial shaft fracture: is malunion important?. J Bone Joint Surg Am. Jun. 2002;84-A(6):971-80. [pmid: 12063331].
1467 Clinical, X-Ray and Ultrasound Findings of Knee in Rheumathoid Arthritis and Osteoarthritis. 2006 Annual European Congress of Rheumatology (EULAR 2006). Amsterdam (Netherlands (The)). 21–24 Jun 2006.
1468 Minas T. Autologous chondrocyte implantation in the arthritic knee. Orthopedics. Sep. 2003;26(9):945-7. [pmid: 14503759].
1469 Minas T, Gomoll AH, Solhpour S, et al. Autologous chondrocyte implantation for joint preservation in patients with early osteoarthritis. Clinical Orthopaedics & Related Research. Jan. 2010;468(1):147-57. [pmid: 19653049].
1470 Miner AL, Lingard EA, Wright EA, et al. Knee range of motion after total knee arthroplasty: how important is this as an outcome measure?. Journal of Arthroplasty. Apr. 2003;18(3):286-94. [pmid: 12728419].
1471 Minns Lowe CJ, Barker KL, Dewey M, et al. Effectiveness of physiotherapy exercise after knee arthroplasty for osteoarthritis: systematic review and meta-analysis of randomised controlled trials. BMJ. Oct. 20. 2007;335(7624):812. [pmid: 17884861].
1472 Minoda Y, Sakawa A, Aihara M, et al. Flexion gap preparation opens the extension gap in posterior cruciate ligament-retaining TKA. Knee Surgery, Sports Traumatology, Arthroscopy. Nov. 2007;15(11):1321-5. [pmid: 17684727].
1473 Minor. Physical Activity and Knee Osteoarthritis: Answers and Questions. Arthritis Care and Research. 2007;57(1):1-2. [pmid: 17266068].
1474 Mintken PE, Carpenter KJ, Eckhoff D, et al. Early neuromuscular electrical stimulation to optimize quadriceps muscle function following total knee arthroplasty: a case report. Journal of Orthopaedic & Sports Physical Therapy. Jul. 2007;37(7):364-71. [pmid: 17710905].
1475 Miranda H, VikariJuntura E, Martikainen R, et al. A prospective study on knee pain and its risk factors. Osteoarthritis and Cartilage. 2002;10(8):623-30. [pmid: 12479384].
1476 Misra AN, Hussain MRA, Fiddian NJ, et al. The role of the posterior cruciate ligament in total knee replacement. Journal of Bone & Joint Surgery - British Volume. Apr. 2003;85(3):389-92. [pmid: 12729115].
1477 Mitchell C, Walker J, Walters S, et al. Costs and effectiveness of pre- and post-operative home physiotherapy for total knee replacement: randomized controlled trial. Journal of Evaluation in Clinical Practice. Jun. 2005;11(3):283-92. [pmid: 15869558].
1478 Mitchell HL, Carr AJ, Scott DL. The management of knee pain in primary care: factors associated with consulting the GP and referrals to secondary care. Rheumatology (Oxford). Jun. 2006;45(6):771-6. [pmid: 16461443].
1479 Miyagi T, Matsuda S, Miura H, et al. Changes in patellar tracking after total knee arthroplasty: 10-year follow-up of Miller-Galante I knees. Orthopedics. Aug. 2002;25(8):811-3. [pmid: 12195906].
1480 Miyaguchi M, Kobayashi A, Kadoya Y, et al. Biochemical change in joint fluid after isometric quadriceps exercise for patients with osteoarthritis of the knee. Osteoarthritis Cartilage. Apr. 2003;11(4):252-9. [pmid: 12681951].
1481 Mizner RL, Petterson SC, Snyder-Mackler L. Quadriceps strength and the time course of functional recovery after total knee arthroplasty. Journal of Orthopaedic & Sports Physical Therapy. Jul. 2005;35(7):424-36. [pmid: 16108583].
1482 Mizner RL, Petterson SC, Stevens JE, et al. Preoperative quadriceps strength predicts functional ability one year after total knee arthroplasty. J Rheumatol. Aug. 2005;32(8):1533-9. [pmid: 16078331].
1483 Mizner RL, Petterson SC, Stevens JE, et al. Early quadriceps strength loss after total knee arthroplasty. The contributions of muscle atrophy and failure of voluntary muscle activation. J Bone Joint Surg Am. May. 2005;87(5):1047-53. [pmid: 15866968].
1484 Mizner RL, Stevens JE, Snyder-Mackler L. Voluntary activation and decreased force production of the quadriceps femoris muscle after total knee arthroplasty. Phys Ther. Apr. 2003;83(4):359-65. [pmid: 12665406].
1485 Mizu-Uchi H, Matsuda S, Miura H, et al. Three-dimensional analysis of computed tomography-based navigation system for total knee arthroplasty: the accuracy of computed tomography-based navigation system. Journal of Arthroplasty. Oct. 2009;24(7):1103-10. [pmid: 18848426].
1486 Modawal A, Ferrer M, Choi HK, et al. Hyaluronic acid injections relieve knee pain. Journal of Family Practice. Sep. 2005;54(9):758-67. [pmid: 16144589].
1487 Mody S, Jolly M, Kwasny MJ, et al. Patient reported outcomes and analgesia use in osteoarthritis of the knee. Osteoarthritis & Cartilage. Nov. 2008;16(11):1294-9. [pmid: 18456521].
1488 Moen MD. Topical diclofenac solution. Drugs. 2009;69(18):2621-32. [pmid: 19943711].
1489 Mohammed R, Syed S, Ahmed N. Manipulation under anaesthesia for stiffness following knee arthroplasty. Annals of the Royal College of Surgeons of England. Apr. 2009;91(3):220-3. [pmid: 19102828].
1490 Mokkink LB, Terwee CB, van der Slikke RM, et al. Reproducibility and validity of the DynaPort KneeTest. Arthritis Rheum. Jun. 15. 2005;53(3):357-63. [pmid: 15934012].
1491 Mokkink LB, Terwee CB, van Lummel RC, et al. Construct validity of the DynaPort KneeTest: a comparison with observations of physical therapists. Osteoarthritis Cartilage. Aug. 2005;13(8):738-43. [pmid: 15951201].
1492 Molfetta L, Caldo D. Computer navigation versus conventional implantation for varus knee total arthroplasty: a case-control study at 5 years follow-up. Knee. Mar. 2008;15(2):75-9. [pmid: 18234498].
1493 Moller I, Perez M, Monfort J, et al. Effectiveness of chondroitin sulphate in patients with concomitant knee osteoarthritis and psoriasis: a randomized, double-blind, placebo-controlled study. Osteoarthritis Cartilage. Jun. Suppl 1. 2010;18:S32-40. [pmid: 20399899].
1494 Mont MA, Haas S, Mullick T, et al. Total knee arthroplasty for patellofemoral arthritis. Journal of Bone & Joint Surgery - American Volume. Nov. 2002;84-A(11):1977-81. [pmid: 12429758].
1495 Mont MA, Lee CW, Sheldon M, et al. Total knee arthroplasty in patients </=50 years old. Journal of Arthroplasty. Aug. 2002;17(5):538-43. [pmid: 12168166].
1496 Mont MA, Rajadhyaksha AD, Low K, et al. Anatomy of the knee extensor mechanism: correlation with patellofemoral arthrosis. J South Orthop Assoc. Spring. 2001;10(1):24-31. [pmid: 12132839].
1497 Mont MA, Yoon TR, Krackow KA, et al. Eliminating patellofemoral complications in total knee arthroplasty: clinical and radiographic results of 121 consecutive cases using the Duracon system. Journal of Arthroplasty. Jun. 1999;14(4):446-55. [pmid: 10428225].
1498 Monteforte P, Sessarego P, Rovetta G. Sonographic assessment of soft tissue alterations in osteoarthritis of the knee. G Ital Med Lav Ergon. Jan–Mar. 2008;30(1):75-7. [pmid: 18700680].
1499 Moon Y-W, Seo J-G, Lim S-J, et al. Variability in femoral component rotation reference axes measured during navigation-assisted total knee arthroplasty using gap technique. Journal of Arthroplasty. Feb. 2010;25(2):238-43. [pmid: 19559562].
1500 Moore RA, Moore OA, Derry S, et al. Responder analysis for pain relief and numbers needed to treat in a meta-analysis of etoricoxib osteoarthritis trials: bridging a gap between clinical trials and clinical practice. Annals of the Rheumatic Diseases. Feb. 2010;69(2):374-9. [pmid: 19364730].
1501 Morgan SL, Baggott JE, Moreland L, et al. The safety of flavocoxid, a medical food, in the dietary management of knee osteoarthritis. J Med Food. Oct. 2009;12(5):1143-8. [pmid: 19857081].
1502 Morone NE, Karp JF, Lynch CS, et al. Impact of chronic musculoskeletal pathology on older adults: a study of differences between knee OA and low back pain. Pain Medicine. May–Jun. 2009;10(4):693-701. [pmid: 19254337].
1503 Morscher E. Orthopaedic surgery in the rehabilitation of geriatric patients. Int Rehabil Med. 1979;1(4):193-9. [pmid: 263008].
1504 The Effect of Gallium Aluminum Arsenide (Galalas) Together with Exercise on the Level of Pain and Function of Knee Osteoarthritis. 2006 Annual Congress of the International Academy of Laser Medicine and Surgery (Laser Florence 2006). Villa Viviani, Florence (Italy). 10–11 Nov 2006.
1505 Morsi E. Continuous-flow cold therapy after total knee arthroplasty. Journal of Arthroplasty. Sep. 2002;17(6):718-22. [pmid: 12216025].
1506 Moschella D, Blasi A, Leardini A, et al. Wear patterns on tibial plateau from varus osteoarthritic knees. Clinical Biomechanics. 2006;21(2):152-8. [pmid: 16260075].
1507 Moseley JB, O’Malley K, Petersen NJ, et al. A controlled trial of arthroscopic surgery for osteoarthritis of the knee. [Summary for patients in J Fam Pract. 2002 Oct;51(10):813; PMID: 12401143]. New England Journal of Medicine. Jul. 11. 2002;347(2):81-8. [pmid: 12110735].
1508 Autologous Conditioned Serum (ACS) Compared to Hyaluronan and Saline-injections for the Treatment of Knee Osteoarthritis: Therapeutic Study, Level I. 7th World Congress on Cartilage Repair (ICRS 2007), Hilton Conference Center. Warsaw (Poland). 29 Sep–2 Oct 2007.
1509 Mosher TJ, Liu Y, Torok CM. Functional cartilage MRI T2 mapping: evaluating the effect of age and training on knee cartilage response to running. Osteoarthritis & Cartilage. Mar. 2010;18(3):358-64. [pmid: 19948266].
1510 Moskowitz RW. Role of collagen hydrolysate in bone and joint disease. Seminars in Arthritis & Rheumatism. Oct. 2000;30(2):87-99. [pmid: 11071580].
1511 Moskowitz RW, Altman RD. Efficacy of intraarticular hyaluronan in the treatment of knee osteoarthritis: comment on the article by Brandt et al. Arthritis & Rheumatism. Jun. 2001;44(6):1471-6. [pmid: 11407712].
1512 Moskowitz RW, Sunshine A, Hooper M, et al. An analgesic model for assessment of acute pain response in osteoarthritis of the knee. Osteoarthritis & Cartilage. Nov. 2006;14(11):1111-8. [pmid: 16784879].
1513 Mounsey A, Ewigman B. Arthroscopic surgery for knee osteoarthritis? Just say no. Journal of Family Practice. Mar. 2009;58(3):143-5. [pmid: 19284940].
1514 Mousavi SJ, Parnianpour M, Askary-Ashtiani AR, et al. Translation and validation study of the Persian version of the Arthritis Impact Measurement Scales 2 (AIMS2) in patients with osteoarthritis of the knee. BMC Musculoskeletal Disorders. 2009;10(Journal Article):95. [pmid: 19646273].
1515 Mullaji AB, Marawar SV, Mittal V. A comparison of coronal plane axial femoral relationships in Asian patients with varus osteoarthritic knees and healthy knees. Journal of Arthroplasty. Sep. 2009;24(6):861-7. [pmid: 18701244].
1516 Muller SD, Deehan DJ, Holland JP, et al. Should we reconsider all-polyethylene tibial implants in total knee replacement?. Journal of Bone & Joint Surgery - British Volume. Dec. 2006;88(12):1596-602. [pmid: 17159170].
1517 Muller-Fassbender H, Bach GL, Haase W, et al. Glucosamine sulfate compared to ibuprofen in osteoarthritis of the knee. Osteoarthritis & Cartilage. Mar. 1994;2(1):61-9. [pmid: 11548225].
1518 Munar A, Gamboa Oscar A, Ortiz Nathalia I. Homeopathy for osteoarthritis, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2007.
1519 Muncie HL Jr. Medical aspects of the multidisciplinary assessment and management of osteoarthritis. Clinical Therapeutics. Suppl B. 1986;9:4-13. [pmid: 3829096].
1520 Mundermann A, Asay JL, Mundermann L, et al. Implications of increased medio-lateral trunk sway for ambulatory mechanics. Journal of Biomechanics. 2008;41(1):165-70. [pmid: 17678933].
1521 Mundermann A, Dyrby CO, Andriacchi TP. Secondary gait changes in patients with medial compartment knee osteoarthritis: increased load at the ankle, knee, and hip during walking. Arthritis & Rheumatism. Sep. 2005;52(9):2835-44. [pmid: 16145666].
1522 Mundermann A, Dyrby CO, Hurwitz DE, et al. Potential strategies to reduce medial compartment loading in patients with knee osteoarthritis of varying severity: reduced walking speed. [Erratum appears in Arthritis Rheum. 2004 Dec;50(12):4073]. Arthritis & Rheumatism. Apr. 2004;50(4):1172-8. [pmid: 15077299].
1523 Muraki S, Akune T, Oka H, et al. Association of occupational activity with radiographic knee osteoarthritis and lumbar spondylosis in elderly patients of population-based cohorts: a large-scale population-based study. Arthritis Rheum. Jun. 15. 2009;61(6):779-86. [pmid: 19479710].
1524 Muraki S, Oka H, Akune T, et al. Prevalence of radiographic knee osteoarthritis and its association with knee pain in the elderly of Japanese population-based cohorts: the ROAD study. Osteoarthritis Cartilage. Sep. 2009;17(9):1137-43. [pmid: 19410032].
1525 Murphy JM, Fink DJ, Hunziker EB, et al. Stem cell therapy in a caprine model of osteoarthritis. Arthritis & Rheumatism. Dec. 2003;48(12):3464-74. [pmid: 14673997].
1526 The Effect of Activity Strategy Training on Pain and Physical Activity in Older Adults with Knee or Hip Osteoarthritis. 2008 Annual Scientific Meeting of the American College of Rheumatology and Association of Rheumatology Health Professionals. Moscone Center, San Francisco, California (USA). 24–29 Oct 2008.
1527 Murray DW. Mobile bearing unicompartmental knee replacement. Orthopedics. Sep. 2007;30(9):768-9. [pmid: 17899931].
1528 Myles CM, Rowe PJ, Nutton RW, et al. The effect of patella resurfacing in total knee arthroplasty on functional range of movement measured by flexible electrogoniometry. Clinical Biomechanics. 2006;21(7):733-9. [pmid: 16603285].
1529 Myles CM, Rowe PJ, Walker CR, et al. Knee joint functional range of movement prior to and following total knee arthroplasty measured using flexible electrogoniometry. Gait and Posture. 2002;16(1):46-54. [pmid: 12127186].
1530 Myllykangas-Luosujarvi R, Lu HS, Chen SL, et al. Comparison of low-dose rofecoxib versus 1000 mg naproxen in patients with osteoarthritis. Results of two randomized treatment trials of six weeks duration. Scandinavian Journal of Rheumatology. 2002;31(6):337-44. [pmid: 12492248].
1531 Naal FD, Impellizzeri FM, Leunig M. Which is the best activity rating scale for patients undergoing total joint arthroplasty? Clinical Orthopaedics &. Related Research. 2009;467(4):958-65. [pmid: 18587624].
1532 Naal FD, Impellizzeri FM, Sieverding M, et al. The 12-item Oxford knee score: Cross-cultural adaptation into German and assessment of its psychometric properties in patients with osteoarthritis of the knee. Osteoarthritis and Cartilage. 2009;17(1):49-52. [pmid: 18602843].
1533 Nabeyama R, Matsuda S, Miura H, et al. Changes in anteroposterior stability following total knee arthroplasty. Journal of Orthopaedic Science. 2003;8(4):526-31. [pmid: 12898305].
1534 Nadaud MC, Komistek RD, Mahfouz MR, et al. In vivo three-dimensional determination of the effectiveness of the osteoarthritic knee brace: a multiple brace analysis. Journal of Bone and Joint Surgery (American). 2005;87(Supp 2):114-9. [pmid: 16326730].
1535 Nagamine R, Inoue S, Miura H, et al. Femoral shaft bowing influences the correction angle for high tibial osteotomy. Journal of Orthopaedic Science. May. 2007;12(3):214-8. [pmid: 17530372].
1536 Nagamine R, Kondo K, Ikemura S, et al. Distal femoral cut perpendicular to the mechanical axis may induce varus instability in flexion in medial osteoarthritic knees with varus deformity in total knee arthroplasty: a pitfall of the navigation system. Journal of Orthopaedic Science. 2004;9(6):555-9. [pmid: 16228670].
1537 Nagura T, Matsumoto H, Kiriyama Y, et al. Tibiofemoral Joint Contact Force in Deep Knee Flexion and Its Consideration in Knee Osteoarthritis and Joint Replacement. Journal of Applied Biomechanics. 2006;22(4):305-13. [pmid: 17293627].
1538 Najm WI, Reinsch S, Hoehler F, et al. S-adenosyl methionine (SAMe) versus celecoxib for the treatment of osteoarthritis symptoms: a double-blind cross-over trial. BMC Musculoskeletal Disorders. 2004;5(Journal Article):6. [pmid: 15102339].
1539 Nakajima M, Kizawa H, Saitoh M, et al. Mechanisms for asporin function and regulation in articular cartilage. J Biol Chem. Nov. 2. 2007;282(44):32185-92. [pmid: 17827158].
1540 Nakamura E, Banks SA, Tanaka A, et al. Three-dimensional tibiofemoral kinematics during deep flexion kneeling in a mobile-bearing total knee arthroplasty. Journal of Arthroplasty. Oct. 2009;24(7):1120-4. [pmid: 18823746].
1541 Nakamura S, Takagi H, Asano T, et al. Fluoroscopic and computed tomographic analysis of knee kinematics during very deep flexion after total knee arthroplasty. Journal of Arthroplasty. Apr. 2010;25(3):486-91. [pmid: 19195826].
1542 Nakashima K, Koshino T, Saito T. Synovial immunohistochemical changes after high tibial osteotomy for osteoarthritis of the knee. Two-year prospective follow-up. Bulletin of the Hospital for Joint Diseases. 1998;57(4):187-94. [pmid: 9926257].
1543 Narasimha Murty A, El Zebdeh MY, Ireland J. Femoral shaft osteotomy for malunited femoral fractures presenting with varus OA of the knee. Knee. Dec. 2004;11(6):445-9. [pmid: 15581762].
1544 Narayan K, Thomas G, Kumar R. Is extreme flexion of the knee after total knee replacement a prerequisite for patient satisfaction?. International Orthopaedics. Jun. 2009;33(3):671-4. [pmid: 18509639].
1545 National Center for C, Alternative M. The NIH Glucosamine/Chondroitin Arthritis Intervention Trial (GAIT). Journal of Pain & Palliative Care Pharmacotherapy. 2008;22(1):39-43. [pmid: 19062354].
1546 Naudie D, Bourne RB, Rorabeck CH, et al. The Install Award. Survivorship of the high tibial valgus osteotomy. A 10- to -22-year followup study. Clinical Orthopaedics & Related Research. 1999;(367):18-27. [pmid: 10546594].
1547 Navazio F. Treatment of degenerative arthritis of the knee. Clinica Terapeutica. Nov–Dec. 2003;154(6):445-6. [pmid: 14994526].
1548 Nelson AE, Golightly YM, Kraus VB, et al. Serum transforming growth factor-beta 1 is not a robust biomarker of incident and progressive radiographic osteoarthritis at the hip and knee: the Johnston County Osteoarthritis Project. Osteoarthritis Cartilage. Jun. 2010;18(6):825-9. [pmid: 20206313].
1549 Neuman P, Englund M, Kostogiannis I, et al. Prevalence of tibiofemoral osteoarthritis 15 years after nonoperative treatment of anterior cruciate ligament injury: a prospective cohort study. American Journal of Sports Medicine. Sep. 2008;36(9):1717-25. [pmid: 18483197].
1550 Neuman P, Kostogiannis I, Friden T, et al. Patellofemoral osteoarthritis 15 years after anterior cruciate ligament injury--a prospective cohort study. Osteoarthritis & Cartilage. Mar. 2009;17(3):284-90. [pmid: 18771938].
1551 Neumann G, Hunter D, Nevitt M, et al. Location specific radiographic joint space width for osteoarthritis progression. Osteoarthritis & Cartilage. Jun. 2009;17(6):761-5. [pmid: 19073368].
1552 Neustadt D, Caldwell J, Bell M, et al. Clinical effects of intraarticular injection of high molecular weight hyaluronan (Orthovisc) in osteoarthritis of the knee: a randomized, controlled, multicenter trial. Journal of Rheumatology. Oct. 2005;32(10):1928-36. [pmid: 16206349].
1553 Neustadt DH. Long-term efficacy and safety of intra-articular sodium hyaluronate (Hyalgan) in patients with osteoarthritis of the knee. Clinical & Experimental Rheumatology. May–Jun. 2003;21(3):307-11. [pmid: 12846048].
1554 Neves EB, Pino AV, Almeida RR, et al. Objective assessment of knee osteroarthritis in parachuters by bioimpedance spectroscopy. Conf Proc IEEE Eng Med Biol Soc. 2008;2008:5620-3. [pmid: 19163991].
1555 Nevitt MC, Felson DT, Williams EN, et al. The effect of estrogen plus progestin on knee symptoms and related disability in postmenopausal women: The Heart and Estrogen/Progestin Replacement Study, a randomized, double-blind, placebo-controlled trial. Arthritis Rheum. Apr. 2001;44(4):811-8. [pmid: 11315920].
1556 Nevitt MC, Peterfy C, Guermazi A, et al. Longitudinal performance evaluation and validation of fixed-flexion radiography of the knee for detection of joint space loss. Arthritis Rheum. May. 2007;56(5):1512-20. [pmid: 17469126].
1557 Nevitt MC, Sharma L. OMERACT workshop radiography session 1. Osteoarthritis & Cartilage. Suppl A. 2006;14:A4-9. [pmid: 16753308].
1558 Newell RS, HubleyKozey CL, Stanish WD, et al. Detecting Differences Between Asymptomatic and Osteoarthritic Gait Is Influenced by Changing the Knee Adduction Moment Model. Gait and Posture. 2008;27(3):485-92. [pmid: 17764948].
1559 Newman J, Pydisetty RV, Ackroyd C. Unicompartmental or total knee replacement: the 15-year results of a prospective randomised controlled trial. Journal of Bone & Joint Surgery - British Volume. 2009;91(1):52-7. [pmid: 19092004].
1560 Ng NTM, Heesch KC, Brown WJ. Efficacy of a progressive walking program and glucosamine sulphate supplementation on osteoarthritic symptoms of the hip and knee: a feasibility trial. Arthritis Research & Therapy. 2010;12(1):R25. [pmid: 20152042].
1561 Nickinson R, Darrah C, Donell S. Accuracy of clinical diagnosis in patients undergoing knee arthroscopy. Int Orthop. Feb. 2010;34(1):39-44. [pmid: 19337731].
1562 Nicklas BJ, Mychaleckyj J, Kritchevsky S, et al. Physical function and its response to exercise: associations with cytokine gene variation in older adults with knee osteoarthritis. J Gerontol A Biol Sci Med Sci. Oct. 2005;60(10):1292-8. [pmid: 16282562].
1563 Niemeyer P, Koestler W, Kaehny C, et al. Two-year results of open-wedge high tibial osteotomy with fixation by medial plate fixator for medial compartment arthritis with varus malalignment of the knee. Arthroscopy. Jul. 2008;24(7):796-804. [pmid: 18589268].
1564 Niethard FU, Gold MS, Solomon GS, et al. Efficacy of topical diclofenac diethylamine gel in osteoarthritis of the knee. Journal of Rheumatology. Dec. 2005;32(12):2384-92. [pmid: 16331769].
1565 Niinimaki T, Ojala R, Niinimaki J, et al. The standing fixed flexion view detects narrowing of the joint space better than the standing extended view in patients with moderate osteoarthritis of the knee. Acta Orthopaedica. Jun. 2010;81(3):344-6. [pmid: 20450420].
1566 Nilsdotter AK, Toksvig-Larsen S, Roos EM. Knee arthroplasty: are patients’ expectations fulfilled? A prospective study of pain and function in 102 patients with 5-year follow-up. Acta Orthopaedica. 2009;80(1):55-61. [pmid: 19234886].
1567 Nilsdotter AK, Toksvig-Larsen S, Roos EM. A 5 year prospective study of patient-relevant outcomes after total knee replacement. Osteoarthritis & Cartilage. May. 2009;17(5):601-6. [pmid: 19091604].
1568 Nilsson KG, Henricson A, Norgren B, et al. Uncemented HA-coated implant is the optimum fixation for TKA in the young patient. Clinical Orthopaedics & Related Research. 2006;448(Journal Article):129-39. [pmid: 16826107].
1569 Niskanen RO. Early repetitive radiography is unnecessary after an uncomplicated cemented hip or knee arthroplasty for osteoarthritis. Acta Orthopaedica Belgica. Dec. 2005;71(6):692-5. [pmid: 16459859].
1570 Nizard RS, Cardinne L, Bizot P, et al. Total knee replacement after failed tibial osteotomy: results of a matched-pair study. Journal of Arthroplasty. Dec. 1998;13(8):847-53. [pmid: 9880174].
1571 Noack W, Fischer M, Forster KK, et al. Glucosamine sulfate in osteoarthritis of the knee. Osteoarthritis & Cartilage. Mar. 1994;2(1):51-9. [pmid: 11548224].
1572 Noda T, Yasuda S, Nagano K, et al. Clinico-radiological study of total knee arthroplasty after high tibial osteotomy. Journal of Orthopaedic Science. 2000;5(1):25-36. [pmid: 10664436].
1573 Nomura E, Inoue M, Kobayashi S. Long-term follow-up and knee osteoarthritis change after medial patellofemoral ligament reconstruction for recurrent patellar dislocation. American Journal of Sports Medicine. Nov. 2007;35(11):1851-8. [pmid: 17724092].
1574 Norvell DC, Czerniecki JM, Reiber GE, et al. The prevalence of knee pain and symptomatic knee osteoarthritis among veteran traumatic amputees and nonamputees. Archives of Physical Medicine and Rehabilitation. 2005;86(3):487-93. [pmid: 15759233].
1575 Novaes AC, Schaiquevich P, Nasswetter G, et al. Multicenter study of hyaluronic acid obtained by biotechnology to evaluate clinical efficacy and safety in knee osteoarthritis. International Journal of Clinical Pharmacology Research. 2005;25(1):1-7. [pmid: 15864872].
1576 Novicoff WM, Rion D, Mihalko WM, et al. Does concomitant low back pain affect revision total knee arthroplasty outcomes? Clinical Orthopaedics &. Related Research. 2009;467(10):2623-9. [pmid: 19434467].
1577 Nunez M, Lozano L, Nunez E, et al. Total knee replacement and health-related quality of life: factors influencing long-term outcomes. Arthritis & Rheumatism. Aug. 15. 2009;61(8):1062-9. [pmid: 19644900].
1578 Nunez M, Nunez E, del Val JL, et al. Health-related quality of life in patients with osteoarthritis after total knee replacement: factors influencing outcomes at 36 months of follow-up. Osteoarthritis & Cartilage. Sep. 2007;15(9):1001-7. [pmid: 17428689].
1579 Nunez M, Nunez E, Segur JM, et al. The effect of an educational program to improve health-related quality of life in patients with osteoarthritis on waiting list for total knee replacement: a randomized study. Osteoarthritis & Cartilage. 2006;14(3):279-85. [pmid: 16309929].
1580 Nutton RW, van der Linden ML, Rowe PJ, et al. A prospective randomised double-blind study of functional outcome and range of flexion following total knee replacement with the NexGen standard and high flexion components. Journal of Bone & Joint Surgery - British Volume. Jan. 2008;90(1):37-42. [pmid: 18160497].
1581 Nyland J, Frost K, Quesada P, et al. Self-reported chair-rise ability relates to stair-climbing readiness of total knee arthroplasty patients: a pilot study. Journal of Rehabilitation Research & Development. 2007;44(5):751-9. [pmid: 17943686].
1582 Oatis CA, Wolff EF, Lennon SK. Knee joint stiffness in individuals with and without knee osteoarthritis: a preliminary study. Journal of Orthopaedic & Sports Physical Therapy. Dec. 2006;36(12):935-41. [pmid: 17193871].
1583 Oberg U, Oberg B, Oberg T. Validity and reliability of a new assessment of lower-extremity dysfunction. Phys Ther. Sep. 1994;74(9):861-71. [pmid: 8066113].
1584 Oberg U, Oberg T. Functional outcome after high tibial osteotomy: a study using individual goal achievement as the primary outcome variable. Journal of Rehabilitation Research & Development. Sep–Oct. 2000;37(5):501-10. [pmid: 11322148].
1585 Extracorporeal Shock-Wave therapy Improves Motor Dysfunction and Pain Originating From Knee Osteoarthritis in Rats. 52nd Annual Meeting of the Orthopaedic Research Society. Lakeside Center, McCormick Place, Chicago, Illinois (USA). 19–22 Mar 2006.
1586 O’Connell NE, Wand BM, Colquhoun D. A failure of the review process? Comment on Ahsin et al. Clinical and endocrinological changes after electro-acupuncture treatment in patients with osteoarthritis of the knee. Pain. Pain. 2010. 149. 2009;147(1):60-6. 160. [pmid: 19766392].
1587 O’Connor MI. Sex differences in osteoarthritis of the hip and knee. Journal of the American Academy of Orthopaedic Surgeons. Suppl 1. 2007;15:S22-5. [pmid: 17766785].
1588 Odole AC, Akinpelu AO. Validity and internal consistency of a Hausa version of the Ibadan Knee/Hip Osteoarthritis Outcome Measure. Health & Quality of Life Outcomes. 2008;6(Journal Article):86. [pmid: 18945365].
1589 Odole AC, Akinpelu AO, Bamgboye EA. Validity and internal consistency of a Yoruba version of the Ibadan knee/hip osteoathritis outcome measure (Yoruba IKHOAM). Afr J Med Med Sci. Sep. 2006;35(3):349-57. [pmid: 17312744].
1590 Odumenya M, Costa ML, Parsons N, et al. The Avon patellofemoral joint replacement: Five-year results from an independent centre. Journal of Bone & Joint Surgery - British Volume. Jan. 2010;92(1):56-60. [pmid: 20044679].
1591 Ogon M, Hartig F, Bach C, et al. Patella resurfacing: no benefit for the long-term outcome of total knee arthroplasty. A 10- to 16.3-year follow-up. Archives of Orthopaedic & Trauma Surgery. May. 2002;122(4):229-34. [pmid: 12029513].
1592 Oh KJ, Pandher DS, Lee SH, et al. Meta-analysis comparing outcomes of fixed-bearing and mobile-bearing prostheses in total knee arthroplasty. Journal of Arthroplasty. Sep. 2009;24(6):873-84. [pmid: 18701243].
1593 Ohsawa S, Hukuda K, Inamori Y, et al. High tibial osteotomy for osteoarthritis of the knee with varus deformity utilizing the hemicallotasis method. Archives of Orthopaedic & Trauma Surgery. Nov. 2006;126(9):588-93. [pmid: 16838154].
1594 Oka H, Akune T, Muraki S, et al. Association of low dietary vitamin K intake with radiographic knee osteoarthritis in the Japanese elderly population: dietary survey in a population-based cohort of the ROAD study. J Orthop Sci. Nov. 2009;14(6):687-92. [pmid: 19997813].
1595 Oka H, Muraki S, Akune T, et al. Fully automatic quantification of knee osteoarthritis severity on plain radiographs. Osteoarthritis Cartilage. Nov. 2008;16(11):1300-6. [pmid: 18424107].
1596 Oka H, Muraki S, Akune T, et al. Normal and threshold values of radiographic parameters for knee osteoarthritis using a computer-assisted measuring system (KOACAD): the ROAD study. J Orthop Sci. Nov. 2010;15(6):781-9. [pmid: 21116896].
1597 Olcott CW, Scott RD. The Ranawat Award. Femoral component rotation during total knee arthroplasty. Clinical Orthopaedics & Related Research. Oct. 1999;(367):39-42. [pmid: 10546596].
1598 Olivecrona C, Tidermark J, Hamberg P, et al. Skin protection underneath the pneumatic tourniquet during total knee arthroplasty: a randomized controlled trial of 92 patients. Acta Orthopaedica. Jun. 2006;77(3):519-23. [pmid: 16819695].
1599 Physiological and accessory motion in subjects with knee osteoarthritis. 2006. 2006 Combined Sections Meetings of the Specialty Sections of the American Physical Therapy Association (CSM 2006). San Diego Convention Center, San Diego, California (USA). 1–5 Feb 2006.
1600 Omololu B, Alonge TO, Ogunlade SO, et al. Double blind clinical trial comparing the safety and efficacy of nimesulide (100mg) and diclofenac in osteoarthrosis of the hip and knee joints. West African Journal of Medicine. Apr–Jun. 2005;24(2):128-33. [pmid: 16092313].
1601 Omori G, Koga Y, Miyao M, et al. High tibial osteotomy using two threaded pins and figure-of-eight wiring fixation for medial knee osteoarthritis: 14 to 24 years follow-up results. Journal of Orthopaedic Science. Jan. 2008;13(1):39-45. [pmid: 18274854].
1602 Onel E, Kolsun K, Kauffman JI. Post-Hoc analysis of a head-to-head hyaluronic acid comparison in knee osteoarthritis using the 2004 OMERACT-OARSI responder criteria. Clinical Drug Investigation. 2008;28(1):37-45. [pmid: 18081359].
1603 Ong SM, Taylor GJSC. Can knee position save blood following total knee replacement?. Knee. Mar. 2003;10(1):81-5. [pmid: 12649032].
1604 Onodera J, Onodera S, Kondo E, et al. A soluble factor (EMMPRIN) in exudate influences knee motion after total arthroplasty. Knee Surgery, Sports Traumatology, Arthroscopy. Mar. 2009;17(3):298-304. [pmid: 19089410].
1605 Orbell S, Espley A, Johnston M, et al. Health benefits of joint replacement surgery for patients with osteoarthritis: prospective evaluation using independent assessments in Scotland. Journal of Epidemiology & Community Health. 1998;52(9):564-70. [pmid: 10320857].
1606 Oregon-Romero E, Vazquez-Del Mercado M, Navarro-Hernandez RE, et al. Tumor necrosis factor receptor 2 M196R polymorphism in rheumatoid arthritis and osteoarthritis: relationship with sTNFR2 levels and clinical features. Rheumatol Int. Nov. 2006;27(1):53-9. [pmid: 16871413].
1607 Ornetti P, Maillefert JF, Laroche D, et al. Gait analysis as a quantifiable outcome measure in hip or knee osteoarthritis: A systematic review. Joint Bone Spine. 2010. May. 13. [pmid: 20471899].
1608 Ornetti P, Parratte S, Gossec L, et al. Cross-cultural adaptation and validation of the French version of the knee injury and osteoarthritis outcome score (koos) in knee osteoarthritis patients. Osteoarthritis and Cartilage. 2008;16(4):423-8. [pmid: 17905602].
1609 Ornetti P, Perruccio AV, Roos EM, et al. Psychometric properties of the French translation of the reduced KOOS and HOOS (KOOS-PS and HOOS-PS). Osteoarthritis & Cartilage. 2009;17(12):1604-8. [pmid: 19589400].
1610 O’Rourke MR, Gardner JJ, Callaghan JJ, et al. The John Insall Award: unicompartmental knee replacement: a minimum twenty-one-year followup, end-result study. Clinical Orthopaedics & Related Research. 2005;440(Journal Article):27-37. [pmid: 16239780].
1611 Orsel S, Altun M, Bekmezci T, et al. Early results of medial opening wedge osteotomy in varus gonarthrosis. Acta Orthopaedica et Traumatologica Turcica. 2006;40(3):193-8. [pmid: 16905890].
1612 Ostergaard K, Andersen CB, Petersen J, et al. Validity of histopathological grading of articular cartilage from osteoarthritic knee joints. Ann Rheum Dis. Apr. 1999;58(4):208-13. [pmid: 10364898].
1613 O’Sullivan S. Acustim in the Treatment of Knee Osteoarthritis: A Single-Subject Research Design. Physiotherapy Canada. 2006;58(4):293-305.
1614 Ottillinger B, Gomor B, Michel BA, et al. Efficacy and safety of eltenac gel in the treatment of knee osteoarthritis. Osteoarthritis & Cartilage. Apr. 2001;9(3):273-80. [pmid: 11300751].
1615 Ou Z-X, Jin J-C, Huang D. Comparative study on effects of combined massage-smouldering-washing therapy and mini-invasive surgery in treating knee osteoarthritis. Zhongguo Zhong Xi Yi Jie He Za Zhi Zhongguo Zhongxiyi Jiehe Zazhi/Chinese Journal of Integrated Traditional & Western Medicine. Oct. 2008;28(10):925-8. [pmid: 19123333].
1616 Ouellet D, Moffet H. Locomotor deficits before and two months after knee arthroplasty. Arthritis & Rheumatism. Oct. 15. 2002;47(5):484-93. [pmid: 12382296].
1617 Owman H, Tiderius CJ, Neuman P, et al. Association between findings on delayed gadolinium-enhanced magnetic resonance imaging of cartilage and future knee osteoarthritis. Arthritis Rheum. Jun. 2008;58(6):1727-30. [pmid: 18512778].
1618 Ozalay M, Ozkoc G, Circi E, et al. The correlation of correction magnitude and tibial slope changes following open wedge high tibial osteotomy. Knee Surgery, Sports Traumatology, Arthroscopy. Oct. 2008;16(10):948-51. [pmid: 18712358].
1619 Ozawa T, Shinomiya Y, Ochi K, et al. Development of new passive exercise equipment inducing contraction of functional muscles around knee joint without pain. Conf Proc IEEE Eng Med Biol Soc. 2008;2008:3447-50. [pmid: 19163450].
1620 Ozcan O, Boya H, Oztekin HH. Clinical evaluation of the proximal tibiofibular joint in knees with severe tibiofemoral primary osteoarthritis. Knee. Aug. 2009;16(4):248-50. [pmid: 19185499].
1621 Ozdemir F, Tukenmez O, Kokino S, et al. How do marginal osteophytes, joint space narrowing and range of motion affect each other in patients with knee osteoarthritis. Rheumatology International. Apr. 2006;26(6):516-22. [pmid: 16025334].
1622 Ozguclu E, Kilic E, Kaymak B. A knee osteoarthritis connected with hallux valgus-related pes planus. Journal of Biomechanics. Dec. 3523;5. 2008;41(16):4.
1623 Oztuna V, Eskandari M, Bugdayci R, et al. Intra-articular injection of tenoxicam in osteoarthritic knee joints with effusion. Orthopedics. Dec. 2007;30(12):1039-42. [pmid: 18198776].
1624 Oztuna V, Karatosun V, Unver B, et al. An alternative patellar resurfacing technique in knee replacement: patellofemoral fascial interposition arthroplasty. Knee Surgery, Sports Traumatology, Arthroscopy. Oct. 2007;15(10):1210-4. [pmid: 17619855].
1625 Padua R, Zanoli G, Ceccarelli E, et al. The Italian version of the Oxford 12-item Knee Questionnaire-cross-cultural adaptation and validation. Int Orthop. 2003;27(4):214-6. [pmid: 12679892].
1626 Pagnano M, Westrich G. Successful nonoperative management of chronic osteoarthritis pain of the knee: safety and efficacy of retreatment with intra-articular hyaluronans. Osteoarthritis & Cartilage. Sep. 2005;13(9):751-61. [pmid: 15967686].
1627 Pagura SM, Thomas SG, Woodhouse LJ, et al. Women awaiting knee replacement have reduced function and growth hormone. Clin Orthop Relat Res. Oct. 2003;(415):202-13. [pmid: 14612647].
1628 Pai YC, Chang HJ, Chang RW, et al. Alteration in multijoint dynamics in patients with bilateral knee osteoarthritis. Arthritis Rheum. Sep. 1994;37(9):1297-304. [pmid: 7945492].
1629 Comparison of the Therapeutic Efficacy of Tens Versus Intra-Articular Hyaluronic Acid Injection in the Patients with Knee Osteoarthritis: A Prospective Randomized Study. 2006 Annual European Congress of Rheumatology (EULAR 2006). Amsterdam (Netherlands (The)). 21–24 Jun 2006.
1630 Exercise beliefs of people with knee osteoarthritis. 2009 Congress of Chartered Society of Physiotherapy (CSP 2009). Liverpool Arena and Convention Centre, Liverpool. 16–17 Oct 2009.
1631 PalmieriSmith RM, Thomas AC. A neuromuscular mechanism of posttraumatic osteoarthritis associated with ACL injury. Exerc Sport Sci Rev. 2009;37(3):147-53. [pmid: 19550206].
1632 Palomo JM. Surgical options for middle-aged patients with osteoarthritis of the knee. Journal of Bone & Joint Surgery - American Volume. Sep. 2001;83-A(9):1429. [pmid: 11568213].
1633 Pandher DS, Oh KJ, Lee SH. Comparison between mobile-bearing and fixed-bearing knees in bilateral total knee replacements. International Orthopaedics. Feb. 2007;31(1):131-2. [pmid: 16821008].
1634 Pandit H, Beard DJ, Jenkins C, et al. Combined anterior cruciate reconstruction and Oxford unicompartmental knee arthroplasty. Journal of Bone & Joint Surgery - British Volume. Jul. 2006;88(7):887-92. [pmid: 16798990].
1635 Pandit H, Jenkins C, Barker K, et al. The Oxford medial unicompartmental knee replacement using a minimally-invasive approach. Journal of Bone & Joint Surgery - British Volume. Jan. 2006;88(1):54-60. [pmid: 16365121].
1636 Pandit H, Jenkins C, Beard DJ, et al. Cementless Oxford unicompartmental knee replacement shows reduced radiolucency at one year. Journal of Bone & Joint Surgery - British Volume. Feb. 2009;91(2):185-9. [pmid: 19190051].
1637 Pandit H, Ward T, Hollinghurst D, et al. Influence of surface geometry and the cam-post mechanism on the kinematics of total knee replacement. Journal of Bone & Joint Surgery - British Volume. Jul. 2005;87(7):940-5. [pmid: 15972907].
1638 Pandya NK, Draganich LF, Mauer A, et al. Osteoarthritis of the knees increases the propensity to trip on an obstacle. Clinical Orthopaedics & Related Research. Feb. 2005;(431):150-6. [pmid: 15685069].
1639 Pandya NK, Piotrowski GA, Pottenger L, et al. Pain relief in knee osteoarthritis reduces the propensity to trip on an obstacle. Gait and Posture. 2007;25(1):106-11. [pmid: 16529934].
1640 Panousis K, Grigoris P, Strover AE. Suction dressings in total knee arthroplasty--an alternative to deep suction drainage. Acta Orthopaedica Belgica. Aug. 2004;70(4):349-54. [pmid: 15481420].
1641 Pap G, Machner A, Awiszus F. Strength and voluntary activation of the quadriceps femoris muscle at different severities of osteoarthritic knee joint damage. Journal of Orthopaedic Research. 2004;22(1):96-103. [pmid: 14656666].
1642 Pap G, Meyer M, Weiler HT, et al. Proprioception after total knee arthroplasty: a comparison with clinical outcome. Acta Orthopaedica Scandinavica. Apr. 2000;71(2):153-9. [pmid: 10852321].
1643 Papachristou G, Plessas S, Sourlas J, et al. Deterioration of long-term results following high tibial osteotomy in patients under 60 years of age. International orthopaedics. 2006;30(5):403-8. [pmid: 16688454].
1644 Papachristou G, Sourlas J, Magnissalis E, et al. ACL reconstruction and the implication of its tibial attachment for stability of the joint: anthropometric and biomechanical study. International Orthopaedics. Aug. 2007;31(4):465-70. [pmid: 16944142].
1645 Papadimitriou GM. The management of osteoarthritis. Landing on the ground of reality. Rheumatology. Jan. 2005;44(1):130-1. [pmid: 15611305].
1646 Papadopoulos EC, Parvizi J, Lai CH, et al. Total knee arthroplasty following prior distal femoral fracture. Knee. Dec. 2002;9(4):267-74. [pmid: 12424033].
1647 Papaioannou G, Demetropoulos CK, King YH. Predicting the effects of knee focal articular surface injury with a patient-specific finite element model. Knee. Jan. 2010;17(1):61-8. [pmid: 19477131].
1648 Papanikolaou A, Droulias K, Nikolaides A, et al. Results of a single total knee prosthesis compared with multiple joint replacement in the lower limb. International Orthopaedics. 2000;24(2):80-2. [pmid: 10894375].
1649 Pape D, Adam F, Seil R, et al. Fixation stability following high tibial osteotomy: a radiostereometric analysis. The Journal of Knee Surgery. Apr. 2005;18(2):108-15. [pmid: 15915831].
1650 Paradowski PT, Englund M, Lohmander LS, et al. The effect of patient characteristics on variability in pain and function over two years in early knee osteoarthritis. Health & Quality of Life Outcomes. 2005;3(Journal Article):59. [pmid: 16188034].
1651 Paradowski PT, Englund M, Roos EM, et al. Similar group mean scores, but large individual variations, in patient-relevant outcomes over 2 years in meniscectomized subjects with and without radiographic knee osteoarthritis. Health & Quality of Life Outcomes. 2004;2(Journal Article):38. [pmid: 15279676].
1652 Parent E, Moffet H. Comparative responsiveness of locomotor tests and questionnaires used to follow early recovery after total knee arthroplasty. Archives of Physical Medicine and Rehabilitation. 2002;83(1):70-80. [pmid: 11782835].
1653 Parent E, Moffet H. Preoperative predictors of locomotor ability two months after total knee arthroplasty for severe osteoarthritis. Arthritis Rheum. Feb. 15. 2003;49(1):36-50. [pmid: 12579592].
1654 Parenti D, Murray CW. Treatment of intraarticular osteoarthritis of the knee with hylan G-F 20: comment on the article by Brandt et al. Arthritis & Rheumatism. Jun. 2001;44(6):1470-1. author reply 3–6. [pmid: 11407711].
1655 Park KK, Shin KS, Chang CB, et al. Functional disabilities and issues of concern in female Asian patients before TKA. Clin Orthop Relat Res. Aug. 2007;461:143-52. [pmid: 17806149].
1656 Park SE, Lee CT. Comparison of robotic-assisted and conventional manual implantation of a primary total knee arthroplasty. Journal of Arthroplasty. Oct. 2007;22(7):1054-9. [pmid: 17920481].
1657 Parker DA, Rorabeck CH, Bourne RB. Long-term followup of cementless versus hybrid fixation for total knee arthroplasty. Clinical Orthopaedics & Related Research. 2001;(388):68-76. [pmid: 11451134].
1658 Parmelee PA, Harralson TL, Smith LA, et al. Necessary and discretionary activities in knee osteoarthritis: do they mediate the pain-depression relationship?. Pain Med. Jul–Aug. 2007;8(5):449-61. [pmid: 17661863].
1659 Parmet S, Lynm C, Glass RM. JAMA patient page. Osteoarthritis of the knee. JAMA. Feb. 26. 2003;289(8):1068. [pmid: 12597762].
1660 Parratte S, Argenson JN, Pearce O, et al. Medial unicompartmental knee replacement in the under-50s. Journal of Bone & Joint Surgery - British Volume. 2009;91(3):351-6. [pmid: 19258611].
1661 Parratte S, Pauly V, Aubaniac JM, et al. Survival of bicompartmental knee arthroplasty at 5 to 23 years. Clinical Orthopaedics & Related Research. 2010;468(1):64-72. [pmid: 19669384].
1662 Parsch D, Kruger M, Moser MT, et al. Follow-up of 11–16 years after modular fixed-bearing TKA. International Orthopaedics. Apr. 2009;33(2):431-5. [pmid: 18392620].
1663 Parsley BS, Bertolusso R, Harrington M, et al. Influence of gender on age of treatment with TKA and functional outcome. Clin Orthop Relat Res. Jul. 2010;468(7):1759-64. [pmid: 20428983].
1664 Parvizi J, Hanssen AD, Spangehl MJ. Total knee arthroplasty following proximal tibial osteotomy: risk factors for failure. Journal of Bone & Joint Surgery - American Volume. Mar. 2004;86-A(3):474-9. [pmid: 14996871].
1665 Parvizi J, Seel MJ, Hanssen AD, et al. Patellar component resection arthroplasty for the severely compromised patella. Clinical Orthopaedics & Related Research. Apr. 2002;(397):356-61. [pmid: 11953628].
1666 Pasquina PF, Dahl E. Total knee replacement in an amputee patient: a case report. Arch Phys Med Rehabil. Jun. 2000;81(6):824-6. [pmid: 10857531].
1667 Patel JV, Masonis JL, Guerin J, et al. The fate of augments to treat type-2 bone defects in revision knee arthroplasty. Journal of Bone & Joint Surgery - British Volume. Mar. 2004;86(2):195-9. [pmid: 15046432].
1668 Pati AB, Perme DC, Trail M, et al. Rehabilitation parameters in total knee replacement patients undergoing epidural vs. conventional analgesia. Journal of Orthopaedic & Sports Physical Therapy. Feb. 1994;19(2):88-92. [pmid: 8148867].
1669 Patil S, Garbuz DS, Greidanus NV, et al. Quality of life outcomes in revision vs primary total hip arthroplasty: a prospective cohort study. Journal of Arthroplasty. Jun. 2008;23(4):550-3. [pmid: 18514873].
1670 Paul S, Das N, Ghosh S. The effects of aceclofenac and nabumetone in osteoarthritis. Jnma, Journal of the Nepal Medical Association. Apr–Jun. 2009;48(174):121-5. [pmid: 20387351].
1671 Pavelka K, Coste P, Geher P, et al. Efficacy and safety of piascledine 300 versus chondroitin sulfate in a 6 months treatment plus 2 months observation in patients with osteoarthritis of the knee. [Erratum appears in Clin Rheumatol. 2010 Jul;29(7):819–20]. Clinical Rheumatology. Jun. 2010;29(6):659-70. [pmid: 20179981].
1672 Pavelka K, Forejtova S, Olejarova M, et al. Hyaluronic acid levels may have predictive value for the progression of knee osteoarthritis. Osteoarthritis and Cartilage. 2004;12(4):277-83. [pmid: 15023379].
1673 Pavelka K, Gatterova J, Altman RD. Radiographic progression of knee osteoarthritis in a Czech cohort. Clin Exp Rheumatol. Jul–Aug. 2000;18(4):473-7. [pmid: 10949722].
1674 Pavelka K, Gatterova J, Olejarova M, et al. Glucosamine sulfate use and delay of progression of knee osteoarthritis: a 3-year, randomized, placebo-controlled, double-blind study. Archives of Internal Medicine. Oct. 14. 2002;162(18):2113-23. [pmid: 12374520].
1675 Pavelka K, Le Loet X, Bjorneboe O, et al. Benefits of transdermal fentanyl in patients with rheumatoid arthritis or with osteoarthritis of the knee or hip: an open-label study to assess pain control. Current Medical Research & Opinion. Dec. 2004;20(12):1967-77. [pmid: 15701214].
1676 Pavelka K, Trc T, Karpas K, et al. The efficacy and safety of diacerein in the treatment of painful osteoarthritis of the knee: a randomized, multicenter, double-blind, placebo-controlled study with primary end points at two months after the end of a three-month treatment period. Arthritis & Rheumatism. Dec. 2007;56(12):4055-64. [pmid: 18050202].
1677 Pawar U, Rao KN, Sundaram PS, et al. Scintigraphic assessment of patellar viability in total knee arthroplasty after lateral release. Journal of Arthroplasty. Jun. 2009;24(4):636-40. [pmid: 18534398].
1678 Payne MW, Petrella RJ. Viscosupplementation effect on proprioception in the osteoarthritic knee. Archives of Physical Medicine & Rehabilitation. 2000;81(5):598-603. [pmid: 10807098].
1679 Pearle AD, O’Loughlin PF, Kendoff DO. Robot-assisted unicompartmental knee arthroplasty. Journal of Arthroplasty. Feb. 2010;25(2):230-7. [pmid: 19056227].
1680 Peat G, McCarney R, Croft P. Knee pain and osteoarthritis in older adults: a review of community burden and current use of primary health care. Annals of the Rheumatic Diseases. 2001;60(2):91-7. [pmid: 11156538].
1681 Predicting the presence of radiographic osteoarthritis in the older patient with knee pain. 2005. 69th Annual Meeting of the American College of Rheumatology and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
1682 Peat G, Thomas E, Duncan R, et al. Estimating the probability of radiographic osteoarthritis in the older patient with knee pain. Arthritis Rheum. Jun. 15. 2007;57(5):794-802. [pmid: 17530679].
1683 Peckett WR, Butler-Manuel A. Intra-articular steroids after arthroscopy for osteoarthritis of the knee. Journal of Bone & Joint Surgery - British Volume. Jul. 2000;82(5):775-6. [pmid: 10963186].
1684 Peeva E, Beals CR, Bolognese JA, et al. A walking model to assess the onset of analgesia in osteoarthritis knee pain. Osteoarthritis & Cartilage. May. 2010;18(5):646-53. [pmid: 20175977].
1685 Pego-Reigosa JM, Rodriguez-Rodriguez M, Hurtado-Hernandez Z, et al. Calcium pyrophosphate deposition disease mimicking polymyalgia rheumatica: a prospective followup study of predictive factors for this condition in patients presenting with polymyalgia symptoms. Arthritis Rheum. Dec. 15. 2005;53(6):931-8. [pmid: 16342107].
1686 Pellecchia GL, Lugo-Larcheveque N, Deluca PA. Differential diagnosis in physical therapy evaluation of thigh pain in an adolescent boy. Journal of Orthopaedic & Sports Physical Therapy. Jan. 1996;23(1):51-5. [pmid: 8749750].
1687 Pelletier JP, Raynauld JP, Caron J, et al. Decrease in serum level of matrix metalloproteinases is predictive of the disease-modifying effect of osteoarthritis drugs assessed by quantitative MRI in patients with knee osteoarthritis. Ann Rheum Dis. Dec. 2010;69(12):2095-101. [pmid: 20570834].
1688 Pells JJ, Shelby RA, Keefe FJ, et al. Arthritis self-efficacy and self-efficacy for resisting eating: relationships to pain, disability, and eating behavior in overweight and obese individuals with osteoarthritic knee pain. Pain. Jun. 2008;136(3):340-7. [pmid: 17764844].
1689 Pendleton A, Millar A, O’Kane D, et al. Can sonography be used to predict the response to intra-articular corticosteroid injection in primary osteoarthritis of the knee?. Scandinavian Journal of Rheumatology. Sep–Oct. 2008;37(5):395-7. [pmid: 18821277].
1690 Pennington DW, Swienckowski JJ, Lutes WB, et al. Lateral unicompartmental knee arthroplasty: survivorship and technical considerations at an average follow-up of 12.4 years. Journal of Arthroplasty. Jan. 2006;21(1):13-7. [pmid: 16446180].
1691 Perrot S, Poiraudeau S, Kabir M, et al. Active or passive pain coping strategies in hip and knee osteoarthritis? Results of a national survey of 4,719 patients in a primary care setting. Arthritis & Rheumatism. Nov. 15. 2008;59(11):1555-62. [pmid: 18975370].
1692 Glucosamine Plasma and Synovial Fluid Concentrations Before and After Oral Administration of Crystalline Glucosamine Sulfate in Knee Osteoarthritis Patients. 69th Annual Meeting of the American College of Rheumatology and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
1693 Pessler F, Ogdie A, Diaz-Torne C, et al. Subintimal Ki-67 as a synovial tissue biomarker for inflammatory arthropathies. Ann Rheum Dis. Feb. 2008;67(2):162-7. [pmid: 17613556].
1694 Peters CL, Erickson J, Kloepper RG, et al. Revision total knee arthroplasty with modular components inserted with metaphyseal cement and stems without cement. Journal of Arthroplasty. Apr. 2005;20(3):302-8. [pmid: 15809946].
1695 Petersen SG, Saxne T, Heinegard D, et al. Glucosamine but not ibuprofen alters cartilage turnover in osteoarthritis patients in response to physical training. Osteoarthritis Cartilage. Jan. 2010;18(1):34-40. [pmid: 19679221].
1696 Petrella RJ. Hyaluronic acid for the treatment of knee osteoarthritis: long-term outcomes from a naturalistic primary care experience. American Journal of Physical Medicine & Rehabilitation. 2005;84(4):278-83. [pmid: 15785261].
1697 Petrella RJ, DiSilvestro MD, Hildebrand C. Effects of hyaluronate sodium on pain and physical functioning in osteoarthritis of the knee: a randomized, double-blind, placebo-controlled clinical trial. Arch Intern Med. Feb. 11. 2002;162(3):292-8. [pmid: 11822921].
1698 Petrella RJ, Petrella M. A prospective, randomized, double-blind, placebo controlled study to evaluate the efficacy of intraarticular hyaluronic acid for osteoarthritis of the knee. Journal of Rheumatology. May. 2006;33(5):951-6. [pmid: 16652426].
1699 Petrou G, Petrou H, Tilkeridis C, et al. Medium-term results with a primary cemented rotating-hinge total knee replacement. A 7- to 15-year follow-up. Journal of Bone & Joint Surgery - British Volume. Aug. 2004;86(6):813-7. [pmid: 15330020].
1700 Petterson S, Snyder-Mackler L. The use of neuromuscular electrical stimulation to improve activation deficits in a patient with chronic quadriceps strength impairments following total knee arthroplasty. Journal of Orthopaedic & Sports Physical Therapy. Sep. 2006;36(9):678-85. [pmid: 17017273].
1701 Petterson SC, Barrance P, Buchanan T, et al. Mechanisms Underlying Quadriceps Weakness in Knee Osteoarthritis. Medicine and science in sports and exercise. 2008;40(3):422-7. [pmid: 18379202].
1702 Petterson SC, Mizner RL, Stevens JE, et al. Improved function from progressive strengthening interventions after total knee arthroplasty: a randomized clinical trial with an imbedded prospective cohort. Arthritis Rheum. Feb. 15. 2009;61(2):174-83. [pmid: 19177542].
1703 Petterson SC, Raisis L, Bodenstab A, et al. Disease-specific gender differences among total knee arthroplasty candidates. J Bone Joint Surg Am. Nov. 2007;89(11):2327-33. [pmid: 17974873].
1704 Pfahler M, Lutz C, Anetzberger H, et al. Long-term results of high tibial osteotomy for medial osteoarthritis of the knee. Acta Chirurgica Belgica. Nov–Dec. 2003;103(6):603-6. [pmid: 14743568].
1705 Pham J, Kumar R. Heterotopic ossification after total knee arthroplasty. Am J Orthop (Belle Mead NJ). Feb. 1997;26(2):141-3. [pmid: 9040889].
1706 Pham T, Le Henanff A, Ravaud P, et al. Evaluation of the symptomatic and structural efficacy of a new hyaluronic acid compound, NRD101, in comparison with diacerein and placebo in a 1 year randomised controlled study in symptomatic knee osteoarthritis. Annals of the Rheumatic Diseases. 2004;63(12):1611-7. [pmid: 15331394].
1707 Phiphobmongkol V, Sudhasaneya V. The effectiveness and safety of intra-articular injection of sodium hyaluronate 500–730 kDa) in the treatment of patients with painful knee osteoarthritis. Journal of the Medical Association of Thailand. Oct. 2009;92(10):1287-94. [pmid: 19845235].
1708 Pierson JL, Ritter MA, Keating EM, et al. The effect of stuffing the patellofemoral compartment on the outcome of total knee arthroplasty. Journal of Bone & Joint Surgery - American Volume. Oct. 2007;89(10):2195-203. [pmid: 17908896].
1709 Pincus T, Koch G, Lei H, et al. Patient Preference for Placebo, Acetaminophen (paracetamol) or Celecoxib Efficacy Studies (PACES): two randomised, double blind, placebo controlled, crossover clinical trials in patients with knee or hip osteoarthritis. Annals of the Rheumatic Diseases. 2004;63(8):931-9. [pmid: 15082468].
1710 Pincus T, Koch GG, Sokka T, et al. A randomized, double-blind, crossover clinical trial of diclofenac plus misoprostol versus acetaminophen in patients with osteoarthritis of the hip or knee. Arthritis & Rheumatism. Jul. 2001;44(7):1587-98. [pmid: 11465710].
1711 Pincus T, Wang X, Chung C, et al. Patient preference in a crossover clinical trial of patients with osteoarthritis of the knee or hip: face validity of self-report questionnaire ratings. J Rheumatol. Mar. 2005;32(3):533-9. [pmid: 15742449].
1712 Poitras S, Rossignol M, Avouac J, et al. Management recommendations for knee osteoarthritis: how usable are they?. Joint Bone Spine. Oct. 2010;77(5):458-65. [pmid: 20851659].
1713 Polyzois D, Stavlas P, Polyzois V, et al. The oblique high tibial osteotomy technique without bone removal and with rigid blade plate fixation for the treatment of medial osteoarthritis of the varus knee: medium and long-term results. Knee Surgery, Sports Traumatology, Arthroscopy. Oct. 2006;14(10):940-7. [pmid: 16552551].
1714 Pongsoipetch B, Tantikul C. Open-wedge high tibial osteotomy in varus knee osteoarthritis: a 5-year prospective cohort study. Journal of the Medical Association of Thailand. Dec. Suppl 6. 2009;92:S109-14. [pmid: 20128075].
1715 Pookarnjanamorakot C, Jaovisidha S, Apiyasawat P. The patellar tilt angle: correlation of MRI evaluation with anterior knee pain. Journal of the Medical Association of Thailand. Dec. 1998;81(12):958-63. [pmid: 9916384].
1716 Pop T, Szczygielska D, Druzbicki M. Epidemiology and cost of conservative treatment of patients with degenerative joint disease of the hip and knee. Ortopedia Traumatologia Rehabilitacja. 2007;9(4):405-12. [pmid: 17882120].
1717 Pope JE, McCrea K, Stevens A, et al. Treatment of osteoarthritis of the hip and knee: a comparison of NSAID use in patients for whom surgery was and was not recommended. Clinical & Experimental Rheumatology. Mar–Apr. 2004;22(2):171-6. [pmid: 15083884].
1718 Popovic N, Lemaire R. Anterior knee pain with a posterior-stabilized mobile-bearing knee prosthesis: the effect of femoral component design. Journal of Arthroplasty. Jun. 2003;18(4):396-400. [pmid: 12820079].
1719 Porcheret M, Jordan K, Jinks C, et al. Primary care treatment of knee pain--a survey in older adults. Rheumatology. Nov. 2007;46(11):1694-700. [pmid: 17938135].
1720 Porteous AJ, Hassaballa MA, Newman JH. Does the joint line matter in revision total knee replacement?. Journal of Bone & Joint Surgery - British Volume. Jul. 2008;90(7):879-84. [pmid: 18591596].
1721 Porter LS, Keefe FJ, Wellington C, et al. Pain communication in the context of osteoarthritis: patient and partner self-efficacy for pain communication and holding back from discussion of pain and arthritis-related concerns. Clin J Pain. Oct. 2008;24(8):662-8. [pmid: 18806530].
1722 Prada SA, Griffin FM, Nelson CL, et al. Allograft reconstruction for extensor mechanism rupture after total knee arthroplasty: 4.8-year follow-up. Orthopedics. Dec. 2003;26(12):1205-8. [pmid: 14690290].
1723 Price AJ, Dodd CAF, Svard UGC, et al. Oxford medial unicompartmental knee arthroplasty in patients younger and older than 60 years of age. Journal of Bone & Joint Surgery - British Volume. Nov. 2005;87(11):1488-92. [pmid: 16260664].
1724 Price AJ, Webb J, Topf H, et al. Rapid recovery after oxford unicompartmental arthroplasty through a short incision. Journal of Arthroplasty. Dec. 2001;16(8):970-6. [pmid: 11740750].
1725 Pritchett JW. Anterior cruciate-retaining total knee arthroplasty. J Arthroplasty. Feb. 1996;11(2):194-7. [pmid: 8648315].
1726 Provelengios S, Papavasiliou KA, Kyrkos MJ, et al. The role of pantalar arthrodesis in the treatment of paralytic foot deformities. A long-term follow-up study. Journal of Bone & Joint Surgery - American Volume. Mar. 1. 2009;91(3):575-83. [pmid: 19255217].
1727 Puopolo A, Boice JA, Fidelholtz JL, et al. A randomized placebo-controlled trial comparing the efficacy of etoricoxib 30 mg and ibuprofen 2400 mg for the treatment of patients with osteoarthritis. Osteoarthritis Cartilage. Dec. 2007;15(12):1348-56. [pmid: 17631392].
1728 Pyne D, Ioannou Y, Mootoo R, et al. Intra-articular steroids in knee osteoarthritis: a comparative study of triamcinolone hexacetonide and methylprednisolone acetate. Clinical rheumatology. 2004;23(2):116-20. [pmid: 15045624].
1729 Qazi AA, Jorgensen DR, Lillholm M, et al. A framework for optimizing measurement weight maps to minimize the required sample size. Med Image Anal. Jun. 2010;14(3):255-64. [pmid: 20189869].
1730 Radke S, Radke J. Total knee arthroplasty in combination with a one-stage tibial osteotomy: a technique for correction of a gonarthrosis with a severe (>15 degrees) tibial extra-articular deformity. Journal of Arthroplasty. Aug. 2002;17(5):533-7. [pmid: 12168165].
1731 Rahmann AE, Brauer SG, Nitz JC. A specific inpatient aquatic physiotherapy program improves strength after total hip or knee replacement surgery: a randomized controlled trial. Arch Phys Med Rehabil. May. 2009;90(5):745-55. [pmid: 19406293].
1732 Rajan RA, Pack Y, Jackson H, et al. No need for outpatient physiotherapy following total knee arthroplasty: a randomized trial of 120 patients. Acta Orthop Scand. Feb. 2004;75(1):71-3. [pmid: 15022811].
1733 Rajasekhar C, Das S, Smith A. Unicompartmental knee arthroplasty. 2- to 12-year results in a community hospital. Journal of Bone & Joint Surgery - British Volume. Sep. 2004;86(7):983-5. [pmid: 15446523].
1734 Rajgopal V, Bourne RB, Chesworth BM, et al. The impact of morbid obesity on patient outcomes after total knee arthroplasty. Journal of Arthroplasty. Sep. 2008;23(6):795-800. [pmid: 18534516].
1735 Ram K. Is Acupuncture Effective For Osteoarthritis of the Knee? - A Review. J Acupunct Ass Chart Physiotherapists. 2006;2006(2):25-31.
1736 Raman R, Dutta A, Day N, et al. Efficacy of Hylan G-F 20 and Sodium Hyaluronate in the treatment of osteoarthritis of the knee -- a prospective randomized clinical trial. Knee. Aug. 2008;15(4):318-24. [pmid: 18430574].
1737 Ramaswamy R, Kosashvili Y, Cameron HU, et al. Total knee replacement with rotational proximal tibial osteotomy for osteoarthritis with severe external tibial torsion and patellar instability. Journal of Bone & Joint Surgery - British Volume. Nov. 2009;91(11):1466-71. [pmid: 19880891].
1738 Rampersaud YR, Ravi B, Lewis SJ, et al. Assessment of health-related quality of life after surgical treatment of focal symptomatic spinal stenosis compared with osteoarthritis of the hip or knee. Spine Journal: Official Journal of the North American Spine Society. Mar–Apr. 2008;8(2):296-304. [pmid: 17669690].
1739 Ranawat AS, Rossi R, Loreti I, et al. Comparison of the PFC Sigma fixed-bearing and rotating-platform total knee arthroplasty in the same patient: short-term results. Journal of Arthroplasty. Jan. 2004;19(1):35-9. [pmid: 14716648].
1740 Rannou F, Boutron I, Jardinaud-Lopez M, et al. Should aggregate scores of the Medical Outcomes Study 36-item Short Form Health Survey be used to assess quality of life in knee and hip osteoarthritis? A national survey in primary care. Osteoarthritis Cartilage. Sep. 2007;15(9):1013-8. [pmid: 17387025].
1741 Rantanen T, Guralnik JM, Ferrucci L, et al. Coimpairments as predictors of severe walking disability in older women. J Am Geriatr Soc. Jan. 2001;49(1):21-7. [pmid: 11207838].
1742 Rao JK, Arick R, Mihaliak K, et al. Using focus groups to understand arthritis patients’ perceptions about unconventional therapy. Arthritis Care & Research. Aug. 1998;11(4):253-60. [pmid: 9791324].
1743 Rapp SR, Rejeski WJ, Miller ME. Physical function among older adults with knee pain: the role of pain coping skills. Arthritis Care Res. Oct. 2000;13(5):270-9. [pmid: 14635295].
1744 Rasquinha VJ, Ranawat CS, Cervieri CL, et al. The press-fit condylar modular total knee system with a posterior cruciate-substituting design. A concise follow-up of a previous report. Journal of Bone & Joint Surgery - American Volume. May. 2006;88(5):1006-10. [pmid: 16651575].
1745 Rat AC, Guillemin F, Pouchot J. Mapping the osteoarthritis knee and hip quality of life (OAKHQOL) instrument to the international classification of functioning, disability and health and comparison to five health status instruments used in osteoarthritis. Rheumatology (Oxford). Nov. 2008;47(11):1719-25. [pmid: 18820312].
1746 Rat A-C, Guillemin F, Osnowycz G, et al. Total hip or knee replacement for osteoarthritis: mid- and long-term quality of life. Arthritis Care & Research. Jan. 15. 2010;62(1):54-62. [pmid: 20191491].
1747 Lifetime Trajectory of Sport and Overall Physical Activity by Time, Energy, Joint Force and Knee Osteoarthritis Status in a Canadian Sample. 2nd World Congress on Sports Injury Prevention. Tromso (Norway). 26–28 Jun 2008.
1748 Rauh MA, Boyle J, Mihalko WM, et al. Reliability of measuring long-standing lower extremity radiographs. Orthopedics. Apr. 2007;30(4):299-303. [pmid: 17424694].
1749 Rauscher I, Stahl R, Cheng J, et al. Meniscal measurements of T1rho and T2 at MR imaging in healthy subjects and patients with osteoarthritis. Radiology. Nov. 2008;249(2):591-600. [pmid: 18936315].
1750 Ravaud P, Auleley GR, Ayral X, et al. Piroxicam therapy: a double blind, randomized, multicenter study comparing 2 versus 4 week treatment in patients with painful knee osteoarthritis with effusion. Journal of Rheumatology. Dec. 1998;25(12):2425-31. [pmid: 9858440].
1751 Ravaud P, Giraudeau B, Auleley GR, et al. Radiographic assessment of knee osteoarthritis: reproducibility and sensitivity to change. J Rheumatol. Oct. 1996;23(10):1756-64. [pmid: 8895154].
1752 Raynauld JP. Magnetic resonance imaging of articular cartilage: toward a redefinition of “primary” knee osteoarthritis and its progression. Journal of Rheumatology. Sep. 2002;29(9):1809-10. [pmid: 12233869].
1753 Raynauld JP. Clinical trials: impact of intraarticular steroid injections on the progression of knee osteoarthritis. Osteoarthritis & Cartilage. May. 1999;7(3):348-9. [pmid: 10329327].
1754 Raynauld JP, Martel-Pelletier J, Abram F, et al. Analysis of the precision and sensitivity to change of different approaches to assess cartilage loss by quantitative MRI in a longitudinal multicentre clinical trial in patients with knee osteoarthritis. Arthritis Research & Therapy. 2008;10(6):R129. [pmid: 18986534].
1755 Raynauld JP, Martel-Pelletier J, Bias P, et al. Protective effects of licofelone, a 5-lipoxygenase and cyclo-oxygenase inhibitor, versus naproxen on cartilage loss in knee osteoarthritis: a first multicentre clinical trial using quantitative MRI. Annals of the Rheumatic Diseases. Jun. 2009;68(6):938-47. [pmid: 18653484].
1756 Raynauld JP, Torrance GW, Band PA, et al. A prospective, randomized, pragmatic, health outcomes trial evaluating the incorporation of hylan G-F 20 into the treatment paradigm for patients with knee osteoarthritis (Part 1 of 2): clinical results. Osteoarthritis & Cartilage. Jul. 2002;10(7):506-17. [pmid: 12127830].
1757 Raynauld J-P, Buckland-Wright C, Ward R, et al. Safety and efficacy of long-term intraarticular steroid injections in osteoarthritis of the knee: a randomized, double-blind, placebo-controlled trial. [Erratum appears in Arthritis Rheum. 2003 Nov;48(11):3300]. Arthritis & Rheumatism. Feb. 2003;48(2):370-7. [pmid: 12571845].
1758 Raynauld J-P, Martel-Pelletier J, Berthiaume M-J, et al. Quantitative magnetic resonance imaging evaluation of knee osteoarthritis progression over two years and correlation with clinical symptoms and radiologic changes. Arthritis & Rheumatism. Feb. 2004;50(2):476-87. [pmid: 14872490].
1759 Razmjou H, Yee A, Ford M, et al. Response shift in outcome assessment in patients undergoing total knee arthroplasty. J Bone Joint Surg Am. Dec. 2006;88(12):2590-5. [pmid: 17142408].
1760 In the Absence of Varus Malalignment, Lower Extremity (LE) Strength Training (ST) may Slow Medial Tibiofemoral Joint Space Narrowing (JSN) in Knee Osteoarthritis (OA). 70th Annual Meeting of the American College of Rheumatology and the 41st Annual Meeting of the Association of Rheumatology Health Professionals (ACR/ARHP 2006). Washington Convention Center, Washington DC (USA). 10–15 Nov 2006.
1761 Rees JL, Price AJ, Beard DJ, et al. Minimally invasive Oxford unicompartmental knee arthroplasty: functional results at 1 year and the effect of surgical inexperience. Knee. Oct. 2004;11(5):363-7. [pmid: 15351410].
1762 Reeuwijk KG, de Rooij M, van Dijk GM, et al. Osteoarthritis of the hip or knee: which coexisting disorders are disabling?. Clin Rheumatol. Jul. 2010;29(7):739-47. [pmid: 20177725].
1763 Reeves KD, Hassanein K. Randomized prospective double-blind placebo-controlled study of dextrose prolotherapy for knee osteoarthritis with or without ACL laxity. Alternative Therapies in Health and Medicine. 2000;6(2):68-74. 7. 80. [pmid: 10710805].
1764 Reeves KD, Hassanein KM. Long-term effects of dextrose prolotherapy for anterior cruciate ligament laxity. Alternative Therapies in Health & Medicine. May–Jun. 2003;9(3):58-62. [pmid: 12776476].
1765 Reginster JY, Deroisy R, Rovati LC, et al. Long-term effects of glucosamine sulphate on osteoarthritis progression: a randomised, placebo-controlled clinical trial. Lancet. Jan. 27. 2001;357(9252):251-6. [pmid: 11214126].
1766 Reichenbach S, Guermazi A, Niu J, et al. Prevalence of bone attrition on knee radiographs and MRI in a community-based cohort. Osteoarthritis & Cartilage. Sep. 2008;16(9):1005-10. [pmid: 18367415].
1767 Reichenbach S, Rutjes AW, Nuesch E, et al. Joint lavage for osteoarthritis of the knee. Cochrane Database Syst Rev. 2010;5:CD007320. [pmid: 20464751].
1768 Reid DA, McNair PJ. Effects of an acute hamstring stretch in people with and without osteoarthritis of the knee. Physiotherapy. Mar. 2010;96(1):14-21. [pmid: 20113758].
1769 Reijman M, Hazes JMW, Bierma-Zeinstra SMA, et al. A new marker for osteoarthritis: cross-sectional and longitudinal approach. Arthritis & Rheumatism. Aug. 2004;50(8):2471-8. [pmid: 15334460].
1770 Reilly DT. By the way, doctor. I have been taking capsules containing hyaluronic acid for my knees. Is there any downside to this medication? Harvard Health Letter. Feb. 2009;34(4):8. [pmid: 19263504].
1771 Reinbolt JA, Haftka RT, Chmielewski TL, et al. A computational framework to predict post-treatment outcome for gait-related disorders. Medical Engineering & Physics. 2008;30(4):434-43. [pmid: 17616425].
1772 Rejeski WJ, Miller ME, Foy C, et al. Self-efficacy and the progression of functional limitations and self-reported disability in older adults with knee pain. J Gerontol B Psychol Sci Soc Sci. Sep. 2001;56(5):S261-5. [pmid: 11522807].
1773 Rene J, Weinberger M, Mazzuca SA, et al. Reduction of joint pain in patients with knee osteoarthritis who have received monthly telephone calls from lay personnel and whose medical treatment regimens have remained stable. Arthritis Rheum. May. 1992;35(5):511-5. [pmid: 1575787].
1774 Renkawitz T, Rieder T, Handel M, et al. Comparison of two accelerated clinical pathways--after total knee replacement how fast can we really go?. Clinical Rehabilitation. Mar. 2010;24(3):230-9. [pmid: 20156984].
1775 Repicci JA. Mini-invasive knee unicompartmental arthroplasty: bone-sparing technique. Surgical Technology International. 2003;11:282-6. [pmid: 12931312].
1776 Rhodes LA, Keenan AM, Grainger AJ, et al. The relationship between limited MRI section analyses and volumetric assessment of synovitis in knee osteoarthritis. Clin Radiol. Dec. 2005;60(12):1295-9. [pmid: 16291311].
1777 Richette P, Francois M, Vicaut E, et al. A high interleukin 1 receptor antagonist/IL-1beta ratio occurs naturally in knee osteoarthritis. J Rheumatol. Aug. 2008;35(8):1650-4. [pmid: 18597398].
1778 Richmond J, Hunter D, Irrgang J, et al. Treatment of osteoarthritis of the knee (nonarthroplasty). J Am Acad Orthop Surg. 2009;17(9):591-600. [pmid: 19726743].
1779 Richmond SJ, Brown SR, Campion PD, et al. Therapeutic effects of magnetic and copper bracelets in osteoarthritis: a randomised placebo-controlled crossover trial. Complementary Therapies in Medicine. Oct–Dec. 2009;17(5–6):249-56. [pmid: 19942103].
1780 Riddle DL, Kong X, Jiranek WA. Two-year incidence and predictors of future knee arthroplasty in persons with symptomatic knee osteoarthritis: preliminary analysis of longitudinal data from the osteoarthritis initiative. Knee. Dec. 2009;16(6):494-500. [pmid: 19419874].
1781 Riddle DL, Lingard EA. Re: Response shift in outcome assessment in patients undergoing total knee arthroplasty. Journal of Bone & Joint Surgery - American Volume. Aug. 2007;89(8):1865. author reply -6. [pmid: 17671027].
1782 Riddle DL, Stratford PW, Singh JA, et al. Variation in outcome measures in hip and knee arthroplasty clinical trials: a proposed approach to achieving consensus. J Rheumatol. Sep. 2009;36(9):2050-6. [pmid: 19738212].
1783 Riddle DL, Wade JB, Jiranek WA, et al. Preoperative pain catastrophizing predicts pain outcome after knee arthroplasty. Clinical Orthopaedics & Related Research. 2010;468(3):798-806. [pmid: 19585177].
1784 Ridgeway SR, McAuley JP, Ammeen DJ, et al. The effect of alignment of the knee on the outcome of unicompartmental knee replacement. [Erratum appears in J Bone Joint Surg Br 2002 Sep;84(7):1091]. Journal of Bone & Joint Surgery - British Volume. Apr. 2002;84(3):351-5. [pmid: 12002491].
1785 Riegger-Krugh C, Gerhart TN, Powers WR, et al. Tibiofemoral contact pressures in degenerative joint disease. Clin Orthop Relat Res. Mar. 1998;(348):233-45. [pmid: 9553558].
1786 Riley D. Quadriceps strength and osteoarthritis progression in malaligned and lax knees. Annals of Internal Medicine. Jan. 20. 2004;140(2):149. [pmid: 14734349].
1787 Rillmann P, Oswald A, Holzach P, et al. Fulkerson’s modified Elmslie-Trillat procedure for objective patellar instability and patellofemoral pain syndrome. Swiss Surgery. 2000;6(6):328-34. [pmid: 11142157].
1788 Rindone JP, Hiller D, Collacott E, et al. Randomized, controlled trial of glucosamine for treating osteoarthritis of the knee. Western Journal of Medicine. 2000;172(2):91-4. [pmid: 10693368].
1789 Risberg MA, Beynnon BD, Peura GD, et al. Proprioception after anterior cruciate ligament reconstruction with and without bracing. Knee Surgery, Sports Traumatology, Arthroscopy. 1999;7(5):303-9. [pmid: 10525700].
1790 Riskowski JL, Mikesky AE, Bahamonde RE, et al. Design and validation of a knee brace with feedback to reduce the rate of loading. Journal of Biomechanical Engineering. Aug. 2009;131(8):084503. [pmid: 19604026].
1791 Ritchie JFS, Al-Sarawan M, Worth R, et al. A parallel approach: the impact of schuss radiography of the degenerate knee on clinical management. Knee. Aug. 2004;11(4):283-7. [pmid: 15261213].
1792 Ritter MA. The Anatomical Graduated Component total knee replacement: a long-term evaluation with 20-year survival analysis. Journal of Bone & Joint Surgery - British Volume. Jun. 2009;91(6):745-9. [pmid: 19483226].
1793 Ritter MA, Faris PM, Thong AE, et al. Intra-operative findings in varus osteoarthritis of the knee. An analysis of pre-operative alignment in potential candidates for unicompartmental arthroplasty. Journal of Bone & Joint Surgery - British Volume. Jan. 2004;86(1):43-7. [pmid: 14765864].
1794 Ritter MA, Lutgring JD, Davis KE, et al. The effect of postoperative range of motion on functional activities after posterior cruciate-retaining total knee arthroplasty. Journal of Bone & Joint Surgery - American Volume. Apr. 2008;90(4):777-84. [pmid: 18381316].
1795 Ritter MA, Lutgring JD, Davis KE, et al. Total knee arthroplasty effectiveness in patients 55 years old and younger: osteoarthritis vs. rheumatoid arthritis. Knee. Jan. 2007;14(1):9-11. [pmid: 17169563].
1796 Ritter MA, Wing JT, Berend ME, et al. The clinical effect of gender on outcome of total knee arthroplasty. Journal of Arthroplasty. Apr. 2008;23(3):331-6. [pmid: 18358368].
1797 Rittmeister M, Starker M, Zichner L. Hip and knee replacement after longstanding hip arthrodesis. Clinical Orthopaedics & Related Research. Feb. 2000;(371):136-45. [pmid: 10693560].
1798 Robbins SM, Birmingham TB, Maly MR, et al. Comparative diagnostic accuracy of knee adduction moments in knee osteoarthritis: a case for not normalizing to body size. Journal of Biomechanics. Mar. 15. 2011;44(5):968-71. [pmid: 21296354].
1799 Robbins SM, Maly MR. The effect of gait speed on the knee adduction moment depends on waveform summary measures. Gait Posture. Nov. 2009;30(4):543-6. [pmid: 19748272].
1800 Robb-Nicholson C. By the way, doctor. I read that glucosamine can affect insulin levels and may be ill-advised for diabetics. Does it cause diabetes in people who don’t already have the disease?. Harvard Women’s Health Watch. Jan. 2005;12(5):8. [pmid: 15803521].
1801 Robb-Nicholson C. By the way, doctor. What can I do about osteoarthritis of the knee? For several months, I’ve been taking a glucosamine/chondroitin supplement, but I still get painful flare-ups. Do these supplements really work? What else can I do to ease the pain?. Harvard Women’s Health Watch. Jun. 2006;13(10):8. [pmid: 16841385].
1802 Robertshawe P. Massage for Osteoarthritis of the Knee. Journal - Australian Traditional-Medicine Society. 2007;13(2):87.
1803 Robertshawe P. Acupuncture and TENS to treat knee osteoarthritis. Journal - Australian Traditional-Medicine Society. 2008;14(4):227-8.
1804 Robertsson O, Knutson K, Lewold S, et al. The routine of surgical management reduces failure after unicompartmental knee arthroplasty. Journal of Bone & Joint Surgery - British Volume. Jan. 2001;83(1):45-9. [pmid: 11245537].
1805 Robon MJ, Perell KL, Fang M, et al. The relationship between ankle plantar flexor muscle moments and knee compressive forces in subjects with and without pain. Clinical Biomechanics. 2000;15(7):522-7. [pmid: 10831812].
1806 Rodriguez JA, Baez N, Rasquinha V, et al. Metal-backed and all-polyethylene tibial components in total knee replacement. Clinical Orthopaedics & Related Research. Nov. 2001;(392):174-83. [pmid: 11716380].
1807 Rodriguez JA, Bhende H, Ranawat CS. Total condylar knee replacement: a 20-year followup study. Clinical Orthopaedics & Related Research. 2001;(388):10-7. [pmid: 11451106].
1808 Rodriguez-Merchan EC, Gomez-Cardero P. The outerbridge classification predicts the need for patellar resurfacing in TKA. Clinical Orthopaedics & Related Research. May. 2010;468(5):1254-7. [pmid: 19844770].
1809 Roemer FW, Guermazi A, Zhang Y, et al. Hoffa’s Fat Pad: Evaluation on Unenhanced MR Images as a Measure of Patellofemoral Synovitis in Osteoarthritis. AJR Am J Roentgenol. Jun. 2009;192(6):1696-700. [pmid: 19457837].
1810 Roemer FW, Lynch JA, Niu J, et al. A comparison of dedicated 1.0 T extremity MRI vs large-bore 1.5 T MRI for semiquantitative whole organ assessment of osteoarthritis: the MOST study. Osteoarthritis Cartilage. Feb. 2010;18(2):168-74. [pmid: 19766580].
1811 Roemer FW, Zhang Y, Niu J, et al. Tibiofemoral joint osteoarthritis: risk factors for MR-depicted fast cartilage loss over a 30-month period in the multicenter osteoarthritis study. Radiology. Sep. 2009;252(3):772-80. [pmid: 19635831].
1812 Rogers J, Watt I, Dieppe P. Comparison of visual and radiographic detection of bony changes at the knee joint. BMJ. Feb. 10. 1990;300(6721):367-8. [pmid: 2106987].
1813 Rogers JC, Holm MB, Beach S, et al. Concordance of four methods of disability assessment using performance in the home as the criterion method. Arthritis Care and Research. 2003;49(5):640-7. [pmid: 14558049].
1814 Rogers JC, Holm MB, Beach S, et al. Task independence, safety, and adequacy among nondisabled and osteoarthritis-disabled older women. Arthritis Rheum. Oct. 2001;45(5):410-8. [pmid: 11642639].
1815 Rogers JC, Irrgang JJ. Measures of adult lower extremity function: The American Academy of Orthopedic Surgeons Lower Limb Questionnaire, The Activities of Daily Living Scale of the Knee Outcome Survey (ADLS), Foot Function Index (FFI), Functional Assessment System (FAS), Harris Hip Score (HHS), Index of Severity for Hip Osteoarthritis (ISH), Index of Severity for Knee Osteoarthritis (ISK), Knee Injury and Osteoarthritis Outcome Score (KOOS), and Western Ontario and McMaster. Arthritis Care and Research. 2003;49(5 Supp):S67-84.
1816 Rolland Y, de Glisezinski I, Crampes F, et al. Sport et arthrose femorotibiale. Science and Sports. 2000;15(3):125-32.
1817 Romanowski MR, Repicci JA. Minimally invasive unicondylar arthroplasty: eight-year follow-up. The Journal of Knee Surgery. 2002;15(1):17-22. [pmid: 11829329].
1818 Romero J, Stahelin T, Binkert C, et al. The clinical consequences of flexion gap asymmetry in total knee arthroplasty. Journal of Arthroplasty. Feb. 2007;22(2):235-40. [pmid: 17275640].
1819 Special Issues: Risk of Developing Knee OA after ACL Injury, Evidence for Exercise Therapy?. 12th Congress of the European Society of Sports Traumatology, Knee Surgery and Arthroscopy (ESSKA 2000). Congress Innsbruck, Innsbruck (Austria). 24–27 May 2006.
1820 Roos EM, Bremander AB, Englund M, et al. Change in self-reported outcomes and objective physical function over 7 years in middle-aged subjects with or at high risk of knee osteoarthritis. Annals of the Rheumatic Diseases. 2008;67(4):505-10. [pmid: 17704069].
1821 Roos EM, Dahlberg L. Positive effects of moderate exercise on glycosaminoglycan content in knee cartilage: a four-month, randomized, controlled trial in patients at risk of osteoarthritis. Arthritis Rheum. Nov. 2005;52(11):3507-14. [pmid: 16258919].
1822 Roos EM, Ostenberg A, Roos H, et al. Long-term outcome of meniscectomy: symptoms, function, and performance tests in patients with or without radiographic osteoarthritis compared to matched controls. Osteoarthritis & Cartilage. May. 2001;9(4):316-24. [pmid: 11399095].
1823 Roos EM, Roos HP, Lohmander LS. WOMAC Osteoarthritis Index--additional dimensions for use in subjects with post-traumatic osteoarthritis of the knee. Western Ontario and MacMaster Universities. Osteoarthritis Cartilage. Mar. 1999;7(2):216-21. [pmid: 10222220].
1824 Roos EM, Roos HP, Ryd L, et al. Substantial disability 3 months after arthroscopic partial meniscectomy: A prospective study of patient-relevant outcomes. Arthroscopy. Sep. 2000;16(6):619-26. [pmid: 10976123].
1825 Rorabeck CH, Bourne RB, Lewis PL, et al. The Miller-Galante knee prosthesis for the treatment of osteoarthrosis. A comparison of the results of partial fixation with cement and fixation without any cement. J Bone Joint Surg Am. Mar. 1993;75(3):402-8. [pmid: 8444919].
1826 Rose PS, Johnson CA, Hungerford DS, et al. Total knee arthroplasty in Ehlers-Danlos syndrome. Journal of Arthroplasty. Feb. 2004;19(2):190-6. [pmid: 14973862].
1827 Rosemann T, Joos S, Szecsenyi J, et al. Health service utilization patterns of primary care patients with osteoarthritis. BMC Health Services Research. 2007;7(Journal Article):169. [pmid: 17956605].
1828 Rosemann T, Korner T, Wensing M, et al. Evaluation and cultural adaptation of a German version of the AIMS2-SF questionnaire (German AIMS2-SF). Rheumatology. 2005;44(9):1190-5. [pmid: 15972355].
1829 Rosemann T, Kuehlein T, Laux G, et al. Osteoarthritis of the knee and hip: a comparison of factors associated with physical activity. Clinical Rheumatology. Nov. 2007;26(11):1811-7. [pmid: 17332977].
1830 Rossi MD, Brown LE, Whitehurst M. Early strength response of the knee extensors during eight weeks of resistive training after unilateral total knee arthroplasty. Journal of Strength & Conditioning Research. Nov. 2005;19(4):944-9. [pmid: 16287362].
1831 Rossi MD, Brown LE, Whitehurst M. Knee extensor and flexor torque characteristics before and after unilateral total knee arthroplasty. Am J Phys Med Rehabil. Sep. 2006;85(9):737-46. [pmid: 16924186].
1832 Rossi MD, Hasson S, Kohia M, et al. Mobility and perceived function after total knee arthroplasty. J Arthroplasty. Jan. 2006;21(1):6-12. [pmid: 16446179].
1833 Rossi R, Ferro A, Bruzzone M, et al. NexGen LPS rotating platform total knee arthroplasty: medium-term results of a prospective study. Musculoskeletal Surgery. Sep. 2009;93(2):65-70. [pmid: 19711003].
1834 Rossignol M, Leclerc A, Allaert FA, et al. Primary osteoarthritis of hip, knee, and hand in relation to occupational exposure. Occup Environ Med. Nov. 2005;62(11):772-7. [pmid: 16234403].
1835 Rossini M, Viapiana O, Ramonda R, et al. Intra-articular clodronate for the treatment of knee osteoarthritis: dose ranging study vs hyaluronic acid. Rheumatology. Jul. 2009;48(7):773-8. [pmid: 19406908].
1836 Roth ML, Tripp DA, Harrison MH, et al. Demographic and psychosocial predictors of acute perioperative pain for total knee arthroplasty. Pain Res Manag. Autumn. 2007;12(3):185-94. [pmid: 17717610].
1837 Roth SH, Shainhouse JZ. Efficacy and safety of a topical diclofenac solution (pennsaid) in the treatment of primary osteoarthritis of the knee: a randomized, double-blind, vehicle-controlled clinical trial. Archives of Internal Medicine. Oct. 11. 2004;164(18):2017-23. [pmid: 15477437].
1838 Rother M, Lavins BJ, Kneer W, et al. Efficacy and safety of epicutaneous ketoprofen in Transfersome (IDEA-033) versus oral celecoxib and placebo in osteoarthritis of the knee: multicentre randomised controlled trial. Ann Rheum Dis. Sep. 2007;66(9):1178-83. [pmid: 17363401].
1839 Rothwell AG, Hooper GJ, Hobbs A, et al. An analysis of the Oxford hip and knee scores and their relationship to early joint revision in the New Zealand Joint Registry. Journal of Bone & Joint Surgery - British Volume. Mar. 2010;92(3):413-8. [pmid: 20190314].
1840 Rousseau JC, Zhu Y, Miossec P, et al. Serum levels of type IIA procollagen amino terminal propeptide (PIIANP) are decreased in patients with knee osteoarthritis and rheumatoid arthritis. Osteoarthritis and Cartilage. 2004;12(6):440-7. [pmid: 15135140].
1841 Rovensky J, Micekova D, Gubzova Z, et al. Treatment of knee osteoarthritis with a topical non-steroidal antiinflammatory drug. Results of a randomized, double-blind, placebo-controlled study on the efficacy and safety of a 5% ibuprofen cream. Drugs Under Experimental & Clinical Research. 2001;27(5–6):209-21. [pmid: 11951579].
1842 Rowe PJ, Myles CM, Nutton R. The effect of total knee arthroplasty on joint movement during functional activities and joint range of motion with particular regard to higher flexion users. Journal of Orthopaedic Surgery. 2005;13(2):131-8. [pmid: 16131674].
1843 Roy BD, de Beer J, Harvey D, et al. Creatine monohydrate supplementation does not improve functional recovery after total knee arthroplasty. Archives of Physical Medicine & Rehabilitation. Jul. 2005;86(7):1293-8. [pmid: 16003653].
1844 Roy V, Gupta U, Sharma S, et al. Comparative efficacy and tolerability of nimesulide and piroxicam in osteoarthritis with specific reference to chondroprotection: a double blind randomised study. Journal of the Indian Medical Association. Oct. 1999;97(10):442-5. [pmid: 10638109].
1845 Royer TD, Wasilewski CA. Hip and knee frontal plane moments in persons with unilateral, trans-tibial amputation. Gait and Posture. 2006;23(3):303-6. [pmid: 15919207].
1846 Rubinstein RA Jr, DeHaan A. The incidence and results of manipulation after primary total knee arthroplasty. Knee. Jan. 2010;17(1):29-32. [pmid: 19664928].
1847 Rudan J, Harrison M, Simurda MA. Optimizing femorotibial alignment in high tibial osteotomy. Canadian Journal of Surgery. Oct. 1999;42(5):366-70. [pmid: 10526522].
1848 Rudan JF, Harrison MM, Grant HJ. Determining patient concerns before joint arthroplasty. Journal of Arthroplasty. Oct. 2009;24(7):1115-9. [pmid: 18835690].
1849 Rudolph KS, Schmitt LC, Lewek MD. Age-related changes in strength, joint laxity, and walking patterns: are they related to knee osteoarthritis?. Phys Ther. Nov. 2007;87(11):1422-32. [pmid: 17785376].
1850 Ruff KJ, Winkler A, Jackson RW, et al. Eggshell membrane in the treatment of pain and stiffness from osteoarthritis of the knee: a randomized, multicenter, double-blind, placebo-controlled clinical study. Clin Rheumatol. Aug. 2009;28(8):907-14. [pmid: 19340512].
1851 RuizSanchez F, RullGarcia S, GonzalezGarcia M, et al. Clinical Functional Assessment After Treatment with Hyaluronic Acid and Short Wave in Patients with Knee Osteoarthritis. Rehabilitacion. 2006;40(5):241-7.
1852 Russo A, Montagna L, Bragonzoni L, et al. Fixation of total knee arthroplasty improved by mobile-bearing design. Clinical Orthopaedics & Related Research. 2005;(437):186-95. [pmid: 16056048].
1853 Rutherford DJ, Hubley-Kozey CL, Deluzio KJ, et al. Foot progression angle and the knee adduction moment: a cross-sectional investigation in knee osteoarthritis. Osteoarthritis & Cartilage. Aug. 2008;16(8):883-9. [pmid: 18182310].
1854 Rutjes AW, Nuesch E, Reichenbach S, et al. S-Adenosylmethionine for osteoarthritis of the knee or hip. Cochrane Database Syst Rev. 2009;(4):CD007321. [pmid: 19821403].
1855 Saadat E, Jobke B, Chu B, et al. Diagnostic performance of in vivo 3-T MRI for articular cartilage abnormalities in human osteoarthritic knees using histology as standard of reference. Eur Radiol. Oct. 2008;18(10):2292-302. [pmid: 18491096].
1856 Saal A, Gaertner J, Kuehling M, et al. Macroscopic and radiological grading of osteoarthritis correlates inadequately with cartilage height and histologically demonstrable damage to cartilage structure. Rheumatol Int. Apr. 2005;25(3):161-8. [pmid: 15703954].
1857 Saari T, Carlsson L, Karlsson J, et al. Knee kinematics in medial arthrosis. Dynamic radiostereometry during active extension and weight-bearing. Journal of Biomechanics. Feb. 2005;38(2):285-92. [pmid: 15598455].
1858 Sackley C, Disler Peter B, Turner-Stokes L, et al. Rehabilitation interventions for foot drop in neuromuscular disease, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2009.
1859 Sah AP, Scott RD. Lateral unicompartmental knee arthroplasty through a medial approach. Study with an average five-year follow-up. Journal of Bone & Joint Surgery - American Volume. Sep. 2007;89(9):1948-54. [pmid: 17768191].
1860 Sairanen E, Brushaber L, Kaskinen M. Felling work, low-back pain and osteoarthritis. Scand J Work Environ Health. Mar. 1981;7(1):18-30. [pmid: 6458885].
1861 Saito N, Tensyo K, Horiuchi H, et al. Brothers with genu recurvatum. Knee. Dec. 2007;14(6):500-1. [pmid: 17900909].
1862 Saito T, Takeuchi R, Ara Y, et al. High tibial osteotomy with anterior advancement of distal fragment for medial and patellofemoral compartmental osteoarthritis of the knee. Knee. May. 2002;9(2):127-32. [pmid: 11950576].
1863 Saito T, Takeuchi R, Yamamoto K, et al. Unicompartmental knee arthroplasty for osteoarthritis of the knee: remaining postoperative flexion contracture affecting overall results. Journal of Arthroplasty. Aug. 2003;18(5):612-8. [pmid: 12934214].
1864 Salaffi F, Carotti M, Stancati A, et al. Health-related quality of life in older adults with symptomatic hip and knee osteoarthritis: a comparison with matched healthy controls. Aging Clin Exp Res. Aug. 2005;17(4):255-63. [pmid: 16285189].
1865 Salaffi F, Leardini G, Canesi B, et al. Reliability and validity of the Western Ontario and McMaster Universities (WOMAC) Osteoarthritis Index in Italian patients with osteoarthritis of the knee. Osteoarthritis Cartilage. Aug. 2003;11(8):551-60. [pmid: 12880577].
1866 Salaffi F, Piva S, Barreca C, et al. Validation of an Italian version of the arthritis impact measurement scales 2 (ITALIAN-AIMS2) for patients with osteoarthritis of the knee. Gonarthrosis and Quality of Life Assessment (GOQOLA) Study Group. Rheumatology. 2000;39(7):720-7. [pmid: 10908689].
1867 Salavati M, Mazaheri M, Negahban H, et al. Validation of a Persian-version of Knee injury and Osteoarthritis Outcome Score (KOOS) in Iranians with knee injuries. Osteoarthritis Cartilage. Oct. 2008;16(10):1178-82. [pmid: 18411065].
1868 Salvi AE, Alia T. Von Langenbeck’s medial parapatellar approach for unicompartmental knee arthroplasty (with reply). Orthopedics. Jul. 2009;32(7):470. author reply. [pmid: 19634858].
1869 Salzmann GM, Paul J, Bauer JS, et al. T2 assessment and clinical outcome following autologous matrix-assisted chondrocyte and osteochondral autograft transplantation. Osteoarthritis & Cartilage. Dec. 2009;17(12):1576-82. [pmid: 19737529].
1870 Sandy JD, Flannery CR, Neame PJ, et al. The structure of aggrecan fragments in human synovial fluid. Evidence for the involvement in osteoarthritis of a novel proteinase which cleaves the Glu 373-Ala 374 bond of the interglobular domain. J Clin Invest. May. 1992;89(5):1512-6. [pmid: 1569188].
1871 Sangdee C, Teekachunhatean S, Sananpanich K, et al. Electroacupuncture versus diclofenac in symptomatic treatment of osteoarthritis of the knee: a randomized controlled trial. BMC Complementary & Alternative Medicine. Journal Article. 2002;2:3. [pmid: 11914160].
1872 Sangwan SS, Siwach RC, Singh Z, et al. Unicompartmental osteoarthritis of the knee: an innovative osteotomy. International Orthopaedics. 2000;24(3):148-50. [pmid: 10990385].
1873 Santaguida Pasqualina L, Gross A, Goldsmith Charles H, et al. Orthoses for mechanical neck disorders, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2007.
1874 Saragaglia D, Estour G, Nemer C, et al. Revision of 33 unicompartmental knee prostheses using total knee arthroplasty: strategy and results. International Orthopaedics. Aug. 2009;33(4):969-74. [pmid: 18563411].
1875 Saragaglia D, Mercier N, Colle PE. Computer-assisted osteotomies for genu varum deformity: which osteotomy for which varus?. International Orthopaedics. Feb. 2010;34(2):185-90. [pmid: 19305996].
1876 Saragaglia D, Picard F, Leitner F. An 8- to 10-year follow-up of 26 computer-assisted total knee arthroplasties. Orthopedics. Oct. 2007;30(10 Suppl):S121-3. [pmid: 17983112].
1877 Sariali E, Catonne Y. Modification of tibial slope after medial opening wedge high tibial osteotomy: clinical study and mathematical modelling. Knee Surgery, Sports Traumatology, Arthroscopy. Oct. 2009;17(10):1172-7. [pmid: 19183955].
1878 Sasanuma H, Sekiya H, Takatoku K, et al. Evaluation of soft-tissue balance during total knee arthroplasty. Journal of Orthopaedic Surgery. Apr. 2010;18(1):26-30. [pmid: 20427829].
1879 Sathappan SS, Pang H-N, Manoj A, et al. Does stress shielding occur with the use of long-stem prosthesis in total knee arthroplasty?. Knee Surgery, Sports Traumatology, Arthroscopy. Feb. 2009;17(2):179-83. [pmid: 18974974].
1880 Savas S, Cetin M, Akdogan M, et al. Endemic fluorosis in Turkish patients: relationship with knee osteoarthritis. Rheumatol Int. Sep. 2001;21(1):30-5. [pmid: 11678300].
1881 Saw A, Kwan MK, Sengupta S. Necrotising fasciitis: a life-threatening complication of acupuncture in a patient with diabetes mellitus. Singapore Medical Journal. 2004;45(4):180-2. [pmid: 15094988].
1882 Sawitzke AD, Shi H, Finco MF, et al. The effect of glucosamine and/or chondroitin sulfate on the progression of knee osteoarthritis: a report from the glucosamine/chondroitin arthritis intervention trial. Arthritis & Rheumatism. Oct. 2008;58(10):3183-91. [pmid: 18821708].
1883 Sawitzke AD, Shi H, Finco MF, et al. Clinical efficacy and safety of glucosamine, chondroitin sulphate, their combination, celecoxib or placebo taken to treat osteoarthritis of the knee: 2-year results from GAIT. Annals of the Rheumatic Diseases. Aug. 2010;69(8):1459-64. [pmid: 20525840].
1884 Saxler G, Temmen D, Bontemps G. Medium-term results of the AMC-unicompartmental knee arthroplasty. Knee. Oct. 2004;11(5):349-55. [pmid: 15351408].
1885 Sayre EC, Li LC, Kopec JA, et al. The effect of disease site (knee, hip, hand, foot, lower back or neck) on employment reduction due to osteoarthritis. PLoS One. 2010;5(5):e10470. [pmid: 20454665].
1886 Scarvell JM, Smith PN, Refshauge KM, et al. Magnetic resonance imaging analysis of kinematics in osteoarthritic knees. Journal of Arthroplasty. Apr. 2007;22(3):383-93. [pmid: 17400095].
1887 Schafer T, Krummenauer F, Mettelsiefen J, et al. Social, educational, and occupational predictors of total hip replacement outcome. Osteoarthritis Cartilage. Aug. 2010;18(8):1036-42. [pmid: 20546906].
1888 Scharf HP, Mansmann U, Streitberger K, et al. Acupuncture and knee osteoarthritis: a three-armed randomized trial. Annals of Internal Medicine. Jul. 4. 2006;145(1):12-20. [pmid: 16818924].
1889 Schein JR, Kosinski MR, Janagap-Benson C, et al. Functionality and health-status benefits associated with reduction of osteoarthritis pain. Current Medical Research & Opinion. May. 2008;24(5):1255-65. [pmid: 18358082].
1890 Scher C, Craig J, Nelson F. Bone marrow edema in the knee in osteoarthrosis and association with total knee arthroplasty within a three-year follow-up. Skeletal Radiology. Jul. 2008;37(7):609-17. [pmid: 18463865].
1891 Schett G, Kiechl S, Bonora E, et al. Vascular cell adhesion molecule 1 as a predictor of severe osteoarthritis of the hip and knee joints. Arthritis Rheum. Aug. 2009;60(8):2381-9. [pmid: 19644856].
1892 Schiff M, Minic M. Comparison of the analgesic efficacy and safety of nonprescription doses of naproxen sodium and Ibuprofen in the treatment of osteoarthritis of the knee. Journal of Rheumatology. Jul. 2004;31(7):1373-83. [pmid: 15229960].
1893 Schmid B, Ludtke R, Selbmann HK, et al. Efficacy and tolerability of a standardized willow bark extract in patients with osteoarthritis: randomized placebo-controlled, double blind clinical trial. Phytotherapy Research. Jun. 2001;15(4):344-50. [pmid: 11406860].
1894 Schmidt WA, Völker L, et al. Colour Doppler ultrasonography to detect pannus in knee joint synovitis. Clinical & Experimental Rheumatology. Jul–Aug. 2000;18(4):439-44. [pmid: 10949717].
1895 Schmidt-Rohlfing B, Silny J, Woodruff S, et al. Effects of pulsed and sinusoid electromagnetic fields on human chondrocytes cultivated in a collagen matrix. Rheumatol Int. Aug. 2008;28(10):971-7. [pmid: 18389240].
1896 Schmidt-Rohlfing B, Thomsen M, Niedhart C, et al. Correlation of bone and cartilage markers in the synovial fluid with the degree of osteoarthritis. Rheumatol Int. Mar. 2002;21(5):193-9. [pmid: 11958436].
1897 Relationships among factors associated with medial knee osteoarthritis. 2006. 2006 Combined Sections Meeting of the Specialty Sections of the American Physical Therapy Association (CSM 2006). San Diego Convention Center, San Diego, CA (USA). 1–5 Feb 2006.
1898 Muscle Stabilization Strategies in Persons with Medial Knee Osteoarthritis: The Effect of Instability. 2007 Combined Sections Meeting of the American Physical Therapy Association (CSM 2007). Boston, Massachusetts (USA). 14–18 Feb 2007.
1899 Schmitt LC, Rudolph KS. Influences on knee movement strategies during walking in persons with medial knee osteoarthritis. Arthritis & Rheumatism. 2007;57(6):1018-26. [pmid: 17665469].
1900 Schmitt LC, Rudolph KS. Muscle stabilization strategies in people with medial knee osteoarthritis: the effect of instability. J Orthop Res. Sep. 2008;26(9):1180-5. [pmid: 18404657].
1901 Schnitzer TJ. Update of ACR guidelines for osteoarthritis: Role of the coxibs. Journal of Pain and Symptom Management. 2002;23(4 SUPPL 1).
1902 Schnitzer TJ, Beier J, Geusens P, et al. Efficacy and safety of four doses of lumiracoxib versus diclofenac in patients with knee or hip primary osteoarthritis: a phase II, four-week, multicenter, randomized, double-blind, placebo-controlled trial. Arthritis & Rheumatism. Aug. 15. 2004;51(4):549-57. [pmid: 15334426].
1903 Schnitzer TJ, Kivitz A, Frayssinet H, et al. Efficacy and safety of naproxcinod in the treatment of patients with osteoarthritis of the knee: a 13-week prospective, randomized, multicenter study. Osteoarthritis Cartilage. May. 2010;18(5):629-39. [pmid: 20202489].
1904 Schnitzer TJ, Kivitz AJ, Lipetz RS, et al. Comparison of the COX-inhibiting nitric oxide donator AZD3582 and rofecoxib in treating the signs and symptoms of Osteoarthritis of the knee. Arthritis & Rheumatism. Dec. 15. 2005;53(6):827-37. [pmid: 16342089].
1905 A 4-Week Comparative Study Evaluating Acetaminophen Extended-Release and Rofecoxib in Treatment of Osteoarthritis of the Knee. 2006 Annual European Congress of Rheumatology (EULAR 2006). Amsterdam (Netherlands (The)). 21–24 Jun 2006.
1906 Schnitzer TJ, Tesser JRP, Cooper KM, et al. A 4-week randomized study of acetaminophen extended-release vs rofecoxib in knee osteoarthritis. Osteoarthritis & Cartilage. Jan. 2009;17(1):1-7. [pmid: 18640856].
1907 Schnitzer TJ, Weaver AL, Polis AB, et al. Efficacy of rofecoxib, celecoxib, and acetaminophen in patients with osteoarthritis of the knee. A combined analysis of the VACT studies. Journal of Rheumatology. Jun. 2005;32(6):1093-105. [pmid: 15940774].
1908 Schroer WC, Diesfeld PJ, LeMarr A, et al. Applicability of the mini-subvastus total knee arthroplasty technique: an analysis of 725 cases with mean 2-year follow-up. Journal of Surgical Orthopaedic Advances. 2007;16(3):131-7. [pmid: 17963656].
1909 Schumacher HR, Paul C, Hitchon CA, et al. Hyaluronate effects on synovium and synovial fluid. A prospective blinded study in patients with osteoarthritis of the knee. Osteoarthritis & Cartilage. May. 2006;14(5):501-3. [pmid: 16431141].
1910 Schurman DJ, Rojer DE. Total knee arthroplasty: range of motion across five systems. Clinical Orthopaedics & Related Research. 2005;(430):132-7. [pmid: 15662314].
1911 Schwerha JJ. Occupational medicine forum. Journal of Occupational & Environmental Medicine. Sep. 2005;47(9):967-71. [pmid: 16155482].
1912 Scopaz KA, Piva SR, Wisniewski S, et al. Relationships of fear, anxiety, and depression with physical function in patients with knee osteoarthritis. Arch Phys Med Rehabil. Nov. 2009;90(11):1866-73. [pmid: 19887210].
1913 Scott BO. The place and benefit of physical (particularly electro-therapeutic) methods of treatment in modern medical practice. Proc R Soc Med. Aug. 1973;66(8):784-7. [pmid: 4542595].
1914 Scott G. Letter to the editor: early outcome of TKA with a medial pivot fixed-bearing prosthesis is worse than with a PFC mobile-bearing prosthesis. Clinical Orthopaedics & Related Research. Mar. 2009;467(3):855-6. author reply 7–8. [pmid: 19096901].
1915 Scott RD. Mobile- versus fixed-bearing unicompartmental knee arthroplasty. Instructional Course Lectures. 2010;59:57-60. [pmid: 20415367].
1916 Scott WN. Arthroscopic debridement: tunnel vision?. Orthopedics. Sep. 1999;22(9):867-8. [pmid: 10507348].
1917 Seckin U, Gunduz S, Borman P, et al. Evaluation of the compliance to exercise therapy in patients with knee osteoarthritis. Journal of Back and Musculoskeletal Rehabilitation. 2000;14(3):133-7.
1918 Segal NA, Anderson DD, Iyer KS, et al. Baseline articular contact stress levels predict incident symptomatic knee osteoarthritis development in the MOST cohort. J Orthop Res. Dec. 2009;27(12):1562-8. [pmid: 19533741].
1919 Segal NA, Felson DT, Torner JC, et al. Greater trochanteric pain syndrome: epidemiology and associated factors. Arch Phys Med Rehabil. Aug. 2007;88(8):988-92. [pmid: 17678660].
1920 Segal NA, Glass NA, Torner J, et al. Quadriceps weakness predicts risk for knee joint space narrowing in women in the MOST cohort. Osteoarthritis Cartilage. Jun. 2010;18(6):769-75. [pmid: 20188686].
1921 Segal NA, Harvey W, Felson DT, et al. Leg-length inequality is not associated with greater trochanteric pain syndrome. Arthritis Research & Therapy. 2008;10(3):R62. [pmid: 18510741].
1922 Segal NA, Toda Y. Absolute reduction in lower limb lean body mass in Japanese women with knee osteoarthritis. J Clin Rheumatol. Oct. 2005;11(5):245-9. [pmid: 16357770].
1923 Segal NA, Torner JC, Felson D, et al. Effect of thigh strength on incident radiographic and symptomatic knee osteoarthritis in a longitudinal cohort. Arthritis & Rheumatism. Sep. 15. 2009;61(9):1210-7. [pmid: 19714608].
1924 Segal NA, Torner JC, Felson DT, et al. Knee extensor strength does not protect against incident knee symptoms at 30 months in the multicenter knee osteoarthritis (MOST) cohort. Pm & R. May. 2009;1(5):459-65. [pmid: 19627933].
1925 Segal NA, Torner JC, Yang M, et al. Muscle mass is more strongly related to hip bone mineral density than is quadriceps strength or lower activity level in adults over age 50 year. J Clin Densitom. Oct–Dec. 2008;11(4):503-10. [pmid: 18456530].
1926 Segal NA, Yack HJ, Brubaker M, et al. Association of dynamic joint power with functional limitations in older adults with symptomatic knee osteoarthritis. Arch Phys Med Rehabil. Nov. 2009;90(11):1821-8. [pmid: 19887204].
1927 Seidler A, Bolm-Audorff U, Abolmaali N, et al. The role of cumulative physical work load in symptomatic knee osteoarthritis - a case-control study in Germany. J Occup Med Toxicol. 2008;3(1):14. [pmid: 18625053].
1928 Seise M, McKenna SJ, Ricketts IW, et al. Learning active shape models for bifurcating contours. IEEE Trans Med Imaging. May. 2007;26(5):666-77. [pmid: 17518061].
1929 Self BP, Greenwald RM, Pflaster DS. A biomechanical analysis of a medial unloading brace for osteoarthritis in the knee. Arthritis Care & Research. 2000;13(4):191-7. [pmid: 14635273].
1930 Sen C, Kocaoglu M, Eralp L. The advantages of circular external fixation used in high tibial osteotomy (average 6 years follow-up). Knee Surgery, Sports Traumatology, Arthroscopy. May. 2003;11(3):139-44. [pmid: 12669193].
1931 Sengupta K, Alluri KV, Satish AR, et al. A double blind, randomized, placebo controlled study of the efficacy and safety of 5-Loxin for treatment of osteoarthritis of the knee. Arthritis Research & Therapy. 2008;10(4):R85. [pmid: 18667054].
1932 Senior CJ, da Assuncao RE, Barlow IW. Knee arthrodesis for limb salvage with an intramedullary coupled nail. Archives of Orthopaedic & Trauma Surgery. Jul. 2008;128(7):683-7. [pmid: 17618443].
1933 Seon JK, Park SJ, Lee KB, et al. Functional comparison of total knee arthroplasty performed with and without a navigation system. International Orthopaedics. Aug. 2009;33(4):987-90. [pmid: 18587573].
1934 Seon JK, Song EK, Yoon TR, et al. Comparison of functional results with navigation-assisted minimally invasive and conventional techniques in bilateral total knee arthroplasty. Computer Aided Surgery. May. 2007;12(3):189-93. [pmid: 17538792].
1935 Sepucha KR, Levin CA, Uzogara EE, et al. Developing instruments to measure the quality of decisions: early results for a set of symptom-driven decisions. Patient Education & Counseling. 2008;73(3):504-10. [pmid: 18718734].
1936 Sezgin M, Demirel AC, Karaca C, et al. Does hyaluronan affect inflammatory cytokines in knee osteoarthritis?. Rheumatol Int. May. 2005;25(4):264-9. [pmid: 14999424].
1937 Sgaglione NA, Chen E, Bert JM, et al. Current strategies for nonsurgical, arthroscopic, and minimally invasive surgical treatment of knee cartilage pathology. Instructional Course Lectures. 2010;59:157-80. [pmid: 20415378].
1938 Shaffer B, Hanypsiak B. Nonoperative and Arthroscopic Approaches to the Postmeniscectomy Arthritic Knee. Arthroscopy - Journal of Arthroscopic and Related Surgery. 2003;19(10 SUPPL 1):122-8.
1939 Shafshak TS. Electroacupuncture and exercise in body weight reduction and their application in rehabilitating patients with knee osteoarthritis. American Journal of Chinese Medicine. 1995;23(1):15-25. [pmid: 7598088].
1940 Shah K, Mohammed A, Patil S, et al. Circulating cytokines after hip and knee arthroplasty: a preliminary study. Clin Orthop Relat Res. Apr. 2009;467(4):946-51. [pmid: 18941856].
1941 Shakespeare D, Ledger M, Kinzel V. Flexion after total knee replacement. A comparison between the Medial Pivot knee and a posterior stabilised implant. Knee. Oct. 2006;13(5):371-3. [pmid: 16828289].
1942 Shakib S, George A. Introduction to monitoring. What is what you prescribed actually doing?. Australian Family Physician. Oct. 2003;32(10):843-5. 64. [pmid: 14596082].
1943 Shakoor N, Lidtke RH, Sengupta M, et al. Effects of specialized footwear on joint loads in osteoarthritis of the knee. Arthritis & Rheumatism. 2008;59(9):1214-20. [pmid: 18759313].
1944 Shakoor N, Sengupta M, Foucher KC, et al. Effects of common footwear on joint loading in osteoarthritis of the knee. Arthritis Care & Research. Jul. 2010;62(7):917-23. [pmid: 20191571].
1945 Shamir L, Ling SM, Scott WW Jr, et al. Knee x-ray image analysis method for automated detection of osteoarthritis. IEEE Transactions on Biomedical Engineering. Feb. 2009;56(2):407-15. [pmid: 19342330].
1946 Shannon FJ, Devitt AT, Poynton AR, et al. Short-term benefit of arthroscopic washout in degenerative arthritis of the knee. International Orthopaedics. 2001;25(4):242-5. [pmid: 11561500].
1947 Sharif M, Kirwan J, Charni N, et al. A 5-yr longitudinal study of type IIA collagen synthesis and total type II collagen degradation in patients with knee osteoarthritis--association with disease progression. Rheumatology. Jun. 2007;46(6):938-43. [pmid: 17387119].
1948 Sharif M, Kirwan JR, Elson CJ, et al. Suggestion of nonlinear or phasic progression of knee osteoarthritis based on measurements of serum cartilage oligomeric matrix protein levels over five years. Arthritis & Rheumatism. Aug. 2004;50(8):2479-88. [pmid: 15334461].
1949 Sharif M, Saxne T, Shepstone L, et al. Relationship between serum cartilage oligomeric matrix protein levels and disease progression in osteoarthritis of the knee joint. British Journal of Rheumatology. Apr. 1995;34(4):306-10. [pmid: 7788143].
1950 Sharma A, Rathod R, Baliga VP. An open prospective study on postmarketing evaluation of the efficacy and tolerability of diacerein in osteo-arthritis of the knee (DOK). Journal of the Indian Medical Association. Jan. 2008;106(1):54-6. [pmid: 18705272].
1951 Sharma H, Rana B, Mahendra A, et al. Outcome of 17 pigmented villonodular synovitis (PVNS) of the knee at 6 years mean follow-up. Knee. Oct. 2007;14(5):390-4. [pmid: 17600720].
1952 Sharma L. Examination of exercise effects of knee osteoarthritis outcomes: why should the local mechanical environment be considered?. Arthritis Care and Research. 2003;49(2):255-60. [pmid: 12687519].
1953 Sharma L, Dunlop DD, Cahue S, et al. Quadriceps strength and osteoarthritis progression in malaligned and lax knees. Annals of Internal Medicine. 2003;138(8):613-9. [pmid: 12693882].
1954 Sharma L, Song J, Felson DT, et al. The role of knee alignment in disease progression and functional decline in knee osteoarthritis. JAMA. Jul. 11. 2001;286(2):188-95. [pmid: 11448282].
1955 Sharma V, Tsailas PG, Maheshwari AV, et al. Does patellar eversion in total knee arthroplasty cause patella baja?. Clinical Orthopaedics & Related Research. Nov. 2008;466(11):2763-8. [pmid: 18568378].
1956 Sharpe I, Tyrrell PN, White SH. Magnetic resonance imaging assessment for unicompartmental knee replacement: a limited role. Knee. Oct. 2001;8(3):213-8. [pmid: 11706729].
1957 Sharpe JR, Ahmed SU, Fleetcroft JP, et al. The treatment of osteochondral lesions using a combination of autologous chondrocyte implantation and autograft: three-year follow-up. Journal of Bone & Joint Surgery - British Volume. May. 2005;87(5):730-5. [pmid: 15855380].
1958 The effects of an 8 week resistance training program in older persons with knee osteoarthritis. 2007. 2007 Combined Sections Meeting of the American Physical Therapy Association (CSM 2007). Boston, Massachusetts (USA). 14–18 Feb 2007.
1959 Shelbourne KD, Benner RW. Isolated anterior cruciate ligament reconstruction in the chronic ACL-deficient knee with degenerative medial arthrosis. The Journal of Knee Surgery. Jul. 2007;20(3):216-22. [pmid: 17665784].
1960 Shelbourne KD, Gray T. Minimum 10-year results after anterior cruciate ligament reconstruction: how the loss of normal knee motion compounds other factors related to the development of osteoarthritis after surgery. American Journal of Sports Medicine. Mar. 2009;37(3):471-80. [pmid: 19059893].
1961 Shelby RA, Somers TJ, Keefe FJ, et al. Domain specific self-efficacy mediates the impact of pain catastrophizing on pain and disability in overweight and obese osteoarthritis patients. J Pain. Oct. 2008;9(10):912-9. [pmid: 18602871].
1962 Sheldon E, Beaulieu A, Paster Z, et al. Efficacy and tolerability of lumiracoxib in the treatment of osteoarthritis of the knee: a 13-week, randomized, double-blind comparison with celecoxib and placebo. Clinical Therapeutics. Jan. 2005;27(1):64-77. [pmid: 15763607].
1963 Shen CL, James CR, Chyu MC, et al. Effects of Tai Chi on gait kinematics, physical function, and pain in elderly with knee osteoarthritis--a pilot study. American Journal of Chinese Medicine. 2008;36(2):219-32. [pmid: 18457357].
1964 Shen H, Sprott H, Aeschlimann A, et al. Analgesic action of acetaminophen in symptomatic osteoarthritis of the knee. Rheumatology. 2006;45(6):765-70. [pmid: 16449370].
1965 Shen X, Zhao L, Ding G, et al. Effect of combined laser acupuncture on knee osteoarthritis: a pilot study. Lasers in Medical Science. 2009;24(2):129-36. [pmid: 18180980].
1966 Sheng P, Hu S, Tian J, et al. Clinical Report on Treating 100 Knee Osteoarthritis Cases with Electro-Warming Acupuncture. International Journal of Clinical Acupuncture. 2007;16(3):183-6.
1967 Sheng P-Y, Jamsen E, Lehto M, et al. Revision total knee arthroplasty with the total condylar III system: a comparative analysis of 71 consecutive cases of osteoarthritis or inflammatory arthritis. Acta Orthopaedica. Jun. 2006;77(3):512-8. [pmid: 16819694].
1968 Shim H, Chang S, Tao C, et al. Knee cartilage: efficient and reproducible segmentation on high-spatial-resolution MR images with the semiautomated graph-cut algorithm method. Radiology. May. 2009;251(2):548-56. [pmid: 19401579].
1969 Shimoyama H, Yonezawa Y, Nakamura H. Enhanced free-energy calculation using multiscale simulation. J Chem Phys. Oct. 7. 2010;133(13):135101. [pmid: 20942558].
1970 Shin K, Lee JC, Choi HJ, et al. Radiation synovectomy using 188Re-tin colloid improves knee synovitis as shown by MRI in refractory rheumatoid arthritis. Nuclear Medicine Communications. 2007;28(4):239-44. [pmid: 17325584].
1971 Shipley MT. Osteoarthritic knee rehabilitation in an elderly male: a functional approach. Journal of Sports Chiropractic and Rehabilitation. 2000;14(3):62-9.
1972 Shrader MW, Draganich LF, Pottenger LA, et al. Effects of knee pain relief in osteoarthritis on gait and stair-stepping. Clinical Orthopaedics & Related Research. Apr. 2004;(421):188-93. [pmid: 15123946].
1973 The Role of Diacerein in the Treatment of Osteoarthritis (OA) of Knee Joints and Spine. 2006 Annual European Congress of Rheumatology (EULAR 2006). Amsterdam (Netherlands (The)). 21–24 Jun 2006.
1974 Sillanpaa P, Mattila VM, Visuri T, et al. Ligament reconstruction versus distal realignment for patellar dislocation. Clinical Orthopaedics & Related Research. 2008;466(6):1475-84. [pmid: 18347890].
1975 Efficacy of Water Exercise in the Treatment of Patients With Knee Osteoarthritis: A Randomized, Single-Blind, Controlled Clinical Trial. 6th Annual European Congress of Rheumatology (EULAR 2005). Vienna (Austria). 8–11 Jun 2005.
1976 Silverman M, Nutini J, Musa D, et al. “Is it half full or half empty?” Affective responses to chronic illness. J Cross Cult Gerontol. Sep. 2009;24(3):291-306. [pmid: 19340567].
1977 Simon HB. On call. I am 46 years old and have arthritis of my knees. Ibuprofen helps, but I still have pain. Should I consider the new joint injections?. Harvard Mens Health Watch. Sep. 2000;5(2):8. [pmid: 10966598].
1978 Simon LS, Grierson LM, Naseer Z, et al. Efficacy and safety of topical diclofenac containing dimethyl sulfoxide (DMSO) compared with those of topical placebo, DMSO vehicle and oral diclofenac for knee osteoarthritis. Pain. Jun. 2009;143(3):238-45. [pmid: 19380203].
1979 Sims EL, Carland JM, Keefe FJ, et al. Sex differences in biomechanics associated with knee osteoarthritis. J Women Aging. Jul. 2009;21(3):159-70. [pmid: 20183142].
1980 Sims EL, Keefe FJ, Kraus VB, et al. Racial differences in gait mechanics associated with knee osteoarthritis. Aging Clin Exp Res. Dec. 2009;21(6):463-9. [pmid: 20154517].
1981 Singh BB, Berman BM, Hadhazy V, et al. Clinical decisions in the use of acupuncture as an adjunctive therapy for osteoarthritis of the knee. Alternative Therapies in Health & Medicine. 2001;7(4):58-65. [pmid: 11452568].
1982 Singh BB, Zarow FM, Mishra LC, et al. Acupuncture as a treatment for osteoarthritis of the knee: clinical relevance. Topics in Clinical Chiropractic. 2000;7(2):39-42.
1983 Singh BB, Zarow FM, Traina A, et al. A specific electrotherapy technique in the treatment of osteoarthritis of the knee: three case reports. Alternative Therapies in Health & Medicine. Sep. 2000;6(5):112. 0-1. [pmid: 11012282].
1984 Singh G. Treatment options for osteoarthritis. Surgical Technology International. 2003;11:287-92. [pmid: 12931313].
1985 Singh JA, O’Byrne M, Harmsen S, et al. Predictors of moderate-severe functional limitation after primary Total Knee Arthroplasty (TKA): 4701 TKAs at 2-years and 2935 TKAs at 5-years. Osteoarthritis & Cartilage. Apr. 2010;18(4):515-21. [pmid: 20060950].
1986 Singh Jasvinder A, Sperling J, Buchbinder R. Surgery for shoulder osteoarthritis, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2009.
1987 Siparsky P, Ryzewicz M, Peterson B, et al. Arthroscopic treatment of osteoarthritis of the knee: are there any evidence-based indications?. Clinical Orthopaedics & Related Research. 2007;455(Journal Article):107-12. [pmid: 17279040].
1988 Sisto DJ, Sarin VK. Custom patellofemoral arthroplasty of the knee. [Reprint in J Bone Joint Surg Am. 2007 Sep;89 Suppl 2 Pt.2:214–25; PMID: 17768216]. Journal of Bone & Joint Surgery - American Volume. Jul. 2006;88(7):1475-80. [pmid: 16818972].
1989 Siston RA, Giori NJ, Goodman SB, et al. Intraoperative passive kinematics of osteoarthritic knees before and after total knee arthroplasty. J Orthop Res. Aug. 2006;24(8):1607-14. [pmid: 16770795].
1990 Siston RA, Goodman SB, Delp SL, et al. Coronal plane stability before and after total knee arthroplasty. Clinical Orthopaedics & Related Research. 2007;463(Journal Article):43-9. [pmid: 17621236].
1991 Sivarasu S, Mathew L. 3D CAD conceptual design of an artificial knee. Journal of Long-Term Effects of Medical Implants. 2007;17(4):313-20. [pmid: 19267686].
1992 Siversson C, Tiderius CJ, Neuman P, et al. Repeatability of T1-quantification in dGEMRIC for three different acquisition techniques: two-dimensional inversion recovery, three-dimensional look locker, and three-dimensional variable flip angle. J Magn Reson Imaging. May. 2010;31(5):1203-9. [pmid: 20432357].
1993 Skwara A, Peterlein CD, Tibesku CO, et al. Changes of gait patterns and muscle activity after intraarticular treatment of patients with osteoarthritis of the knee: a prospective, randomised, doubleblind study. Knee. Dec. 2009;16(6):466-72. [pmid: 19362003].
1994 Skwara A, Ponelis R, Tibesku CO, et al. Gait patterns after intraarticular treatment of patients with osteoarthritis of the knee--hyaluronan versus triamcinolone: a prospective, randomized, doubleblind, monocentric study. European Journal of Medical Research. Apr. 16. 2009;14(4):157-64. [pmid: 19380288].
1995 Slimmon D, Bennell K, Brukner P, et al. Long-term outcome of fasciotomy with partial fasciectomy for chronic exertional compartment syndrome of the lower leg. American Journal of Sports Medicine. Jul–Aug. 2002;30(4):581-8. [pmid: 12130414].
1996 Slutsky J, Atkins D, Chang S, et al. AHRQ series paper 1: comparing medical interventions: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):481-3. [pmid: 18834715].
1997 Smith AJ, Wood DJ, Li MG. Total knee replacement with and without patellar resurfacing: a prospective, randomised trial using the profix total knee system. Journal of Bone & Joint Surgery - British Volume. Jan. 2008;90(1):43-9. [pmid: 18160498].
1998 Smith AM, Peckett WRC, Butler-Manuel PA, et al. Treatment of patello-femoral arthritis using the Lubinus patello-femoral arthroplasty: a retrospective review. Knee. Feb. 2002;9(1):27-30. [pmid: 11830378].
1999 Smith MD, Wetherall M, Darby T, et al. A randomized placebo-controlled trial of arthroscopic lavage versus lavage plus intra-articular corticosteroids in the management of symptomatic osteoarthritis of the knee. Rheumatology. 2003;42(12):1477-85. [pmid: 12867587].
2000 Smith R. The best brace for the case. Rehab Management. Jul. 2009;22(6):22-3. [pmid: 19718869].
2001 Smolinski D, Jones CW, Wu JP, et al. Confocal arthroscopic assessment of osteoarthritis in situ. Arthroscopy. Apr. 2008;24(4):423-9. [pmid: 18375274].
2002 Smugar SS, Schnitzer TJ, Weaver AL, et al. Rofecoxib 12.5 mg, rofecoxib 25 mg, and celecoxib 200 mg in the treatment of symptomatic osteoarthritis: results of two similarly designed studies. Current Medical Research & Opinion. Jul. 2006;22(7):1353-67. [pmid: 16834834].
2003 Snow R, Ruane J, LaLonde M, et al. Randomized trial assessing the impact of a musculoskeletal intervention for pain before participating in a weight management program. J Cardiopulm Rehabil Prev. May–Jun. 2010;30(3):173-80. [pmid: 20040884].
2004 Soininvaara TA, Jurvelin JS, Miettinen HJ, et al. Effect of alendronate on periprosthetic bone loss after total knee arthroplasty: a one-year, randomized, controlled trial of 19 patients. Calcif Tissue Int. Dec. 2002;71(6):472-7. [pmid: 12370800].
2005 Soininvaara TA, Miettinen HJ, Jurvelin JS, et al. Bone mineral density in the proximal femur and contralateral knee after total knee arthroplasty. J Clin Densitom. Winter. 2004;7(4):424-31. [pmid: 15618604].
2006 Solarino G, Luca A, Marzo L, et al. Comparison among total knee arthroplasties with a mobile bearing: menisci versus rotating platform versus AP glide platform. Chirurgia Degli Organi di Movimento. Sep. 2008;92(2):79-83. [pmid: 18587627].
2007 Solomon DH, Avorn J, Warsi A, et al. Which patients with knee problems are likely to benefit from nonarthroplasty surgery? Development of a clinical prediction rule. Arch Intern Med. Mar. 8. 2004;164(5):509-13. [pmid: 15006827].
2008 Somers TJ, Keefe FJ, Carson JW, et al. Pain catastrophizing in borderline morbidly obese and morbidly obese individuals with osteoarthritic knee pain. Pain Research & Management. 2008;13(5):401-6. [pmid: 18958312].
2009 Somers TJ, Keefe FJ, Pells JJ, et al. Pain catastrophizing and pain-related fear in osteoarthritis patients: relationships to pain and disability. J Pain Symptom Manage. May. 2009;37(5):863-72. [pmid: 19041218].
2010 Song E-K, Seon J-K, Park SJ. How to avoid unintended increase of posterior slope in navigation-assisted open-wedge high tibial osteotomy. Orthopedics. Oct. 2007;30(10 Suppl):S127-31. [pmid: 17983114].
2011 Song IH, Althoff CE, Hermann KG, et al. Contrast-enhanced ultrasound in monitoring the efficacy of a bradykinin receptor 2 antagonist in painful knee osteoarthritis compared with MRI. Annals of the Rheumatic Diseases. Jan. 2009;68(1):75-83. [pmid: 18375537].
2012 Song IH, Althoff CE, Hermann KG, et al. Knee osteoarthritis. Efficacy of a new method of contrast-enhanced musculoskeletal ultrasonography in detection of synovitis in patients with knee osteoarthritis in comparison with magnetic resonance imaging. Annals of the Rheumatic Diseases. Jan. 2008;67(1):19-25. [pmid: 19957383].
2013 Sontakke S, Thawani V, Pimpalkhute S, et al. Open, randomized, controlled clinical trial of Boswellia serrata extract as compared to valdecoxib in osteoarthritis of knee. Indian J Pharmacol. 2007;39(1):27-9.
2014 Souchek J, Byrne MM, Kelly PA, et al. Valuation of arthritis health states across ethnic groups and between patients and community members. Medical care. 2005;43(9):921-8. [pmid: 16116357].
2015 Tsaridis E, Sarikloglou S, Papasoulis E, et al. Correction of tibial deformity in Paget’s disease using the Taylor spatial frame. Journal of Bone & Joint Surgery - British Volume. Feb. 2008;90(2):243-4. [pmid: 18256098].
2016 Sowers M, Jannausch ML, Gross M, et al. Performance-based physical functioning in African-American and Caucasian women at midlife: considering body composition, quadriceps strength, and knee osteoarthritis. Am J Epidemiol. May. 15. 2006;163(10):950-8. [pmid: 16554351].
2017 Sowers MF, Karvonen-Gutierrez CA, Yosef M, et al. Longitudinal changes of serum COMP and urinary CTX-II predict X-ray defined knee osteoarthritis severity and stiffness in women. Osteoarthritis Cartilage. Dec. 2009;17(12):1609-14. [pmid: 19563924].
2018 Spahn G. Complications in high tibial (medial opening wedge) osteotomy. Archives of Orthopaedic & Trauma Surgery. Dec. 2004;124(10):649-53. [pmid: 14520581].
2019 Spahn G, Kirschbaum S, Kahl E. Factors that influence high tibial osteotomy results in patients with medial gonarthritis: a score to predict the results. Osteoarthritis & Cartilage. Feb. 2006;14(2):190-5. [pmid: 16275143].
2020 Spahn G, Muckley T, Kahl E, et al. Factors affecting the outcome of arthroscopy in medial-compartment osteoarthritis of the knee. Arthroscopy. Nov. 2006;22(11):1233-40. [pmid: 17084302].
2021 Sparmann M, Wolke B, Czupalla H, et al. Positioning of total knee arthroplasty with and without navigation support. A prospective, randomised study. Journal of Bone & Joint Surgery - British Volume. Aug. 2003;85(6):830-5. [pmid: 12931800].
2022 Spencer BA, Mont MA, McGrath MS, et al. Initial experience with custom-fit total knee replacement: intra-operative events and long-leg coronal alignment. International Orthopaedics. Dec. 2009;33(6):1571-5. [pmid: 19099305].
2023 Spicer DD, Pomeroy DL, Badenhausen WE, et al. Body mass index as a predictor of outcome in total knee replacement. International Orthopaedics. 2001;25(4):246-9. [pmid: 11561501].
2024 Spicer DDM, Curry JI, Pomeroy DL, et al. Range of motion after arthroplasty for the stiff osteoarthritic knee. Journal of the Southern Orthopaedic Association. 2002;11(4):227-30. [pmid: 12597067].
2025 Spreng UJ, Dahl V, Hjall A, et al. High-volume local infiltration analgesia combined with intravenous or local ketorolac+morphine compared with epidural analgesia after total knee arthroplasty. Br J Anaesth. Nov. 2010;105(5):675-82. [pmid: 20736233].
2026 Sprenger TR, Doerzbacher JF. Tibial osteotomy for the treatment of varus gonarthrosis. Survival and failure analysis to twenty-two years. [Erratum appears in J Bone Joint Surg Am 2003 May 85-A(5):912]. Journal of Bone & Joint Surgery - American Volume. Mar. 2003;85-A(3):469-74. [pmid: 12637433].
2027 Stürmer T, et al. Severity and extent of osteoarthritis and low grade systemic inflammation as assessed by high sensitivity C reactive protein. Annals of the Rheumatic Diseases. Feb. 2004;63(2):200-5. [pmid: 14722211].
2028 Stahl R, Krug R, Kelley DA, et al. Assessment of cartilage-dedicated sequences at ultra-high-field MRI: comparison of imaging performance and diagnostic confidence between 3.0 and 7.0 T with respect to osteoarthritis-induced changes at the knee joint. Skeletal Radiology. Aug. 2009;38(8):771-83. [pmid: 19294379].
2029 Stahl R, Luke A, Li X, et al. T1rho, T2 and focal knee cartilage abnormalities in physically active and sedentary healthy subjects versus early OA patients--a 3.0-Tesla MRI study. Eur Radiol. Jan. 2009;19(1):132-43. [pmid: 18709373].
2030 Stambuk B, Pasalic B. Viscosuplementation with hyaluronic acid in osteoarthritis treatment--our experiences. Reumatizam. 2006;53(2):95-7. [pmid: 17580563].
2031 Stamenovic D, Kojic M, Stojanovic B, et al. Pneumatic osteoarthritis knee brace. Journal of Biomechanical Engineering. Apr. 2009;131(4):045001. [pmid: 19275449].
2032 Stannage K, Shakespeare D, Bulsara M. Suction technique to improve cement penetration under the tibial component in total knee arthroplasty. Knee. Mar. 2003;10(1):67-73. [pmid: 12649030].
2033 Starks I, Roberts S, White SH. The Avon patellofemoral joint replacement: independent assessment of early functional outcomes. Journal of Bone & Joint Surgery - British Volume. Dec. 2009;91(12):1579-82. [pmid: 19949120].
2034 Staubli AE, De Simoni C, Babst R, et al. TomoFix: a new LCP-concept for open wedge osteotomy of the medial proximal tibia--early results in 92 cases. Injury. Nov. Suppl 2. 2003;34:B55-62. [pmid: 14580986].
2035 Steadman JR, Ramappa AJ, Maxwell RB, et al. An arthroscopic treatment regimen for osteoarthritis of the knee. Arthroscopy. Sep. 2007;23(9):948-55. [pmid: 17868833].
2036 Steele RG, Hutabarat S, Evans RL, et al. Survivorship of the St Georg Sled medial unicompartmental knee replacement beyond ten years. Journal of Bone & Joint Surgery - British Volume. Sep. 2006;88(9):1164-8. [pmid: 16943465].
2037 Stein DA, Brown H, Bartolozzi AR. Age and ACL reconstruction revisited. Orthopedics. Jun. 2006;29(6):533-6. [pmid: 16786946].
2038 Stein V, Li L, Guermazi A, et al. The relation of femoral notch stenosis to ACL tears in persons with knee, osteoarthritis. Osteoarthritis and Cartilage. 2010;18(2):192-9. [pmid: 19835830].
2039 Stengaard-Pedersen K, Ekesbo R, Karvonen AL, et al. Celecoxib 200 mg q.d. is efficacious in the management of osteoarthritis of the knee or hip regardless of the time of dosing. Rheumatology. 2004;43(5):592-5. [pmid: 14762227].
2040 Sterett WI, Steadman JR. Chondral resurfacing and high tibial osteotomy in the varus knee. American Journal of Sports Medicine. Jul–Aug. 2004;32(5):1243-9. [pmid: 15262649].
2041 Steultjens MP, Dekker J, Bijlsma JW. Coping, pain, and disability in osteoarthritis: a longitudinal study. J Rheumatol. May. 2001;28(5):1068-72. [pmid: 11361191].
2042 Steultjens MP, Dekker J, Bijlsma JW. Avoidance of activity and disability in patients with osteoarthritis of the knee: the mediating role of muscle strength. Arthritis Rheum. Jul. 2002;46(7):1784-8. [pmid: 12124862].
2043 Stevens DG, Beharry R, McKee MD, et al. The long-term functional outcome of operatively treated tibial plateau fractures. J Orthop Trauma. Jun–Jul. 2001;15(5):312-20. [pmid: 11433134].
2044 Stevens JE, Mizner RL, Snyder-Mackler L. Quadriceps strength and volitional activation before and after total knee arthroplasty for osteoarthritis. J Orthop Res. Sep. 2003;21(5):775-9. [pmid: 12919862].
2045 Stevens-Lapsley JE, Balter JE, Kohrt WM, et al. Quadriceps and hamstrings muscle dysfunction after total knee arthroplasty. Clinical Orthopaedics & Related Research. Sep. 2010;468(9):2460-8. [pmid: 20087703].
2046 Stiehl JB. Transepicondylar distal femoral pin placement in computer assisted surgical navigation. Computer Aided Surgery. Jul. 2007;12(4):242-6. [pmid: 17786600].
2047 Stiller CO, Lundblad H, Weidenhielm L, et al. The addition of tramadol to morphine via patient-controlled analgesia does not lead to better post-operative pain relief after total knee arthroplasty. Acta Anaesthesiologica Scandinavica. Mar. 2007;51(3):322-30. [pmid: 17096666].
2048 Stitik TP, Kaplan RJ, Kamen LB, et al. Rehabilitation of orthopedic and rheumatologic disorders. 2. Osteoarthritis assessment, treatment, and rehabilitation. Arch Phys Med Rehabil. Mar. 2005;86(3 Suppl 1):S48-55. [pmid: 15761801].
2049 Stock D, Diezemann ED, Gottstein J, et al. The treatment of osteoarthritis with unconstrained and constrained knee prostheses. Archives of Orthopaedic & Trauma Surgery. 1979;95(4):227-32. [pmid: 547962].
2050 Stone KR, Walgenbach AW, Freyer A, et al. Articular cartilage paste grafting to full-thickness articular cartilage knee joint lesions: a 2- to 12-year follow-up. Arthroscopy. 2006;22(3):291-9. [pmid: 16517314].
2051 Stone KR, Walgenbach AW, Turek TJ, et al. Meniscus allograft survival in patients with moderate to severe unicompartmental arthritis: a 2- to 7-year follow-up. Arthroscopy. May. 2006;22(5):469-78. [pmid: 16651154].
2052 Strand LI, Ljunggren AE, Bogen B, et al. The Short-Form McGill Pain Questionnaire as an outcome measure: test-retest reliability and responsiveness to change. Eur J Pain. Oct. 2008;12(7):917-25. [pmid: 18289893].
2053 Strand T, Molster A, Hordvik M, et al. Long-term follow-up after primary repair of the anterior cruciate ligament: clinical and radiological evaluation 15–23 years postoperatively. Archives of Orthopaedic & Trauma Surgery. May. 2005;125(4):217-21. [pmid: 15875231].
2054 Strand V, Conaghan PG, Lohmander LS, et al. An integrated analysis of five double-blind, randomized controlled trials evaluating the safety and efficacy of a hyaluronan product for intra-articular injection in osteoarthritis of the knee. Osteoarthritis & Cartilage. Sep. 2006;14(9):859-66. [pmid: 16626978].
2055 Stratford PW, Kennedy DM. Does parallel item content on WOMAC’s pain and function subscales limit its ability to detect change in functional status?. BMC Musculoskeletal Disorders. Jun. 9. 2004;5:17. [pmid: 15189563].
2056 Stratford PW, Kennedy DM, Riddle DL. New study design evaluated the validity of measures to assess change after hip or knee arthroplasty. Journal of Clinical Epidemiology. Mar. 2009;62(3):347-52. [pmid: 18834709].
2057 Strauss EJ, Hart JA, Miller MD, et al. Hyaluronic acid viscosupplementation and osteoarthritis: current uses and future directions. American Journal of Sports Medicine. Aug. 2009;37(8):1636-44. [pmid: 19168804].
2058 Straw R, Kulkarni S, Attfield S, et al. Posterior cruciate ligament at total knee replacement. Essential, beneficial or a hindrance?. Journal of Bone & Joint Surgery - British Volume. Jul. 2003;85(5):671-4. [pmid: 12892188].
2059 Street RL Jr, Richardson MN, Cox V, et al. (Mis)understanding in patient-health care provider communication about total knee replacement. Arthritis & Rheumatism. Jan. 15. 2009;61(1):100-7. [pmid: 19116969].
2060 Stricker K, Yu S, Krammer G. A 6-week, multicentre, randomised, double-blind, double-dummy, active-controlled, clinical safety study of lumiracoxib and rofecoxib in osteoarthritis patients. BMC Musculoskelet Disord. 2008;9:118. [pmid: 18778469].
2061 Struglics A, Hansson M. Calpain is involved in C-terminal truncation of human aggrecan. Biochem J. Aug. 27. 2010;430(3):531-8. [pmid: 20618160].
2062 Struyf PA, van Heugten CM, Hitters MW, et al. The prevalence of osteoarthritis of the intact hip and knee among traumatic leg amputees. Archives of Physical Medicine and Rehabilitation. 2009;90(3):440-6. [pmid: 19254609].
2063 Stuart MJ, Beachy AM, Grabowski JJ, et al. Biomechanical evaluation of a proximal tibial opening-wedge osteotomy plate. American Journal of Knee Surgery. 1999;12(3):148-53. discussion 53–4. [pmid: 10496463].
2064 Stuart MJ, Lubowitz JH. What, if any, are the indications for arthroscopic debridement of the osteoarthritic knee?. Arthroscopy. Mar. 2006;22(3):238-9. [pmid: 16523583].
2065 Stucinskas J, Tarasevicius S, Cebatorius A, et al. Conventional drainage versus four hour clamping drainage after total knee arthroplasty in severe osteoarthritis: a prospective, randomised trial. International Orthopaedics. Oct. 2009;33(5):1275-8. [pmid: 18925394].
2066 Sturnieks DL, Besier TF, Mills PM, et al. Knee joint biomechanics following arthroscopic partial meniscectomy. Journal of Orthopaedic Research. Aug. 2008;26(8):1075-80. [pmid: 18327795].
2067 Suarez-Almazor ME, Looney C, Liu Y, et al. A randomized controlled trial of acupuncture for osteoarthritis of the knee: effects of patient-provider communication. Arthritis Care Res (Hoboken). Sep. 2010;62(9):1229-36. [pmid: 20506122].
2068 Sugama R, Kadoya Y, Kobayashi A, et al. Preparation of the flexion gap affects the extension gap in total knee arthroplasty. Journal of Arthroplasty. Aug. 2005;20(5):602-7. [pmid: 16309995].
2069 Sugimoto H, Yamada H, Terada N, et al. Intraarticular injection of high molecular weight hyaluronan for osteoarthritis of the knee - prediction of effectiveness with biological markers. J Rheumatol. Dec. 2006;33(12):2527. [pmid: 17143987].
2070 Sugiyama S, Itokazu M, Suzuki Y, et al. Procollagen II C propeptide level in the synovial fluid as a predictor of radiographic progression in early knee osteoarthritis. Annals of the Rheumatic Diseases. Jan. 2003;62(1):27-32. [pmid: 12480665].
2071 Sullivan M, Tanzer M, Stanish W, et al. Psychological determinants of problematic outcomes following Total Knee Arthroplasty. Pain. May. 2009;143(1–2):123-9. [pmid: 19304392].
2072 Sun S-F, Hsu C-W, Hwang C-W, et al. Hyaluronate improves pain, physical function and balance in the geriatric osteoarthritic knee: a 6-month follow-up study using clinical tests. Osteoarthritis & Cartilage. Jul. 2006;14(7):696-701. [pmid: 16520067].
2073 Sun Y, Gunther KP, Brenner H. Reliability of radiographic grading of osteoarthritis of the hip and knee. Scand J Rheumatol. 1997;26(3):155-65. [pmid: 9225869].
2074 Sutherland AG, Baker AR. Plain radiography in the degenerate knee. Journal of Bone & Joint Surgery - British Volume. Apr. 2000;82(3):462-3. [pmid: 10813193].
2075 Sutton AJ, Muir KR, Mockett S, et al. A case-control study to investigate the relation between low and moderate levels of physical activity and osteoarthritis of the knee using data collected as part of the Allied Dunbar National Fitness Survey. Annals of the Rheumatic Diseases. Aug. 2001;60(8):756-64. [pmid: 11454639].
2076 Swinkels A, Newman JH, Allain TJ. A prospective observational study of falling before and after knee replacement surgery. Age & Ageing. Mar. 2009;38(2):175-81. [pmid: 19029071].
2077 Syed KA, Mahomed NN. Can magnetic resonance imaging of the knee predict future malalignment?. J Rheumatol. Nov. 2005;32(11):2070-1. [pmid: 16265679].
2078 Szabo G, Lovasz G, Kustos T, et al. A prospective comparative analysis of mobility in osteoarthritic knees. J Bone Joint Surg Br. Nov. 2000;82(8):1167-9. [pmid: 11132280].
2079 Szoeke CE, Dennerstein L, Wluka AE, et al. Physician diagnosed arthritis, reported arthritis and radiological non-axial osteoarthritis. Osteoarthritis Cartilage. Jul. 2008;16(7):846-50. [pmid: 18226557].
2080 Szoeke CEI, Cicuttini FM, Guthrie JR, et al. Factors affecting the prevalence of osteoarthritis in healthy middle-aged women: data from the longitudinal Melbourne Women’s Midlife Health Project. Bone. Nov. 2006;39(5):1149-55. [pmid: 16844440].
2081 Taechaarpornkul W, Suvapan D, Theppanom C, et al. Comparison of the effectiveness of six and two acupuncture point regimens in osteoarthritis of the knee: a randomised trial. AcupunctMed. 2009;27(1):3-8. [pmid: 74].
2082 Tai CC, Cross MJ. Five- to 12-year follow-up of a hydroxyapatite-coated, cementless total knee replacement in young, active patients. Journal of Bone & Joint Surgery - British Volume. Sep. 2006;88(9):1158-63. [pmid: 16943464].
2083 Therapeutic Effects of Gelatine Hydrogelbasic Fibroblast Growth Factor System on Experimental Osteoarthritis in the Rabbit Knee. 6th Symposium of the International Cartilage Repair Society (ICRS 2006). San Diego Marriott Hotel & Marina, San Diego, California (USA). 8–11 Jan 2006.
2084 Takahashi M, Naito K, Abe M, et al. Relationship between radiographic grading of osteoarthritis and the biochemical markers for arthritis in knee osteoarthritis. Arthritis Research & Therapy. 2004;6(3):R208-12. [pmid: 15142266].
2085 Takahashi S, Tomihisa K, Saito T. Decrease of osteosclerosis in subchondral bone of medial compartmental osteoarthritic knee seven to nineteen years after high tibial valgus osteotomy. Bulletin of the Hospital for Joint Diseases. 2002;61(1–2):58-62. [pmid: 12828381].
2086 Takeda W, Wessel J. Acupuncture for the treatment of pain of osteoarthritic knees. Arthritis Care Res. Sep. 1994;7(3):118-22. [pmid: 7727550].
2087 Takemae T, Omori G, Nishino K, et al. Three-dimensional knee motion before and after high tibial osteotomy for medial knee osteoarthritis. Journal of Orthopaedic Science. Nov. 2006;11(6):601-6. [pmid: 17139468].
2088 Takeuchi R, Aratake M, Bito H, et al. Simultaneous bilateral opening-wedge high tibial osteotomy with early full weight-bearing exercise. Knee Surgery, Sports Traumatology, Arthroscopy. Nov. 2008;16(11):1030-7. [pmid: 18762910].
2089 Takeuchi R, Ishikawa H, Aratake M, et al. Medial opening wedge high tibial osteotomy with early full weight bearing. Arthroscopy. Jan. 2009;25(1):46-53. [pmid: 19111218].
2090 Takeuchi R, Saito T, Koshino T. Clinical results of a valgus high tibial osteotomy for the treatment of osteoarthritis of the knee and the ipsilateral ankle. Knee. Jun. 2008;15(3):196-200. [pmid: 18367399].
2091 Tallon D, Chard J, Dieppe P. Relation between agendas of the research community and the research consumer. Lancet. Jun. 10. 2000;355(9220):2037-40. [pmid: 10885355].
2092 Tamaki M, Tomita T, Watanabe T, et al. In vivo kinematic analysis of a high-flexion, posterior-stabilized, mobile-bearing knee prosthesis in deep knee bending motion. Journal of Arthroplasty. Sep. 2009;24(6):972-8. [pmid: 19033084].
2093 Tamaki M, Tomita T, Yamazaki T, et al. In vivo kinematic analysis of a high-flexion posterior stabilized fixed-bearing knee prosthesis in deep knee-bending motion. Journal of Arthroplasty. Sep. 2008;23(6):879-85. [pmid: 18555651].
2094 Tamari K, Briffa NK, Tinley P, et al. Variations in torsion of the lower limb in Japanese and Caucasians with and without knee osteoarthritis. Journal of Rheumatology. Jan. 2007;34(1):145-50. [pmid: 17216682].
2095 Tameem HZ, Selva LE, Sinha US. Morphological atlases of knee cartilage: shape indices to analyze cartilage degradation in osteoarthritic and non-osteoarthritic population. Conf Proc IEEE Eng Med Biol Soc. 2007;2007:1310-3. [pmid: 18002204].
2096 Tamir E, Robinson D, Koren R, et al. Intra-articular hyaluronan injections for the treatment of osteoarthritis of the knee: a randomized, double blind, placebo controlled study. Clinical & Experimental Rheumatology. May–Jun. 2001;19(3):265-70. [pmid: 11407078].
2097 Tan J, Balci N, Sepici V, et al. Isokinetic and isometric strength in osteoarthrosis of the knee: a comparative study with healthy women. American Journal of Physical Medicine and Rehabilitation. 1995;74(5):364-9. [pmid: 7576413].
2098 Tanamas SK, Teichtahl AJ, Wluka AE, et al. The associations between indices of patellofemoral geometry and knee pain and patella cartilage volume: a cross-sectional study. BMC Musculoskelet Disord. 2010;11:87. [pmid: 20459700].
2099 Tanavalee A, Thiengwittayaporn S, Itiravivong P. Results of the 136 consecutive minimally invasive total knee arthroplasties. Journal of the Medical Association of Thailand. Sep. Suppl 4. 2005;88:S74-8. [pmid: 16623007].
2100 Tang SF, Chen CP, Chen MJ, et al. Improvement of muscle strength in osteoarthritic knee patients after intraarticular knee injection of hyaluronan. American Journal of Physical Medicine & Rehabilitation. 2005;84(4):274-7. [pmid: 15785260].
2101 Tang SF, Chen CP, Chen MJ, et al. Changes in sagittal ground reaction forces after intra-articular hyaluronate injections for knee osteoarthritis. Archives of Physical Medicine and Rehabilitation. 2004;85(6):951-5. [pmid: 15179649].
2102 Tangtrakulwanich B, Chongsuvivatwong V, Geater AF. Habitual floor activities increase risk of knee osteoarthritis. Clinical Orthopaedics & Related Research. Jan. 2007;454:147-54. [pmid: 16980903].
2103 Tarabichi S, Tarabichi Y. Can an anterior quadriceps release improve range of motion in the stiff arthritic knee?. Journal of Arthroplasty. Jun. 2010;25(4):571-5. [pmid: 19553069].
2104 Tarasevicius S, Stucinskas J, Robertsson O, et al. Introduction of total knee arthroplasty in Lithuania: Results from the first 10 years. Acta Orthop. Feb. 2009;80(1):51-4. [pmid: 19297790].
2105 Tarhan S, Unlu Z. Magnetic resonance imaging and ultrasonographic evaluation of the patients with knee osteoarthritis: a comparative study. Clinical rheumatology. 2003;22(3):181-8. [pmid: 14505208].
2106 Tarigan TJE, Kasjmir YI, Atmakusuma D, et al. The degree of radiographic abnormalities and postural instability in patients with knee osteoarthritis. Acta Medica Indonesiana. Jan. 2009;41(1):15-9. [pmid: 19258675].
2107 Tascioglu F, Armagan O, Tabak Y, et al. Low power laser treatment in patients with knee osteoarthritis. Swiss Medical Weekly. May. 1. 2004;134(17–18):254-8. [pmid: 15243853].
2108 Taylor C, Carballido-Gamio J, Majumdar S, et al. Comparison of quantitative imaging of cartilage for osteoarthritis: T2, T1rho, dGEMRIC and contrast-enhanced computed tomography. Magn Reson Imaging. Jul. 2009;27(6):779-84. [pmid: 19269769].
2109 Taylor PE, Almeida GJ, Kanade T, et al. Classifying human motion quality for knee osteoarthritis using accelerometers. Conf Proc IEEE Eng Med Biol Soc. 2010;2010:339-43. [pmid: 21096970].
2110 Teekachunhatean S, Kunanusorn P, Rojanasthien N, et al. Chinese herbal recipe versus diclofenac in symptomatic treatment of osteoarthritis of the knee: a randomized controlled trial. [ISRCTN70292892]. BMC Complementary & Alternative Medicine. 2004;4(Journal Article):19. [pmid: 15588333].
2111 Teichtahl AJ, Morris ME, Wiuka AE, et al. Foot rotation - A potential target to modify the knee adduction moment. Journal of Science and Medicine in Sport. 2006;9(1–2):67-71. [pmid: 16621703].
2112 Teichtahl AJ, Morris ME, Wluka AE, et al. A comparison of gait patterns between the offspring of people with medial tibiofemoral osteoarthritis and normal controls. Clinical & Experimental Rheumatology. Jul–Aug. 2003;21(4):421-3. [pmid: 12942691].
2113 Teichtahl AJ, Wang Y, Cicuttini FM. Obesity and rural health--a neglected risk factor for knee osteoarthritis. Rural & Remote Health. Jan–Mar. 2007;7(1):698. [pmid: 17352628].
2114 Teichtahl AJ, Wluka AE, Forbes A, et al. Longitudinal effect of vigorous physical activity on patella cartilage morphology in people without clinical knee disease. Arthritis Rheum. Aug. 15. 2009;61(8):1095-102. [pmid: 19644895].
2115 Teichtahl AJ, Wluka AE, Morris ME, et al. The relationship between the knee adduction moment and knee pain in middle-aged women without radiographic osteoarthritis. Journal of Rheumatology. Sep. 2006;33(9):1845-8. [pmid: 16960945].
2116 Temple AR, Benson GD, Zinsenheim JR, et al. Multicenter, randomized, double-blind, active-controlled, parallel-group trial of the long-term 6–12 months) safety of acetaminophen in adult patients with osteoarthritis. Clinical Therapeutics. Feb. 2006;28(2):222-35. [pmid: 16678643].
2117 Terwee CB, Mokkink LB, Steultjens MP, et al. Performance-based methods for measuring the physical function of patients with osteoarthritis of the hip or knee: a systematic review of measurement properties. Rheumatology (Oxford). 2006;45(7):890-902. [pmid: 16461441].
2118 Thadani PJ, Vince KG, Ortaaslan SG, et al. Ten- to 12-year followup of the Insall-Burstein I total knee prosthesis. Clinical Orthopaedics & Related Research. 2000;(380):17-29. [pmid: 11064969].
2119 Thanni LOA. Re: double blind clinical trial comparing the safety and efficacy of nimesulide. (100mg) and diclofenac in osteoarthrosis of the hip and knee joints. West African Journal of Medicine. Apr–Jun. 2006;25(2):157. author reply 8. [pmid: 16918190].
2120 Thawani V. Positive study of Boswellia serrata for knee osteoarthritis suffers from methodological flaws. Focus on Alternative and Complementary Therapies. 2003;8(3):316-7.
2121 Theiler R, Bischoff-Ferrari HA, Good M, et al. Responsiveness of the electronic touch screen WOMAC 3.1 OA Index in a short term clinical trial with rofecoxib. Osteoarthritis & Cartilage. Nov. 2004;12(11):912-6. [pmid: 15501407].
2122 Theiler R, Bruhlmann P. Overall tolerability and analgesic activity of intra-articular sodium hyaluronate in the treatment of knee osteoarthritis. Current Medical Research & Opinion. Nov. 2005;21(11):1727-33. [pmid: 16307692].
2123 Thelin N, Holmberg S, Thelin A. Knee injuries account for the sports-related increased risk of knee osteoarthritis. Scandinavian Journal of Medicine and Science in Sports. 2006;16(5):329-33. [pmid: 16978252].
2124 Therbo M, Petersen MM, Varmarken JE, et al. Influence of pre-operative bone mineral content of the proximal tibia on revision rate after uncemented knee arthroplasty. Journal of Bone & Joint Surgery - British Volume. Sep. 2003;85(7):975-9. [pmid: 14516030].
2125 Thielemann FW, Clemens U, Hadjicostas PT. Computer-assisted surgery in revision total knee arthroplasty: early experience with 46 patients. Orthopedics. Oct. 2007;30(10 Suppl):S132-5. [pmid: 17983115].
2126 Thomas AC, Sowers M, Karvonen-Gutierrez C, et al. Lack of quadriceps dysfunction in women with early knee osteoarthritis. J Orthop Res. May. 2010;28(5):595-9. [pmid: 19918898].
2127 Thomas SG, Pagura SM, Kennedy D. Physical activity and its relationship to physical performance in patients with end stage knee osteoarthritis. Journal of Orthopaedic and Sports Physical Therapy. 2003;33(12):745-54. [pmid: 14743988].
2128 Thomason HC 3rd, Slater RR Jr, Tooma GS, et al. The value of serial postoperative radiographs of total knee arthroplasties. J South Orthop Assoc. Spring. 1998;7(1):27-35. [pmid: 9570729].
2129 Thomee P, Wahrborg P, Borjesson M, et al. A new instrument for measuring self-efficacy in patients with an anterior cruciate ligament injury. Scandinavian Journal of Medicine & Science in Sports. Jun. 2006;16(3):181-7. [pmid: 16643196].
2130 Thomee P, Wahrborg P, Borjesson M, et al. Determinants of self-efficacy in the rehabilitation of patients with anterior cruciate ligament injury. Journal of Rehabilitation Medicine. 2007;39(6):486-92. [pmid: 17624484].
2131 Thompson LR, Boudreau R, Hannon MJ, et al. The knee pain map: reliability of a method to identify knee pain location and pattern. Arthritis Rheum. Jun. 15. 2009;61(6):725-31. [pmid: 19479703].
2132 Thompson NW, Ruiz AL, Breslin E, et al. Total knee arthroplasty without patellar resurfacing in isolated patellofemoral osteoarthritis. Journal of Arthroplasty. Aug. 2001;16(5):607-12. [pmid: 11503120].
2133 Thorp LE, Wimmer MA, Block JA, et al. Bone mineral density in the proximal tibia varies as a function of static alignment and knee adduction angular momentum in individuals with medial knee osteoarthritis. Bone. Nov. 2006;39(5):1116-22. [pmid: 16782419].
2134 Thorpe RJ Jr, Kasper JD, Szanton SL, et al. Relationship of race and poverty to lower extremity function and decline: findings from the Women’s Health and Aging Study. Soc Sci Med. Feb. 2008;66(4):811-21. [pmid: 18164113].
2135 Thorstensson CA, Henriksson M, von Porat A, et al. The effect of eight weeks of exercise on knee adduction moment in early knee osteoarthritis--a pilot study. Osteoarthritis & Cartilage. 2007;15(10):1163-70. [pmid: 17466541].
2136 Thorstensson CA, Petersson IF, Jacobsson LT, et al. Reduced functional performance in the lower extremity predicted radiographic knee osteoarthritis five years later. Annals of the Rheumatic Diseases. 2004;63(4):402-7. [pmid: 15020334].
2137 Thorstensson CA, Roos EM, Petersson IF, et al. How do middle-aged patients conceive exercise as a form of treatment for knee osteoarthritis?. Disabil Rehabil. Jan. 15. 2006;28(1):51-9. [pmid: 16393833].
2138 Thumboo J, Chew LH, Soh CH. Validation of the Western Ontario and Mcmaster University osteoarthritis index in Asians with osteoarthritis in Singapore. Osteoarthritis Cartilage. Jul. 2001;9(5):440-6. [pmid: 11467892].
2139 Tigani D, Fosco M, Amendola L, et al. Total knee arthroplasty in patients with poliomyelitis. Knee. Dec. 2009;16(6):501-6. [pmid: 19443223].
2140 Tillu A, Roberts C, Tillu S. Unilateral versus bilateral acupuncture on knee function in advanced osteoarthritis of the knee--a prospective randomised trial. Acupuncture in Medicine. 2001;19(1):15-8. [pmid: 11471577].
2141 Tillu A, Tillu S, Vowler S. Effect of acupuncture on knee function in advanced osteoarthritis of the knee: a prospective, non-randomised controlled study. Acupuncture in Medicine. 2002;20(1):19-21. [pmid: 11926599].
2142 Toda Y, Tsukimura N. A comparison of intra-articular hyaluronan injection accuracy rates between three approaches based on radiographic severity of knee osteoarthritis. Osteoarthritis & Cartilage. Sep. 2008;16(9):980-5. [pmid: 18339561].
2143 Toh EM, Prasad PS, Teanby D. Correlating the efficacy of knee viscosupplementation with osteoarthritic changes on roentgenological examination. Knee. Dec. 2002;9(4):321-30. [pmid: 12424042].
2144 Tomas Gil J, Lopez Mateu P, Alegre J. Acute adverse reaction to hylan G-F 20: comment on the article by Martens. Arthritis & Rheumatism. Mar. 2003;48(3):866. author reply. [pmid: 12632457].
2145 Topp R, Swank AM, Quesada PM, et al. The effect of prehabilitation exercise on strength and functioning after total knee arthroplasty. Pm & R. 2009;1(8):729-35. [pmid: 19695525].
2146 Torga Spak R, Teitge RA. Fresh osteochondral allografts for patellofemoral arthritis: long-term followup. Clinical Orthopaedics & Related Research. 2006;444(Journal Article):193-200. [pmid: 16523140].
2147 Torrance GW, Raynauld JP, Walker V, et al. A prospective, randomized, pragmatic, health outcomes trial evaluating the incorporation of hylan G-F 20 into the treatment paradigm for patients with knee osteoarthritis (Part 2 of 2): economic results. Osteoarthritis & Cartilage. Jul. 2002;10(7):518-27. [pmid: 12127831].
2148 Torres L, Dunlop DD, Peterfy C, et al. The relationship between specific tissue lesions and pain severity in persons with knee osteoarthritis. Osteoarthritis Cartilage. Oct. 2006;14(10):1033-40. [pmid: 16713310].
2149 Toye F, Barlow J, Wright C, et al. A validation study of the New Zealand score for hip and knee surgery. Clin Orthop Relat Res. Nov. 2007;464:190-5. [pmid: 18062051].
2150 Toyoda T, Matsumoto H, Tsuji T, et al. Heterotopic ossification after total knee arthroplasty. [Erratum appears in J Arthroplasty. 2003 Dec;18(8):1076 Note: Hedeo, Matsumoto [corrected to Hideo, Matsumoto]]. Journal of Arthroplasty. Sep. 2003;18(6):760-4. [pmid: 14513450].
2151 Trattnig S, Huber M, Breitenseher MJ, et al. Imaging articular cartilage defects with 3D fat-suppressed echo planar imaging: comparison with conventional 3D fat-suppressed gradient echo sequence and correlation with histology. J Comput Assist Tomogr. Jan–Feb. 1998;22(1):8-14. [pmid: 9448754].
2152 Travers-Gustafson D. Prediction in descriptive correlational studies. Orthop Nurs. Sep–Oct. 2000;19(5):54. [pmid: 11153387].
2153 Tria AJ Jr. Advancements in minimally invasive total knee arthroplasty. Orthopedics. Aug. 2003;26(8 Suppl):s859-63. [pmid: 12934741].
2154 Triggs E, Victor C, Ross F, et al. Primary care-based evaluation of patient education for osteoarthritis of the knee. Methods of Information in Medicine. Aug. 2000;39(3):241-5. [pmid: 10992752].
2155 Trnavsky K, Fischer M, Vogtle-Junkert U, et al. Efficacy and safety of 5% ibuprofen cream treatment in knee osteoarthritis. Results of a randomized, double-blind, placebo-controlled study. Journal of Rheumatology. Mar. 2004;31(3):565-72. [pmid: 14994406].
2156 Tsai PF, Beck C, Chang JY, et al. The effect of Tai Chi on knee osteoarthritis pain in cognitively impaired elders: Pilot study. Geriatric nursing. 2009;30(2):132-9. [pmid: 19345855].
2157 Tsai PF, Chang JY, Chowdhury N, et al. Enrolling older adults with cognitive impairment in research: lessons from a study of Tai Chi for osteoarthritis knee pain. Res Gerontol Nurs. Oct. 2009;2(4):228-34. [pmid: 20077977].
2158 Tsang RC, Tsang PL, Ko CY, et al. Effects of acupuncture and sham acupuncture in addition to physiotherapy in patients undergoing bilateral total knee arthroplasty--a randomized controlled trial. Clin Rehabil. Aug. 2007;21(8):719-28. [pmid: 17846072].
2159 Tsumaki N, Kakiuchi M, Sasaki J, et al. Low-intensity pulsed ultrasound accelerates maturation of callus in patients treated with opening-wedge high tibial osteotomy by hemicallotasis. J Bone Joint Surg Am. Nov. 2004;86-A(11):2399-405. [pmid: 15523009].
2160 Tsumura H, Ikeda S, Torisu T. Debridement and continuous irrigation for the treatment of pyogenic arthritis caused by the use of intra-articular injection in the osteoarthritic knee: indications and outcomes. Journal of Orthopaedic Surgery. Apr. 2005;13(1):52-7. [pmid: 15872401].
2161 Tucker M. The relative effectiveness of a non-steroidal anti-inflammatory medication (meloxicam) versus manipulation in the treatment of osteo-arthritis of the knee. European Journal of Chiropractic. 2003;50(3):163-84.
2162 Tukmachi E, Jubb R, Dempsey E, et al. The effect of acupuncture on the symptoms of knee osteoarthritis--an open randomised controlled study. Acupuncture in Medicine. Mar. 2004;22(1):14-22. [pmid: 15077933].
2163 The relationship of the quadriceps femoris muscle strength and pain intensity in knee osteoarthritis. 2006. 2006 Annual European Congree of Rheumatology (EULAR 2006). Amsterdam (Netherland (The)). 21–24 Jun 2006.
2164 Time-Benefit in the Physiotherapy Management of Knee Osteoarthritis: Clinical or Group-Based Physiotherapy. 2006 Annual European Congress of Rheumatology (EULAR 2006). Amsterdam (Netherlands (The)). 21–24 Jun 2006.
2165 Tuominen U, Blom M, Hirvonen J, et al. The effect of co-morbidities on health-related quality of life in patients placed on the waiting list for total joint replacement. Health & Quality of Life Outcomes. 2007;5(Journal Article):16. [pmid: 17362498].
2166 Turajane T, Amphansap T, Labpiboonpong V, et al. Total knee replacement following repeated cycles of intra-articular sodium hyaluronate 500–730 Kda) in failed conservative treatment of knee osteoarthritis: a 54-month follow-up. Journal of the Medical Association of Thailand. Dec. Suppl 6. 2009;92:S63-8. [pmid: 20120667].
2167 Turajane T, Labpiboonpong V, Maungsiri S. Cost analysis of intra-articular sodium hyaluronate treatment in knee osteoarthritis patients who failed conservative treatment. Journal of the Medical Association of Thailand. Sep. 2007;90(9):1839-44. [pmid: 17957928].
2168 Therapeutic Effects of Intra-Articular Hyaluronan on Failed Conservative Treatment of Knee Osteoarthritis With Minimum Two Years Follow Up. 6th Annual European Congress of Rheumatology (EULAR 2005). Vienna (Austria). 8–11 Jun 2005.
2169 Turajane T, Larbpaiboonpong V, Kongtharvonskul J, et al. Results of computer assisted mini-incision subvastus approach for total knee arthroplasty. Journal of the Medical Association of Thailand. Dec. Suppl 6. 2009;92:S51-8. [pmid: 20120665].
2170 Turajane T, Tanavaree A, Labpiboonpong V, et al. Outcomes of intra-articular injection of sodium hyaluronate for the treatment of osteoarthritis of the knee. Journal of the Medical Association of Thailand. 2007;90(9):1845-52. [pmid: 17957929].
2171 The relationship between clinical, laboratory, disease activity and serum hyaluronic acid level in patients with knee osteoarthritis. 2005. 6th Annual European Congress of Rheumatology (EULAR 2005). Vienna (Austria). 8–11 Jun 2005.
2172 Turan Y, Bal S, Gurgan A, et al. Serum hyaluronan levels in patients with knee osteoarthritis. Clin Rheumatol. Aug. 2007;26(8):1293-8. [pmid: 17205214].
2173 Turcot K, Aissaoui R, Boivin K, et al. Test-retest reliability and minimal clinical change determination for 3-dimensional tibial and femoral accelerations during treadmill walking in knee osteoarthritis patients. Archives of Physical Medicine and Rehabilitation. 2008;89(4):732-7. [pmid: 18374005].
2174 Turcot K, Aissaoui R, Boivin K, et al. New accelerometric method to discriminate between asymptomatic subjects and patients with medial knee osteoarthritis during 3-d gait. IEEE Transactions on Biomedical Engineering. Apr. 2008;55(4):1415-22. [pmid: 18390333].
2175 Turcot K, Aissaoui R, Boivin K, et al. The responsiveness of three-dimensional knee accelerations used as an estimation of knee instability and loading transmission during gait in osteoarthritis patient’s follow-up. Osteoarthritis & Cartilage. 2009;17(2):213-9. [pmid: 18718767].
2176 Turner AP, Barlow JH, Heathcote-Elliott C. Long term health impact of playing professional football in the United Kingdom. Br J Sports Med. Oct. 2000;34(5):332-6. [pmid: 11049141].
2177 Tuzun EH, Eker L, Aytar A, et al. Acceptability, reliability, validity and responsiveness of the Turkish version of WOMAC osteoarthritis index. Osteoarthritis Cartilage. Jan. 2005;13(1):28-33. [pmid: 15639634].
2178 Uebelhart D, Malaise M, Marcolongo R, et al. Intermittent treatment of knee osteoarthritis with oral chondroitin sulfate: a one-year, randomized, double-blind, multicenter study versus placebo. Osteoarthritis and Cartilage. 2004;12(4):269-76. [pmid: 15023378].
2179 Uehara K, Kadoya Y, Kobayashi A, et al. Bone anatomy and rotational alignment in total knee arthroplasty. Clinical Orthopaedics & Related Research. 2002;(402):196-201. [pmid: 12218484].
2180 Uematsu K, Habata T, Hasegawa Y, et al. Osteochondritis dissecans of the knee: long-term results of excision of the osteochondral fragment. Knee. Jun. 2005;12(3):205-8. [pmid: 15911294].
2181 Uhl M, Allmann KH, Tauer U, et al. Comparison of MR sequences in quantifying in vitro cartilage degeneration in osteoarthritis of the knee. Br J Radiol. Mar. 1998;71(843):291-6. [pmid: 9616238].
2182 Ulstrup AK, Folkmar K, Broeng L. Knee arthrodesis with the Sheffield external ring fixator: fusion in 6 of 10 consecutive patients. Acta Orthopaedica. Jun. 2007;78(3):371-6. [pmid: 17611852].
2183 Underwood MR. Community management of knee pain in older people: is knee pain the new back pain?. Rheumatology. Jan. 2004;43(1):2-3. [pmid: 12923284].
2184 Unitt L, Sambatakakis A, Johnstone D, et al. Short-term outcome in total knee replacement after soft-tissue release and balancing. Journal of Bone & Joint Surgery - British Volume. Feb. 2008;90(2):159-65. [pmid: 18256081].
2185 Unlu Z, Ay K, Tuzun C. Comparison of intra-articular tenoxicam and oral tenoxicam for pain and physical functioning in osteoarthritis of the knee. Clin Rheumatol. Feb. 2006;25(1):54-61. [pmid: 16228108].
2186 Uvehammer J, Karrholm J, Carlsson L. Cemented versus hydroxyapatite fixation of the femoral component of the Freeman-Samuelson total knee replacement: a radiostereometric analysis. Journal of Bone & Joint Surgery - British Volume. Jan. 2007;89(1):39-44. [pmid: 17259414].
2187 Vad V, Hong HM, Zazzali M, et al. Exercise recommendations in athletes with early osteoarthritis of the knee. Sports Med. 2002;32(11):729-39. [pmid: 12196032].
2188 Vad V, Solomon J. Osteoarthritis case study. Orthopedics. Feb. 2005;28(2 Suppl):s221-5. [pmid: 15747610].
2189 Vad VB, Adin DR, Solomon J. Knee Osteoarthritis. Critical Reviews in Physical and Rehabilitation Medicine. 2004;16(3):211-31.
2190 Vad VB, Bhat AL, Sculco TP, et al. Management of knee osteoarthritis: knee lavage combined with hylan versus hylan alone. Arch Phys Med Rehabil. May. 2003;84(5):634-7. [pmid: 12736873].
2191 A semi-quantitative Marrow Edema-based approach for assessing the severity of knee osteoarthritis (OA) using 3 T MRI. 2008. 94th Scientific Assembly and Annual Meeting of the Radiological Society of North America (RSNA 2008). McCormick Place, Chicago, Illinois (USA). 30 Nov–5 Dec 2008.
2192 Vairo GL, McBrier NM, Miller SJ, et al. Premature knee osteoarthritis after anterior cruciate ligament reconstruction dependent on autograft. Journal of Sport Rehabilitation. 2010;19(1):86-97. [pmid: 20231747].
2193 Valdes AM, Spector TD. The contribution of genes to osteoarthritis. Rheum Dis Clin North Am. Aug. 2008;34(3):581-603. [pmid: 18687274].
2194 Valtonen A, Poyhonen T, Heinonen A, et al. Muscle deficits persist after unilateral knee replacement and have implications for rehabilitation. Phys Ther. Oct. 2009;89(10):1072-9. [pmid: 19713269].
2195 van den Broek CM, van Hellemondt GG, Jacobs WCH, et al. Step-cut tibial tubercle osteotomy for access in revision total knee replacement. Knee. Dec. 2006;13(6):430-4. [pmid: 16956763].
2196 Van der Esch M, Heijmans M, Dekker J. Factors contributing to possession and use of walking aids among persons with rheumatoid arthritis and osteoarthritis. Arthritis & Rheumatism. 2003;49(6):838-42. [pmid: 14673971].
2197 van der Esch M, Steultjens M, Harlaar J, et al. Joint proprioception, muscle strength, and functional ability in patients with osteoarthritis of the knee. Arthritis Rheum. Jun. 15. 2007;57(5):787-93. [pmid: 17530678].
2198 van der Esch M, Steultjens M, Harlaar J, et al. Knee varusvalgus motion during gait-a measure of joint stability in patients with osteoarthritis?. Osteoarthritis and Cartilage. 2008;16(4):522-5. [pmid: 17892952].
2199 van der Esch M, Steultjens M, Wieringa H, et al. Structural joint changes, malalignment, and laxity in osteoarthritis of the knee. Scandinavian Journal of Rheumatology. Jul–Aug. 2005;34(4):298-301. [pmid: 16195163].
2200 van der Linden ML, Rowe PJ, Myles CM, et al. Knee kinematics in functional activities seven years after total knee arthroplasty. Clinical Biomechanics. 2007;22(5):537-42. [pmid: 17275150].
2201 van der Linden-van der Zwaag HMJ, Wolterbeek R, Nelissen RGHH. Computer assisted orthopedic surgery; its influence on prosthesis size in total knee replacement. Knee. Aug. 2008;15(4):281-5. [pmid: 18450454].
2202 van der Wal RJP, Thomassen BJW, van Arkel ERA. Long-term clinical outcome of open meniscal allograft transplantation. American Journal of Sports Medicine. Nov. 2009;37(11):2134-9. [pmid: 19542303].
2203 van Dijk GM, Dekker J, Veenhof C, et al. Course of functional status and pain in osteoarthritis of the hip or knee: A systematic review of the literature. Arthritis Care and Research. 2006;55(5):779-85. [pmid: 17013827].
2204 van Dijk GM, Veenhof C, Schellevis F, et al. Comorbidity, limitations in activities and pain in patients with osteoarthritis of the hip or knee. BMC Musculoskeletal Disorders. 2008;9(Journal Article):95. [pmid: 18582362].
2205 van Dijk GM, Veenhof C, Spreeuwenberg P, et al. Prognosis of limitations in activities in osteoarthritis of the hip or knee: a 3-year cohort study. Archives of Physical Medicine & Rehabilitation. Jan. 2010;91(1):58-66. [pmid: 20103397].
2206 van Haselen RA, Fisher PA. A randomized controlled trial comparing topical piroxicam gel with a homeopathic gel in osteoarthritis of the knee. Rheumatology. 2000;39(7):714-9. [pmid: 10908688].
2207 van Hemert WLW, Senden R, Grimm B, et al. Patella retention versus replacement in total knee arthroplasty; functional and clinimetric aspects. Archives of Orthopaedic & Trauma Surgery. Feb. 2009;129(2):259-65. [pmid: 18488236].
2208 van Hemert WLW, Willems K, Anderson PG, et al. Tricalcium phosphate granules or rigid wedge preforms in open wedge high tibial osteotomy: a radiological study with a new evaluation system. Knee. Dec. 2004;11(6):451-6. [pmid: 15581763].
2209 van Ittersum MW, Bieleman HJ, Reneman MF, et al. Functional capacity evaluation in subjects with early osteoarthritis of hip and/or knee; Is two-day testing needed?. Journal of Occupational Rehabilitation. 2009;19(3):238-44. [pmid: 19444597].
2210 van Jonbergen H-PW, Werkman DM, van Kampen A. Conversion of patellofemoral arthroplasty to total knee arthroplasty: A matched case-control study of 13 patients. Acta Orthopaedica. Feb. 2009;80(1):62-6. [pmid: 19234887].
2211 van Loon CJ, Pluk C, de Waal Malefijt MC, et al. The GSB total knee arthroplasty. A medium- and long-term follow-up and survival analysis. Archives of Orthopaedic & Trauma Surgery. 2001;121(1–2):26-30. [pmid: 11195114].
2212 van Loon CJ, Wijers MM, de Waal Malefijt MC, et al. Femoral bone grafting in primary and revision total knee arthroplasty. Acta Orthopaedica Belgica. 1999;65(3):357-63. [pmid: 10546358].
2213 van Mourik JB, Verhaar JA, Heijboer RP, et al. Limited value of arthroscopic evaluation and treatment of painful knee prostheses: a retrospective study of 27 cases. Arthroscopy. Nov–Dec. 1998;14(8):877-9. [pmid: 9848602].
2214 van Raaij T, Reijman M, Brouwer RW, et al. Survival of closing-wedge high tibial osteotomy: good outcome in men with low-grade osteoarthritis after 10–16 years. Acta Orthopaedica. Apr. 2008;79(2):230-4. [pmid: 18484249].
2215 van Raaij TM, Brouwer RW, de Vlieger R, et al. Opposite cortical fracture in high tibial osteotomy: lateral closing compared to the medial opening-wedge technique. Acta Orthopaedica. Aug. 2008;79(4):508-14. [pmid: 18766484].
2216 van Wagenberg JMF, Speigner B, Gosens T, et al. Midterm clinical results of the Autocentric II patellofemoral prosthesis. International Orthopaedics. Dec. 2009;33(6):1603-8. [pmid: 19224212].
2217 Vanlommel J, Porteous AJ, Hassaballa MA, et al. Iatrogenic surface damage during femoral component impaction in total knee arthroplasty. Knee. Jan. 2010;17(1):43-7. [pmid: 19666227].
2218 Effects of ankle muscle strength on WOMAC scores in patients with knee osteoarthritis. 2005. 6th Annual European Congress of Rheumatology (EULAR 2005). Vienna (Austria). 8–11 Jun 2005.
2219 Vardi G, Strover AE. Early complications of unicompartmental knee replacement: the Droitwich experience. Knee. Oct. 2004;11(5):389-94. [pmid: 15351415].
2220 Varela-Egocheaga JR, Suarez-Suarez MA, Fernandez-Villan M, et al. Minimally invasive subvastus approach: improving the results of total knee arthroplasty: a prospective, randomized trial. Clinical Orthopaedics & Related Research. May. 2010;468(5):1200-8. [pmid: 19911245].
2221 Vas J, Mendez C, PereaMilla E. Acupuncture vs Streitberger needle in knee osteoarthritis - an RCT. Acupuncture in Medicine. 2006;24(Suppl 1):15-24.
2222 Vas J, Mendez C, Perea-Milla E, et al. Acupuncture as a complementary therapy to the pharmacological treatment of osteoarthritis of the knee: randomised controlled trial. BMJ. 2004;329(7476):1216. [pmid: 15494348].
2223 Vas J, Perea-Milla E, Mendez C. Acupuncture and moxibustion as an adjunctive treatment for osteoarthritis of the knee--a large case series. Acupuncture in Medicine. 2004;22(1):23-8. [pmid: 15077934].
2224 Vasdev A, Kumar S, Chadha G, et al. Fixed- versus mobile-bearing total knee arthroplasty in Indian patients. Journal of Orthopaedic Surgery. Aug. 2009;17(2):179-82. [pmid: 19721147].
2225 Vavalle G. Ligament reconstruction versus distal realignment for patellar dislocation. Clinical Orthopaedics & Related Research. Jun. 2009;467(6):1643. author reply 4–5. [pmid: 19326180].
2226 Veerapen K, Wigley RD, Valkenburg H. Musculoskeletal pain in Malaysia: a COPCORD survey. J Rheumatol. Jan. 2007;34(1):207-13. [pmid: 17216688].
2227 Severe Knee Osteoarthritis Results in Asymmetry of Quadriceps Strength, but Not of Quadriceps Electromyography Activity during a Dynamic Postural Control Task. 2008 Annual Conference and Exposition of the American Physical Therapy Association (PT 2008). San Antonio, Texas (USA). 11–14 Jun 2008.
2228 Venkataramanan V, Gignac MA, Mahomed NN, et al. Expectations of recovery from revision knee replacement. Arthritis Rheum. Apr. 15. 2006;55(2):314-21. [pmid: 16583381].
2229 Ventura A, Terzaghi C, Legnani C, et al. Synthetic grafts for anterior cruciate ligament rupture: 19-year outcome study. Knee. Mar. 2010;17(2):108-13. [pmid: 19720536].
2230 Verbeek J, Vihtonen T, Pulliainen M, et al. Comments on Jessep SA, Walsh NE, Ratcliffe J, Hurley MV. Long-term clinical benefits and costs of an integrated rehabilitation programme compared with outpatient physiotherapy for chronic knee pain. Physiotherapy. Physiotherapy. 2009. 95. 2009;95(4):94-102. 323. 4. [pmid: 19627690].
2231 Verborgt O, Victor J. Post impingement in posterior stabilised total knee arthroplasty. Acta Orthopaedica Belgica. Feb. 2004;70(1):46-50. [pmid: 15055317].
2232 Verdonk PCM, Pernin J, Pinaroli A, et al. Soft tissue balancing in varus total knee arthroplasty: an algorithmic approach. Knee Surgery, Sports Traumatology, Arthroscopy. Jun. 2009;17(6):660-6. [pmid: 19290507].
2233 Verdonk R, Cottenie D, Almqvist KF, et al. The Oxford unicompartmental knee prosthesis: a 2–14 year follow-up. Knee Surgery, Sports Traumatology, Arthroscopy. Apr. 2005;13(3):163-6. [pmid: 15168007].
2234 Verkleij SP, Luijsterburg PA, Koes BW, et al. Effectiveness of diclofenac versus acetaminophen in primary care patients with knee osteoarthritis: [NTR1485], DIPA-trial: design of a randomized clinical trial. BMC Musculoskelet Disord. 2010;11:7. [pmid: 20067607].
2235 Vidarsson L, Gold GE, Hargreaves B, et al. Linear combination filtering for T2-selective imaging of the knee. Magn Reson Med. May. 2006;55(5):1191-6. [pmid: 16586458].
2236 Villanueva I, Del Mar Guzman M, Javier Toyos F, et al. Relative efficiency and validity properties of a visual analogue vs a categorical scaled version of the Western Ontario and McMaster Universities Osteoarthritis (WOMAC) Index: Spanish versions. Osteoarthritis and Cartilage. 2004;12(3):225-31. [pmid: 14972339].
2237 Vincken PW, ter Braak BP, van Erkel AR, et al. Only MR can safely exclude patients from arthroscopy. Skeletal Radiology. Oct. 2009;38(10):977-82. [pmid: 19305994].
2238 Visuri TI, Pukkala E, Pulkkinen P, et al. Cancer incidence and causes of death among total hip replacement patients: a review based on Nordic cohorts with a special emphasis on metal-on-metal bearings. Proceedings of the Institution of Mechanical Engineers Part H - Journal of Engineering in Medicine. 2006;220(2):399-407.
2239 Vogt JC, Saarbach C. LCS mobile-bearing total knee replacement. A 10-year’s follow-up study. Orthopaedics & traumatology, surgery & research. May. 2009;95(3):177-82. [pmid: 19328763].
2240 Volpi P, Marinoni L, Bait C, et al. Lateral unicompartimental knee arthroplasty: indications, technique and short-medium term results. Knee Surgery, Sports Traumatology, Arthroscopy. Aug. 2007;15(8):1028-34. [pmid: 17497127].
2241 von Engelhardt LV, Lahner M, Klussmann A, et al. Arthroscopy vs. MRI for a detailed assessment of cartilage disease in osteoarthritis: diagnostic value of MRI in clinical practice. BMC Musculoskelet Disord. 2010;11:75. [pmid: 20406481].
2242 von Porat A, Roos EM, Roos H. High prevalence of osteoarthritis 14 years after an anterior cruciate ligament tear in male soccer players: a study of radiographic and patient relevant outcomes. Ann Rheum Dis. Mar. 2004;63(3):269-73. [pmid: 14962961].
2243 Vuorenmaa M, Ylinen J, Kiviranta I, et al. Changes in pain and physical function during waiting time and 3 months after knee joint arthroplasty. Journal of Rehabilitation Medicine. Jul. 2008;40(7):570-5. [pmid: 18758675].
2244 Wada M, Baba H, Imura S, et al. Relationship between radiographic classification and arthroscopic findings of articular cartilage lesions in osteoarthritis of the knee. Clin Exp Rheumatol. Jan–Feb. 1998;16(1):15-20. [pmid: 9543556].
2245 Wada M, Kawahara H, Shimada S, et al. Joint proprioception before and after total knee arthroplasty. Clinical Orthopaedics and Related Research. 2002;403(Journal Article):161-7. [pmid: 12360022].
2246 Wada M, Maezawa Y, Baba H, et al. Relationships among bone mineral densities, static alignment and dynamic load in patients with medial compartment knee osteoarthritis. Rheumatology. 2001;40(5):499-505. [pmid: 11371657].
2247 Waddell D, Rein A, Panarites C, et al. Cost implications of introducing an alternative treatment for patients with osteoarthritis of the knee in a managed care setting. American Journal of Managed Care. Oct. 2001;7(10):981-91. [pmid: 11669362].
2248 Waddell DD. Acute local reaction to intra-articular Hylan G-F 20 (Synvisc): part II. Journal of Bone & Joint Surgery - American Volume. Aug. 2003;85-A(8):1620. author reply -1. [pmid: 12925654].
2249 Waddell DD, Bert JM. The use of hyaluronan after arthroscopic surgery of the knee. Arthroscopy. Jan. 2010;26(1):105-11. [pmid: 20117634].
2250 Waddell DD, Bricker DC. Clinical experience with the effectiveness and tolerability of hylan G-F 20 in 1047 patients with osteoarthritis of the knee. The Journal of Knee Surgery. Jan. 2006;19(1):19-27. [pmid: 16468490].
2251 Waddell DD, Bricker DC. Total knee replacement delayed with Hylan G-F 20 use in patients with grade IV osteoarthritis. Journal of Managed Care Pharmacy. 2007;13(2):113-21. [pmid: 17330972].
2252 Waddell DD, Cefalu CA, Bricker DC. A second course of hylan G-F 20 for the treatment of osteoarthritic knee pain: 12-month patient follow-up. The Journal of Knee Surgery. Jan. 2005;18(1):7-15. [pmid: 15742592].
2253 Wadsworth LT. Acupuncture in sports medicine. Current Sports Medicine Reports. Feb. 2006;5(1):1-3. [pmid: 16483510].
2254 Waikakul S, Un-Nanuntana A, Jaisue N. Recovery of joint position sense after total knee replacement: the effects of soft tissue dissection. Journal of the Medical Association of Thailand. Dec. 1999;82(12):1187-92. [pmid: 10659559].
2255 Wakabayashi S, Akizuki S, Takizawa T, et al. A comparison of the healing potential of fibrillated cartilage versus eburnated bone in osteoarthritic knees after high tibial osteotomy: An arthroscopic study with 1-year follow-up. Arthroscopy. Mar. 2002;18(3):272-8. [pmid: 11877613].
2256 Wakitani S, Imoto K, Yamamoto T, et al. Human autologous culture expanded bone marrow mesenchymal cell transplantation for repair of cartilage defects in osteoarthritic knees. Osteoarthritis & Cartilage. 2002;10(3):199-206. [pmid: 11869080].
2257 Wakitani S, Yamamoto T. Response of the donor and recipient cells in mesenchymal cell transplantation to cartilage defect. Microscopy Research & Technique. Jul. 1. 2002;58(1):14-8. [pmid: 12112417].
2258 Walker AF, Bundy R, Hicks SM, et al. Bromelain reduces mild acute knee pain and improves well-being in a dose-dependent fashion in an open study of otherwise healthy adults. Phytomedicine. Dec. 2002;9(8):681-6. [pmid: 12587686].
2259 Walker CR, Myles C, Nutton R, et al. Movement of the knee in osteoarthritis. The use of electrogoniometry to assess function. Journal of Bone and Joint Surgery (British). 2001;83(2):195-8.
2260 Wallny T, Saker A, Hofmann P, et al. Long-term follow-up after osteotomy for haemophilic arthropathy of the knee. Haemophilia. Jan. 2003;9(1):69-75. [pmid: 12558782].
2261 Walsh M, Kennedy D, Stratford PW, et al. Perioperative functional performance of women and men following total knee arthroplasty. Physiotherapy Canada. 2001;53(2):92-100.
2262 Walsh M, Woodhouse LJ, Thomas SG, et al. Physical impairments and functional limitations: a comparison of individuals 1 year after total knee arthroplasty with control subjects. Phys Ther. Mar. 1998;78(3):248-58. [pmid: 9520970].
2263 Walters SJ, Campbell MJ. The use of bootstrap methods for analysing Health-Related Quality of Life outcomes (particularly the SF-36). Health & Quality of Life Outcomes. 2004;2(Journal Article):70. [pmid: 15588308].
2264 Walton MJ, Newman JH. Pre-operative mental wellbeing and the outcome of knee replacement. Knee. Aug. 2008;15(4):277-80. [pmid: 18417346].
2265 T1p Relaxation Evaluation of Knee OA in a Guinea Pig Model. 16th Scientific Meeting and Exhibition of the International Society for Magnetic Resonance in Medicine (ISMRM 2008). Toronto, Ontario (Canada). 3–9 May 2008.
2266 T1p Relaxation Evaluation of Knee OA in a Guinea Pig Model. 54th Annual Meeting of the Orthopaedic Research Society. The Moscone West Convention Center, San Francisco, California (USA). 2–5 Mar 2008.
2267 Wang C-J, Chen H-S, Huang T-W, et al. Outcome of surgical reconstruction for posterior cruciate and posterolateral instabilities of the knee. Injury. Nov. 2002;33(9):815-21. [pmid: 12379393].
2268 Wang G, Zheng G, Keppler P, et al. Implementation, accuracy evaluation, and preliminary clinical trial of a CT-free navigation system for high tibial opening wedge osteotomy. Computer Aided Surgery. Mar. 2005;10(2):73-85. [pmid: 16298918].
2269 Wang H, Dugan E, Frame J, Rolston L. Gait analysis after bi-compartmental knee replacement. Clinical Biomechanics. 2009;24(9):751-4. [pmid: 19695749].
2270 Wang JW, Wang CJ. Total knee arthroplasty for arthritis of the knee with extra-articular deformity. Journal of Bone & Joint Surgery - American Volume. 2002;84-A(10):1769-74. [pmid: 12377906].
2271 Wang J-W, Hsu CC. Distal femoral varus osteotomy for osteoarthritis of the knee. Journal of Bone & Joint Surgery - American Volume. Jan. 2005;87(1):127-33. [pmid: 15634823].
2272 Wang S-h, Xu M-z, Cui S-y, et al. Randomized controlled clinical trails on treatment of knee osteoarthritis with acupuncture combined with blood-letting therapy. Chen Tzu Yen Chiu Acupuncture Research. Apr. 2010;35(2):129-33. [pmid: 20626146].
2273 Wang X, Miller GD, Messier SP, et al. Knee strength maintained despite loss of lean body mass during weight loss in older obese adults with knee osteoarthritis. J Gerontol A Biol Sci Med Sci. Aug. 2007;62(8):866-71. [pmid: 17702878].
2274 Wang Y, Ebeling PR, Hanna F, et al. Relationship between bone markers and knee cartilage volume in healthy men. J Rheumatol. Nov. 2005;32(11):2200-4. [pmid: 16265703].
2275 Wang Y, Hodge AM, Wluka AE, et al. Effect of antioxidants on knee cartilage and bone in healthy, middle-aged subjects: a cross-sectional study. Arthritis Research & Therapy. 2007;9(4):R66. [pmid: 17617909].
2276 Wang Y, Wluka AE, Pelletier JP, et al. Meniscal extrusion predicts increases in subchondral bone marrow lesions and bone cysts and expansion of subchondral bone in osteoarthritic knees. Rheumatology (Oxford). May. 2010;49(5):997-1004. [pmid: 20181669].
2277 Wangroongsub Y, Tanavalee A, Wilairatana V, et al. Comparable clinical outcomes between glucosamine sulfate-potassium chloride and glucosamine sulfate sodium chloride in patients with mild and moderate knee osteoarthritis: a randomized, double-blind study. Journal of the Medical Association of Thailand. Jul. 2010;93(7):805-11. [pmid: 20649060].
2278 Warden SJ, Morris HG, Crossley KM, et al. Delayed- and non-union following opening wedge high tibial osteotomy: surgeons’ results from 182 completed cases. Knee Surgery, Sports Traumatology, Arthroscopy. Jan. 2005;13(1):34-7. [pmid: 15103456].
2279 Wasielewski RC, Galat DD, Komistek RD. Correlation of compartment pressure data from an intraoperative sensing device with postoperative fluoroscopic kinematic results in TKA patients. Journal of Biomechanics. Feb. 2005;38(2):333-9. [pmid: 15598461].
2280 Wasielewski RC, Komistek RD, Zingde SM, et al. Lack of axial rotation in mobile-bearing knee designs. Clinical Orthopaedics & Related Research. Nov. 2008;466(11):2662-8. [pmid: 18581194].
2281 Wassenaar MJ, Biermasz NR, van Duinen N, et al. High prevalence of arthropathy, according to the definitions of radiological and clinical osteoarthritis, in patients with long-term cure of acromegaly: a case-control study. European Journal of Endocrinology. 2009;160(3):357-65. [pmid: 19050166].
2282 Watanabe H, Urabe K, Takahira N, et al. Quality of life, knee function, and physical activity in Japanese elderly women with early-stage knee osteoarthritis. Journal of Orthopaedic Surgery. Apr. 2010;18(1):31-4. [pmid: 20427830].
2283 Watanabe T, Tomita T, Fujii M, et al. Comparison between mobile-bearing and fixed-bearing knees in bilateral total knee replacements. International Orthopaedics. Jun. 2005;29(3):179-81. [pmid: 15809873].
2284 Watterson JR, Esdaile JM. Viscosupplementation: therapeutic mechanisms and clinical potential in osteoarthritis of the knee. Journal of the American Academy of Orthopaedic Surgeons. Sep–Oct. 2000;8(5):277-84. [pmid: 11029555].
2285 W-Dahl A, Robertsson O, Lidgren L. Surgery for knee osteoarthritis in younger patients. Acta Orthopaedica. Apr. 2010;81(2):161-4. [pmid: 19968599].
2286 W-Dahl A, Toksvig-Larsen S. No clinical benefits using a new design of pins for external fixation: a randomized study in 50 patients operated on by the hemicallotasis technique. Archives of Orthopaedic & Trauma Surgery. Jul. 2008;128(7):661-7. [pmid: 17701189].
2287 W-Dahl A, Toksvig-Larsen S, Roos EM. A 2-year prospective study of patient-relevant outcomes in patients operated on for knee osteoarthritis with tibial osteotomy. BMC Musculoskeletal Disorders. 2005;6(Journal Article):18. [pmid: 15811186].
2288 W-Dahl A, Toksvig-Larsen S, Roos EM. Association between knee alignment and knee pain in patients surgically treated for medial knee osteoarthritis by high tibial osteotomy. A one year follow-up study. BMC Musculoskeletal Disorders. 2009;10(Journal Article):154. [pmid: 19995425].
2289 Weale AE, Halabi OA, Jones PW, et al. Perceptions of outcomes after unicompartmental and total knee replacements. Clinical Orthopaedics & Related Research. 2001;(382):143-53. [pmid: 11153982].
2290 Weale AE, Lee AS, MacEachern AG. High tibial osteotomy using a dynamic axial external fixator. Clinical Orthopaedics & Related Research. 2001;(382):154-67. [pmid: 11153983].
2291 Weale AE, Murray DW, Crawford R, et al. Does arthritis progress in the retained compartments after ‘Oxford’ medial unicompartmental arthroplasty? A clinical and radiological study with a minimum ten-year follow-up. Journal of Bone & Joint Surgery - British Volume. Sep. 1999;81(5):783-9. [pmid: 10530837].
2292 Weaver AL, Messner RP, Storms WW, et al. Treatment of patients with osteoarthritis with rofecoxib compared with nabumetone. JCR: Journal of Clinical Rheumatology. 2006;12(1):17-25. [pmid: 16484875].
2293 Wegener L, Kisner C, Nichols D. Static and dynamic balance responses on persons with bilateral knee osteoarthritis. Journal of Orthopaedic and Sports Physical Therapy. 1997;25(1):13-8. [pmid: 8979171].
2294 Wegener T, Lupke NP. Treatment of patients with arthrosis of hip or knee with an aqueous extract of devil’s claw (Harpagophytum procumbens DC). Phytotherapy Research. Dec. 2003;17(10):1165-72. [pmid: 14669250].
2295 Wegman A, van der Windt D, van Tulder M, et al. Nonsteroidal antiinflammatory drugs or acetaminophen for osteoarthritis of the hip or knee? A systematic review of evidence and guidelines. J Rheumatol. Feb. 2004;31(2):344-54. [pmid: 14760807].
2296 Wegman AC, van der Windt DA, de Haan M, et al. Switching from NSAIDs to paracetamol: a series of n of 1 trials for individual patients with osteoarthritis. Annals of the Rheumatic Diseases. 2003;62(12):1156-61. [pmid: 14644852].
2297 Weidenhielm L. Kinetic and kinematic characteristics of gait in patients with medial knee arthrosis. Acta Orthopaedica Scandinavica. Jun. 2003;74(3):369. author reply -70. [pmid: 12899561].
2298 Weidow J. Lateral osteoarthritis of the knee. Etiology based on morphological, anatomical, kinematic and kinetic observations. Acta Orthopaedica, Supplement. Jun. 2006;77(322):3-44. [pmid: 16886718].
2299 Weidow J, Cederlund CG, Ranstam J, et al. Ahlback grading of osteoarthritis of the knee: poor reproducibility and validity based on visual inspection of the joint. Acta Orthop. Apr. 2006;77(2):262-6. [pmid: 16752288].
2300 Weidow J, Karrholm J, Saari T, et al. Abnormal motion of the medial femoral condyle in lateral knee osteoarthritis. Clinical Orthopaedics & Related Research. Jan. 2007;454:27-34. [pmid: 17091012].
2301 Weigl M, Angst F, Stucki G, et al. Inpatient rehabilitation for hip or knee osteoarthritis: 2 year follow up study. Annals of the Rheumatic Diseases. 2004;63(4):360-8. [pmid: 15020328].
2302 Weinhardt C, Barisic M, Bergmann EG, et al. Early results of subvastus versus medial parapatellar approach in primary total knee arthroplasty. Archives of Orthopaedic & Trauma Surgery. 2004;124(6):401-3. [pmid: 15138774].
2303 Weiss TE, Gum OB, Biundo JJ Jr. Rheumatic diseases. 2. Therapeutic considerations. Postgraduate Medicine. Dec. 1976;60(6):155-9. [pmid: 1087014].
2304 Wells V, Hearn T, Heard A, et al. Incidence and outcomes of knee and hip joint replacement in veterans and civilians. ANZ Journal of Surgery. May. 2006;76(5):295-9. [pmid: 16768685].
2305 Weng HH, Kaplan RM, Boscardin WJ, et al. Development of a decision aid to address racial disparities in utilization of knee replacement surgery. Arthritis & Rheumatism. May. 15. 2007;57(4):568-75. [pmid: 17471558].
2306 Wessel J. The reliability and validity of pain threshold measurements in osteoarthritis of the knee. Scand J Rheumatol. 1995;24(4):238-42. [pmid: 7481589].
2307 Wessel J. Isometric strength measurements of knee extensors in women with osteoarthritis of the knee. J Rheumatol. Feb. 1996;23(2):328-31. [pmid: 8882041].
2308 Wesseling J, Dekker J, van den Berg WB, et al. CHECK (Cohort Hip and Cohort Knee): similarities and differences with the Osteoarthritis Initiative. Ann Rheum Dis. Sep. 2009;68(9):1413-9. [pmid: 18772189].
2309 Westby Marie D, Kennedy D, Carr S, et al. Post-acute physiotherapy for primary total hip arthroplasty, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2006.
2310 Westby Marie D, Kennedy D, Jones D, et al. Post-acute physiotherapy for primary total knee arthroplasty, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2008.
2311 Westrich G, Schaefer S, Walcott-Sapp S, et al. Randomized prospective evaluation of adjuvant hyaluronic acid therapy administered after knee arthroscopy. American Journal of Orthopedics (Chatham, Nj). 2009;38(12):612-6. [pmid: 20145786].
2312 Westwood MJ, White SP, Bannister GC. The St. Leger total knee replacement. A false economy? Knee. Jun. 2003;10(2):179-80. [pmid: 12788003].
2313 White A. Osteoarthritis of the knee - an introduction. Acupuncture in Medicine. 2006;24(Suppl 1):1-6.
2314 White A, Foster N, Cummings M, et al. The effectiveness of acupuncture for osteoarthritis of the knee - a systematic review. Acupuncture in Medicine. 2006;24(Suppl 1):40-8.
2315 White A, Kawakita K. The evidence on acupuncture for knee osteoarthritis - editorial summary on the implications for health policy. Acupuncture in Medicine. 2006;24(Suppl 1):71-6. [pmid: 16783282].
2316 White CM, Ip S, McPheeters ML, et al. Using existing systematic reviews to replace de novo processes in conducting Comparative Effectiveness Reviews. Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness Reviews. [posted September 2009]. Rockville, MD. 2009.
2317 White DK, Jette AM, Felson DT, et al. Are features of the neighborhood environment associated with disability in older adults? Disability &. Rehabilitation. 2010;32(8):639-45. [pmid: 20205576].
2318 Whitehouse SL, Lingard EA, Katz JN, et al. Development and testing of a reduced WOMAC function scale. Journal of Bone & Joint Surgery - British Volume. Jul. 2003;85(5):706-11. [pmid: 12892194].
2319 Whiteside LA. Routine patellar resurfacing: unwise and unwarranted. Orthopedics. Jul. 2003;26(7):685. [pmid: 12875562].
2320 Whitlock EP, Lopez SA, Chang S, et al. AHRQ series paper 3: identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):491-501. [pmid: 19540721].
2321 Whittaker J-P, Naudie DDR, McAuley JP, et al. Does bearing design influence midterm survivorship of unicompartmental arthroplasty?. Clinical Orthopaedics & Related Research. Jan. 2010;468(1):73-81. [pmid: 19597898].
2322 Widman J, Isacson J. Surgical hemostasis after tourniquet release does not reduce blood loss in knee replacement. A prospective randomized study of 81 patients. Acta Orthopaedica Scandinavica. Jun. 1999;70(3):268-70. [pmid: 10429603].
2323 Wigler I, Grotto I, Caspi D, et al. The effects of Zintona EC (a ginger extract) on symptomatic gonarthritis. Osteoarthritis & Cartilage. Nov. 2003;11(11):783-9. [pmid: 14609531].
2324 Wijayaratne SP, Teichtahl AJ, Wluka AE, et al. The determinants of change in patella cartilage volume--a cohort study of healthy middle-aged women. Rheumatology. Sep. 2008;47(9):1426-9. [pmid: 18641040].
2325 Wild JE, Grond S, Kuperwasser B, et al. Long-term safety and tolerability of tapentadol extended release for the management of chronic low back pain or osteoarthritis pain. Pain Pract. Sep–Oct. 2010;10(5):416-27. [pmid: 20602712].
2326 Wilder FV, Barrett JP, Farina EJ. Exercise and osteoarthritis: are we stopping too early? findings from the Clearwater Exercise Study. Journal of Aging & Physical Activity. 2006;14(2):169-80. [pmid: 19462547].
2327 Wilkens P, Scheel IB, Grundnes O, et al. Effect of glucosamine on pain-related disability in patients with chronic low back pain and degenerative lumbar osteoarthritis: a randomized controlled trial. JAMA. Jul. 7. 2010;304(1):45-52. [pmid: 20606148].
2328 Wilkerson GB. Quadriceps strength and knee osteoarthritis. Athletic Therapy Today. 2003;8(1):25-9.
2329 Williams A, Dunning T, Manias E. Continuity of care and general wellbeing of patients with comorbidities requiring joint replacement. Journal of Advanced Nursing. Feb. 2007;57(3):244-56. [pmid: 17233645].
2330 Williams DA, Farrell MJ, Cunningham J, et al. Knee pain and radiographic osteoarthritis interact in the prediction of levels of self-reported disability. Arthritis Rheum. Aug. 15. 2004;51(4):558-61. [pmid: 15334427].
2331 Williams RJ 3rd, Kelly BT, Wickiewicz TL, et al. The short-term outcome of surgical treatment for painful varus arthritis in association with chronic ACL deficiency. The Journal of Knee Surgery. Jan. 2003;16(1):9-16. [pmid: 12568260].
2332 Willson SE, Munro ML, Sandwell JC, et al. Isolated tibial polyethylene insert exchange outcomes after total knee arthroplasty. Clinical Orthopaedics & Related Research. 2010;468(1):96-101. [pmid: 19672671].
2333 Wilson TC, Johnson DL. Articular-cartilage lesions of the knee and osteoarthritis in athletes: an overview. Athletic Therapy Today. 2003;8(1):20-4.
2334 Winther K, Apel K, Thamsborg G. A powder made from seeds and shells of a rose-hip subspecies (Rosa canina) reduces symptoms of knee and hip osteoarthritis: a randomized, double-blind, placebo-controlled clinical trial. Scand J Rheumatol. Jul–Aug. 2005;34(4):302-8. [pmid: 16195164].
2335 Wirth W, Benichou O, Kwoh CK, et al. Spatial patterns of cartilage loss in the medial femoral condyle in osteoarthritic knees: data from the Osteoarthritis Initiative. Magn Reson Med. Mar. 2010;63(3):574-81. [pmid: 20146227].
2336 Wirth W, Buck R, Nevitt M, et al. MRI-based extended ordered values more efficiently differentiate cartilage loss in knees with and without joint space narrowing than region-specific approaches using MRI or radiography--data from the OA initiative. Osteoarthritis Cartilage. Jun. 2011;19(6):689-99. [pmid: 21338702].
2337 Wirth W, Frobell RB, Souza RB, et al. A three-dimensional quantitative method to measure meniscus shape, position, and signal intensity using MR images: a pilot study and preliminary results in knee osteoarthritis. Magn Reson Med. May. 2010;63(5):1162-71. [pmid: 20432287].
2338 Wirth W, Nevitt M, Hellio Le, Graverand MP, et al. Sensitivity to change of cartilage morphometry using coronal FLASH, sagittal DESS, and coronal MPR DESS protocols--comparative data from the Osteoarthritis Initiative (OAI). Osteoarthritis Cartilage. Apr. 2010;18(4):547-54. [pmid: 20060948].
2339 Wislowska M, Jablonska B. Serum cartilage oligomeric matrix protein (COMP) in rheumatoid arthritis and knee osteoarthritis. Clinical Rheumatology. Jun. 2005;24(3):278-84. [pmid: 15940561].
2340 Wisnes Alexander R, Aarskog R, Haugland M, et al. Traction for hip osteoarthritis, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2007.
2341 Witt C, Brinkhaus B, Jena S, et al. Acupuncture in patients with osteoarthritis of the knee: a randomised trial. Lancet. 2005;366(9480):136-43. [pmid: 16005336].
2342 Witt CM, Jena S, Brinkhaus B, et al. Acupuncture in patients with osteoarthritis of the knee or hip: a randomized, controlled trial with an additional nonrandomized arm. Arthritis & Rheumatism. 2006;54(11):3485-93. [pmid: 17075849].
2343 Wittenberg RH, Schell E, Krehan G, et al. First-dose analgesic effect of the cyclo-oxygenase-2 selective inhibitor lumiracoxib in osteoarthritis of the knee: a randomized, double-blind, placebo-controlled comparison with celecoxib. [NCT00267215]. Arthritis Research & Therapy. 2006;8(2):R35. [pmid: 16469112].
2344 Witvrouw E, Pattyn E, Almqvist KF, et al. Catastrophic thinking about pain as a predictor of length of hospital stay after total knee arthroplasty: a prospective study. Knee Surgery, Sports Traumatology, Arthroscopy. Oct. 2009;17(10):1189-94. [pmid: 19468712].
2345 Wluka AE, Stuckey S, Brand C, et al. Supplementary vitamin E does not affect the loss of cartilage volume in knee osteoarthritis: a 2 year double blind randomized placebo controlled study. Journal of Rheumatology. Dec. 2002;29(12):2585-91. [pmid: 12465157].
2346 Wohlrab D, Hube R, Zeh A, et al. Clinical and radiological results of high flex total knee arthroplasty: a 5 year follow-up. Archives of Orthopaedic & Trauma Surgery. Jan. 2009;129(1):21-4. [pmid: 18521616].
2347 Wojtecka-Lukasik E, Ksiezopolska-Orlowska K, Gaszewska E, et al. Cryotherapy decreases histamine levels in the blood of patients with rheumatoid arthritis. Inflamm Res. Mar. Suppl 2. 2010;59:S253-5. [pmid: 20020313].
2348 Wolcott M, Traub S, Efird C. High tibial osteotomies in the young active patient. International Orthopaedics. Feb. 2010;34(2):161-6. [pmid: 20076957].
2349 Wolf S, Foley S, Budiman-Mak E, et al. Predictors of weight loss in overweight veterans with knee osteoarthritis who participated in a clinical trial. Journal of Rehabilitation Research & Development. 2010;47(3):171-81. [pmid: 20665344].
2350 Wolfe F, Hawley DJ, Peloso PM, et al. Back pain in osteoarthritis of the knee. Arthritis Care and Research. 1996;9(5):376-83. [pmid: 8997927].
2351 Wolfe F, Lane NE. The longterm outcome of osteoarthritis: rates and predictors of joint space narrowing in symptomatic patients with knee osteoarthritis. J Rheumatol. Jan. 2002;29(1):139-46. [pmid: 11824950].
2352 Wollheim FA. Early stages of osteoarthritis: the search for sensitive predictors. Annals of the Rheumatic Diseases. Nov. 2003;62(11):1031-2. [pmid: 14583562].
2353 Wolski M, Podsiadlo P, Stachowiak GW. Directional fractal signature analysis of trabecular bone: evaluation of different methods to detect early osteoarthritis in knee radiographs. Proc Inst Mech Eng H. Feb. 2009;223(2):211-36. [pmid: 19278198].
2354 Wong AKO, Inglis D, Beattie KA, et al. Reproducibility of computer-assisted joint alignment measurement in OA knee radiographs. Osteoarthritis & Cartilage. May. 2009;17(5):579-85. [pmid: 19027328].
2355 Wong SK, So WY, Yau PY, et al. Laparoscopic adjustable gastric banding for the treatment of morbidly obese patients: early outcome in a Chinese cohort. Hong Kong Medical Journal. 2005;11(1):20-9. [pmid: 15687512].
2356 Wongsak S, Kawinwonggowit V, Mulpruck P, et al. Accuracy of knee implants sizing predicted by digital images. Journal of the Medical Association of Thailand. Dec. Suppl 6. 2009;92:S85-90. [pmid: 20128074].
2357 Wood L, Peat G, Wilkie R, et al. A study of the noninstrumented physical examination of the knee found high observer variability. J Clin Epidemiol. May. 2006;59(5):512-20. [pmid: 16632140].
2358 Woodard CM, James MK, Messier SP. Computational methods used in the determination of loading rate: experimental and clinical implications. Journal of Applied Biomechanics. 1999;15(4):404-17.
2359 Woolhead GM, Donovan JL, Chard JA, et al. Who should have priority for a knee joint replacement?. Rheumatology (Oxford). Apr. 2002;41(4):390-4. [pmid: 11961168].
2360 Woolhead GM, Donovan JL, Dieppe PA. Outcomes of total knee replacement: a qualitative study. Rheumatology. 2005;44(8):1032-7. [pmid: 15870149].
2361 Worland RL, Jessup DE, Vazquez-Vela Johnson G, et al. The effect of femoral component rotation and asymmetry in total knee replacements. Orthopedics. Oct. 2002;25(10):1045-8. [pmid: 12401010].
2362 Wray NP, Moseley JB, O’Malley K. Arthroscopic treatment of osteoarthritis of the knee. Journal of Bone & Joint Surgery - American Volume. Feb. 2003;85-A(2):381. [pmid: 12571321].
2363 Wright LJ, Zautra AJ, Going S. Adaptation to early knee osteoarthritis: the role of risk, resilience, and disease severity on pain and physical functioning. Ann Behav Med. Aug. 2008;36(1):70-80. [pmid: 18716855].
2364 Wright RW, Boyce RH, Michener T, et al. Radiographs are not useful in detecting arthroscopically confirmed mild chondral damage. Clin Orthop Relat Res. Jan. 2006;442:245-51. [pmid: 16394768].
2365 The Response to Intra-articular Steroids in Knee Osteoarthritis as Defined by Ultrasonographic Outcomes: an Analysis of the Reliability of Sequential Ultrasound Measurements. 69th Annual Meeting of the American College of Rheumatology and 40th Annual Meeting of the Association of Rheumatology Health Professionals. San Diego, California (USA). 13–17 Nov 2005.
2366 Wu CW, Morrell MR, Heinze E, et al. Validation of American College of Rheumatology classification criteria for knee osteoarthritis using arthroscopically defined cartilage damage scores. Seminars in Arthritis & Rheumatism. 2005;35(3):197-201. [pmid: 16325660].
2367 Wu MX, Li XH, Lin MN, et al. Clinical study on the treatment of knee osteoarthritis of Shen-Sui insufficiency syndrome type by electroacupuncture. Chin J Integr Med. Aug. 2010;16(4):291-7. [pmid: 20697938].
2368 Wu SF, Kao MJ, Wu MP, et al. Effects of an osteoarthritis self-management programme. Journal of Advanced Nursing. Jul. 2011;67(7):1491-501. [pmid: 21375573].
2369 Wu SH, Chu NK, Liu YC, et al. Relationship between the emg ratio of muscle activation, and bony structure in osteoarthritic knee patients with and, without patellar malalignment. Journal of Rehabilitation Medicine. 2008;40(5):381-6. [pmid: 18461264].
2370 Xie F, Li SC, Fong KY, et al. What health domains and items are important to patients with knee osteoarthritis? A focus group study in a multiethnic urban Asian population. Osteoarthritis & Cartilage. 2006;14(3):224-30. [pmid: 16290042].
2371 Xie F, Li SC, Goeree R, et al. Validation of Chinese Western Ontario and McMaster Universities Osteoarthritis Index (WOMAC) in patients scheduled for total knee replacement. Quality of Life Research. 2008;17(4):595-601. [pmid: 18415706].
2372 Xie F, Li SC, Luo N, et al. Comparison of the EuroQol and short form 6D in Singapore multiethnic Asian knee osteoarthritis patients scheduled for total knee replacement. Arthritis Rheum. Aug. 15. 2007;57(6):1043-9. [pmid: 17665466].
2373 Xie F, Li SC, Roos EM, et al. Cross-cultural adaptation and validation of Singapore English and Chinese versions of the Knee injury and Osteoarthritis Outcome Score (KOOS) in Asians with knee osteoarthritis in Singapore. Osteoarthritis & Cartilage. 2006;14(11):1098-103. [pmid: 16814575].
2374 Xie F, Lo NN, Lee HP, et al. Validation of the Comprehensive ICF Core Set for Osteoarthritis (OA) in patients with knee OA: a Singaporean perspective. J Rheumatol. Nov. 2007;34(11):2301-7. [pmid: 17937460].
2375 Xie F, Lo NN, Lee HP, et al. Validation of the International Classification of Functioning, Disability, and Health (ICF) Brief Core Set for osteoarthritis. Scand J Rheumatol. Nov–Dec. 2008;37(6):450-61. [pmid: 18666026].
2376 Xie F, Thumboo J, Fong KY, et al. Are they relevant? A critical evaluation of the international classification of functioning, disability, and health core sets for osteoarthritis from the perspective of patients with knee osteoarthritis in Singapore. Ann Rheum Dis. Aug. 2006;65(8):1067-73. [pmid: 16396981].
2377 Yaffe MA, Koo SS, Stulberg SD. Radiographic and navigation measurements of TKA limb alignment do not correlate. Clinical Orthopaedics & Related Research. 2008;466(11):2736-44. [pmid: 18752032].
2378 Yamada H, Koshino T, Sakai N, et al. Hip adductor muscle strength in patients with varus deformed knee. Clinical Orthopaedics & Related Research. May. 2001;(386):179-85. [pmid: 11347832].
2379 Yamakado K, Kitaoka K, Yamada H, et al. Influence of stability on range of motion after cruciate-retaining TKA. Archives of Orthopaedic & Trauma Surgery. Feb. 2003;123(1):1-4. [pmid: 12582788].
2380 Yanasse RH, Cavallari CE, Chaud FL, et al. Measurement of tibial slope angle after medial opening wedge high tibial osteotomy: case series. Sao Paulo Medical Journal = Revista Paulista de Medicina. Jan. 2009;127(1):34-9. [pmid: 19466293].
2381 Yang CC, McFadden LA, Dennis DA, et al. Lateral retinacular release rates in mobile- versus fixed-bearing TKA. Clinical Orthopaedics & Related Research. Nov. 2008;466(11):2656-61. [pmid: 18709430].
2382 Yang KGA, Raijmakers NJH, van Arkel ERA, et al. Autologous interleukin-1 receptor antagonist improves function and symptoms in osteoarthritis when compared to placebo in a prospective randomized controlled trial. Osteoarthritis & Cartilage. Apr. 2008;16(4):498-505. [pmid: 17825587].
2383 Yang KY, Wang MC, Yeo SJ, et al. Minimally invasive unicondylar versus total condylar knee arthroplasty--early results of a matched-pair comparison. Singapore Medical Journal. Nov. 2003;44(11):559-62. [pmid: 15007494].
2384 Yang N, Nayeb-Hashemi H, Canavan PK. The combined effect of frontal plane tibiofemoral knee angle and meniscectomy on the cartilage contact stresses and strains. Annals of Biomedical Engineering. Nov. 2009;37(11):2360-72. [pmid: 19690961].
2385 Yang P, He X, Yang Z, et al. Effects of bushen huoxue decoction on nitric oxide (NO) in serum, articular cartilage and synovium in rabbits of knee osteoarthritis. Journal of Traditional Chinese Medicine. 2004;24(2):149-52. [pmid: 15270275].
2386 Yang W. Forty-seven cases of gonitis treated by a combined therapy of Chinese drugs and acupuncture. Journal of Traditional Chinese Medicine. Jun. 2001;21(2):127-9. [pmid: 11498902].
2387 Yao W, Qu N, Lu Z, et al. The application of T1 and T2 relaxation time and magnetization transfer ratios to the early diagnosis of patellar cartilage osteoarthritis. Skeletal Radiology. Nov. 2009;38(11):1055-62. [pmid: 19688346].
2388 Yau WP, Chiu KY, Zuo JL, et al. Computer navigation did not improve alignment in a lower-volume total knee practice. Clinical Orthopaedics & Related Research. 2008;466(4):935-45. [pmid: 18259827].
2389 Yau W-P, Wong JWK, Chiu K-Y, et al. Patellar clunk syndrome after posterior stabilized total knee arthroplasty. Journal of Arthroplasty. Dec. 2003;18(8):1023-8. [pmid: 14658107].
2390 Yavuzer G, Sonel B, Suldur N, et al. Effects of intra-articular hylan G-F 20 injections on clinical and biomechanical characteristics of the knee in osteoarthritis. International Journal of Rehabilitation Research. 2005;28(4):371-4. [pmid: 16319566].
2391 Yen ZS, Lai MS, Wang CT, et al. Cost-effectiveness of treatment strategies for osteoarthritis of the knee in Taiwan. J Rheumatol. Sep. 2004;31(9):1797-803. [pmid: 15338503].
2392 Yentur EA, Okcu G, Yegul I. The role of trigger point therapy in knee osteoarthritis. Pain Clinic. 2003;15(4):385-90.
2393 Yercan HS, Ait Si, Selmi T, Neyret P. The treatment of patellofemoral osteoarthritis with partial lateral facetectomy. Clinical Orthopaedics & Related Research. Jul. 2005;(436):14-9. [pmid: 15995415].
2394 Yong CK, Choon DSK, Soon HC. Midterm outcome of the Duracon total knee arthroplasty. Journal of Orthopaedic Surgery. Aug. 2008;16(2):197-200. [pmid: 18725672].
2395 Yoo JH, Seong SC, Lee S, et al. Rigid stepped plate for internal fixation for high tibial osteotomy. Orthopedics. 2009;32(10). [pmid: 19824607].
2396 Yoon HS, Kim SE, Suh YR, et al. Correlation between ultrasonographic findings and the response to corticosteroid injection in pes anserinus tendinobursitis syndrome in knee osteoarthritis patients. Journal of Korean Medical Science. 2005;20(1):109-12. [pmid: 15716614].
2397 Yoon RS, Nellans KW, Geller JA, et al. Patient education before hip or knee arthroplasty lowers length of stay. Journal of Arthroplasty. Jun. 2010;25(4):547-51. [pmid: 19427164].
2398 Yoshimura N, Muraki S, Oka H, et al. Prevalence of knee osteoarthritis, lumbar spondylosis, and osteoporosis in Japanese men and women: the research on osteoarthritis/osteoporosis against disability study. J Bone Miner Metab. 2009;27(5):620-8. [pmid: 19568689].
2399 Yoshioka H, Stevens K, Hargreaves BA, et al. Magnetic resonance imaging of articular cartilage of the knee: comparison between fat-suppressed three-dimensional SPGR imaging, fat-suppressed FSE imaging, and fat-suppressed three-dimensional DEFT imaging, and correlation with arthroscopy. J Magn Reson Imaging. Nov. 2004;20(5):857-64. [pmid: 15503323].
2400 Yoshitaka T, Abe N, Minagawa H, et al. Disease-specific screening for deep venous thrombosis and pulmonary thromboembolism using plasma D-dimer values after total knee arthroplasty. Mod Rheumatol. 2008;18(4):359-65. [pmid: 18461274].
2401 Yu F, Xijing H, Yuqiang W, et al. Effects of Xianzhong Injection on the Function of Knee Joint and the Content of Insulin-Like Growth Factor-1 in Rabbits of Early Osteoarthritis. Journal of Traditional Chinese Medicine. 2007;27(4):288-92. [pmid: 18246688].
2402 Yurtkuran M, Alp A, Konur S, et al. Laser acupuncture in knee osteoarthritis: a double-blind, randomized controlled study. Photomedicine and Laser Surgery. 2007;25(1):14-20. [pmid: 17352632].
2403 Zacher J, Feldman D, Gerli R, et al. A comparison of the therapeutic efficacy and tolerability of etoricoxib and diclofenac in patients with osteoarthritis. [Erratum appears in Curr Med Res Opin. 2004 Oct;20(10):1689]. Current Medical Research & Opinion. 2003;19(8):725-36. [pmid: 14687444].
2404 Zaffagnini S, Giordano G, Vascellari A, et al. Arthroscopic collagen meniscus implant results at 6 to 8 years follow up. Knee Surgery, Sports Traumatology, Arthroscopy. Feb. 2007;15(2):175-83. [pmid: 16845545].
2405 Zaki SH, Rae PJ. High tibial valgus osteotomy using the Tomofix plate--medium-term results in young patients. Acta Orthopaedica Belgica. Jun. 2009;75(3):360-7. [pmid: 19681323].
2406 Zalzal P, Papini M, Petruccelli D, et al. An in vivo biomechanical analysis of the soft-tissue envelope of osteoarthritic knees. Journal of Arthroplasty. Feb. 2004;19(2):217-23. [pmid: 14973866].
2407 Zammit Gerard V, Menz Hylton B, Munteanu Shannon E, et al. Interventions for treating osteoarthritis of the big toe joint, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2009.
2408 Zeh A, Davis J, Laskin R, et al. Early results with the Genesis II Posterior Stabilized High Flexion knee prosthesis. A one year follow-up study. Acta Orthopaedica Belgica. Dec. 2009;75(6):792-800. [pmid: 20166362].
2409 Zeni JA Jr, Axe MJ, Snyder-Mackler L. Clinical predictors of elective total joint replacement in persons with end-stage knee osteoarthritis. BMC Musculoskelet Disord. 2010;11:86. [pmid: 20459622].
2410 Zeni JA Jr, Higginson JS. Dynamic knee joint stiffness in subjects with a progressive increase in severity of knee osteoarthritis. Clin Biomech (Bristol, Avon). May. 2009;24(4):366-71. [pmid: 19250725].
2411 Zeni JA Jr, Higginson JS. Differences in gait parameters between healthy subjects and persons with moderate and severe knee osteoarthritis: a result of altered walking speed?. Clin Biomech (Bristol, Avon). May. 2009;24(4):372-8. [pmid: 19285768].
2412 Zeni JA, Rudolph K, Higginson JS. Alterations in quadriceps and hamstrings coordination in persons with medial compartment knee osteoarthritis. Journal of Electromyography & Kinesiology. Feb. 2010;20(1):148-54. [pmid: 19223203].
2413 Zeni JA Jr, Snyder-Mackler L. Most patients gain weight in the 2 years after total knee arthroplasty: comparison to a healthy control group. Osteoarthritis & Cartilage. Apr. 2010;18(4):510-4. [pmid: 20060949].
2414 Zeni JA Jr, Snyder-Mackler L. Clinical outcomes after simultaneous bilateral total knee arthroplasty: comparison to unilateral total knee arthroplasty and healthy controls. Journal of Arthroplasty. Jun. 2010;25(4):541-6. [pmid: 19356894].
2415 Zeni JA Jr, Snyder-Mackler L. Early postoperative measures predict 1- and 2-year outcomes after unilateral total knee arthroplasty: importance of contralateral limb strength. Phys Ther. Jan. 2010;90(1):43-54. [pmid: 19959653].
2416 Zeni JA Jr, Snyder-Mackler L. Preoperative predictors of persistent impairments during stair ascent and descent after total knee arthroplasty. J Bone Joint Surg Am. May. 2010;92(5):1130-6. [pmid: 20439658].
2417 Zgradie I. Comparison of therapeutic efficacy of nimesulide and diclofenac in patients with degenerative joint diseases. Journal of the Indian Medical Association. Apr. 1999;97(4):119-23. [pmid: 10652894].
2418 Zhai G, Ding C, Cicuttini F, et al. A longitudinal study of the association between knee alignment and change in cartilage volume and chondral defects in a largely non-osteoarthritic population. Journal of Rheumatology. Jan. 2007;34(1):181-6. [pmid: 17216686].
2419 Zhang H-m, Zhang Z-q, Min Z-h, et al. Controlled clinical trials on the effects of Chinese traditional medicine for the treatment of osteoarthritis of knee joint at early stage and its MRI changes. Zhongguo Gushang. Sep. 2008;21(9):651-3. [pmid: 19105270].
2420 Zhang H-n, Zhang J, Lv C-y, et al. Modified biplanar open-wedge high tibial osteotomy with rigid locking plate to treat varus knee. Journal of Zhejiang University SCIENCE B. Sep. 2009;10(9):689-95. [pmid: 19735102].
2421 Zhang Q-R, Fu WB. Osteoarthritis of knee joint treated with acupuncture and moxibustion. Zhongguo Zhenjiu. May. 2010;30(5):375-8. [pmid: 20518172].
2422 Zhang Z. Acupuncture treatment of 3 difficult cases according to Dr. Xu Benren’s experience. Journal of Traditional Chinese Medicine. Mar. 2004;24(1):51-2. [pmid: 15119177].
2423 Zhao L, Shen X, Cheng K, et al. Validating a nonacupoint sham control for laser treatment of knee osteoarthritis. Photomedicine and Laser Surgery. Jun. 2010;28(3):351-6. [pmid: 19860569].
2424 Zide MF, Carlton DM, Kent JN. Rheumatoid disease and related arthropathies. I. Systemic findings, medical therapy, and peripheral joint surgery. Oral Surg Oral Med Oral Pathol. Feb. 1986;61(2):119-25. [pmid: 3457333].
2425 Zietz PM, Selesnick H. The use of hylan G-F 20 after knee arthroscopy in an active patient population with knee osteoarthritis. Arthroscopy. 2008;24(4):416-22. [pmid: 18375273].
2426 Zivanovic S, Rackov LP, Vojvodic D, et al. Human cartilage glycoprotein 39--biomarker of joint damage in knee osteoarthritis. Int Orthop. Aug. 2009;33(4):1165-70. [pmid: 19308408].
2427 Zochling J, March L, Lapsley H, et al. Use of complementary medicines for osteoarthritis--a prospective study. Annals of the Rheumatic Diseases. May. 2004;63(5):549-54. [pmid: 15082486].
2428 Zumstein MA, Frauchiger L, Wyss D, et al. Is restricted femoral navigation sufficient for accuracy of total knee arthroplasty?. Clinical Orthopaedics & Related Research. 2006;451(Journal Article):80-6. [pmid: 16691146].
2429 Zuo J, Li X, Banerjee S, et al. Parallel imaging of knee cartilage at 3 Tesla. J Magn Reson Imaging. Oct. 2007;26(4):1001-9. [pmid: 17896394].
2430 Bruyere O, Honore A, Rovati LC, et al. Radiologic features poorly predict clinical outcomes in knee osteoarthritis. Scandinavian journal of rheumatology. 2002;31(1):13-6. [pmid: 11922194].