# Literature Search Strings

June 7, 2010

AMED (Allied and Complementary Medicine)

knee osteoarthritis.mp. or exp Osteoarthritis Knee | 446

Health and Psychosocial Instruments

knee osteoarthritis.mp. or exp Osteoarthritis Knee | 34

Ovid Medline (R)

1 | exp Treatment Outcome/ or exp Physical Therapy Modalities/ or exp “Outcome Assessment (Health Care)”/ or exp Questionnaires/ | | 761338
2 | knee osteoarthritis.mp. or exp Osteoarthritis, Knee/ | | 6740
3 | 1 and 2 | | 2296
4 | limit 3 to (abstracts and English language and full text and journal article and (“therapy (sensitivity)” or “therapy (specificity)” or “therapy (optimized)” or “diagnosis (sensitivity)” or “diagnosis (specificity)” or “diagnosis (optimized)” or “prognosis (sensitivity)” or “prognosis (specificity)” or “prognosis (optimized)”) and last 15 years) | Ovid 1 | 309

PubMed Medline

Search “Physical Therapy Modalities”[Mesh] AND “Osteoarthritis, Knee”[Mesh] Limits: Humans, Journal Article, English | 373
Search “Physical therapy” AND knee osteoarthritis Limits: Humans, Journal Article, English | 336

July 22, 2010

Search Disability AND “knee osteoarthritis” Limits: Humans, Journal Article, English | 472
Search “Disability Evaluation”[Mesh] AND “knee osteoarthritis” Limits: English | 208

Cochrane Library

“Physical Therapy Modalities and Osteoarthritis, Knee in Cochrane Database of Systematic Reviews” -75 records

Ovid Technologies, Inc. Email Service

Search for: limit 19 to (english language and yr=“1990 -Current”)

Database: Ovid Medline (R) <1950 to May Week 4 2010

1 | exp Osteoarthritis, Knee/rh, the [Rehabilitation, Therapy] | 921
2 | exp Pain/rh, the [Rehabilitation, Therapy] | 36659
3 | exp osteoarthritis, knee/ | 6253
4 | 2 and 3 | 155
5 | 1 or 4 | 947
6 | exp Physical Therapy Modalities/ | 97923
7 | 3 and 6 | 467
8 | 5 or 7 | 1012
9 | exp “Outcome and Process Assessment (Health Care)”/ | 494044
10 | exp Pain Measurement/ | 43738
11 | exp “Quality of Life”/ | 82913
12 | exp “Activities of Daily Living”/ | 40273
13 | exp Patient Satisfaction/ | 43917
14 | exp Muscle Strength/ | 9567
15 | exp “Recovery of Function”/ | 18157
16 | outcome$.mp. | 937806
17 | exp “Range of Motion, Articular”/ | 23800
18 | 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 | 1110826
19 | 8 and 18 | 685
20 | limit 19 to (english language and yr=“1990 -Current”) | 619)

June 10 PubMed, Medline

Search Osteoarthritis[Corporate Author] | 24

October 25, 2010

Search predictor disability knee osteoarthritis Limits: Humans, Journal Article, English | 20
Search specificity AND knee osteoarthritis Limits: Humans, Journal Article, English | 439

November 12, 2010

Search Manual AND “knee osteoarthritis” | 71

December 10 2010

Search patient acceptable symptom state | 46

July 14, 2011 Ovid, Medline

1 | Osteoarthritis, Knee/rh, the [Rehabilitation, Therapy] | 1089
2 | exp Osteoarthritis, Knee/ | 7250
3 | exp Health Education/ | 121363
4 | exp Patient Education as Topic/ | 62111
5 | exp Health Knowledge, Attitudes, Practice/ | 55919
6 | exp Counseling/ | 28798
7 | 3 or 4 or 5 or 6 | 188826
8 | 2 and 7 | 109
9 | limit 8 to english language | 98
10 | limit 9 to (case reports or editorial) | 6
11 | 9 not 10 | 92
12 | exp Osteoarthritis, Knee/ | 7250
13 | exp Exercise Therapy/ | 23285
14 | exp Exercise/ | 56182
15 | exp Exercise Movement Techniques/ | 4172
16 | exp Physical Endurance/ | 20397
17 | (aerobic capacity or aerobic endurance).mp. | 2845
18 | (conditioning or reconditioning).mp. | 78552
19 | propulsion.mp. | 2246
20 | aquatic.mp. | 16488
21 | (gait training or locomotor training).mp. | 549
22 | increased workload.mp. | 355
23 | exp “Range of Motion, Articular”/ | 26254
24 | muscle lengthening.mp. | 143
25 | stretching.mp. | 11962
26 | locomotion training.mp. | 9
27 | exp Physical Therapy Modalities/ | 104002
28 | (implement training or device training or perceptual training).mp. | 140
29 | exp Muscle Strength/ | 11677
30 | (strength training or power training or endurance training).mp. | 4712
31 | exp Postural Balance/ | 11197
32 | body mechanics.mp. | 153
33 | (balance training or coordination training or agility training).mp. | 412
34 | exp Relaxation Therapy/ | 6332
35 | 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 | 322420
36 | 12 and 35 | 1564
37 | limit 36 to english language | 1435
38 | limit 37 to humans | 1419
39 | limit 38 to (case reports or editorial) | 59
40 | 38 not 39 | 1360
41 | exp Osteoarthritis, Knee/rh, the [Rehabilitation, Therapy] | 1089
42 | exp Self Care/ | 33911
43 | exp “Activities of Daily Living”/ | 43159
44 | exp Orthopedic Equipment/ | 67082
45 | functional training.mp. | 161
46 | exp “Wounds and Injuries”/pc [Prevention & Control] | 39788
47 | 42 or 43 or 44 or 45 or 46 | 180570
48 | 41 and 47 | 227
49 | limit 48 to english language | 208
50 | limit 49 to (case reports or editorial) | 10
51 | 49 not 50 | 198
52 | exp Osteoarthritis, Knee/rh, th [Rehabilitation, Therapy] | 1089
53 | (assistive device$ or adaptive device$).mp. | 894
54 | equipment training.mp. | 65
55 | device training.mp. | 26
56 | exp Occupational Therapy/ | 8942
57 | exp Leisure Activities/ | 123365
58 | exp Accidents, Occupational/pc [Prevention & Control] | 4338
59 | exp Occupational Diseases/pc [Prevention & Control] | 17424
60 | 53 or 54 or 55 or 56 or 57 or 58 or 59 | 153349
61 | 52 and 60 | 113
62 | limit 61 to english language | 100
63 | limit 62 to (case reports or editorial) | 4
64 | 62 not 63 | 96
65 | exp Osteoarthritis, Knee/rh, th [Rehabilitation, Therapy] | 1089
66 | manual therap$.mp. | 782
67 | (mobilization or manipulation).mp. | 82551
68 | exp Traction/ | 5318
69 | exp Musculoskeletal Manipulations/ | 10444
70 | exp Manipulation, Orthopedic/ | 3183
71 | exp “Range of Motion, Articular”/ | 26254
72 | passive range of motion.mp. | 491
73 | 66 or 67 or 68 or 69 or 70 or 71 or 72 | 118016
74 | 65 and 73 | 144
75 | limit 74 to english language | 136
76 | limit 75 to (case reports or editorial) | 6
77 | 75 not 76 | 130
78 | exp Osteoarthritis, Knee/rh, th [Rehabilitation, Therapy] | 1089
79 | exp Self-Help Devices/ | 7276
80 | exp Orthopedic Equipment/ | 67082
81 | exp Bandages/ | 17549
82 | (adaptive device$ or assistive device$).mp. | 894
83 | orthotic device$.mp. | 4469
84 | protective device$.mp. | 10325
85 | supportive device$.mp. | 39
86 | 79 or 80 or 81 or 82 or 83 or 84 or 85 | 101256
87 | 78 and 86 | 128
88 | limit 87 to english language | 115
89 | limit 88 to (case reports or editorial) | 7
90 | 88 not 89 | 108
91 | exp osteoarthritis, knee/ | 7250
92 | exp Iontophoresis/ | 6454
93 | exp Electric Stimulation/ | 111391
94 | exp Electric Stimulation Therapy/ | 50317
95 | 92 or 93 or 94 | 165802
96 | 91 and 95 | 80
97 | (ems or fes or hvpc or nmes or tens).mp. | 14879
98 | 91 and 97 | 25
99 | 96 or 98 | 82
100 | limit 99 to english language | 70
101 | limit 100 to (case reports or editorial) | 3
102 | 100 not 101 | 67
103 | exp osteoarthritis, knee/ | 7250
104 | exp Physical Therapy Modalities/ | 104002
105 | exp Magnetic Field Therapy/ | 4751
106 | exp Cryotherapy/ | 18562
107 | exp Hydrotherapy/ | 16153
108 | exp Ultrasonic Therapy/ | 7694
109 | exp Hot Temperature/tu [Therapeutic Use] | 2591
110 | exp Hyperthermia, Induced/ | 20568
111 | exp Bandages/ | 17549
112 | exp Intermittent Pneumatic Compression Devices/ | 286
113 | exp Stockings, Compression/ | 661
114 | exp Motion Therapy, Continuous Passive/ | 485
115 | 104 or 105 or 106 or 107 or 108 or 109 or 110 or 111 or 112 or 113 or 114 | 159321
116 | 103 and 115 | 633
117 | limit 116 to english language | 556
118 | limit 117 to (case reports or editorial) | 28
119 | 117 not 118 | 528
120 | exp osteoarthritis, knee/ | 7250
121 | exp Treatment Outcome/ | 499636
122 | treatment duration.mp. | 3753
123 | treatment intensity.mp. | 567
124 | exp Patient Care Team/ | 47915
125 | exp Patient Care Planning/ or exp “Continuity of Patient Care”/ or exp Case Management/ | 57332
126 | coordinated care.mp. | 412
127 | exp Combined Modality Therapy/ | 174206
128 | exp Interdisciplinary Communication/ | 6510
129 | interdisciplinary.mp. | 20982
130 | 121 or 122 or 123 or 124 or 125 or 126 or 127 or 128 or 129 | 747717
131 | 120 and 130 | 1936
132 | limit 131 to english language | 1727
133 | limit 132 to (case reports or editorial) | 73
134 | 132 not 133 | 1654
135 | exp osteoarthritis, knee/ | 7250
136 | lower extremity functional scale.mp. | 54
137 | lefs.mp. | 56
138 | arthritis impact measurement scale.mp. | 108
139 | patient specific functional scale.mp. | 40
140 | psfs.mp. | 143
141 | outpatient physical therapy improvement in movement assessment log.mp. | 2
142 | (optimal and log).mp. | 1320
143 | gait speed.mp. | 899
144 | single leg stance.mp. | 213
145 | tandem stance.mp. | 74
146 | manual muscle test.mp. | 126
147 | manual therapy.mp. or exp musculoskeletal manipulations/ | 10730
148 | exp synovitis/us | 260
149 | muscle relaxation.mp. or exp muscle relaxation/ | 27533
150 | quadriceps strengthening.mp. | 70
151 | exp quadriceps muscle/ | 1335
152 | strengthening.mp. | 10222
153 | 151 and 152 | 35
154 | 150 or 153 | 91
155 | patellar taping.mp. | 52
156 | exp patella/ | 7389
157 | taping.mp. | 716
158 | 156 and 157 | 55
159 | 155 or 158 | 71
160 | functional training.mp. | 161
161 | medical device$.mp. | 5440
162 | exp “equipment and supplies”/ | 991094
163 | device$.mp. | 192212
164 | 162 and 163 | 100683
165 | 161 or 164 | 103180
166 | patient education.mp. or exp patient education/ | 68929
167 | exp hydrotherapy/ or aquatic therapy.mp. | 16169
168 | 136 or 137 or 138 or 139 or 140 or 141 or 142 or 143 or 144 or 145 or 146 or 147 or 148 or 149 or 154 or 159 or 160 or 165 or 166 or 167 | 227807
169 | 135 and 168 | 408
170 | limit 169 to english language | 370

Updated search Ovid MEDLINE(R) 1946 to December Week 4, 2011

# | Searches | Results
1 | exp Arthrometry, Articular/ | 399
2 | exp Biological Markers/ | 517639
3 | exp “Predictive Value of Tests”/ | 114791
4 | exp “Sensitivity and Specificity”/ | 342804
5 | exp exercise test/ | 44821
6 | exp Osteoarthritis, Knee/ | 7686
7 | exp Osteoarthritis, Hip/ | 4847
8 | 6 or 7 | 11636
9 | 1 or 2 or 3 or 4 or 5 | 865620
10 | 8 and 9 | 922
11 | exp Prognosis/ | 896179
12 | exp Disease Progression/ | 94240
13 | exp Treatment Outcome/ | 517052
14 | clinical outcome$.mp. | 56645
15 | exp “Quality of Life”/ | 94592
16 | exp Pain/ | 267912
17 | exp Disability Evaluation/ | 33526
18 | exp Disabled Persons/ | 40737
19 | disabilit$.mp. | 146918
20 | 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 | 1438823
21 | 10 and 20 | 343
22 | limit 21 to (humans and yr=“1990 -Current”) | 336
23 | limit 22 to updaterange=“mesz(20120104112127–20120104112127]” | 0

# | Searches | Results
1 | exp osteoarthritis, knee/ | 7686
2 | lower extremity functional scale.mp. | 54
3 | lefs.mp. | 57
4 | arthritis impact measurement scale.mp. | 110
5 | patient specific functional scale.mp. | 41
6 | psfs.mp. | 148
7 | outpatient physical therapy improvement in movement assessment log.mp. | 2
8 | (optimal and log).mp. | 1362
9 | gait speed.mp. | 918
10 | single leg stance.mp. | 220
11 | tandem stance.mp. | 80
12 | manual muscle test.mp. | 134
13 | manual therapy.mp. or exp musculoskeletal manipulations/ | 11060
14 | exp synovitis/us | 285
15 | muscle relaxation.mp. or exp muscle relaxation/ | 27605
16 | quadriceps strengthening.mp. | 74
17 | exp quadriceps muscle/ | 1406
18 | strengthening.mp. | 10584
19 | 17 and 18 | 39
20 | 16 or 19 | 95
21 | patellar taping.mp. | 51
22 | exp patella/ | 7602
23 | taping.mp. | 715
24 | 22 and 23 | 54
25 | 21 or 24 | 70
26 | functional training.mp. | 165
27 | medical device$.mp. | 5591
28 | exp “equipment and supplies”/ | 1001959
29 | [limit 35 to english language] | 0
30 | exp osteoarthritis, knee/ | 7686
31 | lower extremity functional scale.mp. | 54
32 | lefs.mp. | 57
33 | arthritis impact measurement scale.mp. | 110
34 | patient specific functional scale.mp. | 41
35 | psfs.mp. | 148
36 | outpatient physical therapy improvement in movement assessment log.mp. | 2
37 | (optimal and log).mp. | 1362
38 | gait speed.mp. | 918
39 | single leg stance.mp. | 220
40 | tandem stance.mp. | 80
41 | manual muscle test.mp. | 134
42 | manual therapy.mp. or exp musculoskeletal manipulations/ | 11060
43 | exp synovitis/us | 285
44 | muscle relaxation.mp. or exp muscle relaxation/ | 27605
45 | quadriceps strengthening.mp. | 74
46 | exp quadriceps muscle/ | 1406
47 | strengthening.mp. | 10584
48 | 46 and 47 | 39
49 | 45 or 48 | 95
50 | patellar taping.mp. | 51
51 | exp patella/ | 7602

1 | exp osteoarthritis, knee/ | 7686
2 | exp Iontophoresis/ | 6461
3 | exp Electric Stimulation/ | 111459
4 | exp Electric Stimulation Therapy/ | 50928
5 | 2 or 3 or 4 | 166488
6 | 1 and 5 | 83
7 | (ems or fes or hvpc or nmes or tens).mp. | 15294
8 | 1 and 7 | 25
9 | 6 or 8 | 86
10 | limit 9 to english language | 73
11 | limit 10 to (case reports or editorial) | 3
12 | 10 not 11 | 70
13 | exp Osteoarthritis, Knee/ | 7686
14 | exp Health Education/ | 122790
15 | exp Patient Education as Topic/ | 62839
16 | exp Health Knowledge, Attitudes, Practice/ | 57696
17 | exp Counseling/ | 29099
18 | 14 or 15 or 16 or 17 | 191995
19 | 13 and 18 | 113
20 | limit 19 to english language | 103
21 | limit 20 to (case reports or editorial) | 6
22 | 20 not 21 | 97
23 | exp Osteoarthritis, Knee/rh, th [Rehabilitation, Therapy] | 1159
24 | exp Self Care/ | 33912
25 | exp “Activities of Daily Living”/ | 43836
26 | exp Orthopedic Equipment/ | 68716
27 | functional training.mp. | 165
28 | exp “Wounds and Injuries”/pc [Prevention & Control] | 40720
29 | 24 or 25 or 26 or 27 or 28 | 183761
30 | 23 and 29 | 248
31 | limit 30 to english language | 228
32 | limit 31 to (case reports or editorial) | 12
33 | 31 not 32 | 216
34 | exp Osteoarthritis, Knee/rh, th [Rehabilitation, Therapy] | 1159
35 | (assistive device$ or adaptive device$).mp. | 918
36 | equipment training.mp. | 68
37 | device training.mp. | 28
38 | exp Occupational Therapy/ | 9182
39 | exp Leisure Activities/ | 126029
40 | exp Accidents, Occupational/pc [Prevention & Control] | 4414
41 | exp Occupational Diseases/pc [Prevention & Control] | 17597
42 | 35 or 36 or 37 or 38 or 39 or 40 or 41 | 156505
43 | 34 and 42 | 115
44 | limit 43 to english language | 102
45 | limit 44 to (case reports or editorial) | 4
46 | 44 not 45 | 98
47 | exp Osteoarthritis, Knee/rh, th [Rehabilitation, Therapy] | 1159
48 | manual therap$.mp. | 825
49 | (mobilization or manipulation).mp. | 83447
50 | exp Traction/ | 5455
51 | exp Musculoskeletal Manipulations/ | 10753
52 | exp Manipulation, Orthopedic/ | 3297
53 | exp “Range of Motion, Articular”/ | 27623
54 | passive range of motion.mp. | 500
55 | 48 or 49 or 50 or 51 or 52 or 53 or 54 | 120477
56 | 47 and 55 | 149
57 | limit 56 to english language | 139
58 | limit 57 to (case reports or editorial) | 7
59 | 57 not 58 | 132
60 | exp osteoarthritis, knee/ | 7686
61 | exp Iontophoresis/ | 6461
62 | exp Electric Stimulation/ | 111459
63 | exp Electric Stimulation Therapy/ | 50928
64 | 61 or 62 or 63 | 166488
65 | 60 and 64 | 83
66 | (ems or fes or hvpc or nmes or tens).mp. | 15294
67 | 60 and 66 | 25
68 | 65 or 67 | 86
69 | limit 68 to english language | 73
70 | limit 69 to (case reports or editorial) | 3
71 | 69 not 70 | 70

1 | exp osteoarthritis, knee/ | 7686
2 | exp Iontophoresis/ | 6461
3 | exp Electric Stimulation/ | 111459
4 | exp Electric Stimulation Therapy/ | 50928
5 | 2 or 3 or 4 | 166488
6 | 1 and 5 | 83
7 | (ems or fes or hvpc or nmes or tens).mp. | 15294
8 | 1 and 7 | 25
9 | 6 or 8 | 86
10 | limit 9 to english language | 73
11 | limit 10 to (case reports or editorial) | 3
12 | 10 not 11 | 70
13 | exp Osteoarthritis, Knee/ | 7686
14 | exp Health Education/ | 122790
15 | exp Patient Education as Topic/ | 62839
16 | exp Health Knowledge, Attitudes, Practice/ | 57696
17 | exp Counseling/ | 29099
18 | 14 or 15 or 16 or 17 | 191995
19 | 13 and 18 | 113
20 | limit 19 to english language | 103
21 | limit 20 to (case reports or editorial) | 6
22 | 20 not 21 | 97
23 | exp Osteoarthritis, Knee/rh, th [Rehabilitation, Therapy] | 1159
24 | exp Self Care/ | 33912
25 | exp “Activities of Daily Living”/ | 43836
26 | exp Orthopedic Equipment/ | 68716
27 | functional training.mp. | 165
28 | exp “Wounds and Injuries”/pc [Prevention & Control] | 40720
29 | 24 or 25 or 26 or 27 or 28 | 183761
30 | 23 and 29 | 248
31 | limit 30 to english language | 228
32 | limit 31 to (case reports or editorial) | 12
33 | 31 not 32 | 216
34 | exp Osteoarthritis, Knee/rh, th [Rehabilitation, Therapy] | 1159
35 | (assistive device$ or adaptive device$).mp. | 918
36 | equipment training.mp. | 68
37 | device training.mp. | 28
38 | exp Occupational Therapy/ | 9182
39 | exp Leisure Activities/ | 126029
40 | exp Accidents, Occupational/pc [Prevention & Control] | 4414
41 | exp Occupational Diseases/pc [Prevention & Control] | 17597
42 | 35 or 36 or 37 or 38 or 39 or 40 or 41 | 156505
43 | 34 and 42 | 115
44 | limit 43 to english language | 102
45 | limit 44 to (case reports or editorial) | 4
46 | 44 not 45 | 98
47 | exp Osteoarthritis, Knee/rh, th [Rehabilitation, Therapy] | 1159
48 | manual therap$.mp. | 825
49 | (mobilization or manipulation).mp. | 83447
50 | exp Traction/ | 5455
51 | exp Musculoskeletal Manipulations/ | 10753
52 | exp Manipulation, Orthopedic/ | 3297
53 | exp “Range of Motion, Articular”/ | 27623
54 | passive range of motion.mp. | 500
55 | 48 or 49 or 50 or 51 or 52 or 53 or 54 | 120477
56 | 47 and 55 | 149
57 | limit 56 to english language | 139
58 | limit 57 to (case reports or editorial) | 7
59 | 57 not 58 | 132
60 | exp osteoarthritis, knee/ | 7686
61 | exp Iontophoresis/ | 6461
62 | exp Electric Stimulation/ | 111459
63 | exp Electric Stimulation Therapy/ | 50928
64 | 61 or 62 or 63 | 166488
65 | 60 and 64 | 83
66 | (ems or fes or hvpc or nmes or tens).mp. | 15294
67 | 60 and 66 | 25
68 | 65 or 67 | 86
69 | limit 68 to english language | 73
70 | limit 69 to (case reports or editorial) | 3
71 | 69 not 70 | 70
72 | Osteoarthritis, Knee/rh, th [Rehabilitation, Therapy] | 1159
73 | exp Osteoarthritis, Knee/ | 7686
74 | exp Exercise Therapy/ | 23991
75 | exp Exercise/ | 90305
76 | exp Exercise Movement Techniques/ | 4266
77 | exp Physical Endurance/ | 20700
78 | (aerobic capacity or aerobic endurance).mp. | 2897
79 | (conditioning or reconditioning).mp. | 78627
80 | propulsion.mp. | 2263
81 | aquatic.mp. | 17409
82 | (gait training or locomotor training).mp. | 564
83 | increased workload.mp. | 361
84 | exp “Range of Motion, Articular”/ | 27623
85 | muscle lengthening.mp. | 145
86 | stretching.mp. | 12145
87 | locomotion training.mp. | 9
88 | exp Physical Therapy Modalities/ | 107756
89 | (implement training or device training or perceptual training).mp. | 151
90 | exp Muscle Strength/ | 12275
91 | (strength training or power training or endurance training).mp. | 4793
92 | exp Postural Balance/ | 11506
93 | body mechanics.mp. | 154
94 | (balance training or coordination training or agility training).mp. | 430
95 | exp Relaxation Therapy/ | 6378
96 | 74 or 75 or 76 or 77 or 78 or 79 or 80 or 81 or 82 or 83 or 84 or 85 or 86 or 87 or 88 or 89 or 90 or 91 or 92 or 93 or 94 or 95 | 354657
97 | 73 and 96 | 1835
98 | limit 97 to english language | 1685
99 | limit 98 to humans | 1670
100 | limit 99 to (case reports or editorial) | 64
101 | 99 not 100 | 1606
102 | exp Osteoarthritis, Knee/rh, th [Rehabilitation, Therapy] | 1159
103 | exp Self-Help Devices/ | 7333
104 | exp Orthopedic Equipment/ | 68716
105 | exp Bandages/ | 17498
106 | (adaptive device$ or assistive device$).mp. | 918
107 | orthotic device$.mp. | 4561
108 | protective device$.mp. | 10548
109 | supportive device$.mp. | 41
110 | 103 or 104 or 105 or 106 or 107 or 108 or 109 | 103142
111 | 102 and 110 | 141
112 | limit 111 to english language | 127
113 | limit 112 to (case reports or editorial) | 8
114 | 112 not 113 | 119
115 | exp osteoarthritis, knee/ | 7686
116 | exp Physical Therapy Modalities/ | 107756
117 | exp Magnetic Field Therapy/ | 4963
118 | exp Cryotherapy/ | 18239
119 | exp Hydrotherapy/ | 16297
120 | exp Ultrasonic Therapy/ | 7813
121 | exp Hot Temperature/tu [Therapeutic Use] | 2594
122 | exp Hyperthermia, Induced/ | 20909
123 | exp Bandages/ | 17498
124 | exp Intermittent Pneumatic Compression Devices/ | 294
125 | exp Stockings, Compression/ | 695
126 | exp Motion Therapy, Continuous Passive/ | 487
127 | 116 or 117 or 118 or 119 or 120 or 121 or 122 or 123 or 124 or 125 or 126 | 163035
128 | 115 and 127 | 659
129 | limit 128 to english language | 576
130 | limit 129 to (case reports or editorial) | 30
131 | 129 not 130 | 546
132 | exp osteoarthritis, knee/ | 7686
133 | exp Treatment Outcome/ | 517052
134 | treatment duration.mp. | 3887
135 | treatment intensity.mp. | 572
136 | exp Patient Care Team/ | 48713
137 | exp Patient Care Planning/ or exp “Continuity of Patient Care”/ or exp Case Management/ | 58119
138 | coordinated care.mp. | 422
139 | exp Combined Modality Therapy/ | 177227
140 | exp Interdisciplinary Communication/ | 7056
141 | interdisciplinary.mp. | 21869
142 | 133 or 134 or 135 or 136 or 137 or 138 or 139 or 140 or 141 | 769089
143 | 132 and 142 | 2125
144 | limit 143 to english language | 1908
145 | limit 144 to (case reports or editorial) | 81
146 | 144 not 145 | 1827
147 | exp osteoarthritis, knee/ | 7686
148 | lower extremity functional scale.mp. | 54
149 | lefs.mp. | 57
150 | arthritis impact measurement scale.mp. | 110
151 | patient specific functional scale.mp. | 41
152 | psfs.mp. | 148
153 | outpatient physical therapy improvement in movement assessment log.mp. | 2
154 | (optimal and log).mp. | 1362
155 | gait speed.mp. | 918
156 | single leg stance.mp. | 220
157 | tandem stance.mp. | 80
158 | manual muscle test.mp. | 134
159 | manual therapy.mp. or exp musculoskeletal manipulations/ | 11060
160 | exp synovitis/us | 285
161 | muscle relaxation.mp. or exp muscle relaxation/ | 27605
162 | quadriceps strengthening.mp. | 74
163 | exp quadriceps muscle/ | 1406
164 | strengthening.mp. | 10584
165 | 163 and 164 | 39
166 | 162 or 165 | 95
167 | patellar taping.mp. | 51
168 | exp patella/ | 7602
169 | taping.mp. | 715
170 | 168 and 169 | 54
171 | 167 or 170 | 70
172 | functional training.mp. | 165
173 | medical device$.mp. | 5591
174 | exp “equipment and supplies”/ | 1001959
175 | device$.mp. | 196430
176 | 174 and 175 | 102928
177 | 173 or 176 | 105509
178 | patient education.mp. or exp patient education/ | 69851
179 | exp hydrotherapy/ or aquatic therapy.mp. | 16313
180 | 148 or 149 or 150 or 151 or 152 or 153 or 154 or 155 or 156 or 157 or 158 or 159 or 160 or 161 or 166 or 171 or 172 or 177 or 178 or 179 | 231690
181 | 147 and 180 | 432
182 | limit 181 to english language | 390
183 | drug management.mp. | 453
184 | exp patient care team/ | 48713
185 | exp delivery of health care, integrated/ | 6888
186 | integrated care.mp. | 1018
187 | exp managed care programs/ | 37913
188 | (managed care or coordinated care).mp. | 28145
189 | exp Patient Education as Topic/ | 62839
190 | exp Health Education/ | 122790
191 | drug surveillance.mp. | 428
192 | exp drug monitoring/ | 11592
193 | 183 or 184 or 185 or 186 or 187 or 188 or 189 or 190 or 191 or 192 | 226362
194 | exp patient compliance/ | 44452
195 | exp patient satisfaction/ | 49973
196 | exp patient care management/ | 459932
197 | 194 or 195 or 196 | 536805
198 | exp migraine disorders/dt | 5882
199 | 193 and 198 | 111
200 | 197 and 198 | 353

Updated search in February 29, 2012 Ovid Technologies, Inc. Email Service Search for: limit 305 to english language Results: 100 Database: Ovid MEDLINE(R) <1946 to February Week 4 2012> Search Strategy:
1. Osteoarthritis, Knee/rh, th [Rehabilitation, Therapy] (1190)
2. exp Osteoarthritis, Knee/ (7907)
3. exp Health Education/ (123620)
4. exp Patient Education as Topic/ (63339)
5. exp Health Knowledge, Attitudes, Practice/ (58629)
6. exp Counseling/ (29342)
7. 3 or 4 or 5 or 6 (193764)
8. 2 and 7 (114)
9. limit 8 to english language (104)
10. limit 9 to (case reports or editorial) (6)
11. 9 not 10 (98)
12. exp Osteoarthritis, Knee/ (7907)
13. exp Exercise Therapy/ (24372)
14. exp Exercise/ (91673)
15. exp Exercise Movement Techniques/ (4330)
16. exp Physical Endurance/ (20945)
17. (aerobic capacity or aerobic endurance).mp. (2938)
18. (conditioning or reconditioning).mp. (79440)
19. propulsion.mp. (2288)
20. aquatic.mp. (17727)
21. (gait training or locomotor training).mp. (578)
22. increased workload.mp. (365)
23. exp “Range of Motion, Articular”/ (28011)
24. muscle lengthening.mp. (146)
25. stretching.mp. (12308)
26. locomotion training.mp. (9)
27. exp Physical Therapy Modalities/ (108793)
28. (implement training or device training or perceptual training).mp. (153)
29. exp Muscle Strength/ (12626)
30. (strength training or power training or endurance training).mp. (4846)
31. exp Postural Balance/ (11704)
32. body mechanics.mp. (156)
33. (balance training or coordination training or agility training).mp. (439)
34. exp Relaxation Therapy/ (6427)
35. 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 (358887)
36. 12 and 35 (1902)
37. limit 36 to english language (1749)
38. limit 37 to humans (1733)
39. limit 38 to (case reports or editorial) (73)
40. 38 not 39 (1660)
41. exp Osteoarthritis, Knee/rh, th [Rehabilitation, Therapy] (1190)
42. exp Self Care/ (34322)
43. exp “Activities of Daily Living”/ (44317)
44. exp Orthopedic Equipment/ (69264)
45. functional training.mp. (167)
46. exp “Wounds and Injuries”/pc [Prevention & Control] (41151)
47. 42 or 43 or 44 or 45 or 46 (185606)
48. 41 and 47 (259)
49. limit 48 to english language (238)
50. limit 49 to (case reports or editorial) (13)
51. 49 not 50 (225)
52. exp Osteoarthritis, Knee/rh, th [Rehabilitation, Therapy] (1190)
53. (assistive device$ or adaptive device$).mp. (930)
54. equipment training.mp. (70)
55. device training.mp. (28)
56. exp Occupational Therapy/ (9232)
57. exp Leisure Activities/ (127534)
58. exp Accidents, Occupational/pc [Prevention & Control] (4437)
59. exp Occupational Diseases/pc [Prevention & Control] (17677)
60. 53 or 54 or 55 or 56 or 57 or 58 or 59 (158167)
61. 52 and 60 (122)
62. limit 61 to english language (107)
63. limit 62 to (case reports or editorial) (5)
64. 62 not 63 (102)
65. exp Osteoarthritis, Knee/rh, th [Rehabilitation, Therapy] (1190)
66. manual therap$.mp. (840)
67. (mobilization or manipulation).mp. (84467)
68. exp Traction/ (5480)
69. exp Musculoskeletal Manipulations/ (10857)
70. exp Manipulation, Orthopedic/ (3318)
71. exp “Range of Motion, Articular”/ (28011)
72. passive range of motion.mp. (503)
73. 66 or 67 or 68 or 69 or 70 or 71 or 72 (121941)
74. 65 and 73 (153)
75. limit 74 to english language (143)
76. limit 75 to (case reports or editorial) (7)
77. 75 not 76 (136)
78. exp Osteoarthritis, Knee/rh, th [Rehabilitation, Therapy] (1190)
79. exp Self-Help Devices/ (7394)
80. exp Orthopedic Equipment/ (69264)
81. exp Bandages/ (17621)
82. (adaptive device$ or assistive device$).mp. (930)
83. orthotic device$.mp. (4608)
84. protective device$.mp. (10616)
85. supportive device$.mp. (42)
86. 79 or 80 or 81 or 82 or 83 or 84 or 85 (103946)
87. 78 and 86 (147)
88. limit 87 to english language (133)
89. limit 88 to (case reports or editorial) (9)
90. 88 not 89 (124)
91. exp osteoarthritis, knee/ (7907)
92. exp Iontophoresis/ (6503)
93. exp Electric Stimulation/ (112571)
94. exp Electric Stimulation Therapy/ (51546)
95. 92 or 93 or 94 (168235)
96. 91 and 95 (85)
97. (ems or fes or hvpc or nmes or tens).mp. (15513)
98. 91 and 97 (25)
99. 96 or 98 (88)
100. limit 99 to english language (75)
101. limit 100 to (case reports or editorial) (3)
102. 100 not 101 (72)
103. exp osteoarthritis, knee/ (7907)
104. exp Treatment Outcome/ (526614)
105. treatment duration.mp. (3967)
106. treatment intensity.mp. (576)
107. exp Patient Care Team/ (49041)
108. exp Patient Care Planning/ or exp “Continuity of Patient Care”/ or exp Case Management/ (58505)
109. coordinated care.mp. (428)
110. exp Combined Modality Therapy/ (179059)
111. exp Interdisciplinary Communication/ (7280)
112. interdisciplinary.mp. (22266)
113. 104 or 105 or 106 or 107 or 108 or 109 or 110 or 111 or 112 (780767)
114. 103 and 113 (2192)
115. limit 114 to english language (1973)
116. limit 115 to (case reports or editorial) (90)
117. 115 not 116 (1883)
118. exp osteoarthritis, knee/ (7907)
119. lower extremity functional scale.mp. (54)
120. lefs.mp. (57)
121. arthritis impact measurement scale.mp. (110)
122. patient specific functional scale.mp. (47)
123. psfs.mp. (153)
124. outpatient physical therapy improvement in movement assessment log.mp. (2)
125. (optimal and log).mp. (1385)
126. gait speed.mp. (949)
127. single leg stance.mp. (221)
128. tandem stance.mp. (80)
129. manual muscle test.mp. (136)
130. manual therapy.mp. or exp musculoskeletal manipulations/ (11170)
131. exp synovitis/us (292)
132. muscle relaxation.mp. or exp muscle relaxation/ (27846)
133. quadriceps strengthening.mp. (76)
134. exp quadriceps muscle/ (1463)
135. strengthening.mp. (10798)
136. 134 and 135 (41)
137. 133 or 136 (98)
138. patellar taping.mp. (52)
139. exp patella/ (7634)
140. taping.mp. (723)
141. 139 and 140 (54)
142. 138 or 141 (71)
143. functional training.mp. (167)
144. medical device$.mp. (5685)
145. exp “equipment and supplies”/ (1010757)
146. device$.mp. (199081)
147. 145 and 146 (104249)
148. 144 or 147 (106884)
149. patient education.mp. or exp patient education/ (70439)
150. exp hydrotherapy/ or aquatic therapy.mp. (16374)
151. 119 or 120 or 121 or 122 or 123 or 124 or 125 or 126 or 127 or 128 or 129 or 130 or 131 or 132 or 137 or 142 or 143 or 148 or 149 or 150 (234130)
152. 118 and 151 (443)
153. limit 152 to english language (401)
154. Osteoarthritis, Knee/rh, th [Rehabilitation, Therapy] (1190)
155. exp Osteoarthritis, Knee/ (7907)
156. exp Health Education/ (123620)
157. exp Patient Education as Topic/ (63339)
158. exp Health Knowledge, Attitudes, Practice/ (58629)
159. exp Counseling/ (29342)
160. 156 or 157 or 158 or 159 (193764)
161. 155 and 160 (114)
162. limit 161 to english language (104)
163. limit 162 to (case reports or editorial) (6)
164. 162 not 163 (98)
165. exp Osteoarthritis, Knee/ (7907)
166. exp Exercise Therapy/ (24372)
167. exp Exercise/ (91673)
168. exp Exercise Movement Techniques/ (4330)
169. exp Physical Endurance/ (20945)
170. (aerobic capacity or aerobic endurance).mp. (2938)
171. (conditioning or reconditioning).mp. (79440)
172. propulsion.mp. (2288)
173. aquatic.mp. (17727)
174. (gait training or locomotor training).mp. (578)
175. increased workload.mp. (365)
176. exp “Range of Motion, Articular”/ (28011)
177. muscle lengthening.mp. (146)
178. stretching.mp. (12308)
179. locomotion training.mp. (9)
180. exp Physical Therapy Modalities/ (108793)
181. (implement training or device training or perceptual training).mp. (153)
182. exp Muscle Strength/ (12626)
183. (strength training or power training or endurance training).mp. (4846)
184. exp Postural Balance/ (11704)
185. body mechanics.mp. (156)
186. (balance training or coordination training or agility training).mp. (439)
187. exp Relaxation Therapy/ (6427)
188. 166 or 167 or 168 or 169 or 170 or 171 or 172 or 173 or 174 or 175 or 176 or 177 or 178 or 179 or 180 or 181 or 182 or 183 or 184 or 185 or 186 or 187 (358887)
189. 165 and 188 (1902)
190. limit 189 to english language (1749)
191. limit 190 to humans (1733)
192. limit 191 to (case reports or editorial) (73)
193. 191 not 192 (1660)
194. exp Osteoarthritis, Knee/rh, th [Rehabilitation, Therapy] (1190)
195. exp Self Care/ (34322)
196. exp “Activities of Daily Living”/ (44317)
197. exp Orthopedic Equipment/ (69264)
198. functional training.mp. (167)
199. exp “Wounds and Injuries”/pc [Prevention & Control] (41151)
200. 195 or 196 or 197 or 198 or 199 (185606)
201. 194 and 200 (259)
202. limit 201 to english language (238)
203. limit 202 to (case reports or editorial) (13)
204. 202 not 203 (225)
205. exp Osteoarthritis, Knee/rh, th [Rehabilitation, Therapy] (1190)
206. (assistive device$ or adaptive device$).mp. (930)
207. equipment training.mp. (70)
208. device training.mp. (28)
209. exp Occupational Therapy/ (9232)
210. exp Leisure Activities/ (127534)
211. exp Accidents, Occupational/pc [Prevention & Control] (4437)
212. exp Occupational Diseases/pc [Prevention & Control] (17677)
213. 206 or 207 or 208 or 209 or 210 or 211 or 212 (158167)
214. 205 and 213 (122)
215. limit 214 to english language (107)
216. limit 215 to (case reports or editorial) (5)
217. 215 not 216 (102)
218. exp Osteoarthritis, Knee/rh, th [Rehabilitation, Therapy] (1190)
219. manual therap$.mp. (840)
220. (mobilization or manipulation).mp. (84467)
221. exp Traction/ (5480)
222. exp Musculoskeletal Manipulations/ (10857)
223. exp Manipulation, Orthopedic/ (3318)
224. exp “Range of Motion, Articular”/ (28011)
225. passive range of motion.mp. (503)
226. 219 or 220 or 221 or 222 or 223 or 224 or 225 (121941)
227. 218 and 226 (153)
228. limit 227 to english language (143)
229. limit 228 to (case reports or editorial) (7)
230. 228 not 229 (136)
231. exp Osteoarthritis, Knee/rh, th [Rehabilitation, Therapy] (1190)
232. exp Self-Help Devices/ (7394)
233. exp Orthopedic Equipment/ (69264)
234. exp Bandages/ (17621)
235. (adaptive device$ or assistive device$).mp. (930)
236. orthotic device$.mp. (4608)
237. protective device$.mp. (10616)
238. supportive device$.mp. (42)
239. 232 or 233 or 234 or 235 or 236 or 237 or 238 (103946)
240. 231 and 239 (147)
241. limit 240 to english language (133)
242. limit 241 to (case reports or editorial) (9)
243. 241 not 242 (124)
244. exp osteoarthritis, knee/ (7907)
245. exp Iontophoresis/ (6503)
246. exp Electric Stimulation/ (112571)
247. exp Electric Stimulation Therapy/ (51546)
248. 245 or 246 or 247 (168235)
249. 244 and 248 (85)
250. (ems or fes or hvpc or nmes or tens).mp. (15513)
251. 244 and 250 (25)
252. 249 or 251 (88)
253. limit 252 to english language (75)
254. limit 253 to (case reports or editorial) (3)
255. 253 not 254 (72)
256. exp osteoarthritis, knee/ (7907)
257. exp Treatment Outcome/ (526614)
258. treatment duration.mp. (3967)
259. treatment intensity.mp. (576)
260. exp Patient Care Team/ (49041)
261. exp Patient Care Planning/ or exp “Continuity of Patient Care”/ or exp Case Management/ (58505)
262. coordinated care.mp. (428)
263. exp Combined Modality Therapy/ (179059)
264. exp Interdisciplinary Communication/ (7280)
265. interdisciplinary.mp. (22266)
266. 257 or 258 or 259 or 260 or 261 or 262 or 263 or 264 or 265 (780767)
267. 256 and 266 (2192)
268. limit 267 to english language (1973)
269. limit 268 to (case reports or editorial) (90)
270. 268 not 269 (1883)
271. exp osteoarthritis, knee/ (7907)
272. lower extremity functional scale.mp. (54)
273. lefs.mp. (57)
274. arthritis impact measurement scale.mp. (110)
275. patient specific functional scale.mp. (47)
276. psfs.mp. (153)
277. outpatient physical therapy improvement in movement assessment log.mp. (2)
278. (optimal and log).mp. (1385)
279. gait speed.mp. (949)
280. single leg stance.mp. (221)
281. tandem stance.mp. (80)
282. manual muscle test.mp. (136)
283. manual therapy.mp. or exp musculoskeletal manipulations/ (11170)
284. exp synovitis/us (292)
285. muscle relaxation.mp. or exp muscle relaxation/ (27846)
286. quadriceps strengthening.mp. (76)
287. exp quadriceps muscle/ (1463)
288. strengthening.mp. (10798)
289. 287 and 288 (41)
290. 286 or 289 (98)
291. patellar taping.mp. (52)
292. exp patella/ (7634)
293. taping.mp. (723)
294. 292 and 293 (54)
295. 291 or 294 (71)
296. functional training.mp. (167)
297. medical device$.mp. (5685)
298. exp “equipment and supplies”/ (1010757)
299. device$.mp. (199081)
300. 298 and 299 (104249)
301. 297 or 300 (106884)
302. patient education.mp. or exp patient education/ (70439)
303. exp hydrotherapy/ or aquatic therapy.mp. (16374)
304. 272 or 273 or 274 or 275 or 276 or 277 or 278 or 279 or 280 or 281 or 282 or 283 or 284 or 285 or 290 or 295 or 296 or 301 or 302 or 303 (234130)
305. 271 and 304 (443)
306. limit 305 to english language (401)