# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: We would like to thank the librarian, Judy Stanke, M.A., for her contribution to the literature search; Rema Ramakrishnan, M.P.H., and Jae Young Choi, Ph.D. candidate, for their assistance with the literature search and data abstraction; Jeannine Ouellette for her help in writing the report; Marilyn Eells and Nancy Russell for editing and formatting the report; and Christa Prodzinski and Kirsten Johnson for assistance with data entry, quality control, and formatting tables.