# Abbreviations

ADL: Activities of Daily Living
AHRQ: Agency for Healthcare Research and Quality
AMED: Allied and Complementary Medicine
APTA: American Physical Therapy Association
BMI: Body Mass Index
CAS(K): Clinical Assessment Study of the Knee
CHECK: Cohort Hip and Cohort Knee Study
CI: Confidence Interval
EQ-5D: European Quality of Life-5 Dimensions
FAST: Fitness Arthritis and Seniors Trial
FDA: Food and Drug Administration
HSS: Hospital for Special Surgery
IADL: Instrumental Activities of Daily Living
K/L: Kellgren and Lawrence Scale
MAK: Mechanical Factors in Arthritis of the Knee
MCID: Minimum Clinically Important Difference
MeSH: Medical Subject Heading
MVC: Maximum voluntary contraction of quadriceps
OA: Osteoarthritis
OARSI: Osteoarthritis Research Society International
OMERACT: Outcomes Measures in Rheumatoid Arthritis Clinical Trials
OR: Odds Ratio
PASS: Patient Acceptable Symptom State
PEDro: Physiotherapy Evidence Database
PEMF: Pulsed Electromagnetic Fields
PICOT: Population, Intervention, Comparison, Outcomes, Timing
PT: Physical Therapy
QUADAS: Quality Assessment of Diagnostic Accuracy Studies
QWB: Quality of Well Being
RCT: Randomized Controlled Trial
ROC: Receiver Operating Characteristic
ROM: Range of Motion
SF-36: 36-Item Short Form Health Survey
SMD: Standard Mean Difference
TEP: Technical Expert Panel
TUG: Timed Up and Go Test
VAS: Visual Analog Scale
WOMAC: Western Ontario and McMaster Universities Osteoarthritis Index