# Results

## Overview

The search and selection of articles are summarized in the study flow diagram (Figure 2). Of the 1,096 citations identified at the title and abstract level in the original search, 215 articles met inclusion criteria and were selected for further review of the full text. From updated searches and peer reviewer suggested citations, an additional 2,352 citations were identified, and 164 of these met inclusion criteria and were selected for full-text review. Of the 379 articles reviewed at the full-text level, a total of 90 studies met inclusion criteria.

Figure 2 Study flow diagram: Treatment for hepatitis C virus infection in adults

This figure is a flow chart that summarizes the search and selection of articles related to treatment for hepatitis C virus infection in adults. Citations were identified through bibliographnic databases, including CCRCT, CDSR, MEDLINE, Scopus, and PsychINFO, as well as through other sources, including experts, reference lists and gray literature. For the treatment of hepatitis C virus infection in asymptomatic adults: there were 1,177 abstracts of potentially relevant articles reviewed in the original search. After removing 4 duplicates and 883 abstracts that were not relevant to key questions, and 46 additional studies were added by hand searches, a set of 294 articles met inclusion criteria and were selected for further review of the full text. From an updated search and peer reviewer suggested citations, an additional 1,719 citations were identified, and 36 of these met inclusion criteria and were selected for full-text review. Studies were excluded at the full-text level for the following reasons: wrong population, wrong intervention, wrong outcomes, wrong study design for key question, no original data, wrong drug, wrong population, wrong study design, or not relevant. Of the 330 articles reviewed at the full-text level, a total of 77 studies met inclusion criteria. The bottom of the diagram depicts the number of studies that apply to each key question, and a note is shown in the total includes box that explains that some studies apply to more than one question.

## Key Question 1a What is the comparative effectiveness of antiviral treatment in improving health outcomes in patients with HCV infection?

- No randomized trial or observational study evaluated the comparative effectiveness of current antiviral treatment regimens for chronic HCV infection on improving long-term clinical outcomes (strength of evidence: insufficient).
- Three trials that compared current antiviral regimens found no differences in risk of short-term mortality, but reported very few (20 total) events (strength of evidence: low).
- One open-label randomized trial of patients with genotype 4 infection found dual therapy with pegylated interferon alfa-2a plus ribavirin associated with statistically significant, slightly better short-term scores on some generic and liver disease-specific quality of life assessments than dual therapy with pegylated interferon alfa-2b plus ribavirin (strength of evidence: low).

No trial evaluated comparative effects of current antiviral treatment regimens for chronic HCV infection (dual therapy with pegylated interferon alfa-2a or alfa-2b plus ribavirin or triple therapy with pegylated interferon alfa-2a or alfa-2b, ribavirin, and a protease inhibitor) on risk of long-term clinical outcomes.

Three trials reported short-term mortality (through 6 months after the completion of antiviral therapy), but reported few deaths (20 total), resulting in very imprecise estimates (Appendix H: Evidence Table 1). One large trial found no difference between dual therapy with standard dose pegylated interferon alfa-2b (1.5 mcg/kg/week) plus ribavirin versus pegylated interferon alfa-2a plus ribavirin in risk of short-term mortality (risk ratio [RR] 0.85, 95% confidence interval (CI) 0.26 to 2.8), based on 11 deaths in over 2000 subjects.22 Another trial found no difference between triple therapy with boceprevir and dual therapy in risk of short-term all-cause mortality (RR 0.25, 95% CI 0.03 to 2.2), but only reported 5 deaths in over 700 patients.32 One trial of response-guided triple therapy with telaprevir versus dual therapy reported four deaths in over 1088 patients, resulting in a very imprecise estimate (RR 1.5, 95% CI 0.16 to 14).51

Two trials evaluated comparative effects of current antiviral regimens for chronic HCV infection on short-term quality of life (Appendix H: Evidence Table 11).52, 53 One trial of patients with genotype 4 infection found dual therapy with pegylated interferon alfa-2a plus ribavirin associated with slightly higher (better) scores on some Short-Form 36 (SF-36) health survey subscales than dual therapy with pegylated interferon alfa-2b plus ribavirin 24 weeks after the end of treatment (differences of 3.2 to 5.7 points on the Bodily Pain, Vitality, Social Functioning, and Role Emotional subscales, each on a 0 to 100 scale).53 Dual therapy with pegylated interferon alfa-2a was also associated with slightly higher scores on the Physical Component Summary score (3.2, points, p<0.02), but there was no difference on the Mental Component Summary score, or on five of six domains on the Chronic Liver Disease questionnaire, though dual therapy with pegylated interferon alfa-2a plus ribavirin was associated with a slightly higher overall score (difference 0.4 point on a 1 to 7 scale, p=0.02). The trial was open-label and patients do not appear to have been blinded to virologic response status, which could have affected quality of life assessments. A trial of patients with genotype 1 infection with undetectable HCV-RNA after 24 weeks of pegylated interferon alfa-2a plus ribavirin found continuation of dual therapy for another 24 weeks associated with worse quality of life scores at the end of treatment than pegylated interferon alone for the last 24 weeks, but the clinical relevance of this finding is limited since the shorter regimen was associated with lower likelihood of achieving an SVR and is not considered the standard of care for genotype 1 infection.52

## Key Question 1b How does the comparative effectiveness of antiviral treatment for health outcomes vary according to patient subgroup characteristics, including but not limited to HCV genotype, age, race, sex, stage of disease or genetic markers?

- No randomized trial or observational study evaluated comparative effects of current antiviral treatment regimens on any clinical outcomes in patients stratified by HCV genotype, age, race, sex, stage of disease, genetic markers, or other factors (strength of evidence: insufficient).

## Key Question 2a What is the comparative effectiveness of antiviral treatments on intermediate outcomes, such as the rate of SVR or histologic changes in the liver?

### Dual Therapy With Pegylated Interferon Alfa-2a or Alfa-2b Plus Ribavirin

- Seven trials found dual therapy with standard doses of pegylated interferon alfa-2b plus ribavirin associated with lower likelihood of achieving an SVR than pegylated interferon alfa-2a plus ribavirin (pooled RR 0.87, 95% CI 0.80 to 0.95, I^2^=27.4%), with an absolute difference in SVR rates of 8 percentage points (95% CI 3 to 14) (strength of evidence: moderate).

### Dual Therapy With Pegylated Interferon Alfa-2a or Alfa-2b Plus Ribavirin: Duration Effects

- Two trials of patients with genotype 2 or 3 infection found no difference in likelihood of achieving an SVR between 48 versus 24 weeks of dual therapy with pegylated interferon alfa-2a plus ribavirin (pooled RR 0.97, 95% CI 0.84 to 1.11, I^2^=42.7%) (strength of evidence: moderate).
- Four trials of patients with genotype 2 or 3 infection found 24 weeks of dual therapy with pegylated interferon (alfa-2a or alfa-2b) more effective than 12–16 weeks for achieving an SVR (pooled RR 1.15, 95% CI 1.02 to 1.29, I^2^=79.5%). Relative risk estimates ranged from 1.0 to 1.3 (strength of evidence: moderate).
- Three trials of patients with genotype 2 or 3 infection with a rapid virologic response (undetectable HCV-RNA by week 4) found no differences between 24 versus 12–16 weeks of dual therapy with pegylated interferon (alfa-2a or alfa-2b) plus ribavirin (pooled RR 0.99, 95% CI 0.86 to 1.14, I^2^=66.7%). Relative risk estimates ranged from 0.89 to 1.1 (strength of evidence: moderate).

### Dual Therapy With Pegylated Interferon Alfa-2a or Alfa-2b Plus Ribavirin: Dose Effects

- Six trials of patients with genotype 2 or 3 infection found lower doses of pegylated interferon alfa-2b (0.75–1.0 mcg/kg or 50 mcg) associated with lower likelihood of achieving an SVR than higher doses (1.5 mcg/kg or 100–150 mcg) (pooled RR 0.90, 95% CI 0.81 to 0.99, I^2^=20.2%) (strength of evidence: moderate).
- Three trials of patients with genotype 2 or 3 infection who did not specifically have advanced fibrosis or cirrhosis found no clear difference in likelihood of SVR between lower doses of ribavirin (400 or 800 mg flat dose or 600 to 800 mg weight-based dose) versus higher doses (800 or 1200 mg flat dose or 800 to 1400 mg weight-based dose) (strength of evidence: moderate).
- One small trial of patients with genotype 2 or 3 infection (N=60) and advanced fibrosis or cirrhosis (Ishak stage 4–6) found 600 to 800 mg daily of ribavirin associated with lower likelihood of SVR than 1000 to 1200 mg daily (45 vs. 72 percent, RR 0.62, 95% C I 0.40 to 0.98) (strength of evidence: low).

### Trials of Triple Therapy With Pegylated Interferon Alfa-2b, Ribavirin, and Boceprevir

- Two trials of patients with HCV genotype 1 infection found dual therapy lead-in with pegylated interferon alfa-2b plus ribavirin for 4 weeks followed by 44 weeks of triple therapy with boceprevir associated with higher likelihood of SVR than dual therapy for 48 weeks (pooled RR 1.81, 95% CI 1.58 to 2.06, I^2^=0.0%), with an absolute increase in SVR rate of 31 percentage points (95% CI 23 to 39) (strength of evidence: moderate).
- One trial of patients with genotype 1 infection found 48 weeks of triple therapy with boceprevir using low dose of ribavirin (400–1000 mg daily) associated with a non–statistically significant trend towards lower likelihood of SVR than 48 weeks of triple therapy with a standard ribavirin dose (800–1400 mg daily) (36 vs. 50 percent, RR 0.71, 95% CI 0.39 to 1.3) (strength of evidence: low).

### Trials of Triple Therapy With Pegylated Interferon Alfa-2a or Alfa-2b, Ribavirin, and Telaprevir

- Three trials of patients with genotype 1 infection found triple therapy with telaprevir for 24 weeks (12 weeks of pegylated interferon alfa-2a or alfa-2b, ribavirin, and telaprevir followed by 12 weeks of pegylated interferon alfa-2a or alfa-2b plus ribavirin) associated with higher likelihood of SVR than dual therapy with pegylated interferon alfa-2a or alfa-2b plus ribavirin for 48 weeks (pooled RR 1.48, 95% CI 1.26 to 1.75, I^2^=0.0%), with an absolute increase in SVR rate of 22 percentage points (95% CI 13 to 31) (strength of evidence: moderate).
- One trial of patients with genotype 1 infection found no difference in likelihood of SVR between triple therapy with pegylated interferon alfa-2a, ribavirin, and telaprevir for 12 weeks versus dual therapy with pegylated interferon alfa-2a plus ribavirin for 48 weeks (strength of evidence: moderate).
- One trial of patients with genotype 1 infection found response-guided triple therapy with telaprevir (pegylated interferon alfa-2a, ribavirin, and telaprevir for 8 or 12 weeks followed by response-guided dual therapy with pegylated interferon alfa-2a plus ribavirin for an additional 12 or 36 weeks) associated with higher likelihood of SVR than dual therapy with pegylated interferon alfa-2a plus ribavirin for 48 weeks (RR 1.6, 95% CI 1.4 to 1.9), with an absolute increase in SVR rate ranging from 25 to 31 percent. The regimen with 8 weeks of telaprevir was associated with a slightly lower SVR rate than the 12 week telaprevir regimen (69 vs. 75 percent) (strength of evidence: low).
- One trial of patients with genotype 1 infection found no difference in likelihood of SVR between triple therapy with telaprevir for 48 weeks (12 weeks of triple therapy with pegylated interferon alfa-2a, ribavirin, and telaprevir followed by 36 weeks of dual therapy with pegylated interferon alfa-2a plus ribavirin) versus triple therapy with telaprevir for 24 weeks (12 weeks of triple therapy followed by 12 weeks of dual therapy) (strength of evidence: low).
- One trial of response-guided triple therapy with telaprevir (24 or 48 weeks, based on absence or presence of HCV-RNA from weeks 4 through 20) found similar SVR rates (81–85 percent) for regimens that varied on telaprevir dose (750 mg three times daily vs. 1125 mg two times daily) and type of pegylated interferon (alfa-2a or alfa-2b) (strength of evidence: low).
- One trial of patients with an extended rapid virologic response to initial triple therapy with telaprevir reported similar high (92 and 88 percent) SVR rates (92 and 88 percent) in patients randomized to a total of 24 or 48 weeks of therapy (strength of evidence: low).

### Dual Therapy With Pegylated Interferon Alfa-2a Plus Ribavirin Compared With Dual Therapy With Pegylated Interferon Alfa-2b Plus Ribavirin

Ten trials that directly compared dual therapy with pegylated interferon alfa-2a plus ribavirin to dual therapy with pegylated interferon alfa-2b plus ribavirin in patients with genotypes 1, 2, or 3 infection met inclusion criteria (Table 2, Appendix H: Evidence Table 1).20–23, 53–58 Two of these trials were published only as abstracts and were included only in sensitivity analyses; we could not adequately assess their quality due to limited information in the abstracts.54, 56 One other trial compared pegylated interferon alfa-2a versus pegylated interferon alfa-2b as part of response-guided triple therapy with telaprevir and was also only included in sensitivity analysis.59 One trial enrolled a mix of treatment naïve and treatment experienced patients but reported SVR in the treatment-naïve subgroup.57 Of the eight trials that could be quality rated, two21, 58 were rated poor quality and six were rated fair quality (Appendix H: Evidence Table 2). Frequent methodologic shortcomings were open-label design,20, 21, 23, 53, 55, 57 high or unclear loss to followup,20–23 and unclear or inadequate methods of allocation concealment.21, 23, 53, 55, 57, 58 Sample sizes ranged from 66 to 3,070. Five trials, including the trial that compared triple therapy regimens, only enrolled patients with genotype 1 HCV infection;22, 55, 57–59 the others enrolled either a mix of genotypes or a specific genotype other than genotype 1. The proportion of patients with cirrhosis at baseline ranged from <5–20 percent,20, 23, 59, 60 and the proportion of patients with elevated transaminases ranged from 60–100 percent20, 21, 23, 53, 58, 60 in trials that reported this information. All but two trials54, 57 included a comparison of a standard dose of pegylated interferon alfa-2a (180 mcg/week) with a standard dose of pegylated interferon alfa-2b (1.5 mcg/kg/week). One trial evaluated multiple pegylated interferon alfa-2b doses.22 Ribavirin dosing varied across studies. All trials used weight-based dosing of ribavirin except for one, which used an 800 mg daily flat dose (it also enrolled only genotype 3 patients).54 Three trials used different ribavirin doses with pegylated interferon alfa-2a and alfa-2b.22, 23, 59 Nine trials evaluated fixed-duration regimens, with 48 weeks of treatment for genotypes 1 or 4 and 24 weeks for genotypes 2 or 3.^20, 21, 23, 53–58^

Table 2 Trials of dual therapy with pegylated interferon alfa-2a plus ribavirin versus dual therapy with pegylated interferon alfa-2b plus ribavirin

Trial Country N Quality | Population Characteristics | Genotype Mix | Weekly Pegylated Interferon Dose | Daily Ribavirin Dose | Duration (weeks) | Sustained Virologic Response Rate
Ascione, 2010^20^ Italy N=320 Quality: Fair | A vs. B Age (mean): 51 vs. 49 years Female: 49% vs. 61% Race: Not reported Cirrhosis: 21% vs. 16% Minimal or no fibrosis: Not reported Elevated transaminases: 100% | ~60% genotype 1 or 4 | A. Alfa-2a 180 mcg B. Alfa-2b 1.5 mcg/kg | 1000–1200 mg | 24–48 by genotype | A. 69% B. 54%
Escudero, 2008^21^ Spain N=183 Quality: Poor | A vs. B Age (mean): 44 vs. 44 years Female: 30% vs. 39% Race: Not reported Cirrhosis: Not reported Minimal or no fibrosis: Not reported (100% had at least periportal fibrosis) Elevated transaminases: 100% | ~75% genotype 1 or 4 | A. Alfa-2a 180 mcg B. Alfa-2b 1.5 mcg/kg | 800–1200 mg | 24–48 by genotype | A. 66% B. 62%
Kamal, 2011^53^ Egypt N=217 Quality: Fair | A vs. B Age (mean): 42 vs. 41 years Female: 46% vs. 56% Race: Not reported Cirrhosis: Not reported Minimal or no fibrosis: Not reported Elevated transaminases: 100% | 100% genotype 4 | A. Alfa-2a 180 mcg B. Alfa-2b 1.5 mcg/kg | 1000–1200 mg | 48 | A. 71% B. 55%
Khan, 2007^54^ Pakistan N=66 Quality: Not assessed^b^ | A vs. B Age: Not reported Female: Not reported Race: Not reported Cirrhosis: Not reported Minimal or no fibrosis: Not reported Elevated transaminases: Not reported | 100% genotype 3 | A. Alfa-2a 180 mcg B. Alfa-2b 1.0 mcg/kg | 800 mg | 24 | A. 79% B. 82%
Mach 2011^55^ Poland N=260 Quality: Fair | A vs. B Age: 44 vs. 45.2 years Female: 37.7% vs. 42% Race: Not reported (Polish centers) Cirrhosis: Not reported Minimal or no fibrosis: Not reported (78% vs. 73% F0–F2 fibrosis) Elevated transaminases: Not reported | 100% genotype 1b | A: Alfa-2a 180 mcg B:Alfa-2b 1.5 mg/kg | 1000–1200 mg | 48 | A. 49% B. 44%
Magni, 2009^56^ Italy N=218 Quality: Not assessed^b^ | A vs. B Age: Not reported Female: Not reported Race: Not reported Cirrhosis: Not reported Minimal or no fibrosis: Not reported Elevated transaminases: Not reported | ~55% genotype 1 or 4 | A. Alfa-2a 180 mcg B. Alfa-2b 1.5 mcg/kg | 10.5 mg/kg | 24–48 by genotype | A. 68% B. 67%
Marcellin, 2011^59,a^ Europe N=161 Quality: Fair | A vs. B vs. C vs. D Age (median): 47 vs. 46 vs. 40 vs. 49 years Female: 50% vs. 52% vs. 48% vs. 51 Non-White race: 10% vs. 10% vs. 10% vs. 8% Cirrhosis: 2.5% vs. 2.4% vs. 0% vs. 5.1% Minimal or no fibrosis: 38% vs. 36% vs. 55% vs. 28% Elevated transaminases: Not reported | 100% genotype 1 | A. Alfa-2a 180 mcg B. Alfa-2b 1.5 mcg/kg C. Alfa-2a 180 mcg D. Alfa-2b 1.5 mcg/kg | A. 1000–1200 mg B. 800–1200 mg C. 1000–1200 mg D. 800–1200 mg | 24/48 | A. 85% B. 81% C. 83% D. 82%
McHutchison, 2008 (IDEAL)60 U.S. N=3070 Quality: Fair | A vs. B vs. C Age (mean): 48 vs. 48 vs. 48 years Female: 40% vs. 40% vs. 41% Non-White race: 29% vs. 28% vs. 29% Cirrhosis: Not reported (10% vs. 11% vs. 11% severe fibrosis or cirrhosis) Minimal or no fibrosis: Not reported Elevated transaminases: 80% vs. 81% vs. 81% | 100% genotype 1 | A. Alfa-2a 180 mcg B. Alfa-2b 1.5 mcg/kg C. Alfa-2b 1.0 mcg/kg | A. 1000–1200 mg B. 800–1400 mg C. 800–1400 mg | 48 | A. 41% B. 40% C. 38%
Miyase, 2012^57^ Japan N=201 Quality: Fair | A vs. B Age mean: 59.2 vs. 58.9 years Female: 61.4% vs. 60% Nonwhite race: Not reported Cirrhosis: 20% vs. 17% Minimal or no fibrosis: Not reported Elevated transaminases: Not reported | 100% genotype 1 | A: Alfa-2a 180 mcg B: Alfa-2b 60–150 mcg/kg (weight-based) | 600–1000 mg | 48 | A. 66% B. 51%
Rumi, 2010^23^ Italy N=431 Quality: Fair | A vs. B Age (mean): 52 vs. 53 years Female: 40% vs. 45% Race: Not reported Cirrhosis: 20% vs. 18% Minimal or no fibrosis: Not reported Elevated transaminases (>2 times upper limit of normal): 59% vs. 59% | 41% genotype 1 33% genotype 2 15% genotype 3 10% genotype 4 | A. Alfa-2a 180 mcg B. Alfa-2b 1.5 mcg/kg | Genotype 1/4: A. 1000–1200 mg/day for 48 weeks B. 800–1200 mg/day for 48 weeks Genotype 2/3: A. 800 mg/day for 24 weeks B. 800–1200 mg/day for 24 weeks | 24–48 by genotype | A: 66% B: 54%
Yenice, 2006^58^ Turkey N=74 Quality: Poor | A vs. B Age (mean): 48 vs. 51 years Female: 35% vs. 27% Race: Not reported Cirrhosis: Not reported Minimal or no fibrosis: Not reported (all patients had at least minimal fibrosis) Elevated transaminases: 70% vs. 76% | 100% genotype 1 (1a vs. 1b vs. 1c) | A. Alfa-2a 180 mcg B. Alfa-2b 1.5 mcg/kg | 800–1200 mg | 24–48 by genotype | A. 49% B. 35%

Note: Cirrhosis = METAVIR F4, Ishak 5–6, or equivalent. Minimal or no fibrosis=METAVIR F0–F1, Ishak 0–2, or equivalent.

a All arms included 12 weeks of telaprevir; because this trial compared triple therapy regimens it was excluded from the primary analysis and only included in sensitivity analysis.

b Published as abstract only; only included in sensitivity analysis.

Dual therapy with a standard dose of pegylated interferon alfa-2b (1.5 mcg/kg/week) plus ribavirin was associated with slightly lower likelihood of achieving an SVR than a standard dose of pegylated interferon alfa-2a (180 mcg/week) plus ribavirin (seven trials, pooled RR 0.87, 95% CI 0.80 to 0.95, I^2^=27.4%) (Figure 3).20–23, 53, 55, 58 The pooled absolute reduction in likelihood of SVR was 8 percentage points (95% CI 3 to 14). Results were similar when the meta-analysis included the trial59 that evaluated pegylated interferon alfa-2b versus pegylated interferon alfa-2a as part of a triple therapy regimen with telaprevir and ribavirin (eight trials, pooled RR 0.89, 95% CI 0.82 to 0.96, I^2^=26%) and a trial56 only available as a conference abstract (nine trials, pooled RR 0.90, 95% CI 0.83 to 0.97, I^2^=25%), or excluded two poor-quality trials (five trials, pooled RR 0.86, 95% CI 0.78 to 0.95, I^2^=47%).21, 58 Two trials, one published only as an abstract, compared only a standard dose of pegylated interferon alfa-2a (180 mcg weekly) versus nonstandard doses of pegylated interferon alfa-2b (1.0 mcg/kg/week or 60–150 mcg/week).54, 57 Pooled estimates were similar when these trials were included in the analysis (nine trials, pooled RR 0.88, 95% CI 0.82 to 0.95, I^2^=22%).

Figure 3 Sustained virologic response: Dual therapy with pegylated interferon alfa-2b plus ribavirin versus dual therapy with pegylated interferon alfa-2a plus ribavirin (standard doses of pegylated interferon only)

Figure 3 is a forest plot (i.e., a graph that depicts a meta-analysis plot) showing the individual and pooled relative risks and 95% confidence intervals (random effects model) from 8 trials for the comparison of dual therapy with pegylated interferon alfa-2b plus ribavirin versus dual therapy with pegylated interferon alfa-2a plus ribavirin on sustained virological response. In the center of the graph is a solid vertical line corresponding to no effect. The individual studies are depicted at varying distances along this line as horizontal lines with a solid square in the middle. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The pooled effect is represented by a diamond at the bottom of the graph. Based on trials that evaluated standard doses of pegylated interferon, pegylated interferon alfa-2b was associated with slightly lower likelihood of achieving an SVR compared to pegylated interferon alfa-2a. Relative risk estimates ranged from 0.72 (95% confidence interval 0.42 to 1.25) to 0.97 (95% confidence interval 0.88 to 1.08). The pooled relative risk was 0.87, with a 95% confidence interval of 0.80–0.95. Heterogeneity was minimal, I-squared = 27.4%, p = 0.220

The largest head-to-head trial was the Individualized Dosing Efficacy vs. Flat Dosing to Assess Optimal Pegylated Interferon Therapy (IDEAL) study (n=3070, compared with 66 to 477 in the other trials).22 It was rated fair quality because loss to followup exceeded 20 percent. A three-armed trial, IDEAL randomized patients with HCV genotype 1 infection to one of two doses of pegylated interferon alfa-2b (1.0 mcg/kg/week or 1.5 mcg/kg/week) plus ribavirin 800 to1400 mg daily (800 mg 40 to 65 kg; 1000 mg >65 to 85 kg; 1200 mg >85 to 105 kg; 1400 >105 to 125 kg) or pegylated interferon alfa-2a 180 mcg/week plus ribavirin 1000 to 1200 mg/day (1000 mg <75 kg; 1200 mg ≥75 kg). Overall, SVR rates were similar at 38–41 percent in the three arms. However, differences in ribavirin dosing could have affected treatment comparability. Excluding IDEAL22 had little effect on the pooled estimate and eliminated statistical heterogeneity (six trials, pooled RR 0.83, 95% CI 0.76 to 0.90, I^2^= 0%) (Figure 4).20, 21, 23, 53, 55, 58

Figure 4 Sustained virologic response: Dual therapy with pegylated interferon alfa-2b plus ribavirin versus dual therapy with pegylated interferon alfa-2a plus ribavirin (excluding trials with differential ribavirin dosing or that evaluated triple therapy regimens)

Figure 4 is a forest plot (i.e., a graph that depicts a meta-analysis plot) showing the individual and pooled relative risks and 95% confidence intervals (random effects model) from 6 trials for the comparison of dual therapy with pegylated interferon alfa-2b plus ribavirin versus dual therapy with pegylated interferon alfa-2a plus ribavirin on sustained virological response excluding trials with differential ribavirin dosing. In the center of the graph is a solid vertical line corresponding to no effect. The individual studies are depicted at varying distances along this line as horizontal lines with a solid square in the middle. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The pooled effect is represented by a diamond at the bottom of the graph. Excluding these trials had little effect on estimates, though statistical heterogeneity was slightly reduced. Relative risk estimates ranged from 0.72 (95% confidence interval 0.42 to 1.25) to 0.94 (95% confidence interval 0.76 to 1.17). The pooled relative risk for SVR, pegylated interferon alfa-2b vs. alfa-2a was 0.83, with a 95% confidence interval of 0.76 to 0.90. I-squared = 0%, p = 0.765

### Dual Therapy With Pegylated Interferon Alfa-2a or Alfa-2b Plus Ribavirin: Duration Effects

Eleven trials compared effects of different treatment durations of dual therapy with pegylated interferon (alfa-2a or alfa-2b) plus ribavirin on SVR rates in patients with HCV genotype 2 or 3 infection (Table 3, Appendix H: Evidence Table 5).61–71 Nine trials61, 62, 64–70 only enrolled patients with genotype 2 or 3 infection and the other two63, 71 reported results in the subgroup of patients with genotype 2 or 3 infection. Sample sizes ranged from 117 to 1,465 subjects. One trial68 was rated good quality, one trial poor quality,66 and the remainder fair quality (Appendix H: Evidence Table 6). Common methodological shortcomings included open-label design61, 62, 64, 65, 67, 70–72 and inadequately described randomization or treatment allocation procedures62, 64–67, 69–71 One trial also reported high attrition.66 Most trials evaluated standard dosing of pegylated interferon alfa-2a (180 mcg/week) and pegylated interferon alfa-2b (1.5 mcg/kg/week), although ribavirin dosing varied across the trials.

Table 3 Trials on effects of duration with dual therapy with pegylated interferon (alfa-2a or alfa-2b) plus ribavirin^a^

Trial Country N Quality | Population Characteristics | Percent Genotype 2 or 3 | Weekly Pegylated Interferon Dose | Daily Ribavirin Dose | Duration | Sustained Virologic Response Among Patients with Genotype 2 or 3 Infection
48 Weeks vs. 24 Weeks
Hadziyannis, 2004^63^ World-wide N=492 with genotype 2 or 3 infection N(total) = 1284 Quality: Fair | A vs. B vs. C vs. D: Age (mean): 41 vs. 42 vs. 43 vs. 43. years Female: vs. 32% vs. 34% vs. 27% vs. 34% Non-White race: 13% vs. 10% vs. 12% vs. 9% Cirrhosis: 7% vs. 8% vs. 5% vs. 7% Minimal or no fibrosis: Not reported | 38% | Alfa-2a 180 mcg | A. 800 mg B. 1200 mg C. 800 mg D. 1200 mg | A/B. 48 weeks C/D. 24 weeks | A/B. 75% C/D. 82%
Zeuzem, 2004^71^ (PEGASYS) Australia, Europe, New Zealand, North & South America N=117 with genotype 2 or 3 infection N(total) = 491 Quality: Fair | A vs. B Age (Mean): 44 vs. 44 Female: 61% vs. 58% Non-White race: 14% vs. 14% Cirrhosis: 1% vs. 0% Minimal or no fibrosis: 69% vs. 66% | 28% | Alfa-2a 180 mcg | 800 mg | A. 48 weeks B. 24 weeks | A. 78% B. 72%
24 Weeks vs. 12–16 Weeks
Lagging, 2008^64^ Denmark & Finland N=382 Quality: Fair | A vs. B: Age (mean): 42 vs. 42 years Female: 44% vs. 37% Non-White race: Not reported Cirrhosis: 13% vs. 13% Minimal or no fibrosis: Not reported | 100% | Alfa-2a 180 mcg | 800 mg | A. 24 weeks B. 12 weeks | A. 78% B. 59%
Manns, 2011^66^ International N=458 Quality: Poor | A vs. B Age (Mean): 40 vs. 40 years Female: 35% vs. 36% Non-White race: Not reported Cirrhosis: Not reported Minimal or no fibrosis: Not reported | 100% | Alfa-2b 1.5 mcg | 800–1400 mg | A. 24 weeksB. 16 weeks | A. 67% B. 57%
Shiffman, 2007^68^ 132 Centers World-wide N=1465 Quality: Good | A vs. B: Age (mean): 45.6 vs. 46 years Female: 37% vs. 39% Non-White race: 13% vs. 13% Cirrhosis: Not reported (23% vs. 25% severe fibrosis or cirrhosis) Minimal or no fibrosis: Not reported | 100% | Alfa-2a 180 mcg | 800 mg | A. 24 weeks B. 16 weeks | A. 70% B. 62%
Yu, 2007^70^ Taiwan N=150 Quality: Fair | A vs. B: Age (mean): 50 vs. 49 years Female: 34% vs. 40% Non-White race: Not reported Cirrhosis: Not reported (severe fibrosis or cirrhosis 22% vs. 20%) Minimal or no fibrosis: Not reported (mild, minimal, or no fibrosis 78% vs. 80%) | 100% | Alfa-2a 180 mcg | 1000–1200 mg | A. 24 weeks B. 16 weeks | A. 95% B. 94%
24 Weeks vs. 12–16 Weeks Among Those With Undetectable Virus by Week 4
Dalgard, 2008^62^ Denmark, Sweden, Norway N=298 Quality: Fair | A vs. B: : Age (median): 38 vs. 38 years Female: 35% vs. 36% Non-White race: Not reported Cirrhosis: Not reported Minimal or no fibrosis: Not reported | 100% | Alfa-2b 1.5 mcg/kg | 800–1400 mg | A. 24 weeks B. 14 weeks | A. 91% B. 81%
Mecenate, 2010 (CLEO)67 Italy N=143 Quality: Fair | Demographics reported overall only Age (mean): 43 years Female: 19% Non-White race: Not reported Cirrhosis: 10% (overall) Minimal or no fibrosis: Not reported | 100% | Alfa-2a 180 mcg | 800–1200 mg | A. 24 weeks B. 12 weeks | A. 75% B. 83%
von Wagner, 2005^69^ Germany N=142 Quality: Fair | A vs. B: Age (mean): 39 vs. 38 Female: 42% vs. 26% Non-White race: Not reported Cirrhosis: Not reported Minimal or no fibrosis: Not reported | 100% | Alfa-2a 180 mcg | 800–1200 mg | A. 24 weeks B. 16 weeks | A. 80% B. 82%
Other Duration Comparisons
Andriulli, 2009^61,b^ Italy N=120 Quality: Fair | A vs. B: Age (mean): 53 vs. 53 years Female: 51% vs. 41% Race: Not reported Cirrhosis: Not reported Minimal or no fibrosis: Not reported | 100% | Alfa-2a 180 mcg | A. 1000–1200 mg for 12 weeks B. 1000–1200 mg for 6 weeks | 12 weeks | A. 82% B. 54%
Mangia, 2005^65^ Italy N=283 Quality: Fair | A vs. B: Age (mean): 47 vs. 50 years Female: 44% vs. 44% Race: Not reported Cirrhosis: Not reported (16% vs. 23% severe fibrosis or cirrhosis) Minimal or no fibrosis: Not reported | 100% | Alfa-2b 1.0 mcg/kg | 1000–1200 mg | A. 24 weeks B. 12–24 weeks^c^ | A. 77% B. 76%

Note: Cirrhosis = METAVIR F4, Ishak 5–6, or equivalent. Minimal or no fibrosis=METAVIR F0–F1, Ishak 0–2, or equivalent.

a Sample sizes and results restricted to patients with genotype 2 or 3 infection.

b Patients who had undetectable HCV-RNA at 4 weeks randomized to 6 or 12 weeks of ribavirin.

c Treatment for 12 weeks if HCV RNA undetectable at 4 weeks, and for 24 weeks if detectable.

Six trials compared fixed-duration regimens of dual therapy with pegylated interferon (alfa-2a or alfa-2b) plus ribavirin in patients with genotype 2 or 3 infection.63, 64, 66, 68, 70, 71 Two trials found no difference between 48 versus 24 weeks of dual therapy in likelihood of achieving an SVR (pooled RR 0.97, 95% CI 0.84 to 1.1, I^2^=43%) (Figure 5).63, 71 Four other trials found 24 weeks of dual therapy associated with a higher likelihood of achieving an SVR than 12 to 16 weeks of dual therapy (pooled RR 1.2, 95% CI 1.0 to 1.3; I^2^=80%),64, 66, 68, 70 but substantial statistical heterogeneity was present (I^2^=80%) (Figure 6). Of the four trials, three found 12 to 16 weeks of dual therapy associated with lower likelihood of SVR compared with 24 weeks.64, 66, 68 The fourth trial,70 which found no difference between 16 versus 24 weeks of dual therapy (RR 1.0, 95% CI 0.93 to 1.1), used weight-based dosing of ribavirin starting at 1,000 mg (1,000–1,200 mg), compared with a flat dose of 800 mg or weight-based dosing starting at 800 mg (800–1,400 mg) in the other three trials. This trial also enrolled only patients with a genotype 2 infection, whereas the others enrolled genotype 2 or 3. It reported substantially higher overall SVR rates (94 vs. 95 percent) than the other trials (57–62 percent vs. 67–78 percent). Excluding this trial from the meta-analysis reduced statistical heterogeneity, with no appreciable impact on the pooled estimate of effect (three trials, pooled RR 1.2, 95% CI 1.1 to 1.3, I^2^=47%).64, 66, 68 Another potential source of heterogeneity was the evaluation of pegylated interferon alfa-2b and high attrition in one of the trials.66 However, excluding this trial did not affect the pooled estimate or reduce statistical heterogeneity (three trials, pooled RR 1.1, 95% CI 0.99 to 1.3, I^2^=86%).64, 68, 70

Figure 5 Sustained virologic response: Dual therapy with pegylated interferon (alfa-2a or alfa-2b) plus ribavirin for 48 versus 24 weeks in patients with genotype 2 or 3 infection

Figure 5 is a forest plot (i.e., a graph that depicts a meta-analysis plot) showing the individual and pooled relative risks and 95% confidence intervals (random effects model) from 2 trials for the comparison of dual therapy with pegylated interferon plus ribavirin for 48 versus 24 weeks in patients with genotype 2 or 3 infection on sustained virological response. In the center of the graph is a solid vertical line corresponding to no effect. The individual studies are depicted at varying distances along this line as horizontal lines with a solid square in the middle. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The pooled effect is represented by a diamond at the bottom of the graph. The two trials found no difference between 48 versus 24 weeks of dual therapy in the likelihood of achieving an SVR, the pooled relative risk was 0.97, with a 95% confidence interval of 0.84 to 1.11; I-squared = 32.1%, p = 0.186.

Figure 6 Sustained virologic response: Dual therapy with pegylated interferon (alfa-2a or alfa-2b) plus ribavirin for 24 weeks versus 12 to 16 weeks in patients with genotype 2 or 3 infection

Figure 6 is a forest plot (i.e., a graph that depicts a meta-analysis plot) showing the individual and pooled relative risks and 95% confidence intervals (random effects model) from 4 trials for the comparison of dual therapy with pegylated interferon plus ribavirin for 12 to 16 versus 24 weeks in patients with genotype 2 or 3 infection on sustained virological response. In the center of the graph is a solid vertical line corresponding to no effect. The individual studies are depicted at varying distances along this line as horizontal lines with a solid square in the middle. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The pooled effect is represented by a diamond at the bottom of the graph. There was no difference between 12 to 16 versus 24 weeks of dual therapy in likelihood of achieving a SVR. The pooled relative risk was 1.15, with a 95% confidence interval of 1.08 to 1.29; I-squared = 79.5%, p = 0.002. Relative risk estimates ranged from 1.01 (95% confidence interval 0.93 to 1.10) to 1.18 (95% confidence interval 0.93 to 1.10).

Three trials of patients with genotype 2 or 3 infection who achieved a rapid virologic response (defined as undetectable HCV-RNA by week 4) found no difference between patients randomized to a total of 24 versus 12 to 16 weeks of dual therapy with pegylated interferon alfa-2a (two trials) or alfa-2b (one trial) plus ribavirin (pooled RR 0.99, 95% CI 0.86 to 1.1, I^2^=66%) (Figure 7).62, 67, 69 Although statistical heterogeneity was present, absolute differences were relatively small, ranging from 10 percentage points favoring 24 over 16 weeks of therapy62 to 9 percentage points favoring 12 over 24 weeks of therapy.67 One trial used the alfa-2b form of pegylated interferon and a somewhat different weight-based ribavirin dosing algorithm, which might account for some of the heterogeneity.62

Figure 7 Sustained virologic response: Dual therapy with pegylated interferon (alfa-2a or alfa-2b) plus ribavirin for a total of 24 versus 12 to 16 weeks in patients with genotype 2 or 3 infection with a rapid virologic response

Figure 7 is a forest plot (i.e., a graph that depicts a meta-analysis plot) showing the individual and pooled relative risks and 95% confidence intervals (random effects model) from 3 trials for the comparison of dual therapy with pegylated interferon plus ribavirin for a total of 24 versus 12 to 16 weeks in patients with genotype 2 or 3 infection with a rapid virological response on sustained virological response. Rapid virologic response was defined by undetectable HCV-RNA by week 4. In the center of the graph is a solid vertical line corresponding to no effect. The individual studies are depicted at varying distances along this line as horizontal lines with a solid square in the middle. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The pooled effect is represented by a diamond at the bottom of the graph. Based on trials that evaluated sustained virological response, dual therapy with pegylated interferon plus ribavirin for a total of 24 versus 12 to 16 weeks in patients with genotype 2 or 3 infection with a rapid virological response there was no difference between patients randomized to a total of 24 versus 12 to 16 weeks of pegylated interferon alfa-2a (two trials) or alfa-2b (one trial) plus ribavirin. Relative risk estimates ranged from 0.89 (95% confidence interval 0.81 to 0.98) to 1.12 (95% confidence interval 0.94 to 1.32). The pooled relative risk was 0.99, with a 95% confidence interval of 0.86 to 1.14. I-squared = 65.7%, p = 0.054.

Two other trials evaluated other comparisons related to duration of dual therapy with pegylated interferon plus ribavirin in patients with HCV genotype 2 or 3 infection.61, 65 One trial found fixed duration therapy with low dose (1.0 mcg/kg/week) pegylated interferon alfa-2b plus ribavirin for 24 weeks associated with nearly identical likelihood of achieving an SVR versus response-guided therapy for 12 or 24 weeks, based on absence or presence of a rapid virologic response (76 vs. 77 percent).65 A trial of patients who experienced a rapid virologic response found 12 weeks of pegylated interferon alfa-2a with early discontinuation of ribavirin after 6 weeks associated with lower likelihood of SVR than dual therapy for 12 weeks (54 vs. 82 percent; RR 0.66, 95% CI 0.51 to 0.86).61

### Dual Therapy With Pegylated Interferon Alfa-2a or Alfa-2b Plus Ribavirin: Dose Effects of Pegylated Interferon (Alfa-2a or Alfa-2b)

Six trials of dual therapy with pegylated interferon plus ribavirin compared lower versus higher doses of pegylated interferon alfa-2b in patients with genotype 2 or 3 infection (Table 4, Appendix H: Evidence Table 7).66, 73–77 Three trials66, 74, 77 restricted enrollment to patients with genotype 2 or 3 infection and three trials73, 75, 76 enrolled other genotypes but reported results in the subgroup of patients with genotype 2 or 3 infection. Sample sizes ranged from 53 to 454 people with genotype 2 or 3 infection. Two trials66, 76 were rated poor quality and the remainder fair quality (Appendix H: Evidence Table 8). Methodologic shortcomings included open-label or inadequately described blinding procedures66, 73–77 and unclear randomization methods.66, 73–77 Five trials compared standard dose pegylated interferon alfa-2b (1.5 mcg/kg/week) compared with lower doses (1.0 or 0.75 mcg/kg/week).66, 73, 74, 76, 77 The sixth trial evaluated an atypical pegylated interferon alfa-2b dosing regimen of 100–150 mcg weekly (100 mcg if <75 kg or 150 mcg if ≥75 kg) compared with 50 mcg weekly.75

Table 4 Dose effects of pegylated interferon, trials of with dual therapy with pegylated interferon (alfa-2a or alfa-2b) plus ribavirin^a^

Author Country N Quality | Population Characteristics | Percent Genotype 2 or 3 | Weekly Pegylated Interferon Dose | Daily Ribavirin Dose | Duration | Sustained Virologic Response Among Genotype 2 or 3
Trials of Higher vs. Lower Doses of Pegylated Interferon Alfa-2b
Abergel, 2006^73^ France N=78 with genotype 2 or 3 infection N(total)=203 Quality: Fair | A vs. B Age (mean): 50 vs. 52 years Female: 36% vs. 32% Race: Not reported Cirrhosis: 46% vs. 57% Minimal or no fibrosis: Not reported | 38% | A. Alfa-2b 1.5 mcg/kg B. Alfa-2b 0.75 mcg/kg | 800 mg | 48 weeks | A. 73% B. 73%
Kawaoka, 2009^74^ Japan N=53 Quality: Fair | A vs. B Age (median): 57 vs. 55 years Female: 65% vs. 44% Race: Not reported (study conducted in Japan) Cirrhosis: None Minimal or no fibrosis: 55% vs. 48% | 100% | A. Alfa-2b 1.0 mcg/kg B. Alfa-2b 1.5 mcg/kg | 600–1000 mg | 24 weeks | A. 39% B. 74%
Krawitt, 2006^75^ U.S. N=86 with genotype 2 or 3 infection N(total) = 301 Quality: Fair | A vs. B Age >50 years: 18% vs. 19% Female: 38% vs. 36% Non-White race: 4.6% vs. 3.1% Cirrhosis: 17% vs. 10% Minimal or no fibrosis: 30% vs. 33% | 29% | A. Alfa-2b 50 mcg B. Alfa-2b 100–150 mcg | 1000 mg | 48 weeks | A. 56% B. 65%
Meyer-Wyss, 2006^76^ Switzerland N=91 with genotype 2 or 3 infection N(total)=219 Quality: Poor | A vs. B Age (median): 39 vs. 42 years Female: 43% vs. 28% Race: Not reported Cirrhosis: None Minimal or no fibrosis: 58% vs. 49% | 42% | A. Alfa-2b 1.0 mcg/kg B. Alfa-2b 1.5 mcg/kg | 800 mg | 24–48 weeks by genotype | A. 71% B. 81%
Sood, 2008^77^ India N=103 Quality: Fair | A vs. B Age (mean): 43 vs. 37 years Female: 12% vs. 22% Race: Not reported Cirrhosis: Not reported Minimal or no fibrosis: Not reported | 100% | A. Alfa-2b 1.0 mcg/kg B. Alfa-2b 1.5 mcg/kg | 10–12 mg/kg | 24 weeks | A. 79% B. 93%
Manns, 2011^66^ International N=454 (24 week) N(total)=602 Quality: Poor | A vs. B Age (Mean): 40 vs. 39 vs. years Female: 35% vs. 40% vs. Non-White race: Not reported Cirrhosis: Not reported Minimal or no fibrosis: Not reported | 100% | A: Alfa-2b 1.5 mcg B: Alfa-2b 1.0 mcg | 800–1400 mg | 24 weeks | A. 67% B. 64%
Trials of Induction Dosing Regimens
Manns, 2001^78^ U.S. & UK N=1530 Quality: Fair | A vs. B Age (mean): Female: Non-White race: Cirrhosis: Not reported (29% vs. 30% severe fibrosis or cirrhosis) Minimal or no fibrosis: Not reported | 29% | A. Alfa-2b 1.5 mcg/kg × 4 weeks, then 0.5 mcg/kg × 44 weeks B. Alfa-2b 1.5 mcg/kg × 48 weeks | A. 1000–1200 mg B. 800 mg | 48 weeks | A. 80% B. 88%
Mimidis, 2006^79^ Greece N=120 Quality: Poor | A vs. B Age (mean): Not reported Female: : 49% vs. 51% Race: Not reported Cirrhosis: Not reported Minimal or no fibrosis: Not reported | 51% | A. Alfa-2b 3.0 mcg/kg × 12 weeks, 1.5 mcg/kg × 36 weeks B. Alfa-2b 1.5 mcg/kg × 48 weeks | 800–1200 mg | 48 weeks | A. 48% B. 59%

HCV = hepatitis C virus; NA = not applicable; SD = standard deviation; U.K. = United Kingdom; U.S. = United States.

Note: Cirrhosis = METAVIR F4, Ishak 5–6, or equivalent. Minimal or no fibrosis=METAVIR F0–F1, Ishak 0–2, or equivalent.

a Sample sizes and results restricted to patients with genotype 2 or 3 infection.

Lower dose pegylated interferon alfa-2b as part of dual therapy with ribavirin was associated with lower likelihood of SVR than standard dose (six trials, pooled RR 0.90, 95% CI 0.81 to 0.99, I^2^=20%) (Figure 8).66, 73–77 Excluding two poor quality trials66, 76 (four trials, pooled RR 0.85, 95% CI 0.71 to 1.0, I^2^=38%) or the trial that compared atypical dosing regimens75 (five trials, pooled RR 0.89, 95% CI 0.79 to 1.0, I^2^=35%) had little effect on the pooled estimates.

Figure 8 Sustained virologic response: Dual therapy with lower dose pegylated interferon alfa-2b plus ribavirin versus higher dose pegylated interferon alfa-2b plus ribavirin in patients with genotype 2 or 3 infection

Figure 8 is a forest plot (i.e., a graph that depicts a meta-analysis plot) showing the individual and pooled relative risks and 95% confidence intervals (random effects model) from 6 trials for the comparison of dual therapy with pegylated interferon plus ribavirin with lower dose pegylated interferon on sustained virological response in patients with genotype 2 or 3 infection. In the center of the graph is a solid vertical line corresponding to no effect. The individual studies are depicted at varying distances along this line as horizontal lines with a solid square in the middle. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The pooled effect is represented by a diamond at the bottom of the graph. Based on trials that evaluated sustained virological response, lower dose pegylated interferon and ribavirinwas associated with decreased likelihood of achieving an SVR compared to standard doses of pegylated interferon and ribavirin.. Relative risk estimates ranged from 0.52 (95% confidence interval 0.30 to 0.89) to 1.00 (95% confidence interval 0.76 to 1.31). The pooled relative risk was 0.90, with a 95% confidence interval of 0.81 to 0.99. Heterogeneity was minimal, I-squared = 20.2%, p = 0.281.

Two other trials evaluated induction regimens of pegylated interferon alfa-2b (higher initial doses followed by lower doses until completion of therapy) plus ribavirin compared with standard fixed-dose regimens of pegylated interferon alfa-2b plus ribavirin.78, 79 One good quality trial found dual therapy with pegylated interferon alfa-2b (3.0 mcg/kg/week) plus ribavirin for 12 weeks followed by 36 weeks of standard dose pegylated interferon alfa-2b plus ribavirin associated with a nonstatistically significant trend towards decreased likelihood of SVR versus standard fixed dose dual therapy for 48 weeks (48 vs. 59 percent, p>0.05).79 Another trial found no clear difference in likelihood of achieving an SVR between dual therapy with standard dose pegylated interferon alfa-2b plus ribavirin for 4 weeks followed by 0.5 mcg/kg/week for 44 weeks versus fixed dose dual therapy with standard doses of pegylated interferon alfa-2b for 48 weeks (82 vs. 80 percent), but results are difficult to interpret because ribavirin dosing was higher (1000 to 1200 mg daily) in the induction compared with the standard therapy arm (800 mg daily).78

### Ribavirin

Four trials compared effects of dual therapy with pegylated interferon plus ribavirin with different doses of ribavirin in patients with genotype 2 or 3 infection (Table 5, Appendix H: Evidence Table 5).63, 80–82 One trial80 restricted enrollment to patients with genotype 2 or 3 infection and three trials63, 81, 82 enrolled other genotypes but reported results in the subgroup of patients with genotype 2 or 3 infection. Sample sizes ranged from 60 to 1831 with genotype 2 or 3 infection. All four trials were rated fair quality (Appendix H: Evidence Table 6). Methodological shortcomings included open-label design or inadequately described blinding63, 80–82 and high loss to followup.63, 82 Three trials63, 80, 81 evaluated ribavirin in combination with pegylated interferon alfa-2a and one trial in combination with pegylated interferon alfa-2b.82

Table 5 Dose effects of ribavirin: Trials of with dual therapy with pegylated interferon (alfa-2a or alfa-2b) plus ribavirin^a^

Author Country Study Name N Quality | Population Characteristics | Percent Genotype 2 or 3 | Pegylated Interferon Dose | Ribavirin Dose | Duration | Sustained Virologic Response Among Genotype 2 or 3
Ferenci, 2008^80^ Austria N= 282 Quality: Poor | A vs. B Age (mean): 37 vs. 36 years Female: 40% vs. 38% Race: Not reported Cirrhosis: Not reported Minimal or no fibrosis: Not reported | 100% | Alfa-2a 180 mcg | A. 400 mg B. 800 mg | 24 weeks | A. 64% B. 69%
Hadziyannis, 2004 (PEGASYS)63 Worldwide N=492 with genotype 2 or 3 infection Quality: Fair | A vs. B vs. C vs. D: Age (mean): 41 vs. 42 vs. 43 vs. 43 years Female: 32% vs. 34% vs. 27% vs. 34% Nonwhite race: 12% vs. 9% vs. 13% vs. 10% Cirrhosis: 5% vs. 7% vs. 7% vs. 8% Minimal or no fibrosis: Not reported | 38% | Alfa-2a 180 mcg | A/C. 800 mg B/D. 1000–1200 mg | A. 24 weeks B. 24 weeks C. 48 weeks D. 48 weeks | A/C. 82% B/D. 80%
Helbling, 2006^81^ Switzerland N= 60 (genotype 2 or 3) N(total)=97 Quality: Fair | A vs. B Age (median): 47 vs. 47 years Female: 30% vs. 40% Race: Not reported Cirrhosis: 57% vs. 52% Minimal or no fibrosis: 6% vs. 2% | 48% | Alfa-2a 180 mcg | A. 1000–1200 mg B. 600–800 mg | 24–48 weeks by genotype | A. 72% B. 45%
Jacobson, 2007a (WIN-R)82 U.S. N=1831 with genotype 2 or 3 infection N(total)=4913 Quality: Fair | A vs. B Age (mean): 46 vs. 46 years Female - 37.7% vs. 36.2% Nonwhite race: 19% vs. 21% Cirrhosis: 10% vs. 10% Minimal or no fibrosis: Not reported (mild, minimal, or no fibrosis 70% vs. 70%) | 37% | Alfa-2b 1.5 mcg | A. 800 mg B. 800–1400 mg | 24–48 weeks by genotype | A. 60% B. 62%

Cirrhosis = METAVIR F4, Ishak 5–6, or equivalent. Minimal or no fibrosis=METAVIR F0–F1, Ishak 0–2, or equivalent.

a Sample sizes and results restricted to patients with genotype 2 or 3 infection.

The trials each evaluated a different ribavirin dose comparison, precluding pooled analyses. The two largest trials found no clear differences between lower flat doses of ribavirin versus higher or weight-based doses.63, 82 One trial (n=492 with genotype 2 or 3 infection) randomized patients to dual therapy with pegylated interferon alfa-2a 180 mcg/week plus flat-dose ribavirin, in one of four regimens: 24 weeks with ribavirin 800 mg/day, 24 weeks with ribavirin 1000–1200 mg/day, 48 weeks with ribavirin 800 mg/day, and 48 weeks with ribavirin 1000–1200 mg/day.63 Rates of SVR were very similar in the combined 800 mg versus the combined 1200 mg arms (82 vs. 80 percent, RR 1.1, 95% CI 0.99 to 1.2). Another trial (n=1831 with genotype 2 or 3 infection) found no difference between dual therapy for 24 weeks with pegylated interferon alfa-2b 1.5 mcg/kg week and flat-dose ribavirin 800 mg versus weight-dosed ribavirin 800 to 1400 mg (60 vs. 62 percent, RR 0.96, 95% CI 0.89 to 1.0).82 One other smaller trial (n=282) found no difference between dual therapy with pegylated interferon alfa-2a with flat doses of ribavirin 400 mg versus ribavirin 800 mg in likelihood of an SVR (64 vs. 69 percent, RR 0.92, 95% C I 0.78 to 1.1). 80

One trial (n=60 with genotype 2 or 3 infection) of pegylated interferon alfa-2a found 600–800 mg daily of ribavirin associated with lower likelihood of SVR than 1000–1200 mg daily (45 vs. 72 percent, RR 0.62, 95% CI 0.40 to 0.98), but differed from the others in that it enrolled subjects primarily with advanced fibrosis or cirrhosis (Ishak stage F4–F6).81

### Trials of Triple Therapy With Pegylated Interferon Alfa-2b, Ribavirin, and Boceprevir

Two randomized trials compared triple therapy with boceprevir, pegylated interferon alfa-2b and weight-based ribavirin with dual therapy with pegylated interferon alfa-2b plus ribavirin in antiviral treatment-naïve patients with chronic HCV genotype 1 infection (Table 6, Appendix H: Evidence Table 3).30, 32 The Serine Protease Inhibitor Therapy (SPRINT-1)30 and SPRINT-2^32^ trials (n=1088 and 520, respectively) were conducted in the U.S., Canada, and Europe. In SPRINT-1,^30^ 7 percent of enrolled patients had cirrhosis at baseline and in SPRINT-2^32^ about 10 percent had either severe fibrosis or cirrhosis. Both trials were rated fair quality (Appendix H: Evidence Table 4). SPRINT-1 was an open label trial, and in SPRINT-2, 24 percent of patients did not complete followup. Neither trial evaluated the FDA-recommended dosing regimen for boceprevir in antiviral-naïve patients without cirrhosis at baseline (4 weeks of dual therapy lead-in with pegylated interferon alfa-2a or alfa-2b plus ribavirin, followed by triple therapy with the addition of boceprevir for either 24 or 32 weeks, based on virologic response at weeks 8 and 24),84 although both trials evaluated the FDA-recommended dosing regimen for boceprevir in antiviral treatment-naïve patients with cirrhosis at baseline (4 weeks of dual therapy lead-in, followed by triple therapy for the final 44 weeks).

Table 6 Trials of triple therapy with pegylated interferon alfa-2b, ribavirin, and boceprevir versus dual therapy with pegylated interferon alfa-2b plus ribavirin

Trial Country Study Name N Quality | Population characteristics | Boceprevir Dose/Duration | Weekly Pegylated interferon dose | Daily Ribavirin Dose | Overall Duration of Therapy (weeks) | Sustained Virologic Response
Kwo, 2010^30^ U.S., Canada, Europe Serine Protease Inhibitor Therapy 1 (SPRINT-1) Trial N(total)=520 Quality: Fair | A vs. B vs. C vs. D vs. E Age (mean): 47 vs. 46 vs. 48 vs. 48. vs. 48 years Female: 39% vs. 41% vs. 44% vs. 50% vs. 33% Nonwhite race: 16% vs. 20% vs. 17% vs. 17% vs. 20% Genotype 1: 100% Cirrhosis: 7% (overall) Minimal or no fibrosis: Not reported Elevated transaminases: Not reported | A. BCP 800 mg tid weeks 1–48 B. BCP 800 mg tid weeks 1–28 C. BCP 800 mg tid weeks 5–48^a^ D. BCP 800 mg tid weeks 5–28 E. placebo | Alfa-2b 1.5 mcg/kg | 800–1400 mg | A. 48 B. 28 C. 48 D. 28 E. 48 | A. 67% B. 54% C. 75%^a^ D. 56% E. 38%
Poordad, 2011^32^ U.S. and Europe Serine Protease Inhibitor Therapy 2 (SPRINT-2) N=1,088 Quality: Fair | A vs. B vs. C Age (mean) 49 vs. 50 vs. 49 years Female: 40% vs. 38% vs. 43% Nonwhite race: 19% vs. 17% vs. 18% Genotype 1: 100% Cirrhosis: Not reported (Severe fibrosis or cirrhosis 11% vs. 9% vs. 7%) Minimal or no fibrosis: Not reported Elevated transaminases: | A. 800 mg tid weeks 5–48 B. 800 mg tid weeks 5–28 C. placebo | Alfa-2b 1.5 mcg/kg | A. 600–1400 mg weeks 5–48 B. 600–1400 mg weeks 5–28 C. 600–1400 mg | A. 48 B. 28/48^b^ C. 48 | A. 66%^a^ B. 63% C. 38%

BCP = boceprevir; bid = twice daily; eRVR = extended rapid virologic response; TCP = telaprevir; tid = three times daily

Note: Cirrhosis=METAVIR F4, Ishak 5–6, or equivalent. Minimal or no fibrosis=METAVIR F0–F1, Ishak 0–2, or equivalent.

a Dosing recommended by the U.S. Food and Drug Administration for boceprevir in antiviral-naïve patients with cirrhosis at baseline.

b Response-guided duration: 28 weeks of pegylated interferon/ribavirin if HCV-RNA negative from week 8 through week 24. Patients not meeting these criteria continued until week 48.

SPRINT-1 randomized patients to five different antiviral regimens: (1) 4-week dual therapy lead-in with pegylated interferon alfa-2b plus ribavirin followed by the addition of boceprevir for 24 weeks (total 28 weeks); (2) 28 weeks of triple therapy with pegylated interferon alfa-2b, ribavirin, and boceprevir with no lead-in; (3) 4-week dual therapy lead-in followed by triple therapy for 44 weeks (total 48 weeks); (4) 48 weeks of triple therapy with no lead-in; or (5) dual therapy for 48 weeks.30 SVR rates were 56 percent and 54 percent in the 28-week boceprevir treatment arms and 75 percent and 67 percent in the 48-week boceprevir treatment arms (with and without dual therapy lead- in, respectively), versus 38 percent with dual therapy (p<0.01 for each triple therapy arm vs. dual therapy), for an absolute risk difference for triple compared with dual therapy that ranged from 19–37 percent. Versus dual therapy, the relative risk for achieving an SVR for the two 48-week triple therapy arms combined was 1.9 (95% CI 1.5 to 2.5), and for the two 28-week triple therapy arms combined was 1.5 (95% CI 1.1 to 1.9). Four-week dual therapy lead-in was associated with an increased absolute rate of achieving an SVR versus no lead-in of 2 percent for the 28-week regimens and 8 percent for the 48-week regimens.

SPRINT-2 compared a fixed duration triple therapy regimen, a response-guided triple therapy regimen, and dual therapy.32 The fixed duration regimen consisted of four weeks of dual therapy lead-in with pegylated interferon alfa-2b plus ribavirin followed by the addition of boceprevir for 44 weeks (48 weeks total). The response-guided approach consisted of a four-week dual therapy lead-in, followed by triple therapy for 24 weeks. Patients with undetectable serum HCV-RNA from weeks 8 through 24 completed their antiviral treatment at week 28. Patients with detectable HCV-RNA at any time between weeks 8 and 24 continued dual therapy for another 20 weeks (48 weeks total). The third (control) arm consisted of dual therapy for 48 weeks. SVR rates for the three regimens were 66, 63, and 38 percent, respectively, (p<0.001 for either boceprevir regimen vs. dual therapy), with an absolute risk difference of 25–28 percent for triple compared with dual therapy. Compared with dual therapy, the relative risk for achieving an SVR for the two regimens with boceprevir combined was 1.7 (95% CI 1.5 to 2.0).

The only treatment regimen evaluated in both SPRINT trials was the 48-week regimen with dual therapy lead-in for the first 4 weeks and boceprevir added for the final 44 weeks. Based on data from both trials, triple therapy was associated with a higher likelihood of SVR than dual therapy (pooled RR 1.8, 95% CI 1.6 to 2.1, I^2^=0%), with a pooled absolute increase in SVR of 31 percentage points (95% CI 23 to 39) (Figure 9).30, 32

Figure 9 Sustained virologic response: 48 weeks of triple therapy with boceprevir (4 weeks of dual therapy lead-in with pegylated interferon alfa-2b followed by the addition of 44 weeks boceprevir) versus 48 weeks of dual therapy in patients with genotype 1 infection

Figure 9 is a forest plot (i.e., a graph that depicts a meta-analysis plot) showing the individual and pooled relative risks and 95% confidence intervals (random effects model) from 2 trials for the comparison of 4 weeks of dual therapy lead-in followed by 44 weeks of triple therapy with boceprevir versus 48 weeks of dual therapy in patients with genotype 1 infection on sustained virological response In the center of the graph is a solid vertical line corresponding to no effect. The individual studies are depicted at varying distances along this line as horizontal lines with a solid square in the middle. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The pooled effect is represented by a diamond at the bottom of the graph. Based on data from both trials, triple therapy was associated with an increased likelihood of SVR compared to dual therapy. The relative risk estimates ranged from 1.75 (95% confidence interval 1.52–2.04) to 1.99 (95% confidence interval 1.52–2.62). The pooled relative risk was 1.80, with a 95% confidence interval of 1.6 to 2.1; I-squared = 0.0 %, p = 0.416.

SPRINT-1 also included a separate trial of 75 patients randomized to weight-based low dose (400–1000 mg) or standard dose (800–1400 mg) ribavirin as part of 48 weeks of triple therapy with boceprevir without dual therapy lead in30 Low dose ribavirin was associated with a non–statistically significant trend towards lower likelihood of SVR (36 vs. 50%, RR 0.71, 95% CI 0.39 to 1.3).

### Trials of Triple Therapy With Pegylated Interferon (Alfa-2a or Alfa-2b), Ribavirin, and Telaprevir

Six randomized trials compared triple therapy with telaprevir, pegylated interferon alfa-2a or alfa-2b and weight-based ribavirin compared with dual therapy with pegylated interferon alfa-2a or alfa-2b and ribavirin for antiviral treatment-naïve patients with chronic HCV genotype 1 infection (Table 7, Appendix H: Evidence Table 3).31, 51, 59, 85–87 A seventh, small trial was excluded because it evaluated patients with HCV genotype 2 or 3 (telaprevir is only approved for use in genotype 1 infection).88 One trial31 was rated good quality and the remainder fair quality (Appendix H: Evidence Table 4). The proportion of patients with cirrhosis at baseline in the trials ranged from 0–10 percent. Methodological shortcomings included open-label design or unclear blinding procedures,59, 85, 87 unclear randomization methods,31, 85 and unclear reporting of attrition.31, 86 Three trials (n=189 to 323) evaluated fixed duration triple compared with dual therapy regimens (12, 24, or 48 weeks).31, 85, 86 Two other trials51, 59 (n=161 and 1088) evaluated response-guided duration triple therapy regimens, including one trial51 that compared the FDA-recommended telaprevir dosing regimen (12 weeks of triple therapy followed by 12 or 36 weeks of dual therapy, depending on early virologic response) with dual therapy.84 The sixth trial (n=322) compared different durations of antiviral therapy in patients who experienced an extended rapid virologic response.87 In all evaluated triple therapy regimens, telaprevir was administered with pegylated interferon (alfa-2a or alfa-2b) plus ribavirin for the first 8 to 12 weeks. For regimens longer than 12 weeks, dual therapy with pegylated interferon alfa-2a or alfa-2b plus ribavirin without telaprevir was continued for the remainder of the regimen.

Table 7 Trials of triple therapy with pegylated interferon alfa-2b, ribavirin, and telaprevir

Author Country Study Name N Quality | Population Characteristics | Telaprevir Dose/Duration | Weekly Pegylated interferon Dose | Daily Ribavirin Dose | Overall Duration of Therapy (weeks) | Sustained Virologic Response
Hezode, 2009^85^ Europe N=323 Quality: Fair | A vs. B vs. C vs. D Age (median): 46 vs. 44 vs. 45 vs. 45 years Female: 33% vs. 40% vs. 45% vs. 44% Non White race: 7% vs. 7% vs. 1% vs. 7% Genotype 1: 100% Cirrhosis: 0% vs. 0% vs. 1% vs. 0% Minimal or no fibrosis: 43% vs. 37% vs. 40% vs. 34% Elevated transaminases: Not reported | A. 750 mg tid weeks 1–12 B. 750 mg tid weeks 1–12 C. 750 mg tid weeks 1–12 D. placebo | Alfa-2a 180 mcg | A. 1000–1200 mg B. 1000–1200 mg C. placebo D. 1000–1200 mg | A. 12 B. 24 C. 12 D. 48 | A. 69% B. 60% C. 36% D. 46%
Jacobson, 2011^51^ Worldwide N=1088 Quality: Good | A vs. B vs. C Age (median): 49 vs. 49 vs. 49 years Female: 41% vs. 42% vs. 42% Non White race: 10% vs. 13% vs. 12% Genotype 1: 100% Cirrhosis: 6% overall Minimal or no fibrosis: 28% overall Elevated transaminases: Not reported | A. 750 mg tid weeks 1–8 B. 750 mg tid weeks 1–12^b^ C. placebo | Alfa-2a 180 mcg | 1000–1200 mg | A. 24/48^a^ B. 24/48^a^ C. 48 | A. 69% B. 75%^b^ C. 44%
Kumada, 2012^86^ Japan N=189 Quality: Fair | A vs. B Age (mean): 53 vs. 55 Female: 48% vs. 48% Non White: Not reported (conducted in Japan) Minimal or no fibrosis: Not reported Elevated transaminases: Not reported | A. 750 mg tid weeks 1–12 B. placebo | Alfa-2b 1.5 mcg/kg | 600–1000 mg | A. 24 B. 48 | A. 73% B. 49%
Marcellin, 2011^59^ Europe N=161 Quality: Fair | A vs. B vs. C vs. D Age (median): 47 vs. 46 vs. 40 vs. 49 years Female: 50% vs. 52% vs. 48% vs. 51% Non White race: 10% vs. 10% vs. 10% vs. 8% Genotype 1: 100% Cirrhosis: 2.5% vs. 2.4% vs. 0 vs. 5.1% Minimal or no fibrosis: 39% overall Elevated transaminases: Not reported | A. 750 mg tid weeks 1–12 B. 750 mg tid weeks 1–12 C. 1125 mg bid weeks 1–12 D. 1125 mg bid weeks 1–12 | A. Alfa-2a 180 mcg B. Alfa-2b 1.5 mcg/kg C. Alfa-2a 180 mcg D. Alfa-2a 1.5 mcg/kg | A. 1000–1200 mg B. 800–1200 mg C. 1000–1200 mg D. 800–1200 mg | 24/48^c^ | A. 85% B. 81% C. 83% D. 82%
McHutchison, 2009^31^ U.S. PROVE1 N=250 Quality: Fair | A vs. B vs. C vs. D Age (median): 49 vs. 50 vs. 49 vs. 49 years Female: 32% vs. 39% vs. 29% vs. 43% Non White race: 24% vs. 24% vs. 24% vs. 21% Cirrhosis: 0% Minimal or no fibrosis: 31% (overall) Elevated transaminases: Not reported | A. 750 mg tid weeks 1–12 B. 750 mg tid weeks 1–12 C. 750 mg tid weeks 1–12 D. placebo | Alfa-2a 180 mcg | 1000–1200 mg | A. 12 B. 24 C. 48 D. 48 | A. 35% B. 61% C. 67% D. 41%
Sherman, 2011^87^ U.S. Name: ILLUMINATE N=322^d^ Quality: Fair | A vs. B Age (median): 51 vs. 50 years Female: 36% vs. 39% Non White race: 17% vs. 18% Cirrhosis: 11% vs. 8% Minimal or no fibrosis: 27% (overall) Elevated transaminases: Not reported | A. 750 mg tid weeks 1–12 B. 750 mg tid weeks 1–12 | Alfa-2a 180 mcg | 1000–1200 mg | A. 24 B. 48 | A. 92% B. 88%

bid = two times daily; eRVR = extended rapid virologic response; HCV = hepatitis C virus; NA = not applicable; TCP = telaprevir; tid = three times daily

Note: Cirrhosis=METAVIR F4, Ishak 5–6, or equivalent. Minimal or no fibrosis=METAVIR F0–F1, Ishak 0–2, or equivalent.

a Response-guided duration: 24 weeks of pegylated interferon/ribavirin if HCV-RNA negative from week 4 through week 12. Patients not meeting these criteria continued until week 48.

b Dosing regimen recommended by the U.S. Food and Drug Administration for telaprevir.

c Response-guided duration: 24 weeks of pegylated interferon/ribavirin if HCV-RNA negative from week 4 through week. Patients not meeting these criteria continued until week 48.

d Patients with undetectable HCV RNA at week 4 and week 12 randomized to either 24 or 48 weeks of dual therapy.

Three trials found the 24-week fixed duration triple therapy with pegylated interferon alfa-2a or alfa-2b, ribavirin, and telaprevir associated with higher likelihood of achieving an SVR than 48 weeks of dual therapy (pooled RR 1.5, 95% CI 1.3 to 1.8, I^2^=0%) (Figure 10).31, 85, 86 The pooled absolute increase in SVR rates was 22 percentage points (95% CI 13 to 31). Two of the trials found no difference between the 12-week fixed duration triple therapy regimen versus 48 weeks of dual therapy (pooled RR 1.2, 95% CI 0.86 to 1.6, I^2^=14%) (Figure 11).31, 85 One of the trials also found a 48-week triple therapy regimen with telaprevir associated with similar likelihood of SVR versus a 24-week triple therapy regimen (RR 1.1, 95% CI 0.87 to 1.4).31 The other trial also found a 12-week triple therapy regimen of telaprevir plus pegylated interferon without ribavirin associated with a non–statistically significant trend towards lower likelihood of achieving an SVR than pegylated interferon alfa-2a plus ribavirin for 48 weeks (RR 0.77, 95% CI 0.53 to 1.1).85 One trial of 24-week fixed duration triple therapy with telaprevir was conducted in Japan,86 while the other two were conducted in the United States and Europe. Additionally, the Japanese trial studied telaprevir with pegylated interferon alfa-2b, compared with pegylated interferon alfa-2a in the other fixed duration trials. Excluding this trial did not change the pooled result for SVR (two trials, pooled RR 1.5, 95% CI 1.20 to 1.8, I^2^=0%).31, 85

Figure 10 Sustained virologic response: Triple therapy with pegylated interferon alfa-2a, ribavirin, and telaprevir for 12 weeks followed by dual therapy for 12 weeks versus dual therapy with pegylated interferon alfa-2a plus ribavirin for 48 weeks in patients with genotype 1 infection

Figure 10 is a forest plot (i.e., a graph that depicts a meta-analysis plot) showing the individual and pooled relative risks and 95% confidence intervals (random effects model) from 3 trials for the comparison triple therapy with telaprevir for 12 weeks followed by dual therapy for 12 weeks versus dual therapy for 48 weeks in patients with genotype 1 infection on sustained virological response. In the center of the graph is a solid vertical line corresponding to no effect. The individual studies are depicted at varying distances along this line as horizontal lines with a solid square in the middle. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The pooled effect is represented by a diamond at the bottom of the graph. Based on three trials that evaluated triple therapy with telaprevir for 12 weeks followed by dual therapy for 12 weeks versus dual therapy for 48 weeks in patients with genotype 1 infection, the 24 week fixed duration triple therapy regimen was associated with increased likelihood of achieving an SVR compared to 48 weeks of dual therapy. The relative risk estimates ranged from 1.47 (95% confidence interval 1.06–2.03) to 1.49 (1.13–1.96). The pooled relative risk was 1.48, with a 95% confidence interval of 1.26 to 1.75; I-squared = 0.0%, p = 0.998.

Figure 11 Sustained virologic response: Triple therapy with pegylated interferon alfa-2a, ribavirin, and telaprevir for 12 weeks versus dual therapy with pegylated interferon alfa-2a plus ribavirin for 48 weeks in patients with genotype 1 infection

Figure 11 is a forest plot (i.e., a graph that depicts a meta-analysis plot) showing the individual and pooled relative risks and 95% confidence intervals (random effects model) from 2 trials for the comparison of triple therapy with telaprevir for 12 weeks versus dual therapy for 48 weeks in patients with genotype 1 infection on sustained virological response. In the center of the graph is a solid vertical line corresponding to no effect. The individual studies are depicted at varying distances along this line as horizontal lines with a solid square in the middle. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The pooled effect is represented by a diamond at the bottom of the graph. The two trials that evaluated triple therapy with telaprevir for 12 weeks versus dual therapy for 48 weeks in patients with genotype 1 infection found no difference between the 12 week fixed duration triple therapy regimen versus 48 weeks of dual therapy. The relative risk estimates ranged from 0.85 (95% confidence interval 0.42–1.72) to 1.29 (95% confidence interval 0.96–1.73). The pooled relative risk was 1.19, with a 95% confidence interval of 0.86 to 1.64; I-squared = 13.8%, p = 0.281.

One trial compared response-guided duration triple therapy with telaprevir compared with dual therapy.51 Patients were randomized to 8 weeks of initial triple therapy with pegylated interferon alfa-2a, ribavirin, and telaprevir, 12 weeks of initial triple therapy, or dual therapy with pegylated interferon alfa-2a plus ribavirin. In the telaprevir arms, patients with an extended rapid viral response (HCV-RNA undetectable between weeks 4 and 12) continued pegylated interferon plus ribavirin for a total of 24 weeks, while those without an extended rapid viral response continued dual therapy for a total of 48 weeks. Patients randomized to dual therapy received pegylated interferon alfa-2a plus ribavirin for a fixed duration of 48 weeks. Both telaprevir treatment-guided response regimens were associated with higher SVR rates than dual therapy (69, 75, and 44 percent for 8 weeks of telaprevir, 12 weeks of telaprevir, and dual therapy, respectively; p<0.001 for either telaprevir regimen vs. dual therapy), with an absolute increase in SVR ranging from 25–31 percent for triple therapy compared with dual therapy. The relative risk for achieving an SVR in the combined telaprevir arms versus dual therapy was 1.6 (95% CI 1.4 to 1.9).

One trial of response-guided triple therapy with telaprevir (24 or 48 weeks, based on absence or presence of HCV-RNA from weeks 4 through 20) found similar SVR rates (81–85 percent) for regimens that varied on telaprevir dose (750 mg three times daily vs. 1,125 mg two times daily) and type of pegylated interferon (alfa-2a or alfa-2b).59 Another trial of patients with an extended rapid virologic response to initial triple therapy with telaprevir reported similar, high (92 and 88 percent) SVR rates in patients randomized to a total of 24 or 48 weeks of therapy, meeting the study’s predefined noninferiority threshold.87

## Key Question 2b How does the comparative effectiveness of antiviral treatment for intermediate outcomes vary according to patient subgroup characteristics, including but not limited to HCV genotype, age, race, sex, stage of disease, or genetic markers?

- The largest randomized trial (n=3070) of dual therapy with pegylated interferon alfa-2a plus ribavirin compared with dual therapy with pegylated interferon alfa-2b plus ribavirin found no clear differences in relative risk estimates for SVR in genotype 1 patients stratified by race, sex, age, baseline fibrosis stage, or baseline viral load. Characteristics associated with lower absolute SVR rates across dual therapy regimens were older age, Black race, advanced fibrosis or cirrhosis, and high baseline viral load (strength of evidence: low).
- Four randomized trials of dual therapy with pegylated interferon alfa-2a plus ribavirin versus dual therapy with pegylated interferon alfa-2b plus ribavirin found no clear differences in relative risk estimates for SVR in patients stratified by genotype. Genotype 1 infection was associated with a lower absolute SVR rate than genotypes 2 or 3 (strength of evidence: moderate).
- Two trials of triple therapy with boceprevir for 48 weeks (4 weeks of dual therapy lead-in with pegylated interferon plus ribavirin followed by 44 weeks of triple therapy with pegylated interferon, ribavirin, and boceprevir) found no difference in relative risk estimates for SVR in men versus women, and no clear difference in relative risk estimates for Black versus non-Black patients. Black race was associated with a lower absolute SVR rate than non-Black race (strength of evidence: moderate).
- Two trials found triple therapy with pegylated interferon alfa-2b, ribavirin, and boceprevir associated with higher likelihood of achieving SVR than dual therapy with pegylated interferon alfa-2b plus ribavirin in patients with high baseline HCV-RNA viral load (>600,000 or ≥800,000 IU/mL), but found no difference in likelihood of SVR in patients with lower viral load (strength of evidence: moderate).
- One trial of response-guided triple therapy with telaprevir (12 weeks of pegylated interferon alfa-2a, ribavirin, and telaprevir followed by response-guided dual therapy with pegylated interferon alfa-2a and ribavirin) versus dual therapy with pegylated interferon plus ribavirin for 48 weeks found no clear differences in relative risk estimates in patients stratified by age, sex, race, baseline fibrosis status, or body mass index. Characteristics associated with lower absolute rates of SVR were older age, Black race, advanced fibrosis or cirrhosis, and higher body mass index. One other trial of 24-week fixed duration triple therapy with telaprevir, pegylated interferon alfa-2b, and ribavirin versus 48 weeks of dual therapy found no differences in estimates of effect in patients stratified by sex or age (strength of evidence: moderate).
- Two trials of triple therapy with pegylated interferon (alfa-2a or alfa-2b), ribavirin, and telaprevir versus dual therapy depending reported inconsistent findings for differential relative risk estimates according baseline viral load (strength of evidence: insufficient).

### Dual Therapy With Pegylated Interferon Alfa-2a Plus Ribavirin Compared With Pegylated Interferon Alfa-2b Plus Ribavirin

Five trials of dual therapy with pegylated interferon alfa-2a plus ribavirin versus pegylated interferon alfa-2b evaluated SVR rates in patients subgroups defined by demographic and clinical characteristics (Appendix H: Evidence Table 1 and Evidence Table 2).20–23, 56 The largest study (n=3070), the IDEAL trial, which only enrolled patients with genotype 1 infection, reported no clear differences in relative risk estimates for SVR dual therapy with pegylated interferon alfa-2b plus ribavirin versus dual therapy with pegylated interferon alfa-2a plus ribavirin in patients stratified by race (RR 0.88, 95% CI 0.59 to 1.3 for Black patients and RR 0.98, 95% CI 0.84 to 1.2 for white patients), sex (RR 0.92, 95% CI 0.77 to 1.1 for males and RR 1.1, 95% CI 0.86 to 1.3 for females), age (RR 0.95, 95% CI 0.77 to 1.2 for <40 years and RR 0.99, 95% CI 0.88 to 1.1 for age >40 years), baseline fibrosis (RR 0.88, 95% CI 0.53 to 1.4 for METAVIR F3 or F4 and RR 0.97, 95% CI 0.87 to 1.1 for METAVIR F0 to F2), and baseline viral load (RR 0.99, 95% CI 0.87 to 1.1 for HCV-RNA >600,000 IU/mL and RR 0.93, 95% CI 0.79 to 1.1 for HCV-RNA ≤600,000 IU/mL).22 However, overall absolute SVR rates across dual therapy regimens were lower in older (38 percent) versus younger (53–56 percent) patients, Black patients (23–26 percent) versus white patients (53–55 percent), patients with F3 or F4 (21–24 percent) versus F0 to F2 fibrosis (42–44 percent), and patients with high (35–36 percent) versus low viral load (61–66 percent). The relative risk estimate was somewhat lower for patients 75 to 85 kg (RR 0.80, 95% CI 0.65 to 0.98) than other weight groups (RR ranged from 0.89 to 1.1) but the confidence intervals for the estimates overlapped, and results were potentially confounded by differential ribavirin dosing according to weight.

Four smaller (n=183 to 431) trials found no clear differences in relative risk estimates in patients stratified by genotype, although rates of SVR were lower by 24–42 percent for genotype 1 infection than genotypes 2 and 3 infection.20, 21, 23, 56 One of these trials also found no clear differences in relative risk estimates in patient groups stratified by presence or absence of cirrhosis, or high or low viral load.20

Two trials that compared different durations of therapy in patients with genotype 2 or 3 infection reported risk estimates for SVR stratified by patient characteristics.68, 70 They found no differences in relative risk estimates for 16 weeks of therapy compared with 24 weeks of therapy when patients were stratified according to fibrosis stage, body mass index, sex, or age (all RR estimates close to 1). Although the pooled estimates suggested lower likelihood of SVR with 16 compared with 24 weeks of therapy in patients with HCV-RNA >800,000 IU/mL (pooled RR 0.84, 95% CI 0.77 to 0.93, I^2^=0%) and no difference in those with a viral load less than 800,000 IU/mL (pooled RR 0.99, 95% CI 0.93 to 1.06, I^2^=0%), the estimates were imprecise and the confidence intervals overlapped.68, 70

Another large trial that compared 48 weeks with 24 weeks of dual therapy with pegylated interferon alfa-2a plus ribavirin found similar rates of SVR in patients with genotype 2 or 3 infection regardless of baseline viral load.63

### Triple Therapy With Pegylated Interferon (Alfa-2a or Alfa-2b), Ribavirin, and Boceprevir or Telaprevir

#### Boceprevir

Two trials (n=520 and 1097) of triple therapy with boceprevir for a total of 48 weeks (4 weeks dual therapy lead-in with pegylated interferon alfa-2b plus ribavirin followed by the addition of 44 weeks of boceprevir) versus 48 weeks of dual therapy with pegylated interferon alfa-2b plus ribavirin found no difference in relative risk estimates for SVR in men (pooled RR 1.8, 95% CI 1.6 to 2.2, I^2^=0%) versus women (pooled RR 1.9, 95% CI 1.3 to 2.8, I^2^=57%).30, 32 There was also no clear difference in the relative risk estimates for Black (pooled RR 2.5, 95% CI 1.5 to 4.2, I^2^=0%) and non-Black patients (pooled RR 1.7, 95% CI 1.5 to 2.0, I^2^=0%), although the overall absolute SVR rate across regimens was lower in Black (53 percent) compared with non-Black (63–78 percent) patients. The relative risk estimate was higher for patients with HCV-RNA viral load >600–800,000 IU/mL at baseline (pooled RR 2.0, 95% CI 1.7 to 2.3, I^2^=0%) than those with a lower viral load (pooled RR 1.3, 95% CI 1.0 to 1.5, I^2^=0%), with an absolute SVR rate of 63–73 percent in individuals with a high viral load and 85–91 percent in individuals with a lower viral load. Although triple therapy with boceprevir was associated with no difference in likelihood of SVR in the subgroup of patients with advanced fibrosis or cirrhosis, the number of patients randomized to triple therapy was small (n=30) and the estimate was imprecise (pooled RR 1.1, 95% CI 0.55 to 2.1, I^2^=0%).

#### Telaprevir

One trial (n=1088) of response-guided duration triple therapy with telaprevir (12 weeks of pegylated interferon alfa-2a, ribavirin, and telaprevir followed by response-guided duration dual therapy) versus 48 weeks of dual therapy with pegylated interferon alfa-2a plus ribavirin found no clear differences in relative risk estimates in patients stratified by age, sex, race, baseline fibrosis status, or body mass index.51 Absolute SVR rates were higher in patients younger than 45 years versus those older (83 vs. 70 percent), white patients versus Black patients (75 vs. 62 percent), patients with no or minimal fibrosis versus those with advanced fibrosis or cirrhotics (81 vs. 62 percent), and those with body mass index <25 versus those with higher body mass index (83 vs. 69 percent). Triple therapy was more effective than dual therapy in patients with a baseline HCV-RNA viral load ≥800,000 IU/mL (RR 2.0, 95% CI 1.7 to 2.4), but there was no difference in likelihood of achieving an SVR in those with a baseline viral load <800,000 IU/mL (RR 1.1, 95% CI 0.93 to 1.3), with triple therapy associated with similar absolute SVR rates across viral load strata (78 and 74 percent). In a second trial, SVR rates were similar among men (76 percent) and women (70 percent), age less than or greater than 50 (85 vs. 67 percent), and high versus low baseline viral load (69 vs. 74 percent).86

Another trial of patients with an extended rapid virologic response on triple therapy with telaprevir reported similar, high (80–90 percent) SVR rates with either 12 versus 36 additional weeks of dual therapy in patients stratified by race, body mass index, or fibrosis stage.87

## Key Question 3a What are the comparative harms associated with antiviral treatments?

- Dual therapy with pegylated interferon alfa-2b was associated with slightly greater risk of headache (three trials, pooled RR 1.1, 95% CI 1.1 to 1.2, I^2^=0%), lower risk of serious adverse events (two trials, pooled RR 0.76, 95% CI 0. 71 to 0. 88, I^2^=0%), lower risk of neutropenia (five trials, pooled RR 0.61, 95% CI 0.46 to 0.83, I^2^=38%), and lower risk of rash (two trials, pooled RR 0.79, 95% CI 0.71 to 0.88, I^2^=0%) than dual therapy with pegylated interferon alfa-2a plus ribavirin, with no differences in withdrawals due to adverse events (strength of evidence: moderate).
- Triple therapy with boceprevir for 48 weeks (pegylated interferon alfa-2b plus ribavirin for 4 weeks followed by addition of boceprevir for 44 weeks) was associated with increased risk of neutropenia (two trials, pooled RR 1.8, 95% CI 1.5 to 2.3, I^2^=0%), dysgeusia (two trials, pooled RR 2.5, 95% CI 2.0 to 3.2, I^2^=0%), anemia (two trials, pooled RR 2.0, 95% CI 1.4 to 2.8, I^2^=0%), and thrombocytopenia (two trials, pooled RR 3. 2, 95% CI 1. 2 to 8.2, I^2^=0%) than dual therapy with pegylated interferon alfa-2b plus ribavirin. The incidence of anemia was about 25 percent with triple therapy and the incidence of neutropenia about 33 percent, with severe anemia in 4–5 percent and severe neutropenia in 8–15 percent. There was no difference in the overall risk of withdrawal due to adverse events (strength of evidence: moderate).
- In two trials, there were no statistically significant differences between a 12-week regimen of triple therapy with pegylated interferon alfa-2a, ribavirin, and telaprevir versus dual therapy with pegylated interferon alfa-2a plus ribavirin in risk of any assessed adverse event (strength of evidence: moderate).
- In three trials, a 24-week regimen of triple therapy with telaprevir (pegylated interferon alfa-2a or alfa-2b, ribavirin, and telaprevir for 12 weeks followed by pegylated interferon alfa-2a plus ribavirin for 12 weeks) was associated with increased risk of anemia (three trials, pooled RR 1.3, 95% CI 1.1 to 1.5, I^2^=0%) and rash (three trials, pooled RR 1.4, 95% CI 1.1 to 1.7, I^2^=0%) versus dual therapy with pegylated interferon alfa-2a plus ribavirin for 48 weeks. Among patients randomized to the 24-week telaprevir regimen, one to two-thirds experienced rash (7–10 percent experienced severe rash) and 27–91 percent experienced anemia (4–11 percent experienced severe anemia). There was no difference in risk of withdrawal due to adverse events (strength of evidence: moderate).
- In one trial, response-guided triple therapy with telaprevir (pegylated interferon alfa-2a, ribavirin, and telaprevir for 8 or 12 weeks followed by response-guided duration pegylated interferon alfa-2a and ribavirin) was associated with increased risk of withdrawal due to adverse events (27 vs. 7.2 percent, RR 3.8, 95% CI 2.6 to 5.7), anemia (38 vs. 19 percent, RR 2.0, 95% CI 1.6 to 2.5), any rash (36 vs. 24 percent, RR 1.5, 95% CI 1.2 to 1.8), and severe rash (5 vs. 1 percent, RR 4.6, 95% CI 1.6 to 13) versus dual therapy with pegylated interferon alfa-2a plus ribavirin for 48 weeks (strength of evidence: low).

### Dual Therapy With Pegylated Interferon Alfa-2b Plus Ribavirin Compared With Dual Therapy With Pegylated Interferon Alfa-2a Plus Ribavirin

Seven head-to-head randomized trials of dual therapy with pegylated interferon alfa-2b plus ribavirin versus dual therapy with pegylated interferon alfa-2a plus ribavirin reported adverse events (Table 8, Appendix H: Evidence Table 1 and Evidence Table 2).20–23, 53, 57, 58 Characteristics of the trials were described earlier (see Key Question 2a).

Table 8 Harms: Dual therapy with pegylated interferon alfa-2b plus ribavirin versus dual therapy with pegylated interferon alfa-2a plus ribavirin

Outcome | Relative Risk (95% CI); I^2^ | Number of Trials
All-cause mortality | RR 0.85 (95% CI 0.26 to 2.8) | 1^22^
Serious adverse events | RR 0.76 (0. 61 to 0.95); I^2^=0% | 2^22, 23^
Withdrawal due to adverse events | RR 1.1 (0.73 to 1.7); I^2^=42% | 6^20, 22, 23, 53, 57, 58^
Neutropenia | RR 0.61 (0.46 to 0.83); I^2^=38% | 5^20–23, 57^
Anemia | RR 0.97 (0.72 to 1.3); I^2^=64% | 4^20, 22, 23, 57^
Thrombocytopenia | RR 0.87 (0.59 to 1.3); I^2^=0% | 3^20, 23, 57^
Depression | RR 1.1 (0.92 to 1.2); I^2^=0% | 3^20, 22, 57^
Fatigue | RR 1.0 (0.96 to 1.1): I^2^=7% | 3^20, 22, 57^
Flulike symptoms | RR 0.98 (0.85 to 1.1) | 1^23^
Headache | RR 1.1 (1.1 to 1.2); I^2^=0% | 3^20, 22, 57^
Myalgia | RR 1.1 (0.86 to 1.5); I^2^=33% | 3^20, 22, 57^
Rash | RR 0.79 (0.71 to 0.88); I^2^=0% | 2^22, 57^

RR = relative risk

There was no difference between dual therapy with pegylated interferon alfa-2b and dual therapy with pegylated interferon alfa-2a in risk of withdrawal due to adverse events (six trials, pooled RR 1.1, 95% CI 0.73 to 1.7, I^2^=42%) (Figure 12).20, 22, 23, 53, 57, 58 In the largest study, the IDEAL trial, about 13 percent of patients randomized to dual therapy with standard doses of pegylated interferon alfa-2b or pegylated interferon alfa-2a plus ribavirin withdrew due to adverse events, versus about 10 percent in those randomized to low-dose pegylated interferon alfa-2b plus ribavirin.22 Excluding the low-dose pegylated interferon alfa-2b arm of IDEAL from the pooled analysis resulted in a similar pooled estimate (six trials, RR 1.2, 95% CI 0.8 to 1.7, I^2^=30%).20, 22, 23, 53, 57, 58 One outlier trial found dual therapy with pegylated interferon alfa-2b associated with substantially higher risk of withdrawal due to adverse events than dual therapy with pegylated interferon alfa-2a (RR 4.2, 95% CI 1.5 to 12).20 Excluding it eliminated statistical heterogeneity, but the association remained non–statistically significant (five trials, pooled RR 0.88, 95% CI 0.7 to 1.1, I^2^=0%).22, 23, 53, 57, 58

Figure 12 Withdrawal due to adverse events: Dual therapy with pegylated interferon alfa-2b plus ribavirin versus dual therapy with pegylated interferon alfa-2a plus ribavirin

Figure 12 is a forest plot (i.e., a graph that depicts a meta-analysis plot) showing the individual and pooled relative risks and 95% confidence intervals (random effects model) from 6 trials for the comparison of pegylated interferon alfa-2a versus pegylated interferon alfa-2b on withdrawal due to adverse events. In the center of the graph is a solid vertical line corresponding to no effect. The individual studies are depicted at varying distances along this line as horizontal lines with a solid square in the middle. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The pooled effect is represented by a diamond at the bottom of the graph. Based on trials that evaluated withdrawal due to adverse events, pegylated interferon alfa-2a versus pegylated interferon alfa-2b there was no difference between pegylated interferon alfa-2b versus pegylated interferon alfa-2a in risk of withdrawal due to adverse events. Relative risk estimates ranged from 0.86 (95% confidence interval 0.70 to 1.04) to 4.25 (95% confidence interval 1.46 to 12.35). The pooled relative risk was 1.12, with a 95% confidence interval of 0.73 to 1.73; I-squared = 42.3%, p = 0.123.

Two trials found dual therapy with pegylated interferon alfa-2b plus ribavirin associated with lower risk of serious adverse events than dual therapy with pegylated interferon alfa-2a plus ribavirin (pooled RR 0. 76, 95% CI 0. 61 to 0.95, I^2^=0%).22, 23 In the IDEAL trial, serious treatment-related adverse events occurred in about 4 percent of patients.22 There were no statistically significant differences between regimens in risk of anemia, thrombocytopenia, depression, fatigue, myalgia, or flulike symptoms (Table 8). Dual therapy with pegylated interferon alfa-2b plus ribavirin was associated with slightly greater risk of headache (three trials, pooled RR 1. 1, 95% CI 1.1 to 1. 2, I^2^=0%)20, 22, 57 and slightly lower risk of rash (two trials, pooled RR 0.79, 95% CI 0.71 to 0.88, I^2^=0%)22, 57 and neutropenia (five trials, pooled RR 0.61, 95% CI 0.46 to 0.83, I^2^=38%)20–23, 57 than dual therapy with pegylated interferon alfa-2a plus ribavirin. In the IDEAL trial, dual therapy with either pegylated interferon (alfa-2a or alfa-2b) was associated with fatigue in about 65 percent of patients, headache in about 45 percent, nausea in about 40 percent, and myalgia in about 25 percent, neutrophil count <500/mm^3^ in about 5 percent, and hemoglobin <8.5 g/dL in about 3 percent.22

Excluding data from the IDEAL trial22 for patients who received pegylated interferon alfa-2b at a lower dose of 1.0 mcg/kg/week had little effect on pooled results, except the pooled estimate for depression became greater and statistically significant in favor of dual therapy with pegylated interferon alfa-2a (three trials, pooled RR 1.2, 95% CI 1.0 to 1.4, I^2^=0%)20, 22, 57 There was also reduced statistical heterogeneity in the analysis of neutropenia, but the risk estimate was unchanged (five trials, pooled RR 0.64, 95% CI 0.51 to 0.80, I^2^=0%).20–23, 57 Excluding two poor-quality trials21, 58 from the pooled analysis also had little effect on estimates.

### Trials of Triple Therapy With Pegylated Interferon (Alfa-2a or Alfa-2b), Ribavirin, and Boceprevir or Telaprevir

Five trials of triple therapy with pegylated interferon (alfa-2a or alfa-2b), ribavirin, and either boceprevir or telaprevir versus dual therapy with pegylated interferon (alfa-2a or alfa-2b) plus ribavirin without a protease inhibitor in patients with genotype 1 infection reported adverse events (Appendix H: Evidence Table 3 and Evidence Table 4).30–32, 85, 86 Characteristics of the trials were described earlier (see Key Question 2a).

#### Boceprevir

For boceprevir, two trials evaluated a 48-week fixed duration regimen consisting of dual therapy lead-in for 4 weeks with pegylated interferon alfa-2b plus ribavirin, with the addition of boceprevir from weeks 5 through 48.^30, 32^ Triple therapy was associated with increased risk of neutropenia (two trials, pooled RR 1.8, 95% CI 1.5 to 2.3, I^2^=0%), dysgeusia (two trials, pooled RR 2.5, 95% CI 2.0 to 3.2, I^2^=0%), anemia (two trials, pooled RR 2.0, 95% CI 1.4 to 2.8, I^2^=0%), and thrombocytopenia (two trials, pooled RR 3.2, 95% CI 1.2 to 8.2, I^2^=0%) versus dual therapy with pegylated interferon alfa-2b plus ribavirin (Table 9). About 25 percent of patients on triple therapy experienced anemia and about 33 percent neutropenia, with an incidence of severe neutropenia (neutrophil count <500 cells per mL) that ranged from 8–15 percent and an incidence of severe anemia (hemoglobin <80 or <85 g/L) of 4–5 percent. In addition, more patients randomized to boceprevir triple therapy used erythropoietin (43 and 87 percent) than those randomized to dual therapy (24 and 33 percent). One of the trials reported similar use of granulocyte stimulating agents with boceprevir triple therapy and dual therapy (8 vs. 6 percent).32 There were no statistically significant differences between triple therapy and dual therapy in risk of withdrawal due to adverse events, serious adverse events, depression, fatigue, headache, myalgia, chills/rigors, rash, or flulike symptoms (Table 9).

Table 9 Harms: Triple therapy with boceprevir, pegylated interferon alfa-2b, and ribavirin versus dual therapy with pegylated interferon alfa-2b plus ribavirin

Outcome | Triple Therapy With Pegylated Interferon and Ribavirin for 48 Weeks With Boceprevir From Weeks 5 to 48 vs. Dual Therapy for 48 Weeks: Relative Risk (95% CI); I^2^ | Number of Trials
Serious adverse events | RR 1.4 (0.93 to 2.2) | 1^32^
Withdrawal due to adverse events | RR 1.1 (0.77 to 1.4); I^2^=0% | 2^30, 32^
Neutropenia | RR 1.8 (1.5 to 2.3); I^2^=0% | 2^30, 32^
Anemia | RR 2.0 (1.4 to 2.8); I^2^=0% | 2^30, 32^
Thrombocytopenia | RR 3.2 (1.2 to 8.2); I^2^=0%), | 2^30, 32^
Depression | RR 0.87 (0.65 to 1.2) | 1^32^
Fatigue | RR 1.1 (0.82 to 1.5); I^2^=82% | 2^30, 32^
Flulike symptoms | RR 0.80 (0.58 to 1.1); I^2^=27% | 2^30, 32^
Headache | RR 1.1 (0.96 to 1.3); I^2^=0% | 2^30, 32^
Myalgia | RR 0.97 (0.76 to 1.2) | 1^32^
Rash | RR 1.1 (0.81 to 1.4) | 1^32^
Dysgeusia | RR 2.5 (2.0 to 3.2); I^2^=0% | 2^30, 32^

RR = relative risk

#### Telaprevir

For fixed duration triple therapy with telaprevir (administered during the first 12 weeks in combination with pegylated interferon and ribavirin), we focused on 12- or 24-week regimens, as 48 week triple therapy regimens have not been shown to be more effective than 24 weeks.31, 87 There were no differences between a 12-week regimen of triple therapy with telaprevir versus dual therapy with pegylated interferon alfa-2a plus ribavirin for 48 weeks in risk of serious adverse events, neutropenia, anemia, depression, fatigue, headache, myalgia, chills/rigors, rash, or flulike symptoms (Table 10). Rash was reported in 44–77 percent of patients randomized to 12 weeks of triple therapy with telaprevir, with 6 percent of patients reporting severe rash.31, 85

Table 10 Harms: Triple therapy with telaprevir, pegylated interferon (alfa-2a or alfa-2b), and ribavirin versus dual therapy with pegylated interferon (alfa-2a or alfa-2b) plus ribavirin

Outcome | 12-Week Regimen With Telaprevir vs. Dual Therapy for 48 Weeks: Relative Risk (95% CI); I^2^ | Number of Trials | 24-Week Regimen With Telaprevir vs. Dual Therapy for 48 Weeks: Relative Risk (95% CI); I^2^ | Number of Trials
All-cause mortality | No deaths reported | No deaths reported | No deaths reported | No deaths reported
Serious adverse events | RR 1.3 (0.68 to 2.5) | 1^85^ | RR 1.0, 95% CI 0.50 to 2.0) | 1^85^
Withdrawal due to adverse events | RR 1.5 (0.56 to 4.0) | 1^85^ | RR 1.1 (0.45 to 2.6); I^2^=60% | 2^85, 86^
Neutropenia | RR 0.11 (0.01 to 1.8) | 1^31^ | RR 0.81 (0.51 to 1.3); I^2^=53% | 2^31, 86^
Anemia | RR 1.2 (0.72 to 1.9); I^2^=0% | 2^31, 85^ | RR 1.3 (1.1 to 1.5); I^2^=0% | 3^31, 85, 86^
Thrombocytopenia | Not reported | Not reported | RR 1.8 (1.2 to 2.5) | 1^86^
Depression | RR 0. 90 (0.53 to 1.5); I^2^=0% | 2^31, 85^ | RR 1.0 (0.66 to 1.6); I^2^=0% | 2^31, 85^
Fatigue | RR 0.94 (0.63 to 1.4); I^2^=61% | 2^31, 85^ | RR 0.96 (0.74 to 1.2); I^2^=53% | 3^31, 85^
Flulike symptoms | RR 0.76 (0.56 to 1.0); I^2^=0% | 2^31, 85^ | RR 0.87(0.63 to 1.2); I^2^=50% | 3^31, 85, 86^
Headache | RR 0.87 (0.65 to 1.2); I^2^=0% | 2^31, 85^ | RR 0.83 (0.69 to 1.0); I^2^=0% | 3^31, 85, 86^
Myalgia | RR 0.71 (0.40 to 1.3); I^2^=0% | 2^31, 85^ | RR 0.76 (0.43 to 1.3); I^2^=57% | 3^31, 85^
Rash | RR 1.2 (0.92 to 1.7); I^2^=0% | 2^31, 85^ | RR 1.4 (1.1 to 1.7);I^2^=0% | 3^31, 85, 86^

CI = confidence interval; RR = relative risk

A 24-week regimen of triple therapy with telaprevir was associated with increased risk of anemia (three trials, pooled RR 1.3, 95% CI 1.1 to 1.5, I^2^=0%) and increased risk of rash (three trials, pooled RR 1.4, 95% CI 1.1 to 1.7, I^2^=0%) versus dual therapy for 48 weeks, but there were no statistically significant differences in risk of serious adverse events, neutropenia, depression, fatigue, headache, chills/rigors, or flulike symptoms (Table 10).31, 85, 86 Triple therapy was also associated with increased risk of thrombocytopenia, but this outcome was only evaluated in one trial (RR 1.8, 95% CI 1.2 to 2.5).86 One-third to two-thirds of patients randomized to the 24-week regimen with telaprevir experienced a rash, with the incidence of severe rash ranging from 7–10 percent.31, 85, 86 The incidence of anemia with telaprevir was 27–91 percent,31, 85, 86 with two trials31, 85 reporting severe anemia in 4–9 percent of patients and another trial86 reporting grade 3 anemia (hemoglobin <8 g/dl) in 11 percent of patients. Two trials found no difference in risk of withdrawal due to adverse events (RR 1.1, 95% CI 0.45 to 2.6, I^2^=60%).85, 86 The third trial did not report withdrawal due to adverse events separately for the 24 week telaprevir regimen, but reported a similar trend towards higher risk of withdrawal due to adverse events for all telaprevir regimens combined (12, 24, or 48 weeks) versus dual therapy (21 vs. 11 percent, RR 2.0, 95% CI 0.97 to 4.1).31

One trial evaluated triple therapy with telaprevir for 8 or 12 weeks followed by response-guided dual therapy for 12 or 36 weeks versus dual therapy for 48 weeks.51 Since the two telaprevir regimens were associated with similar rates of harms, results were combined. The trial found response-guided therapy with telaprevir associated with increased risk of withdrawal due to adverse events (27 vs. 7.2 percent, RR 3.8, 95% CI 2.6 to 5.7), anemia (38 vs. 19 percent, RR 2.0, 95% CI 1.6 to 2.5), any rash (36 vs. 24 percent, RR 1.5, 95% CI 1.2 to 1.8), and severe rash (5 vs. 1 percent, RR 4.6, 95% CI 1.6 to 13).

A trial of extended early virologic responders (undetectable HCV-RNA levels at weeks 4 and 12) to telaprevir triple therapy reported very similar rates of adverse events in patients randomized after 20 weeks of therapy to 4 weeks versus 28 more weeks of dual therapy.87 The overall incidence of rash was 38 percent (severe rash 5 percent) and the incidence of anemia 42 percent (severe anemia 6 percent).

## Key Question 3b Do these harms differ according to patient subgroup characteristics, including HCV genotype, age, race, sex, stage of disease, or genetic markers?

- No trial of dual therapy with pegylated interferon alfa-2b plus ribavirin versus dual therapy with pegylated interferon alfa-2a plus ribavirin reported harms in patients stratified by factors such as HCV genotype, age, race, sex, stage of disease, or genetic markers. Three trials that restricted enrollment to patients with genotype 1 infection reported risk estimates for risk of harms that were similar to the risk estimates based on all trials (strength of evidence: insufficient).
- No trial evaluated harms associated with triple therapy with pegylated interferon, ribavirin, and boceprevir or telaprevir versus dual therapy with pegylated interferon plus ribavirin in patient subgroups. All trials evaluated patients with genotype 1 infection (strength of evidence: insufficient).

No trial of dual therapy with pegylated interferon alfa-2b plus ribavirin versus dual therapy with pegylated interferon alfa-2a plus ribavirin reported harms in patients stratified by factors such as HCV genotype, age, race, sex, stage of disease, or genetic markers. A subgroup of three trials of dual therapy with pegylated interferon alfa-2a versus pegylated interferon alfa-2b that restricted enrollment to patients with genotype 1 infection reported pooled estimates for risk of harms that were similar to the risk estimates based on all trials.22, 58, 59 All trials of triple therapy including protease inhibitors restricted enrollment to patients with genotype 1 infection.

## Key Question 4 Have improvements in intermediate outcomes (SVR, histologic changes) been shown to reduce the risk or rates of adverse health outcomes from HCV infection?

- A large Veterans Affairs (VA) study that controlled well for potential confounders found an SVR after antiviral therapy associated with lower risk of all-cause mortality versus no SVR (adjusted HR 0.71 [0.60–0.86], 0.62 [0.44–0.87] and 0.51 [0.35–0.75] for genotypes 1, 2, and 3, respectively). Eighteen other cohort studies found an SVR associated with decreased risk of all-cause mortality, liver-related mortality, HCC, and other complications of end-stage liver disease versus no SVR, with stronger effect estimates than the VA study (adjusted HRs generally ranged from around 0.10 to 0.33). However, the studies had methodological shortcomings, including inadequate handling of confounders, and 10 were conducted in Asia (strength of evidence: moderate).
- Nine studies found an SVR associated with greater improvement in measures related to quality of life (generic or disease-specific) 24 weeks after the end of antiviral treatment versus no SVR, with differences averaging less than 5 to 10 points on various SF-36 domains. All studies were poor quality and were characterized by failure to adjust for confounders, high loss to followup, and failure to blind patients to SVR status (strength of evidence: low).

### All-Cause Mortality, Liver-Related Mortality, and Complications Related to Chronic Hepatitis C Virus Infection

Nineteen cohort studies evaluated the association between achieving an SVR following interferon-based antiviral therapy and mortality (all-cause or liver-related) or complications related to chronic HCV infection, such as HCC, ascites, hepatic encephalopathy, or gastrointestinal bleeding, and these 19 studies reported risk estimates adjusted for potential confounders (Table 11, Appendix F, Appendix H: Evidence Table 9).8, 9, 89–105 Sample sizes ranged from 105 to 16,864 subjects and duration of followup ranged from 3 to 9 years. Ten studies were conducted in Asia.89, 95–100, 102, 104, 105 Four studies focused on patients who received pegylated interferon (alfa-2a or alfa-2b) plus ribavirin.8, 9, 91, 94 The others evaluated patients who received nonpegylated interferon plus ribavirin, or either pegylated or nonpegylated interferon monotherapy. Ten studies8, 89, 92, 97–101, 104, 105 evaluated general populations of HCV patients treated with antiviral therapy (baseline rate of cirrhosis ranged from 3–20 percent) and nine studies9, 90, 91, 93–96, 102, 103 focused on patients with advanced fibrosis or cirrhosis at the time of antiviral treatment. Six studies90, 93–96, 102 enrolled patients with cirrhosis only, and the baseline rate of cirrhosis ranged from 21–77 percent in three others.9, 91, 103

Table 11 Sustained virologic response and clinical outcomes

Author Country N Quality | Comparison Definition of Sustained Virologic Response | Population Characteristics | Treatments | Results
Arase, 2007^89^ Japan N=500 Quality: Fair | SVR vs. no SVR SVR=Undetectable HCV-RNA 6 months after completion of long-term IFN therapy | SVR (n=140) vs. no SVR (n=360) Mean age (years): 63 vs. 64 (p=0.07) Female: 41% vs. 53% (p=0.01) Race: Not reported Genotype 1b: 34% vs. 71% (p<0.0001) Viral load (kIU/ml): 172 vs. 661 (p<0.0001) Cirrhosis (Knodell F4): 9% vs. 16% (p=0.009) | Interferon-2a or Interferon-2b monotherapy: 94% Interferon plus ribavirin combination therapy: 6% | SVR vs. no SVR HCC: Adjusted HR 0.19 (0.08–0.45) All-cause mortality: Adjusted HR 0.39 (0.16–0.93) Liver-related mortality: Adjusted HR 0.13 (0.03–0.59)
Backus, 2011^8^ U.S. N=16,864 Quality: Fair | SVR vs. no SVR SVR=Undetectable HCV-RNA 6 months after completion of antiviral therapy | SVR vs. no SVR (genotypes 1 [n=12,166], 2 [n=2904], and 3 [n=1794], respectively) Mean age (years): 51 vs. 52, 53 vs. 53. and 51 vs. 51 Female: 5% vs. 4%, 4% vs. 3%, and 4% vs. 3% Non-White: 40% vs. 51%, 33% vs. 31%, and 30% vs. 29% Genotype: Results stratified by genotype Viral load ≥500,000 IU/mL: 70% vs. 82%, 78% vs. 83%, and 64% vs. 68% Cirrhosis: 9% vs. 15%, 7% vs. 12%, and 12% vs. 20% | Pegylated interferon (alfa-2a or alfa-2b) plus ribavirin | SVR vs. no SVR (genotypes 1, 2, and 3, respectively) All-cause mortality: Adjusted HR 0.71 (0.60–0.86), 0.62 (0.44–0.87), and 0.51 (0.35–0.75)
Bruno, 2007^90^ Italy N=883 Quality: Fair | SVR vs. no SVR SVR=Undetectable HCV-RNA 6 months after completion of antiviral therapy | SVR (n=124) vs. no SVR (n=759) Mean age (years): 53 vs. 44 (p=0.004) Female: 27% vs. 38% (p<0.001) Non White: 0 (0%) vs. 0 (0%) Race: Not reported Genotypes 1 and 4: 37% vs. 63% (p<0.001) Viral load: Not reported Cirrhosis: All (inclusion criterion) | Interferon monotherapy | SVR vs. no SVR Ascites, encephalopathy, or gastrointestinal bleeding: Not calculated, 0 events/1061 person-years vs. 107 events/5703 person-years (1.88 events/100 person-years) HCC: Adjusted HR 0.39 (0.17–0.88) Liver-related mortality: 0.14 (0.04–0.59)
Cardoso, 2010^91^ France N=307 Quality: Fair | SVR vs. no SVR SVR=Undetectable HCV-RNA 6 months after completion of antiviral therapy | SVR (n=103) vs. no-SVR (n=204) Mean age (years): 55 vs. 55 (p=0.93) Female: 30% vs. 34% (p=0.51) Race: Not reported Genotype 1: 36% vs. 72% (p<0.001) Viral load (log_10_ l/ml): 5.5 vs. 5.7 (p=0.08) Cirrhosis (METAVIR F4): 53% vs. 61% (p=0.19) | Pegylated interferon (alfa-2a or alfa-2b) and ribavirin: 252 (82%) Pegylated interferon monotherapy: 22 (7%) Nonpegylated interferon with or without ribavirin: 33 (11%) | SVR vs. no SVR HCC: Adjusted HR 0.33 (0.23–0.89) Ascites or variceal bleeding: Adjusted HR 0.21 (0.05–0.92) Liver-related mortality: Adjusted HR 0.27 (0.08–0.95)
Coverdale, 2004^92^ Australia N=343 Quality: Poor | SVR vs. response relapse vs. nonresponse SVR=Undetectable HCV-RNA on at least 2 occasions at least 2 years after completion of therapy | Demographics for all treated patients (not reported by SVR status) Median age (years): 37 Female: 33% Race: Not reported Genotype 1: 38% Viral load: Not reported Median fibrosis score (Scheuer): 2 | Interferon-2a or Interferon-2b | SVR vs. response-relapse vs. nonresponse Liver-related complications (hepatic decompensation, complications of portal hypertension, HCC, liver transplantation, and liver-related mortality) at 10 years: Not statistically significant in multivariate analysis, adjusted HR not reported (p=0.06) HCC at 10 years: Not statistically significant in multivariate analysis, adjusted HR and p value not reported Liver transplant or liver-related death at 10 years: Not statistically significant in multivariate analysis, adjusted HR not reported (p=0.20)
El Braks, 2007^93^ France N=113 Quality: Poor | SVR vs. no SVR SVR=Undetectable HCV-RNA 6 months after completion of antiviral therapy | SVR (n=37) vs. no SVR (n=76) Mean age (years): 51 vs. 56 (p=0.02) Female: 16% vs. 50% (p=0.0005) Race: Not reported HCV genotype 1: 36% vs. 73% (p=0.0001) Viral load: Not reported Cirrhosis: All (inclusion criterion) | Interferon monotherapy: 35/113 (31%) Interferon + ribavirin: 40/113 (35%) Pegylated interferon + ribavirin: 38/113 (34%) | SVR (n=37) vs. no SVR (n=76) Clinical events (HCC, ascites, hepatic encephalopathy, or death): Adjusted HR 0.14 (0.04–0.45)
Fernandez-Rodriguez, 2010^94^ Spain N=509 Quality: Poor | SVR vs. no SVR SVR=Undetectable HCV-RNA 6 months after completion of antiviral therapy | SVR (n=174) vs. no SVR (n=394) Mean age (years): 51 vs. 52 (p=0.31) Female: 69% vs. 73%, p=0.37 Genotype 1: 24% vs. 55% (p=0.001) Race: Not reported Viral load (10^6^ IU/ml): 1.7 vs. 3.1 (p=0.001) Cirrhosis: All (inclusion criterion) | Pegylated interferon-2a or 2b | SVR vs. no SVR Combined clinical endpoint (hepatic decompensation, upper gastrointestinal bleeding secondary to rupture of esophageal or gastric varices, HCC, liver transplantation, and liver-related or liver-unrelated mortality): Adjusted HR 0.38 (0.18–0.76)
Hasegawa, 2007^95^ Japan N=105 Quality: Fair | SVR vs. no SVR SVR=Sustained undetectable HCV-RNA after completion of antiviral therapy (duration of undetectability not specified) | SVR (n=48) vs. no SVR (n=58) Age >56 years: 60% vs. 55% (p>0.05) Female: 35% vs. 34% (p>0.05) Race: Not reported Genotype 1b: 19% vs. 21% (p>0.05) Viral load ≥100 KIU/ml or ≥1 mg/mL: 25% vs. 62% (p<0.001) Cirrhosis: All (inclusion criterion) | Natural or recombinant interferon alfa: 67% Natural interferon-beta: 31% Both: 1.6% | SVR vs. no SVR HCC: Adjusted HR 0.18 (0.04–0.81)
Hung, 2006^96^ Taiwan N=132 Quality: Fair | SVR vs. no SVR SVR=Undetectable HCV-RNA 6 months after completion of antiviral therapy | SVR (n=73) vs. no SVR (n=59) Mean age (years): 55 vs. 58 (p=0.07) Female: 43% vs. 54% (p=0.12) Race: Not reported Genotype 1b: 27% vs. 78% (p<0.001) Viral load ≥2 × 10^6^ copies/ml: 21% vs. 51% (p<0.001) Cirrhosis: 100% (inclusion criterion) | Interferon-2b plus ribavirin | SVR vs. no SVR HCC: Adjusted HR 0.28 (0.09–0.92)
Imazeki, 2003^97^ Japan N=459 Quality: Fair | SVR vs. no SVR SVR=Undetectable HCV-RNA 6 months after completion of antiviral therapy | Demographics for all treated patients (not reported by SVR status) Mean age (years): 49 Female: 36% Race: Not reported Genotype 1: 74% Viral load: Not reported Cirrhosis (Desmet F4): 13% | Interferon-2a: 84% Interferon-2b: 12% Both: 4% | SVR vs. no SVR^a^ Liver-related mortality: Adjusted HR 0.11 (0.01–0.96) All-cause mortality: Adjusted HR 0.12 (0.01–1.3)
Innes, 2011^98^ UK N=1,215 Quality: Fair | SVR vs. no SVR SVR=Undetectable HCV-RNA > 6 months after completion of antiviral therapy | SVR (560) vs. no SVR (655) Mean age (years): 42 overall Female: 34% vs. 28% Non-White: 10% vs. 6% Genotype 1: 19% vs. 50% Viral load: Not reported Cirrhosis: 10% vs. 18% | Pegylated interferon plus ribavirin: 61% Pegylated interferon monotherapy: 1% Interferon plus ribavirin: 21% Interferon monotherapy: 18% | SVR vs. no SVR Liver-related mortality: Adjusted HR 0.22 (0.09–0.58) Liver-related hospital episode: Adjusted HR 0.22 (0.15–0.34)
Izumi 2005^99^ Japan N=495 Quality: Fair | SVR vs. no SVR SVR=Undetectable HCV-RNA 6 months after completion of antiviral therapy | Demographics for patients treated with interferon monotherapy and interferon plus ribavirin combination therapy, respectively (not reported by SVR status) Mean age (years): 52 and 58 Female: 43% and 44% Race: Not reported Genotype 1b: 71% and 80% Median viral load (kIU/ml): 470 and 680 Cirrhosis: 7% and 2% | Interferon monotherapy: 69% Interferon-2b plus ribavirin combination therapy: 34% | SVR vs. no SVR HCC: Adjusted HR 0.36 (0.04–0.83)
Kasahara 2004^100^ Japan N=2,698 Quality: Poor | SVR vs. no SVR SVR=Undetectable HCV-RNA 6 months after completion of antiviral therapy | SVR (n=738) vs. no-SVR (n=1930) Median age (years): 51 vs. 54 (p=0.12) Female: 31% vs. 37% (p=0.32) Race: Not reported Genotype 1: Not reported Viral load: Not reported Cirrhosis (Desmet F4): 3.0% vs. 5.4% (p=0.34) | Interferon | SVR vs. no SVR Liver-related mortality: Adjusted HR 0.04 (0.005–0.30) All-cause mortality: Adjusted HR 0.14 (0.06–0.35)
Maruoka 2012^101^ Japan N=577 Quality: Fair | SVR vs. no SVR SVR=Undetectable HCV-RNA >6 months after completion of antiviral therapy | For all treated patients (not reported by SVR status) Mean age (years): 50 Female: 36% Non-White: Not reported Genotype 1: 73% Viral load high (≥100 KIU, 100 kc, 1.0 Meq, 10^4^/50 microL, or 30 core antigens): 69% Cirrhosis: 10% | Interferon-alfa or -beta monotherapy: 83% Interferon-alfa or -beta sequential therapy: 3.3% Interferon-alfa plus ribavirin combination therapy: 14% | SVR vs. no SVR^a^ All-cause mortality: Adjusted HR 0.20 (0.08–0.54) HCC: Adjusted HR: 0.12 (0.04–0.40)
Morgan, 2010^9^ U.S. Name: HALT-C N=526 Quality: Fair | SVR vs. no SVR SVR=Undetectable HCV-RNA 6 months after completion of antiviral therapy | SVR (n=140) vs. breakthrough/relapse (n=77) vs. no SVR (n=309) Mean age (years): 49 vs. 49 vs. 50 (p=0.23) Female: 24% vs. 26% vs. 30% (p=0.30) Non-White: 20% vs. 20% vs. 32% (p=0.001) Genotype 1: 72% vs. 86% vs. 94% (p<0.0001) Viral load: Not reported Cirrhosis (Ishak 5 or 6): 21% vs. 31% vs. 43% (p<0.0001) | Pegylated interferon-2a-180 μg/week + ribavirin 1000–12000 mg/day for 24weeks | SVR vs. no SVR All-cause mortality or liver transplantation: Adjusted HR 0.17 (0.06–0.46) Any liver-related outcome (decompensated liver disease [ascites, variceal bleeding, hepatic encephalopathy, spontaneous bacterial peritonitis], HCC, liver transplantation, liver-related mortality): Adjusted HR 0.15 (0.06–0.38) Decompensated liver disease: Adjusted HR 0.13 (0.03–0.53) HCC: Adjusted HR 0.19 (0.04–0.80) Liver-related mortality or liver transplantation: Adjusted HR 0.12 (0.03–0.48)
Shiratori, 2005^102^ Japan N=271 Quality: Poor | SVR vs. no SVR SVR=Undetectable HCV-RNA 6 months after completion of antiviral therapy | For all treated patients (not reported by SVR status) Mean age (years): 57 Female: 62% Race: Not reported Genotype 1: 75% Viral load (log_10_ copies/ml): 5.8 Cirrhosis: 100% (inclusion criterion) | Interferon alfa-2a: 58% Natural interferon alfa: 42% | SVR vs. no SVR^a^ HCC: Adjusted HR 0.40 (0.18–0.89) All-cause mortality: Adjusted HR 0.07 (0.01–0.56)
Veldt, 2007^103^ Europe and Canada N=479 Quality: Poor | SVR vs. no SVR SVR=Undetectable HCV-RNA 6 months after completion of antiviral therapy | SVR (n=142) vs. no-SVR (n=337) Mean age (years): 48 vs. 49 (p=0.45) Female: 27% vs. 32% (p=0.23) Race: Not reported Genotype 1: 39% vs. 67% (p<0.001) Viral load (x10^5^ IU/mL): 8.5 vs. 8.0 (p=0.75) Cirrhosis (Ishak 5 or 6): 71% vs. 77% (p=0.45) | Interferon monotherapy: 27% Interferon and ribavirin: 27% Pegylated interferon monotherapy: 2.1% Pegylated interferon and ribavirin: 43% | SVR vs. no SVR Any event (death, liver failure, and HCC): Adjusted HR 0.20 (0.07–0.58) All-cause mortality: Adjusted HR 0.31 (0.07–1.4) Liver-related mortality: Adjusted HR 0.19 (0.02–1.4) HCC: Adjusted HR 0.46 (0.12–1.70)
Yoshida, 2002^104^ Japan N=459 Quality: Poor | SVR vs. no SVR SVR=Undetectable HCV-RNA 6 months after completion of antiviral therapy | SVR (817) vs. non-SVR (1613) Mean age (years): 48 vs. 51 Female: 30% vs. 40% Race: Not reported Genotype: Not reported Viral load: Not reported Cirrhosis (Desmet F4): 6.5% vs. 11% | Interferon-alfa: 84% Interferon-beta: 14% Both: 2% | SVR vs. no SVR^a^ Liver-related mortality: Adjusted HR 0.13 (0.02–0.66) All-cause mortality Adjusted HR 0.32 (0.12–0.86)
Yu, 2006^105^ Taiwan N=1,057 Quality: Poor | SVR vs. no SVR SVR=Undetectable HCV-RNA 6 months after completion of antiviral therapy | For all treated patients (not reported by SVR status) Mean age (years): 47 Female: 40% Race: Not reported Genotype 1: 46% Viral load: Not reported Cirrhosis (criteria not reported): 16% | Interferon monotherapy: 28% Interferon plus ribavirin combination therapy: 72% | SVR vs. no SVR^a^ All-cause mortality: Adjusted HR 0.28 (0.08–1.0) HCC: Adjusted HR 0.25 (0.13–0.50)

HCV = hepatitis C virus; HR = hazard ratio; NA = not applicable; HCC = hepatocellular carcinoma; HCV-RNA = hepatitis C virus-ribonucleic acid; SVR = sustained virologic response

a Calculated from estimates of SVR compared with untreated and no SVR compared with untreated.

All studies had methodological shortcomings (Appendix H: Evidence Table 10). Eight studies92–94, 100, 102–105 were rated poor quality and the remainder fair quality. Although all of the studies reported adjusted risk estimates, only eight8, 89, 91, 95–98, 101 of the 19 studies evaluated five key potential confounders (age, sex, genotype, viral load, and fibrosis stage). No study clearly described assessment of outcomes blinded to SVR status and only five studies8, 94, 97, 98, 102 reported the number of patients who met inclusion criteria but were excluded due to missing data or loss to followup.

For general populations of HCV patients treated with antiviral therapy, the largest study (n=16,864) had the fewest methodological shortcomings and was also conducted in the United States. (Appendix H: Evidence Table 11).8 It adjusted for multiple potential confounders, including age, sex, viral load, presence of cirrhosis, multiple comorbidities, aspartate aminotransferase (AST) and alanine aminotransferase (ALT) levels, and others; and stratified results by genotype. In a predominantly male (>95 percent) population of veterans, the study found SVR after antiviral therapy associated with decreased risk of all-cause mortality versus no SVR, after a median followup of 3.8 years (adjusted HR 0.71 [0.60 to 0.86], 0.62 [0.44 to 0.87] and 0.51 [0.35 to 0.75] for genotypes 1, 2, and 3, respectively). Although point estimates showed somewhat smaller effects for genotype 1 compared with genotypes 2 or 3, the confidence intervals for the three genotypes overlapped. The very rapid (within 3 months after assessing for SVR for genotype 3) separation of mortality curves suggests possible residual confounding, given the expected duration required to observe benefits in long-term clinical outcomes. Clinical outcomes other than mortality were not assessed.

Nine other studies also evaluated the association between achieving an SVR and mortality or hepatic complications in general populations of HCV patients (Appendix H: Evidence Table 11).89, 92, 97–101, 104, 105 One fair-quality study from Scotland found an SVR after antiviral therapy associated with decreased risk of liver-related mortality (adjusted HR 0.22, 95% CI 0.09 to 0.58) and liver-related hospital episodes (adjusted HR 0.22, 95% CI 0.15 to 0.34) versus no SVR.98 One Australian study (poor quality) found no statistically significant association between virologic response status (SVR, response-relapse, or nonresponse) and all-cause mortality, liver-related mortality, or HCC, although trends favored the SVR group.92 The other seven studies (three poor quality), all conducted in Asia, each found an SVR after antiviral therapy associated with substantially lower risk of all-cause mortality, liver-related mortality, or HCC versus no SVR.89, 97, 99–101, 104, 105 Six studies reported substantially lower risk for all-cause mortality than the U.S. study described above (adjusted HR range 0.12 to 0.39).89, 97, 100, 101, 104, 105 For liver-related mortality, four studies89, 97, 100, 104 reported adjusted HRs that ranged from 0.04 to 0.17 and for HCC, four studies reported adjusted HRs that ranged from of 0.12 to 0.36.^89, 99, 101, 105^

Six studies of European or North American populations (two poor quality) evaluated the association between achieving an SVR after antiviral therapy and clinical outcomes in patients with advanced fibrosis and cirrhosis prior to antiviral treatment (Appendix H: Evidence Table 11).9, 90, 91, 93, 94, 103 One study (fair quality) found an SVR after antiviral therapy associated with decreased risk of all-cause mortality or liver transplantation versus no SVR (adjusted HR 0.17, 95% CI 0.06 to 0.46).9 Another study (poor quality) found an SVR associated with decreased risk of all-cause mortality (adjusted HR 0.31, 95% CI 0.07 to 1.4).103 Four studies found an SVR associated with decreased risk of liver-related mortality and HCC versus no SVR (adjusted HRs ranged from 0.12 to 0.27 and from 0.19 to 0.46, respectively).9, 90, 91, 103 For complications of chronic HCV infection (variably defined), six studies reported adjusted HRs that ranged from 0.13 to 0.38.^9, 90, 91, 93, 94, 103^ Results from three Asian studies95, 96, 102 (one poor quality) were consistent with the North American and European studies. One study102 found an SVR associated with lower risk of all-cause mortality versus no SVR (adjusted HR 0.07, 95% CI 0.09 to 0.56) and three studies95, 96, 102 found an SVR associated with lower risk of HCC versus no SVR (adjusted HR range 0.18 to 0.40).

One study stratified results according to presence or absence of cirrhosis of baseline. Although effects of an SVR versus no SVR on all-cause mortality appeared more favorable in patients with cirrhosis compared with those without cirrhosis, estimates were imprecise and confidence intervals overlapped substantially, precluding strong conclusions.104

The only study to evaluate the association between improvement in histological outcomes and clinical outcomes did not meet inclusion criteria because it did not report adjusted risk estimates.106 In 96 patients with chronic HCV infection and cirrhosis, it found regression of cirrhosis (defined as a decrease in METAVIR fibrosis score from 4 to ≤2) after interferon-based therapy associated with decreased risk of liver-related events (ascites, hepatic encephalopathy, variceal bleeding, spontaneous bacterial peritonitis, HCC, or liver transplantation) or death (0 vs. 4 events/100 patients-years, p=0.002) after a median followup of 10.5 years. Transplantation-free survival was 100 percent in patients with regression of cirrhosis compared with 74 percent in those without regression (p=0.02). In addition to failure to analyze potential confounders, the study only included patients who underwent a post-treatment biopsy, which could have resulted in selection bias, and cirrhosis regression only occurred in 13 patients, resulting in low precision.

### Quality of Life

Nine cohort studies evaluated the association between an SVR following interferon-based antiviral therapy and outcomes related to quality of life (Appendix H: Evidence Table 12).107–115 Sample sizes ranged from 138 to 1121. Only one study107 reported adjusted risk estimates, thus we included studies that reported unadjusted risk estimates. Eight studies107, 108, 110–115 evaluated patients originally enrolled in randomized trials27, 41, 116–119 of antiviral treatments. Two studies evaluated the same cohort of patients113, 115 and one study114 evaluated a cohort of patients included in a study108 that reported results for three pooled cohorts. One study included patients randomized to pegylated interferon (alfa-2a or alfa-2b) plus ribavirin, although results were not stratified according to what type of antiviral therapy was received.111 The remainder of the studies evaluated nonpegylated interferon plus ribavirin combination therapy, or nonpegylated or pegylated interferon monotherapy.

All studies were rated poor quality (Appendix H: Evidence Table 13). One study adjusted for potential confounders,107 one study reported low loss to followup,112 and one study reported blinding of patients to virologic outcomes.110 Followup was at 24 weeks after treatment (typically 72 weeks from start of treatment) in all studies. No study evaluated longer term quality of life according to SVR status.

All of the studies found patients with an SVR experienced better improvement from baseline on individual SF-36 domains as well as SF-36 physical and mental component summary scores compared with those with no SVR (Appendix H: Evidence Table 14). In most studies, differences between patients with and without an SVR on various SF-36 domains were less than 5 to 10 points. Patients with an SVR also reported greater improvements from baseline on hepatitis C specific quality of life measures (health distress and limitations) and measures related to fatigue and sleep somnolence. However, results are subject to the methodological limitations of the studies.

One study also found achieving an overall response (defined as SVR plus 2-point improvement in the Histological Activity Index) associated with improved quality of life compared with those without an overall response.113