# Peer Reviewers

Robert Gish, M.D.

School of Medicine

University of California, San Diego

San Diego, CA

Adelita Gonzales Cantu, Ph.D., R.N.

School of Nursing

University of Texas Health Science Center at San Antonio

San Antonio, TX

Fasiha Kanwal, M.D.

Saint Louis University School of Medicine

St. Louis, MO

Averell Sherker, M.D.

National Institutes of Health, NIDDK

Bethesda, MD

Donna Sweet, M.D., M.A.C.P.

Via Christi Regional Medical Center-St. Francis Campus

Wichita, KS