# Technical Expert Panel

Miriam Alter, Ph.D., M.P.H.

Professor, Infectious Disease Epidemiology

Department of Internal Medicine

Division of Infectious Disease

University of Texas

Austin, TX

Kirsten Bibbins-Domingo, Ph.D., M.D.

Associate Professor of Medicine and Epidemiology & Biostatistics

University of California, San Francisco

San Francisco, CA

Robert Gish, M.D.

Co-director, Chief of Clinical Hepatology

Professor of Clinical Medicine

University of California, San Diego

San Diego, CA

Stephen E. Livingston, M.D.

Alaska Native Tribal Health Consortium

Liver Disease and Hepatitis Program

Anchorage, AK

Bruce A. Runyon, M.D.

Chief, Liver Service

Professor of Medicine

Loma Linda University Medical Center

Loma Linda, CA

Bryce Smith, Ph.D.

Viral Hepatitis Division

Centers for Disease Control and Prevention

Atlanta, GA

Donna E. Sweet, M.D., M.A.C.P.

American College of Physicians

Professor of Medicine

University of Kansas School of Medicine

Wichita, KS

Timothy Wilt, M.D., M.P.H.

Professor, Department of Medicine,

Minneapolis VA Medical Center

University of Minnesota

Minneapolis, MN