# Key Informants

Miriam Alter, Ph.D., M.P.H.

Professor, Infectious Disease Epidemiology

Department of Internal Medicine

Division of Infectious Disease

University of Texas

Austin, TX

Michael Ninburg, M.P.A.

Executive Director

Hepatitis Education Project

Seattle, WA

Janet Patin, M.D.

Oregon Rural Practice-based Research Network (ORPRN)

Dunes Family Clinic

Reedsport, OR

John Ward, M.D., M.P.H.

Director, Viral Hepatitis Division

Centers for Disease Control and Prevention

Atlanta, GA

Barbara Yawn, M.D., M.Sc., F.A.A.C.P.

Director of Research, Olmstead Medical Center

University of Minnesota

Minneapolis, MN