# Overall Strength of Evidence

Key Question | Number of Studies | Quality (Good, Fair, Poor) | Consistency (High, Moderate, Low) | Directness (Direct or Indirect) | Precision (High, Moderate, Low) | Number of Subjects | Strength of Evidence
1a. What is the comparative effectiveness of antiviral treatment in improving health outcomes in patients with HCV infection?
Long-term clinical outcomes | No studies | No studies | Unknown (no studies) | No studies | No studies | No subjects | Insufficient
Short-term mortality | 3 randomized trials | Fair | High | Direct | Low | N = 5,255 | Low
Short-term quality of life | 1 randomized trial | Fair | Unknown (one study) | Direct | Low | N = 516 | Low
1b. How does the comparative effectiveness of antiviral treatment for health outcomes vary according to patient subgroup characteristics, including but not limited to HCV genotype, race, sex, disease severity or genetic markers?
Any clinical outcome | No studies | No studies | No studies | No studies | No studies | No subjects | Insufficient
2a. What is the comparative effectiveness of antiviral treatments in improving intermediate outcomes, such as the rate of viremia, aminotransaminase levels, and histologic changes?
SVR: Dual therapy with pegylated interferon alfa-2a plus ribavirin vs. pegylated interferon alfa-2b plus ribavirin | 7 randomized trials | Fair | High | Direct | High | N = 4,660 | Moderate
Duration effects, dual therapy with pegylated interferon plus ribavirin (genotype 2 or 3)
SVR: 48 vs. 24 weeks | 2 randomized trials | Fair | High | Direct | Moderate | N = 609 | Moderate
SVR: 24 vs. 12–16 weeks | 4 randomized trials | Fair | High | Direct | Moderate | N = 2,599 | Moderate
SVR: 24 vs. 12–16 weeks in patients with rapid virological response | 3 randomized trials | Fair | High | Direct | Moderate | N = 583 | Moderate
Dose effects, dual therapy with pegylated interferon plus ribavirin (genotype 2 or 3)
SVR: Lower vs. higher dose pegylated interferon | 6 randomized trials | Fair | High | Direct | Moderate | N = 865 | Moderate
SVR: Lower vs. higher dose ribavirin | 3 randomized trials | Fair | Moderate | Direct | Moderate | N = 2,605 | Moderate
SVR: Lower vs. higher dose ribavirin, patients with advanced fibrosis or cirrhosis | 1 randomized trial | Fair | Unknown (one study) | Direct | Low | N = 60 | Low
Triple therapy with boceprevir
SVR: Triple therapy with boceprevir vs. dual therapy | 2 randomized trials | Fair | High | Direct | Moderate | N = 1608 | Moderate
SVR: Lower vs. higher dose ribavirin | 1 randomized trial | Fair | Unknown (one study) | Direct | Low | N = 75 | Low
Triple therapy with telaprevir
SVR: 24 weeks fixed duration triple therapy with telaprevir vs. 48 weeks dual therapy | 3 randomized trials | Fair | High | Direct | Moderate | N= 506 | Moderate
SVR: 12 weeks fixed duration triple therapy with telaprevir vs. 48 weeks dual therapy | 1 randomized trial | Fair | Unknown (one study) | Direct | Low | N = 209 | Low
SVR: 48 weeks fixed duration triple therapy with telaprevir vs. 24 weeks triple therapy | 1 randomized trial | Fair | Unknown (one study) | Direct | Low | N = 189 | Low
SVR: Response-guided triple therapy with telaprevir vs. dual therapy | 1 randomized trial | Fair | Unknown (one study) | Direct | Low | N = 1,088 | Low
SVR: Triple therapy with telaprevir, lower versus higher telaprevir dose and pegylated interferon alfa-2a vs. alfa-2b | 1 randomized trial | Fair | Unknown (one study) | Direct | Low | N = 161 | Low
SVR: 48 vs. 24 weeks in patients with an extended rapid virological response | 1 randomized trial | Fair | Unknown (one study) | Direct | Low | N = 540 | Low
2b. How does the comparative effectiveness of antiviral treatment for intermediate outcomes vary according to patient subgroup characteristics, including but not limited to HCV genotype, race, sex, disease severity or genetic markers?
SVR: Dual therapy with pegylated interferon alfa-2a plus ribavirin vs. dual therapy with pegylated interferon alfa-2b plus ribavirin: effects of race, sex, age, baseline fibrosis stage, or baseline viral load | 1 randomized trial | Fair | Unknown (one study) | Direct | Moderate | N = 3070 | Low
SVR: Dual therapy with pegylated interferon alfa-2a plus ribavirin vs. dual therapy with pegylated interferon alfa-2b plus ribavirin: effects of genotype | 4 randomized trials | Fair | High | Direct | High | N = 1,152 | Moderate
SVR: Triple therapy with boceprevir vs. dual therapy: effects of sex and race | 2 randomized trials | Fair | High | Direct | Moderate | N = 1,617 | Moderate
SVR: Triple therapy with boceprevir vs. dual therapy: effects of baseline viral load | 2 randomized trials | Fair | High | Direct | Moderate | N = 1,617 | Moderate
SVR: Triple therapy with telaprevir vs. dual therapy: effects of age, sex, race, baseline fibrosis, and body weight | 1 randomized trial | Fair | Unknown (1 study) | Direct | Moderate | N = 1,088 | Moderate (for age and sex) to low (for other factors)
SVR: Triple therapy with telaprevir vs. dual therapy: effects of baseline viral load | 2 randomized trials | Fair | Low | Direct | Moderate | N = 729 | Insufficient
3a. What are the comparative harms (including intolerance to treatment) associated with antiviral treatment?
Harms: Dual therapy with pegylated interferon alfa-2b plus ribavirin vs. pegylated interferon alfa-2a plus ribavirin | 5 randomized trials, depending on specific harm | Fair | High | Direct | Moderate | N = 4,047 | Moderate
Harms: Triple therapy with boceprevir | 2 randomized trials | Fair | High | Direct | Moderate | N = 3,501 | Moderate
Harms: 24 weeks fixed duration triple therapy with telaprevir vs. 48 weeks dual therapy | 3 randomized trials | Fair | High | Direct | Moderate | N = 3,591 | Moderate
Harms: 12 weeks fixed duration triple therapy with telaprevir vs. 48 weeks dual therapy | 2 randomized trials | Fair | High | Direct | Moderate | N = 573 | Moderate
Harms: Response-guided triple therapy with telaprevir vs. dual therapy | 1 randomized trial | Fair | Unknown (one study) | Direct | Low | N = 189 | Low
3b. Do these harms differ according to patient subgroup characteristics, including HCV genotype, race, sex, disease severity or genetic markers?
Dual therapy with pegylated interferon alfa-2b plus ribavirin vs. pegylated interferon alfa-2a plus ribavirin | 3 randomized trials | Fair | High | Indirect (no study stratified harms by patient subgroups, 3 trials evaluated only genotype 1 patients) | Moderate | N = 3,305 | Insufficient
Triple therapy with pegylated interferon, ribavirin, and telaprevir or boceprevir | No studies | No studies | Unknown (no studies) | No studies | No studies | No subjects | Insufficient
4. Have improvements in intermediate outcomes (viremia, liver function tests, histologic changes) been shown to reduce the risk or rates of health outcomes from HCV infection?
Mortality and long-term hepatic complications | 19 cohort studies | Fair | High | Direct | High | N = 27,992 | Moderate
Short-term quality of life | 9 cohort studies | Poor | High | Direct | High | N = 4,981 | Low

Note: HCV=hepatitis C virus, SVR=sustained virologic response.