# Included Studies List

## Key Question 1: Not Applicable

## Key Questions 2 and 3

Abergel A, Hezode C, Leroy V, et al. Peginterferon alpha-2b plus ribavirin for treatment of chronic hepatitis C with severe fibrosis: a multicentre randomized controlled trial comparing two doses of peginterferon alpha-2b. Journal of Viral Hepatitis. Dec. 2006;13(12):811-20. [pmid: 17109680].
Andriulli A, Cursaro C, Cozzolongo R, et al. Early discontinuation of ribavirin in HCV-2 and HCV-3 patients responding to Peg-interferon alpha-2a and ribavirin. Journal of Viral Hepatitis. Jan. 2009;16(1):28-35. [pmid: 18761603].
Ascione A, De Luca M, Tartaglione MT, et al. Peginterferon alfa-2a plus ribavirin is more effective than peginterferon alfa-2b plus ribavirin for treating chronic hepatitis C virus infection. Gastroenterology. Jan. 2010;138(1):116-22. [pmid: 19852964].
Berg T, von Wagner M, Nasser S, et al. Extended treatment duration for hepatitis C virus type 1: comparing 48 versus 72 weeks of peginterferon-alfa-2a plus ribavirin. Gastroenterology. Apr. 2006;130(4):1086-97. [pmid: 16618403].
Berg T, Weich V, Teuber G, et al. Individualized treatment strategy according to early viral kinetics in hepatitis C virus type 1-infected patients. Hepatology. Aug. 2009;50(2):369-77. [pmid: 19575366].
Brady DE, Torres DM, An JW, et al. Induction pegylated interferon alfa-2b in combination with ribavirin in patients with genotypes 1 and 4 chronic hepatitis C: a prospective, randomized, multicenter, open-label study. Clinical Gastroenterology & Hepatology. Jan. 2010;8(1):66-71. [pmid: 19747986].
Brandao C, Barone A, Carrilho F, et al. The results of a randomized trial looking at 24 weeks vs 48 weeks of treatment with peginterferon alpha-2a (40 kDa) and ribavirin combination therapy in patients with chronic hepatitis C genotype 1. Journal of Viral Hepatitis. Aug. 2006;13(8):552-9. [pmid: 16901286].
Bronowicki J-P, Ouzan D, Asselah T, et al. Effect of ribavirin in genotype 1 patients with hepatitis C responding to pegylated interferon alfa-2a plus ribavirin. Gastroenterology. Oct. 2006;131(4):1040-8. [pmid: 17030174].
Bruno R, Sacchi P, Ciappina V, et al. Viral dynamics and pharmacokinetics of peginterferon alpha-2a and peginterferon alpha-2b in naive patients with chronic hepatitis c: a randomized, controlled study. Antiviral Therapy. 2004;9(4):491-7. [pmid: 15456079].
Buti M, Lurie Y, Zakharova NG, et al. Randomized trial of peginterferon alfa-2b and ribavirin for 48 or 72 weeks in patients with hepatitis C virus genotype 1 and slow virologic response. Hepatology. Oct. 2010;52(4):1201-7. [pmid: 20683847].
Dalgard O, Bjoro K, Ring-Larsen H, et al. Pegylated interferon alfa and ribavirin for 14 versus 24 weeks in patients with hepatitis C virus genotype 2 or 3 and rapid virological response. Hepatology. Jan. 2008;47(1):35-42. [pmid: 17975791].
Di Bisceglie AM, Ghalib RH, Hamzeh FM, et al. Early virologic response after peginterferon alpha-2a plus ribavirin or peginterferon alpha-2b plus ribavirin treatment in patients with chronic hepatitis C. Journal of Viral Hepatitis. Oct. 2007;14(10):721-9. [pmid: 17875007].
Escudero A, Rodriguez F, Serra MA, et al. Pegylated alpha-interferon-2a plus ribavirin compared with pegylated alpha-interferon-2b plus ribavirin for initial treatment of chronic hepatitis C virus: prospective, non-randomized study. Journal of Gastroenterology & Hepatology. Jun. 2008;23(6):861-6. [pmid: 18422960].
Ferenci P, Laferl H, Scherzer T-M, et al. Peginterferon alfa-2a/ribavirin for 48 or 72 weeks in hepatitis C genotypes 1 and 4 patients with slow virologic response. [Reprint in Korean J Hepatol. 2010 Jun;16(2):201–5; PMID: 20606507]. Gastroenterology. Feb. 2010;138(2):503-12. [pmid: 19909752].
Ferenci P, Brunner H, Laferl H, et al. A randomized, prospective trial of ribavirin 400 mg/day versus 800 mg/day in combination with peginterferon alfa-2a in hepatitis C virus genotypes 2 and 3. Hepatology. Jun. 2008;47(6):1816-23. [pmid: 18454510].
Fried MW, Jensen DM, Rodriguez-Torres M, et al. Improved outcomes in patients with hepatitis C with difficult-to-treat characteristics: randomized study of higher doses of peginterferon alpha-2a and ribavirin. Hepatology. Oct. 2008;48(4):1033-43. [pmid: 18697207].
Hadziyannis SJ, Sette H Jr, Morgan TR, et al. Peginterferon-alpha2a and ribavirin combination therapy in chronic hepatitis C: a randomized study of treatment duration and ribavirin dose. Annals of Internal Medicine. Mar. 2. 2004;140(5):346-55. [pmid: 14996676].
Helbling B, Jochum W, Stamenic I, et al. HCV-related advanced fibrosis/cirrhosis: randomized controlled trial of pegylated interferon alpha-2a and ribavirin. Journal of Viral Hepatitis. Nov. 2006;13(11):762-9. [pmid: 17052276].
Hezode C, Forestier N, Dusheiko G, et al. Telaprevir and peginterferon with or without ribavirin for chronic HCV infection. New England Journal of Medicine. Apr. 30. 2009;360(18):1839-50. [pmid: 19403903].
Ide T, Hino T, Ogata K, et al. A randomized study of extended treatment with peginterferon alpha-2b plus ribavirin based on time to HCV RNA negative-status in patients with genotype 1b chronic hepatitis C. American Journal of Gastroenterology. Jan. 2009;104(1):70-5. [pmid: 19098852].
Jacobson IM, Brown RS Jr, Freilich B, et al. Peginterferon alfa-2b and weight-based or flat-dose ribavirin in chronic hepatitis C patients: a randomized trial. Hepatology. Oct. 2007;46(4):971-81. [pmid: 17894303].
Jacobson IM, Brown RS Jr, McCone J, et al. Impact of weight-based ribavirin with peginterferon alfa-2b in African Americans with hepatitis C virus genotype 1. Hepatology. Oct. 2007;46(4):982-90. [pmid: 17894323].
Jacobson IM, McHutchison JG, Dusheiko G, et al. Telaprevir for Previously Untreated Chronic Hepatitis C Virus Infection. New England Journal of Medicine. 2011;364(25):2405-16. [pmid: 21696307].
Kamal SM, Ahmed A, Mahmoud S, et al. Enhanced efficacy of pegylated interferon alpha-2a over pegylated interferon and ribavirin in chronic hepatitis C genotype 4A randomized trial and quality of life analysis. Liver Int. 2011;31(3):401-11. [pmid: 21281434].
Kamal SM, El Tawil AA, Nakano T, et al. Peginterferon {alpha}-2b and ribavirin therapy in chronic hepatitis C genotype 4: impact of treatment duration and viral kinetics on sustained virological response. Gut. Jun. 2005;54(6):858-66. [pmid: 15888797].
Kawaoka T, Kawakami Y, Tsuji K, et al. Dose comparison study of pegylated interferon-alpha-2b plus ribavirin in naive Japanese patients with hepatitis C virus genotype 2: a randomized clinical trial. Journal of Gastroenterology & Hepatology. Mar. 2009;24(3):366-71. [pmid: 19032459].
Khan AQAA, Shahbuddin S, Iqbal Q. Abstract # S1231: Peginterferon Alfa 2a/Ribavirin versus Peginterferon Alfa 2b/Ribavirin combination therapy in Chronic Hepatitis C Genotype 3. Gastroenterology. 2007;132(4):A200.
Krawitt EL, Gordon SR, Grace ND, et al. A study of low dose peginterferon alpha-2b with ribavirin for the initial treatment of chronic hepatitis C. American Journal of Gastroenterology. Jun. 2006;101(6):1268-73. [pmid: 16771948].
Kumada H, Toyota J, Okanoue T, et al. Telaprevir with peginterferon and ribavirin for treatment-naive patients chronically infected with HCV of genotype 1 in Japan. Journal of Hepatology. 2012;56(1):78-84. [pmid: 21827730].
Kwo PY, Lawitz EJ, McCone J, et al. Efficacy of boceprevir, an NS3 protease inhibitor, in combination with peginterferon alfa-2b and ribavirin in treatment-naive patients with genotype 1 hepatitis C infection (SPRINT-1): an open-label, randomised, multicentre phase 2 trial. [Erratum appears in Lancet. 2010 Oct 9;376(9748):1224 Note: SPRINT-1 investigators [added]; multiple investigator names added]. Lancet. Aug. 28. 2010;376(9742):705-16. [pmid: 20692693].
Lagging M, Langeland N, Pedersen C, et al. Randomized comparison of 12 or 24 weeks of peginterferon alpha-2a and ribavirin in chronic hepatitis C virus genotype 2/3 infection. Hepatology. Jun. 2008;47(6):1837-45. [pmid: 18454508].
Lam KD, Trinh HN, Do ST, et al. Randomized controlled trial of pegylated interferon-alfa 2a and ribavirin in treatment-naive chronic hepatitis C genotype 6. Hepatology. Nov. 2010;52(5):1573-80. [pmid: 21038410].
Liu C-H, Liu C-J, Lin C-L, et al. Pegylated interferon-alpha-2a plus ribavirin for treatment-naive Asian patients with hepatitis C virus genotype 1 infection: a multicenter, randomized controlled trial. Clinical Infectious Diseases. Nov. 15. 2008;47(10):1260-9. [pmid: 18834319].
Mach TH, Ciesla A, Warunek W, et al. Efficacy of pegylated interferon alfa-2a or alfa-2b in combination with ribavirin in the treatment of chronic hepatitis caused by hepatitis C virus genotype 1b. Polskie Archiwum Medycyny Wewnetrznej. 2011:434-40. [pmid: 22157768].
Magni CNF, Argenteri B, Giorgi R, et al. Abstract #883: Antiviral activity and tolerability between pegylated interferon alpha 2a and alpha 2b in naive patients with chronic hepatitis C: Results of a prospective monocentric randomized trial. Hepatology. 2009;50(S4):720A.
Mangia A, Santoro R, Minerva N, et al. Peginterferon alfa-2b and ribavirin for 12 vs. 24 weeks in HCV genotype 2 or 3. New England Journal of Medicine. Jun. 23. 2005;352(25):2609-17. [pmid: 15972867].
Manns MP, McHutchison JG, Gordon SC, et al. Peginterferon alfa-2b plus ribavirin compared with interferon alfa-2b plus ribavirin for initial treatment of chronic hepatitis C: a randomised trial. Lancet. 2001;358(9286):958-65. [pmid: 11583749].
Manns M, Zeuzem S, Sood A, et al. Reduced dose and duration of peginterferon alfa-2b and weight-based ribavirin in patients with genotype 2 and 3 chronic hepatitis C. Journal of Hepatology. 2011;55(3):554-63. [pmid: 21237227].
Marcellin P, Forns X, Goeser T, et al. Telaprevir is effective given every 8 or 12 hours with ribavirin and peginterferon alfa-2a or -2b to patients with chronic hepatitis C. Gastroenterology. Feb. 2011;140(2):459-68. [pmid: 21034744].
McHutchison JG, Everson GT, Gordon SC, et al. Telaprevir with peginterferon and ribavirin for chronic HCV genotype 1 infection. [Erratum appears in N Engl J Med. 2009 Oct 8;361(15):1516]. New England Journal of Medicine. Apr. 30. 2009;360(18):1827-38. [pmid: 19403902].
McHutchison JG, Lawitz EJ, Shiffman ML, et al. Peginterferon alfa-2b or alfa-2a with ribavirin for treatment of hepatitis C infection. [Erratum appears in N Engl J Med. 2009 Sep 3;361(10):1027]. New England Journal of Medicine. Aug. 6. 2009;361(6):580-93. [pmid: 19625712].
Mecenate F, Pellicelli AM, Barbaro G, et al. Short versus standard treatment with pegylated interferon alfa-2A plus ribavirin in patients with hepatitis C virus genotype 2 or 3: the cleo trial. BMC Gastroenterology. 2010;10:21. [pmid: 20170514].
Meyer-Wyss B, Rich P, Egger H, et al. Comparison of two PEG-interferon alpha-2b doses (1.0 or 1.5 microg/kg) combined with ribavirin in interferon-naive patients with chronic hepatitis C and up to moderate fibrosis. Journal of Viral Hepatitis. Jul. 2006;13(7):457-65. [pmid: 16792539].
Mimidis K, Papadopoulos VP, Elefsiniotis I, et al. Hepatitis C virus survival curve analysis in naive patients treated with peginterferon alpha-2b plus ribavirin. A randomized controlled trial for induction with high doses of peginterferon and predictability of sustained viral response from early virologic data. Journal of Gastrointestinal & Liver Diseases. Sep. 2006;15(3):213-9. [pmid: 17013444].
Miyase S. Randomized trial of peginterferon α--2a plus ribavirin versus peginterferon α--2b plus ribavirin for chronic hepatitis C in Japanese patients. Journal of Gastroenterology. 2012:1-8. [pmid: 22215058].
Pearlman BL, Ehleben C, Saifee S. Treatment extension to 72 weeks of peginterferon and ribavirin in hepatitis c genotype 1-infected slow responders. Hepatology. Dec. 2007;46(6):1688-94. [pmid: 18046717].
Poordad F, McCone J Jr, Bacon BR, et al. Boceprevir for untreated chronic HCV genotype 1 infection. New England Journal of Medicine. Mar. 31. 2011;364(13):1195-206. [pmid: 21449783].
Reddy KR, Shiffman ML, Rodriguez-Torres M, et al. Induction pegylated interferon alfa-2a and high dose ribavirin do not increase SVR in heavy patients with HCV genotype 1 and high viral loads. Gastroenterology. Dec. 2010;139(6):1972-83. [pmid: 20816836].
Roberts SK, Weltman MD, Crawford DHG, et al. Impact of high-dose peginterferon alfa-2A on virological response rates in patients with hepatitis C genotype 1: a randomized controlled trial. Hepatology. Oct. 2009;50(4):1045-55. [pmid: 19676125].
Rumi MG, Aghemo A, Prati GM, et al. Randomized study of peginterferon-alpha2a plus ribavirin vs peginterferon-alpha2b plus ribavirin in chronic hepatitis C. Gastroenterology. Jan. 2010;138(1):108-15. [pmid: 19766645].
Sanchez-Tapias JM, Diago M, Escartin P, et al. Peginterferon-alfa2a plus ribavirin for 48 versus 72 weeks in patients with detectable hepatitis C virus RNA at week 4 of treatment. [Erratum appears in Gastroenterology. 2006 Oct;131(4):1363]. Gastroenterology. Aug. 2006;131(2):451-60. [pmid: 16890599].
Sherman KE, Flamm SL, Afdhal NH, et al. Response-guided telaprevir combination treatment for hepatitis C virus infection. New England Journal of Medicine. 2011;365(11):1014-24. [pmid: 21916639].
Shiffman ML, Suter F, Bacon BR, et al. Peginterferon alfa-2a and ribavirin for 16 or 24 weeks in HCV genotype 2 or 3. New England Journal of Medicine. Jul. 12. 2007;357(2):124-34. [pmid: 17625124].
Silva M, Poo JL, Wagner F, et al. A randomised trial to compare the pharmacokinetic, pharmacodynamic, and antiviral effects of peginterferon alfa-2b and peginterferon alfa-2a in patients with chronic hepatitis C (COMPARE). Journal of Hepatology. 2006;45(2):204-13. [pmid: 16780997].
Sood A, Midha V, Hissar S, et al. Comparison of low-dose pegylated interferon versus standard high-dose pegylated interferon in combination with ribavirin in patients with chronic hepatitis C with genotype 3: an Indian experience. Journal of Gastroenterology & Hepatology. Feb. 2008;23(2):203-7. [pmid: 17645472].
von Wagner M, Huber M, Berg T, et al. Peginterferon-alpha-2a (40KD) and ribavirin for 16 or 24 weeks in patients with genotype 2 or 3 chronic hepatitis C. Gastroenterology. Aug. 2005;129(2):522-7. [pmid: 16083709].
Yenice N, Mehtap O, Gumrah M, et al. The efficacy of pegylated interferon alpha 2a or 2b plus ribavirin in chronic hepatitis C patients. Turkish Journal of Gastroenterology. Jun. 2006;17(2):94-8. [pmid: 16830289].
Yu M-L, Dai C-Y, Huang J-F, et al. Rapid virological response and treatment duration for chronic hepatitis C genotype 1 patients: a randomized trial. Hepatology. Jun. 2008;47(6):1884-93. [pmid: 18508296].
Yu M-L, Dai C-Y, Huang J-F, et al. A randomised study of peginterferon and ribavirin for 16 versus 24 weeks in patients with genotype 2 chronic hepatitis C. Gut. Apr. 2007;56(4):553-9. [pmid: 16956917].
Yu M-L, Dai C-Y, Lin Z-Y, et al. A randomized trial of 24- vs. 48-week courses of PEG interferon alpha-2b plus ribavirin for genotype-1b-infected chronic hepatitis C patients: a pilot study in Taiwan. Liver International. Feb. 2006;26(1):73-81. [pmid: 16420512].
Zeuzem S, Diago M, Gane E, et al. Peginterferon alfa-2a (40 kilodaltons) and ribavirin in patients with chronic hepatitis C and normal aminotransferase levels. Gastroenterology. Dec. 2004;127(6):1724-32. [pmid: 15578510].

## Key Question 4

Arase Y, Ikeda K, Suzuki F, et al. Long-term outcome after interferon therapy in elderly patients with chronic hepatitis C. Intervirology. 2007;50(1):16-23. [pmid: 17164553].
Arora S, O'Brien C, Zeuzem S, et al. Treatment of chronic hepatitis C patients with persistently normal alanine aminotransferase levels with the combination of peginterferon alpha-2a (40 kDa) plus ribavirin: impact on health-related quality of life. Journal of Gastroenterology & Hepatology. Feb. 2006;21(2):406-12. [pmid: 16509866].
Backus LI, Boothroyd DB, Phillips BR, et al. A sustained virologic response reduces risk of all-cause mortality in patients with hepatitis C. Clinical Gastroenterology & Hepatology. 2011;9:509-16. [pmid: 21397729].
Bernstein D, Kleinman L, Barker CM, et al. Relationship of health-related quality of life to treatment adherence and sustained response in chronic hepatitis C patients. Hepatology. Mar. 2002;35(3):704-8. [pmid: 11870387].
Bini EJ, Mehandru S. Sustained virological response rates and health-related quality of life after interferon and ribavirin therapy in patients with chronic hepatitis C virus infection and persistently normal alanine aminotransferase levels. Alimentary Pharmacology & Therapeutics. 2006;23(6):777-85. [pmid: 16556180].
Bonkovsky HL, Woolley JM. Reduction of health-related quality of life in chronic hepatitis C and improvement with interferon therapy. The Consensus Interferon Study Group. Hepatology. 1999;29(1):264-70. [pmid: 9862876].
Bruno S, Stroffolini T, Colombo M, et al. Sustained virological response to interferon-alpha is associated with improved outcome in HCV-related cirrhosis: a retrospective study. Hepatology. Mar. 2007;45(3):579-87. [pmid: 17326216].
Cardoso A-C, Moucari R, Figueiredo-Mendes C, et al. Impact of peginterferon and ribavirin therapy on hepatocellular carcinoma: incidence and survival in hepatitis C patients with advanced fibrosis. Journal of Hepatology. May. 2010;52(5):652-7. [pmid: 20346533].
Coverdale SA, Khan MH, Byth K, et al. Effects of interferon treatment response on liver complications of chronic hepatitis C: 9-year follow-up study. American Journal of Gastroenterology. Apr. 2004;99(4):636-44. [pmid: 15089895].
El Braks RE, Ganne-Carrie N, Fontaine H, et al. Effect of sustained virological response on long-term clinical outcome in 113 patients with compensated hepatitis C-related cirrhosis treated by interferon alpha and ribavirin. World Journal of Gastroenterology. 2007;13(42):5648-53. [pmid: 17948941].
Fernández-Rodríguez CM, Alonso S, Martinez SM, et al. Peginterferon Plus Ribavirin and Sustained Virological Response in HCV-Related Cirrhosis: Outcomes and Factors Predicting Response. American Journal of Gastroenterology. 2010;105(10):2164-72. [pmid: 20700116].
Hasegawa E, Kobayashi M, Kawamura Y, et al. Efficacy and anticarcinogenic activity of interferon for hepatitis C virus-related compensated cirrhosis in patients with genotype 1b low viral load or genotype 2. Hepatology Research. 2007;37(10):793-800. [pmid: 17593231].
Hassanein T, Cooksley G, Sulkowski M, et al. The impact of peginterferon alfa-2a plus ribavirin combination therapy on health-related quality of life in chronic hepatitis C. Journal of Hepatology. 2004;40(4):675-81. [pmid: 15030985].
Hung CH, Lee CM, Lu SN, et al. Long-term effect of interferon alpha-2b plus ribavirin therapy on incidence of hepatocellular carcinoma in patients with hepatitis C virus-related cirrhosis. Journal of Viral Hepatitis. 2006;13(6):409-14. [pmid: 16842444].
Imazeki F, Yokosuka O, Fukai K, et al. Favorable prognosis of chronic hepatitis C after interferon therapy by long-term cohort study. Hepatology. Aug. 2003;38(2):493-502. [pmid: 12883494].
Innes HA, Hutchinson SJ, Allen S, et al. Excess liver-related morbidity of chronic hepatitis C patients, who achieve a sustained viral response, and are discharged from care. Hepatology. 2011;54(5):1547-58. [pmid: 22045672].
Izumi N, Yasuhiro A, Kurosaki M, et al. Development of hepatocellular carcinoma after interferon therapy in chronic hepatitis C. Is it possible to reduce the incidence by ribanirin and IFN combination therapy?. Intervirology. 2005;48(1):59-63. [pmid: 15785091].
Kasahara A, Tanaka H, Okanoue T, et al. Interferon treatment improves survival in chronic hepatitis C patients showing biochemical as well as virological responses by preventing liver-related death. Journal of Viral Hepatitis. Mar. 2004;11(2):148-56. [pmid: 14996350].
Maruoka D, Imazeki F, Arai M, et al. Long-term cohort study of chronic hepatitis C according to interferon efficacy. Journal of Gastroenterology and Hepatology. 2012;27(2):291-99. [pmid: 21793911].
McHutchison J, Manns M, Harvey J, et al. Adherence to therapy enhanges sustained response in chronic hepatitis C patients receiving PEG-Interferon alfa-2b plus Ribavirin[abstract]. Journal of Hepatology. 2001;34(1):2-3.
McHutchison J, Sulkowski M. Scientific rationale and study design of the individualized dosing efficacy vs flat dosing to assess optimal pegylated interferon therapy (IDEAL) trial: determining optimal dosing in patients with genotype 1 chronic hepatitis C. Journal of Viral Hepatitis. 2008;1.
Morgan TR, Ghany MG, Kim H-Y, et al. Outcome of sustained virological responders with histologically advanced chronic hepatitis C. Hepatology. Sep. 2010;52(3):833-44. [pmid: 20564351].
Neary MP, Cort S, Bayliss MS, et al. Sustained virologic response is associated with improved health-related quality of life in relapsed chronic hepatitis C patients. Seminars in Liver Disease. 1999;19(1):77-85. [pmid: 10349695].
Rasenack J, Zeuzem S, Feinman SV, et al. Peginterferon alpha-2a (40kD) [Pegasys] improves HR-QOL outcomes compared with unmodified interferon alpha-2a [Roferon-A]: in patients with chronic hepatitis C. [Erratum appears in Pharmacoeconomics. 2003;21(17):1290]. Pharmacoeconomics. 2003;21(5):341-9. [pmid: 12627987].
Shiratori Y, Ito Y, Yokosuka O, et al. Antiviral therapy for cirrhotic hepatitis C: association with reduced hepatocellular carcinoma development and improved survival. Annals of Internal Medicine. Jan. 18. 2005;142(2):105-14. [pmid: 15657158].
Veldt BJ, Heathcote EJ, Wedemeyer H, et al. Sustained virologic response and clinical outcomes in patients with chronic hepatitis C and advanced fibrosis. Annals of Internal Medicine. 2007;147(10):677-84. [pmid: 18025443].
Ware JE, Bayliss MS, Mannocchia M, et al. Health-related quality of life in chronic hepatitis C: impact of disease and treatment response. The Interventional Therapy Group. Hepatology. 1999;30(2):550-5. [pmid: 10421667].
Yoshida H, Arakawa Y, Sata M, et al. Interferon therapy prolonged life expectancy among chronic hepatitis C patients. Gastroenterology. Aug. 2002;123(2):483-91. [pmid: 12145802].
Yu M-L, Lin S-M, Chuang W-L, et al. A sustained virological response to interferon or interferon/ribavirin reduces hepatocellular carcinoma and improves survival in chronic hepatitis C: a nationwide, multicentre study in Taiwan. Antiviral Therapy. 2006;11(8):985-94. [pmid: 17302368].