# Exact Search Strategy

The following databases have been searched for relevant information:

Database Searches: Hepatitis C: Treatment

Name | Date Limits | Platform Provider
Medline | 2002 through August 2012 | OvidSP
Embase | 2002 through April 2012 | Embase (Elsevier)
Cochrane Library: CDSR, DARE, CCRCT | 2002 through August 2012 | Cochrane Library
Clinical Trials.gov | 2002 through August 2012
Drugs@FDA | 2002 through August 2012
Health Canada Drug Products Database | 2002 through August 2012
European Public Assessment Reports (European Medicine Agency) | 2002 through August 2012
Scopus | 2002 through August 2012 | Scopus
PsycINFO | 2002 through August 2012 | OvidSP

Hand Search of Journals & Supplements - Topic-Specific Search Terms

Concept | Controlled Vocabulary | Keywords
Hepatitis C | Hepatitis C/ Hepatitis C, Chronic/ Hepacivirus/OR | hcv.mp hepacivirus$.mp
Treatment | Antiviral agents/ Interferons/ Interferon-alpha/ Interferon Alfa-2a/ Interferon Alpha-2b/ Exp Polyethylene Glycols/ Ribavirin/ Exp Protease Inhibitors/ | Interferon$ interferon alpha-2a interferon alpha-2b IFNalpha2a IFNalpha2b interferon alpha 2a interferon alpha 2b pegasys Peg-intron peginterferon alpha-2a peginterferon alpha-2b peginterferon alpha 2a peginterferon alpha 2b pegylated interferon$ IFN$ PEG IFN$ Ribavirin RBV protease inhibitor$ polymerase inhibit$ HCV protease$ Telaprevir boceprevir
Harms - treatment | AE.fs MO.fs PO.fs TO.fs CT.fs AE=adverse effects CT=contraindications MO=mortality PO=poisoning TO=toxicity | Unsafe Safety harm$ complication$ poison$ risk$ side-effect$ side effect$ (undesirable ADJ1 effect$) (treatment ADJ1 emergent) tolerab$ toxic$ adrs (adverse ADJ2 (effect or effects or reaction or reactions or event or events or outcome or outcomes)) (undesirable ADJ1 effect$) (treatment ADJ1 emergent) tolerab$ toxic$ adrs (adverse ADJ2 (effect or effects or reaction or reactions or event or events or outcome or outcomes))

## Original Search: 12/16/2011

### Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) 1946 to November Week 3 2011, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations December 15, 2011

1 | Hepatitis C/ or Hepatitis C, Chronic/ or Hepacivirus/ or Hepatitis C.mp. or hepacivirus$.mp. or HCV.mp. | 58901
2 | Antiviral agents/ or Interferons/ or Interferon-alpha/ or Interferon Alfa-2a/ or Interferon Alpha-2b/ or Interferon$.mp. or interferon alpha-2a.mp. or interferon alpha-2b.mp. or IFNalpha2a.mp. or IFNalpha2b.mp. or interferon alpha 2a.mp. or interferon alpha 2b.mp. or exp Polyethylene Glycols/ or pegasys.mp. or Peg-intron.mp. or peginterferon alpha-2a.mp. or peginterferon alpha-2b.mp. or peginterferon alpha 2a.mp. or peginterferon alpha 2b.mp. or pegylated interferon$.mp. or IFN$.mp. or PEG IFN$.mp. or Ribavirin/ or ribavirin.mp. or RBV.mp. or exp Protease Inhibitors/ or protease inhibitor$.mp. or polymerase inhibit$.mp. or HCV protease$.mp. or telaprevir.mp. or boceprevir.mp. | 379981
3 | 1 and 2 | 17670
4 | (randomized controlled trial or controlled clinical trial or meta analysis or review).pt. or clinical trials as topic/ or cohort studies/ or randomized.ab. or randomly.ab. or placebo.ab. or (systematic adj1 review).ti,ab. | 2498350
5 | 3 and 4 | 5896
6 | limit 5 to (yr="2002 -Current" and ("adult (19 to 44 years)" or "middle age (45 to 64 years)" or "all aged (65 and over)")) | 1382
7 | (unsafe or safety or harm$ or complication$ or poison$ or risk$).mp. or AE.fs. or MO.fs. or PO.fs. or TO.fs. or CT.fs. or side-effect$.mp. or (undesirable adj1 effect$).mp. or (treatment adj1 emergent).mp. or tolerab$.mp. or toxic$.mp. or adrs.mp. or (adverse adj2 (effect or effects or reaction or reactions or event or events or outcome or outcomes)).mp. | 3892024
8 | 1 and 2 and 7 | 7401
9 | 4 and 8 | 3168
10 | limit 9 to (yr="2002 -Current" and ("adult (19 to 44 years)" or "middle age (45 to 64 years)" or "all aged (65 and over)")) | 885
11 | Counseling/ or Sex Counseling/ or Health Education/ or Patient Education as Topic/ or Psychotherapy/ or Behavior Therapy/ or Cognitive Therapy/ or Immunization/ or Immunotherapy/ or Psychotherapy, Brief/ or Socioenvironmental Therapy/ | 268601
12 | 1 and 11 | 662
13 | 6 and (201102* or 201103* or 201104* or 201105* or 201106* or 201107* or 201108* or 201109* or 201110* or 201111* or 201112*).ed. | 132
14 | 10 and (201102* or 201103* or 201104* or 201105* or 201106* or 201107* or 201108* or 201109* or 201110* or 201111* or 201112*).ed. | 90
15 | 12 and (201102* or 201103* or 201104* or 201105* or 201106* or 201107* or 201108* or 201109* or 201110* or 201111* or 201112*).ed. | 33

## Additional Treatment Search: 2/28/2011

### Ovid MEDLINE (R) and Ovid OLDMED (R) 1947 to February Week 3 2011 Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations February 28, 2011

1 | Hepatitis C/ or Hepatitis C, Chronic/ or Hepacivirus/ or Hepatitis C.mp. or hepacivirus$.mp. or HCV.mp. | 58837
2 | Antiviral agents/ or Interferons/ or Interferon-alpha/ or Interferon Alfa-2a/ or Interferon Alpha-2b/ or Interferon$.mp. or interferon alpha-2a.mp. or interferon alpha-2b.mp. or IFNalpha2a.mp. or IFNalpha2b.mp. or interferon alpha 2a.mp. or interferon alpha 2b.mp. or exp Polyethylene Glycols/ or pegasys.mp. or Peg-intron.mp. or peginterferon alpha-2a.mp. or peginterferon alpha-2b.mp. or peginterferon alpha 2a.mp. or peginterferon alpha 2b.mp. or pegylated interferon$.mp. or IFN$.mp. or PEG IFN$.mp. or Ribavirin/ or ribavirin.mp. or RBV.mp. or exp Protease Inhibitors/ or protease inhibitor$.mp. or polymerase inhibit$.mp. or HCV protease$.mp. or telaprevir.mp. or boceprevir.mp. | 379770
3 | 1 and 2 | 17643
4 | (randomized controlled trial or controlled clinical trial or meta analysis or review).pt. or clinical trials as topic/ or cohort studies/ or randomized.ab. or randomly.ab. or placebo.ab. or (systematic adj1 review).ti,ab. | 2497187
5 | 3 and 4 | 5889
6 | limit 5 to (yr="2002 -Current" and ("adult (19 to 44 years)" or "middle age (45 to 64 years)" or "all aged (65 and over)")) | 1380
7 | (unsafe or safety or harm$ or complication$ or poison$ or risk$).mp. or AE.fs. or MO.fs. or PO.fs. or TO.fs. or CT.fs. or side-effect$.mp. or (undesirable adj1 effect$).mp. or (treatment adj1 emergent).mp. or tolerab$.mp. or toxic$.mp. or adrs.mp. or (adverse adj2 (effect or effects or reaction or reactions or event or events or outcome or outcomes)).mp. | 3889277
8 | 1 and 2 and 7 | 7391
9 | 4 and 8 | 3164
10 | limit 9 to (yr="2002 -Current" and ("adult (19 to 44 years)" or "middle age (45 to 64 years)" or "all aged (65 and over)")) | 883
11 | Counseling/ or Sex Counseling/ or Health Education/ or Patient Education as Topic/ or Psychotherapy/ or Behavior Therapy/ or Cognitive Therapy/ or Immunization/ or Immunotherapy/ or Psychotherapy, Brief/ or Socioenvironmental Therapy/ | 268554
12 | 1 and 11 | 660

## Updated Search after Peer Review: 4/04/2012

Ovid MEDLINE Search Strategy 1947 to February Week 3 2011 Searched February 28, 2011; Update Search April 04, 2012

1 | Hepatitis C/ or Hepatitis C, Chronic/ or Hepacivirus/ or Hepatitis C.mp. or hepacivirus$.mp. or HCV.mp.
2 | Antiviral agents/ or Interferons/ or Interferon-alpha/ or Interferon Alfa-2a/ or Interferon Alpha-2b/ or Interferon$.mp. or interferon alpha-2a.mp. or interferon alpha-2b.mp. or IFNalpha2a.mp. or IFNalpha2b.mp. or interferon alpha 2a.mp. or interferon alpha 2b.mp. or exp Polyethylene Glycols/ or pegasys.mp. or Peg-intron.mp. or peginterferon alpha-2a.mp. or peginterferon alpha-2b.mp. or peginterferon alpha 2a.mp. or peginterferon alpha 2b.mp. or pegylated interferon$.mp. or IFN$.mp. or PEG IFN$.mp. or Ribavirin/ or ribavirin.mp. or RBV.mp. or exp Protease Inhibitors/ or protease inhibitor$.mp. or polymerase inhibit$.mp. or HCV protease$.mp. or telaprevir.mp. or boceprevir.mp.
3 | 1 and 2
4 | (randomized controlled trial or controlled clinical trial or meta analysis or review).pt. or clinical trials as topic/ or cohort studies/ or randomized.ab. or randomly.ab. or placebo.ab. or (systematic adj1 review).ti,ab.
5 | 3 and 4
6 | limit 5 to (yr="2002 -Current" and ("adult (19 to 44 years)" or "middle age (45 to 64 years)" or "all aged (65 and over)"))
7 | (unsafe or safety or harm$ or complication$ or poison$ or risk$).mp. or AE.fs. or MO.fs. or PO.fs. or TO.fs. or CT.fs. or side-effect$.mp. or (undesirable adj1 effect$).mp. or (treatment adj1 emergent).mp. or tolerab$.mp. or toxic$.mp. or adrs.mp. or (adverse adj2 (effect or effects or reaction or reactions or event or events or outcome or outcomes)).mp.
8 | 1 and 2 and 7
9 | 4 and 8
10 | limit 9 to (yr="2002 -Current" and ("adult (19 to 44 years)" or "middle age (45 to 64 years)" or "all aged (65 and over)"))
11 | Counseling/ or Sex Counseling/ or Health Education/ or Patient Education as Topic/ or Psychotherapy/ or Behavior Therapy/ or Cognitive Therapy/ or Immunization/ or Immunotherapy/ or Psychotherapy, Brief/ or Socioenvironmental Therapy/
12 | 1 and 11

EMBASE Search Strategy 1976 – 2011 Searched April 11, 2011; Update Search April 4, 2012

13 | #12 AND (2002:py OR 2003:py OR 2004:py OR 2005:py OR 2006:py OR 2007:py OR 2008:py OR 2009:py OR 2010:py OR 2011:py)
12 | #3 AND #11
11 | #1 AND #10
10 | 'counseling'/exp OR 'patient guidance'/exp OR 'patient counseling'/exp OR 'sexual counseling'/exp OR 'psychotherapy'/exp OR 'cognitive therapy'/exp OR 'behavior therapy'/exp OR 'sex therapy'/exp OR 'patient education'/exp OR 'immunization'/exp OR 'virus vaccine'/exp OR 'immunotherapy'/exp OR counsel* OR 'socioenvironmental therapy'/de AND [embase]/lim
9 | #8 AND (2002:py OR 2003:py OR 2004:py OR 2005:py OR 2006:py OR 2007:py OR 2008:py OR 2009:py OR 2010:py OR 2011:py)
8 | #3 AND #7
7 | #1 AND #2 AND #6
6 | 'adverse drug reaction'/exp OR 'adverse outcome'/exp OR 'toxicity'/exp OR 'drug toxicity'/exp OR 'drug tolerability'/exp OR 'drug safety'/exp OR 'patient safety'/exp OR unsafe OR 'safety'/exp OR harm* OR complication* OR poison* OR 'side effect'/exp OR 'side effects' OR undesirable NEAR/1 effect* OR treatment NEAR/1 emergen* OR tolerab* OR toxic* OR adrs OR adverse NEAR/2 (effect OR effects OR reaction OR reactions OR event OR events OR outcome OR outcomes) AND [embase]/lim
5 | #4 AND (2002:py OR 2003:py OR 2004:py OR 2005:py OR 2006:py OR 2007:py OR 2008:py OR 2009:py OR 2010:py OR 2011:py)
4 | #1 AND #2 AND #3
3 | 'cohort analysis'/exp OR 'meta analysis'/exp OR 'randomized controlled trial'/exp OR 'systematic review'/exp OR 'controlled clinical trial'/exp OR 'placebo'/exp OR 'clinical trial'/exp OR 'controlled study'/exp OR randomized.ab OR randomly.ab AND [embase]/lim
2 | 'antivirus agent'/exp OR 'antivirus agent' OR 'interferon'/exp OR interferon OR 'alpha interferon'/exp OR 'alpha interferon' OR 'alpha2a interferon'/exp OR 'alpha2a interferon' OR 'alpha2b interferon'/exp OR 'alpha2b interferon' OR 'macrogol derivative'/exp OR 'macrogol derivative' OR 'peginterferon'/exp OR peginterferon OR 'peginterferon alpha2a'/exp OR 'peginterferon alpha2a' OR 'peginterferon alpha2b'/exp OR 'peginterferon alpha2b' OR 'ribavirin'/exp OR ribavirin OR 'protease inhibitor'/exp OR 'protease inhibitor' OR 'rna directed dna polymerase inhibitor'/exp OR 'rna directed dna polymerase inhibitor' OR 'rna directed rna polymerase inhibitor'/exp OR 'rna directed rna polymerase inhibitor' OR 'telaprevir'/exp OR telaprevir OR 'boceprevir'/exp OR boceprevir OR 'antiviral agent':ab,ti OR interferon*:ab,ti OR 'interferon-alpha2a':ab,ti OR 'interferon-alpha2b':ab,ti OR 'interferon alpha':ab,ti OR 'interferon alpha 2a':ab,ti OR 'interferon alpha 2b':ab,ti OR 'polyethylene glycols':ab,ti OR pegasys:ab,ti OR 'peg intron':ab,ti OR 'peginterferon alpha':ab,ti OR 'peginterferon alpha 2a':ab,ti OR 'peginterferon alpha 2b':ab,ti OR 'pegylated interferon':ab,ti OR ifn:ab,ti OR 'peg ifn':ab,ti OR 'peg ifns':ab,ti OR ribavirin:ab,ti OR rbv:ab,ti OR 'protease inhibitor':ab,ti OR 'protease inhibitors':ab,ti OR 'polymerase inhibitor':ab,ti OR 'polymerase inhibitors':ab,ti OR 'hcv protease':ab,ti OR telaprevir:ab,ti OR boceprevir:ab,ti AND [embase]/lim
1 | 'hepatitis c virus':de OR 'hepatitis c':de OR 'chronic active hepatitis':de OR 'hepatitis non a non b':de AND [embase]/lim

Cochrane Library: Cochrane Database of Systematic Reviews & Database of Abstracts of Reviews of Effects 2002–2011 Searched April 11, 2011, Update Search April 4, 2012

“Hepatitis C” OR Hepacivirus OR HCV (Title, Abstract, Keyword)
Limit to reviews, published 2002–2011

Cochrane Library: Cochrane Central Register of Controlled Trials 2002–2011 Searched April 11, 2011; Update Search April 04, 2012

"Interferon-alpha" OR "Interferon Alfa-2a" OR "Interferon Alpha-2b" OR "IFNalpha2a" OR "IFNalpha2b" OR "Interferon alpha 2a" OR "interferon alpha 2b" OR "Polyethylene Glycol*" OR pegasys OR Peg-intron OR "peginterferon alpha-2a" OR "peginterferon alpha-2b" OR "peginterferon alpha 2a" OR "peginterferon alpha 2b" OR "pegylated interferon*" OR IFN* OR "PEG IFN*" OR Ribavirin OR RBV OR "protease inhibitor*" OR "polymerase inhibit*" OR "HCV protease*" OR telaprevir OR boceprevir (Title, Abstract, Keyword)

SCOPUS Search Strategy 1960–2011 Searched April 11, 2011; Update Search April 04, 2012

11 | (TITLE-ABS-KEY(“hepatitis c” OR hepacivirus OR hcv)) AND (TITLE-ABS-KEY(cohort* OR "meta analysis" OR "randomized controlled trial*" OR "systematic review*" OR "controlled clinical trial*" OR "placebo" OR "clinical trial*" OR randomized OR randomly)) AND (TITLE-ABS-KEY(counseling OR “health education” OR “patient education” OR psychotherapy OR “behavior therapy” OR “cognitive therapy” OR immuniz* OR immunotherapy OR “socioenvironmental therapy” OR “cognitive behavior* therapy” OR vaccine*))
10 | TITLE-ABS-KEY(counseling OR “health education” OR “patient education” OR psychotherapy OR “behavior therapy” OR “cognitive therapy” OR immuniz* OR immunotherapy OR “socioenvironmental therapy” OR “cognitive behavior* therapy” OR vaccine*)
9 | (TITLE-ABS-KEY(“hepatitis c” OR hepacivirus OR hcv)) AND ((TITLE-ABS-KEY(“antiviral agent*” OR interferon* OR interferon-alpha OR “interferon alfa-2a” OR “interferon alpha-2b” OR ifnalpha2a OR ifnalpha2b OR “interferon alpha 2a” OR “interferon alpha 2b” OR “polyethylene glycols” OR pegasys OR peg-intron) OR TITLE-ABS-KEY(“peginterferon alpha-2a” OR “peginterferon alpha-2b” OR “peginterferon alpha 2a” OR “peginterferon alpha 2b” OR “pegylated interferon*” OR ifn* OR peg ifn* OR ribavirin OR rbv OR “protease inhibitor*” OR “polymerase inhibitor*” OR “hcv protease*” OR telapr))) AND (TITLE-ABS-KEY(cohort* OR "meta analysis" OR "randomized controlled trial*" OR "systematic review*" OR "controlled clinical trial*" OR "placebo" OR "clinical trial*" OR randomized OR randomly)) AND (TITLE-ABS-KEY(unsafe OR safety OR harm* OR complication* OR poison* OR risk* OR side-effect* OR “side effect*” OR “undesirable effect* OR “treatment emergent” OR tolerab* OR toxic* OR “adverse effect*” OR “adverse reaction*” OR “adverse event*” OR “adverse outcome*”)) AND (LIMIT-TO(PUBYEAR, 2011) OR LIMIT-TO(PUBYEAR, 2010) OR LIMIT-TO(PUBYEAR, 2009) OR LIMIT-TO(PUBYEAR, 2008) OR LIMIT-TO(PUBYEAR, 2007) OR LIMIT-TO(PUBYEAR, 2006) OR LIMIT-TO(PUBYEAR, 2005) OR LIMIT-TO(PUBYEAR, 2004) OR LIMIT-TO(PUBYEAR, 2003))
8 | (TITLE-ABS-KEY(“hepatitis c” OR hepacivirus OR hcv)) AND ((TITLE-ABS-KEY(“antiviral agent*” OR interferon* OR interferon-alpha OR “interferon alfa-2a” OR “interferon alpha-2b” OR ifnalpha2a OR ifnalpha2b OR “interferon alpha 2a” OR “interferon alpha 2b” OR “polyethylene glycols” OR pegasys OR peg-intron) OR TITLE-ABS-KEY(“peginterferon alpha-2a” OR “peginterferon alpha-2b” OR “peginterferon alpha 2a” OR “peginterferon alpha 2b” OR “pegylated interferon*” OR ifn* OR peg ifn* OR ribavirin OR rbv OR “protease inhibitor*” OR “polymerase inhibitor*” OR “hcv protease*” OR telapr))) AND (TITLE-ABS-KEY(cohort* OR "meta analysis" OR "randomized controlled trial*" OR "systematic review*" OR "controlled clinical trial*" OR "placebo" OR "clinical trial*" OR randomized OR randomly)) AND (TITLE-ABS-KEY(unsafe OR safety OR harm* OR complication* OR poison* OR risk* OR side-effect* OR “side effect*” OR “undesirable effect* OR “treatment emergent” OR tolerab* OR toxic* OR “adverse effect*” OR “adverse reaction*” OR “adverse event*” OR “adverse outcome*”))
7 | TITLE-ABS-KEY(unsafe OR safety OR harm* OR complication* OR poison* OR risk* OR side-effect* OR “side effect*” OR “undesirable effect* OR “treatment emergent” OR tolerab* OR toxic* OR “adverse effect*” OR “adverse reaction*” OR “adverse event*” OR “adverse outcome*”)
6 | (TITLE-ABS-KEY(“hepatitis c” OR hepacivirus OR hcv)) AND ((TITLE-ABS-KEY(“antiviral agent*” OR interferon* OR interferon-alpha OR “interferon alfa-2a” OR “interferon alpha-2b” OR ifnalpha2a OR ifnalpha2b OR “interferon alpha 2a” OR “interferon alpha 2b” OR “polyethylene glycols” OR pegasys OR peg-intron) OR TITLE-ABS-KEY(“peginterferon alpha-2a” OR “peginterferon alpha-2b” OR “peginterferon alpha 2a” OR “peginterferon alpha 2b” OR “pegylated interferon*” OR ifn* OR peg ifn* OR ribavirin OR rbv OR “protease inhibitor*” OR “polymerase inhibitor*” OR “hcv protease*” OR telapr))) AND (TITLE-ABS-KEY(cohort* OR "meta analysis" OR "randomized controlled trial*" OR "systematic review*" OR "controlled clinical trial*" OR "placebo" OR "clinical trial*" OR randomized OR randomly)) AND (LIMIT-TO(PUBYEAR, 2011) OR LIMIT-TO(PUBYEAR, 2010) OR LIMIT-TO(PUBYEAR, 2009) OR LIMIT-TO(PUBYEAR, 2008) OR LIMIT-TO(PUBYEAR, 2007) OR LIMIT-TO(PUBYEAR, 2006) OR LIMIT-TO(PUBYEAR, 2005) OR LIMIT-TO(PUBYEAR, 2004) OR LIMIT-TO(PUBYEAR, 2003) OR LIMIT-TO(PUBYEAR, 2002))
5 | (TITLE-ABS-KEY(“hepatitis c” OR hepacivirus OR hcv)) AND ((TITLE-ABS-KEY(“antiviral agent*” OR interferon* OR interferon-alpha OR “interferon alfa-2a” OR “interferon alpha-2b” OR ifnalpha2a OR ifnalpha2b OR “interferon alpha 2a” OR “interferon alpha 2b” OR “polyethylene glycols” OR pegasys OR peg-intron) OR TITLE-ABS-KEY(“peginterferon alpha-2a” OR “peginterferon alpha-2b” OR “peginterferon alpha 2a” OR “peginterferon alpha 2b” OR “pegylated interferon*” OR ifn* OR peg ifn* OR ribavirin OR rbv OR “protease inhibitor*” OR “polymerase inhibitor*” OR “hcv protease*” OR telapr))) AND (TITLE-ABS-KEY(cohort* OR "meta analysis" OR "randomized controlled trial*" OR "systematic review*" OR "controlled clinical trial*" OR "placebo" OR "clinical trial*" OR randomized OR randomly))
4 | (TITLE-ABS-KEY(“hepatitis c” OR hepacivirus OR hcv)) AND ((TITLE-ABS-KEY(“antiviral agent*” OR interferon* OR interferon-alpha OR “interferon alfa-2a” OR “interferon alpha-2b” OR ifnalpha2a OR ifnalpha2b OR “interferon alpha 2a” OR “interferon alpha 2b” OR “polyethylene glycols” OR pegasys OR peg-intron) OR TITLE-ABS-KEY(“peginterferon alpha-2a” OR “peginterferon alpha-2b” OR “peginterferon alpha 2a” OR “peginterferon alpha 2b” OR “pegylated interferon*” OR ifn* OR peg ifn* OR ribavirin OR rbv OR “protease inhibitor*” OR “polymerase inhibitor*” OR “hcv protease*” OR telapr))) AND (TITLE-ABS-KEY(cohort* OR "meta analysis" OR "randomized controlled trial*" OR "systematic review*" OR "controlled clinical trial*" OR "placebo" OR "clinical trial*" OR randomized OR randomly))
3 | TITLE-ABS-KEY(cohort* OR "meta analysis" OR "randomized controlled trial*" OR "systematic review*" OR "controlled clinical trial*" OR "placebo" OR "clinical trial*" OR randomized OR randomly)
2 | (TITLE-ABS-KEY(“antiviral agent*” OR interferon* OR interferon-alpha OR “interferon alfa-2a” OR “interferon alpha-2b” OR ifnalpha2a OR ifnalpha2b OR “interferon alpha 2a” OR “interferon alpha 2b” OR “polyethylene glycols” OR pegasys OR peg-intron) OR TITLE-ABS-KEY(“peginterferon alpha-2a” OR “peginterferon alpha-2b” OR “peginterferon alpha 2a” OR “peginterferon alpha 2b” OR “pegylated interferon*” OR ifn* OR peg ifn* OR ribavirin OR rbv OR “protease inhibitor*” OR “polymerase inhibitor*” OR “hcv protease*” OR telaprevir))
1 | TITLE-ABS-KEY(“hepatitis c” OR hepacivirus OR hcv)

OvidSP PSYCINFO Search Strategy 1806 to February Week 4 2011 Searched April 12, 2011; Update Search April 4, 2012

1 | hepatitis/ or (Hepatitis C or hepacivirus$ or HCV).mp.
2 | [exp treatment/ or exp intervention/ or exp psychotherapy/ or exp alcohol rehabilitation/ or exp counseling/ or exp support groups/ or exp rehabilitation/ or exp mental health services/ or exp community services/ or exp outreach programs/ or exp drug rehabilitation/ or exp sobriety/ or exp detoxification/ or exp drug rehabilitation/ or exp treatment outcomes/ or exp alcoholics anonymous/]
3 | alcohol*.mp.
4 | 1 and 2 and 3

Clinicaltrials.gov Searched April 12, 2011; Update Search April 4, 2012

interferon alfa OR peginterferon OR ribavirin OR telaprevir OR boceprevir \| Closed Studies \| Studies With Results \| hepatitis c \| Adult, Senior

## Updated Search: 8/28/2012

Ovid MEDLINE Search Strategy 1947 to February Week 3 2011 Searched February 28, 2011; Update Search April 04, 2012; Update Search August 28, 2012

1 | Hepatitis C/ or Hepatitis C, Chronic/ or Hepacivirus/ or Hepatitis C.mp. or hepacivirus$.mp. or HCV.mp.
2 | Antiviral agents/ or Interferons/ or Interferon-alpha/ or Interferon Alfa-2a/ or Interferon Alpha-2b/ or Interferon$.mp. or interferon alpha-2a.mp. or interferon alpha-2b.mp. or IFNalpha2a.mp. or IFNalpha2b.mp. or interferon alpha 2a.mp. or interferon alpha 2b.mp. or exp Polyethylene Glycols/ or pegasys.mp. or Peg-intron.mp. or peginterferon alpha-2a.mp. or peginterferon alpha-2b.mp. or peginterferon alpha 2a.mp. or peginterferon alpha 2b.mp. or pegylated interferon$.mp. or IFN$.mp. or PEG IFN$.mp. or Ribavirin/ or ribavirin.mp. or RBV.mp. or exp Protease Inhibitors/ or protease inhibitor$.mp. or polymerase inhibit$.mp. or HCV protease$.mp. or telaprevir.mp. or boceprevir.mp.
3 | 1 and 2
4 | (randomized controlled trial or controlled clinical trial or meta analysis or review).pt. or clinical trials as topic/ or cohort studies/ or randomized.ab. or randomly.ab. or placebo.ab. or (systematic adj1 review).ti,ab.
5 | 3 and 4
6 | limit 5 to (yr="2002 -Current" and ("adult (19 to 44 years)" or "middle age (45 to 64 years)" or "all aged (65 and over)"))
7 | (unsafe or safety or harm$ or complication$ or poison$ or risk$).mp. or AE.fs. or MO.fs. or PO.fs. or TO.fs. or CT.fs. or side-effect$.mp. or (undesirable adj1 effect$).mp. or (treatment adj1 emergent).mp. or tolerab$.mp. or toxic$.mp. or adrs.mp. or (adverse adj2 (effect or effects or reaction or reactions or event or events or outcome or outcomes)).mp.
8 | 1 and 2 and 7
9 | 4 and 8
10 | limit 9 to (yr="2002 -Current" and ("adult (19 to 44 years)" or "middle age (45 to 64 years)" or "all aged (65 and over)"))
11 | Counseling/ or Sex Counseling/ or Health Education/ or Patient Education as Topic/ or Psychotherapy/ or Behavior Therapy/ or Cognitive Therapy/ or Immunization/ or Immunotherapy/ or Psychotherapy, Brief/ or Socioenvironmental Therapy/
12 | 1 and 11

EMBASE Search Strategy 1976 – 2011

An updated search for August 28, 2012 was not conducted as Oregon Health and Sciences University no longer subscribes to this database.

Cochrane Library: Cochrane Database of Systematic Reviews & Database of Abstracts of Reviews of Effects 2002–2011 Searched April 11, 2011, Update Search April 4, 2012; Update Search August 28, 2012

“Hepatitis C” OR Hepacivirus OR HCV (Title, Abstract, Keyword)
Limit to reviews, published 2002–2011

Cochrane Library: Cochrane Central Register of Controlled Trials 2002–2011 Searched April 11, 2011; Update Search April 04, 2012; Update Search August 28, 2012

"Interferon-alpha" OR "Interferon Alfa-2a" OR "Interferon Alpha-2b" OR "IFNalpha2a" OR "IFNalpha2b" OR "Interferon alpha 2a" OR "interferon alpha 2b" OR "Polyethylene Glycol*" OR pegasys OR Peg-intron OR "peginterferon alpha-2a" OR "peginterferon alpha-2b" OR "peginterferon alpha 2a" OR "peginterferon alpha 2b" OR "pegylated interferon*" OR IFN* OR "PEG IFN*" OR Ribavirin OR RBV OR "protease inhibitor*" OR "polymerase inhibit*" OR "HCV protease*" OR telaprevir OR boceprevir (Title, Abstract, Keyword)

SCOPUS Search Strategy 1960–2011 Searched April 11, 2011; Update Search April 04, 2012; Update Search August 28, 2012

11 | (TITLE-ABS-KEY(“hepatitis c” OR hepacivirus OR hcv)) AND (TITLE-ABS-KEY(cohort* OR "meta analysis" OR "randomized controlled trial*" OR "systematic review*" OR "controlled clinical trial*" OR "placebo" OR "clinical trial*" OR randomized OR randomly)) AND (TITLE-ABS-KEY(counseling OR “health education” OR “patient education” OR psychotherapy OR “behavior therapy” OR “cognitive therapy” OR immuniz* OR immunotherapy OR “socioenvironmental therapy” OR “cognitive behavior* therapy” OR vaccine*))
10 | TITLE-ABS-KEY(counseling OR “health education” OR “patient education” OR psychotherapy OR “behavior therapy” OR “cognitive therapy” OR immuniz* OR immunotherapy OR “socioenvironmental therapy” OR “cognitive behavior* therapy” OR vaccine*)
9 | (TITLE-ABS-KEY(“hepatitis c” OR hepacivirus OR hcv)) AND ((TITLE-ABS-KEY(“antiviral agent*” OR interferon* OR interferon-alpha OR “interferon alfa-2a” OR “interferon alpha-2b” OR ifnalpha2a OR ifnalpha2b OR “interferon alpha 2a” OR “interferon alpha 2b” OR “polyethylene glycols” OR pegasys OR peg-intron) OR TITLE-ABS-KEY(“peginterferon alpha-2a” OR “peginterferon alpha-2b” OR “peginterferon alpha 2a” OR “peginterferon alpha 2b” OR “pegylated interferon*” OR ifn* OR peg ifn* OR ribavirin OR rbv OR “protease inhibitor*” OR “polymerase inhibitor*” OR “hcv protease*” OR telapr))) AND (TITLE-ABS-KEY(cohort* OR "meta analysis" OR "randomized controlled trial*" OR "systematic review*" OR "controlled clinical trial*" OR "placebo" OR "clinical trial*" OR randomized OR randomly)) AND (TITLE-ABS-KEY(unsafe OR safety OR harm* OR complication* OR poison* OR risk* OR side-effect* OR “side effect*” OR “undesirable effect* OR “treatment emergent” OR tolerab* OR toxic* OR “adverse effect*” OR “adverse reaction*” OR “adverse event*” OR “adverse outcome*”)) AND (LIMIT-TO(PUBYEAR, 2011) OR LIMIT-TO(PUBYEAR, 2010) OR LIMIT-TO(PUBYEAR, 2009) OR LIMIT-TO(PUBYEAR, 2008) OR LIMIT-TO(PUBYEAR, 2007) OR LIMIT-TO(PUBYEAR, 2006) OR LIMIT-TO(PUBYEAR, 2005) OR LIMIT-TO(PUBYEAR, 2004) OR LIMIT-TO(PUBYEAR, 2003))
8 | (TITLE-ABS-KEY(“hepatitis c” OR hepacivirus OR hcv)) AND ((TITLE-ABS-KEY(“antiviral agent*” OR interferon* OR interferon-alpha OR “interferon alfa-2a” OR “interferon alpha-2b” OR ifnalpha2a OR ifnalpha2b OR “interferon alpha 2a” OR “interferon alpha 2b” OR “polyethylene glycols” OR pegasys OR peg-intron) OR TITLE-ABS-KEY(“peginterferon alpha-2a” OR “peginterferon alpha-2b” OR “peginterferon alpha 2a” OR “peginterferon alpha 2b” OR “pegylated interferon*” OR ifn* OR peg ifn* OR ribavirin OR rbv OR “protease inhibitor*” OR “polymerase inhibitor*” OR “hcv protease*” OR telapr))) AND (TITLE-ABS-KEY(cohort* OR "meta analysis" OR "randomized controlled trial*" OR "systematic review*" OR "controlled clinical trial*" OR "placebo" OR "clinical trial*" OR randomized OR randomly)) AND (TITLE-ABS-KEY(unsafe OR safety OR harm* OR complication* OR poison* OR risk* OR side-effect* OR “side effect*” OR “undesirable effect* OR “treatment emergent” OR tolerab* OR toxic* OR “adverse effect*” OR “adverse reaction*” OR “adverse event*” OR “adverse outcome*”))
7 | TITLE-ABS-KEY(unsafe OR safety OR harm* OR complication* OR poison* OR risk* OR side-effect* OR “side effect*” OR “undesirable effect* OR “treatment emergent” OR tolerab* OR toxic* OR “adverse effect*” OR “adverse reaction*” OR “adverse event*” OR “adverse outcome*”)
6 | (TITLE-ABS-KEY(“hepatitis c” OR hepacivirus OR hcv)) AND ((TITLE-ABS-KEY(“antiviral agent*” OR interferon* OR interferon-alpha OR “interferon alfa-2a” OR “interferon alpha-2b” OR ifnalpha2a OR ifnalpha2b OR “interferon alpha 2a” OR “interferon alpha 2b” OR “polyethylene glycols” OR pegasys OR peg-intron) OR TITLE-ABS-KEY(“peginterferon alpha-2a” OR “peginterferon alpha-2b” OR “peginterferon alpha 2a” OR “peginterferon alpha 2b” OR “pegylated interferon*” OR ifn* OR peg ifn* OR ribavirin OR rbv OR “protease inhibitor*” OR “polymerase inhibitor*” OR “hcv protease*” OR telapr))) AND (TITLE-ABS-KEY(cohort* OR "meta analysis" OR "randomized controlled trial*" OR "systematic review*" OR "controlled clinical trial*" OR "placebo" OR "clinical trial*" OR randomized OR randomly)) AND (LIMIT-TO(PUBYEAR, 2011) OR LIMIT-TO(PUBYEAR, 2010) OR LIMIT-TO(PUBYEAR, 2009) OR LIMIT-TO(PUBYEAR, 2008) OR LIMIT-TO(PUBYEAR, 2007) OR LIMIT-TO(PUBYEAR, 2006) OR LIMIT-TO(PUBYEAR, 2005) OR LIMIT-TO(PUBYEAR, 2004) OR LIMIT-TO(PUBYEAR, 2003) OR LIMIT-TO(PUBYEAR, 2002))
5 | (TITLE-ABS-KEY(“hepatitis c” OR hepacivirus OR hcv)) AND ((TITLE-ABS-KEY(“antiviral agent*” OR interferon* OR interferon-alpha OR “interferon alfa-2a” OR “interferon alpha-2b” OR ifnalpha2a OR ifnalpha2b OR “interferon alpha 2a” OR “interferon alpha 2b” OR “polyethylene glycols” OR pegasys OR peg-intron) OR TITLE-ABS-KEY(“peginterferon alpha-2a” OR “peginterferon alpha-2b” OR “peginterferon alpha 2a” OR “peginterferon alpha 2b” OR “pegylated interferon*” OR ifn* OR peg ifn* OR ribavirin OR rbv OR “protease inhibitor*” OR “polymerase inhibitor*” OR “hcv protease*” OR telapr))) AND (TITLE-ABS-KEY(cohort* OR "meta analysis" OR "randomized controlled trial*" OR "systematic review*" OR "controlled clinical trial*" OR "placebo" OR "clinical trial*" OR randomized OR randomly))
4 | (TITLE-ABS-KEY(“hepatitis c” OR hepacivirus OR hcv)) AND ((TITLE-ABS-KEY(“antiviral agent*” OR interferon* OR interferon-alpha OR “interferon alfa-2a” OR “interferon alpha-2b” OR ifnalpha2a OR ifnalpha2b OR “interferon alpha 2a” OR “interferon alpha 2b” OR “polyethylene glycols” OR pegasys OR peg-intron) OR TITLE-ABS-KEY(“peginterferon alpha-2a” OR “peginterferon alpha-2b” OR “peginterferon alpha 2a” OR “peginterferon alpha 2b” OR “pegylated interferon*” OR ifn* OR peg ifn* OR ribavirin OR rbv OR “protease inhibitor*” OR “polymerase inhibitor*” OR “hcv protease*” OR telapr))) AND (TITLE-ABS-KEY(cohort* OR "meta analysis" OR "randomized controlled trial*" OR "systematic review*" OR "controlled clinical trial*" OR "placebo" OR "clinical trial*" OR randomized OR randomly))
3 | TITLE-ABS-KEY(cohort* OR "meta analysis" OR "randomized controlled trial*" OR "systematic review*" OR "controlled clinical trial*" OR "placebo" OR "clinical trial*" OR randomized OR randomly)
2 | (TITLE-ABS-KEY(“antiviral agent*” OR interferon* OR interferon-alpha OR “interferon alfa-2a” OR “interferon alpha-2b” OR ifnalpha2a OR ifnalpha2b OR “interferon alpha 2a” OR “interferon alpha 2b” OR “polyethylene glycols” OR pegasys OR peg-intron) OR TITLE-ABS-KEY(“peginterferon alpha-2a” OR “peginterferon alpha-2b” OR “peginterferon alpha 2a” OR “peginterferon alpha 2b” OR “pegylated interferon*” OR ifn* OR peg ifn* OR ribavirin OR rbv OR “protease inhibitor*” OR “polymerase inhibitor*” OR “hcv protease*” OR telaprevir))
1 | TITLE-ABS-KEY(“hepatitis c” OR hepacivirus OR hcv)

OvidSP PSYCINFO Search Strategy 1806 to February Week 4 2011 Searched April 12, 2011; Update Search April 4, 2012; Update Search August 28, 2012

1 | hepatitis/ or (Hepatitis C or hepacivirus$ or HCV).mp.
2 | [exp treatment/ or exp intervention/ or exp psychotherapy/ or exp alcohol rehabilitation/ or exp counseling/ or exp support groups/ or exp rehabilitation/ or exp mental health services/ or exp community services/ or exp outreach programs/ or exp drug rehabilitation/ or exp sobriety/ or exp detoxification/ or exp drug rehabilitation/ or exp treatment outcomes/ or exp alcoholics anonymous/]
3 | alcohol*.mp.
4 | 1 and 2 and 3

Clinicaltrials.gov Searched April 12, 2011; Update Search April 4, 2012, Update Search August 28, 2012

interferon alfa OR peginterferon OR ribavirin OR telaprevir OR boceprevir \| Closed Studies \| Studies With Results \| hepatitis c \| Adult, Senior