# Acknowledgments

We thank our colleagues at the Oregon Evidence-based Practice Center, Robin Paynter, M.L.I.S., and Rose Campbell, M.L.I.S., for conducting the literature searches, and Leah Williams, B.S., Ed Reid, M.A., and Elaine Graham, M.L.S. for editorial support. We appreciate and acknowledge the contributions of AHRQ Task Order Officer Christine Chang, M.D., M.P.H.; USPSTF Medical Officer Iris Mabry-Hernandez, M.D., M.P.H.; and Evidence-based Practice Center Program Associate Editor Kathleen N. Lohr, Ph.D. We also thank the Key Informants, members of the Technical Expert Panel, and Peer Reviewers.