# Abbreviations and Acronyms

AHRQ: Agency for Healthcare Research and Quality
ALT: Alanine aminotransferase
CER: Comparative effectiveness review
CHIP: Children’s Health Insurance Program
CI: Confidence Interval
EPC: Evidence-based Practice Center
ESLD: End-stage liver disease
HCC: Hepatocellular carcinoma
HCV: Hepatitis C virus
HCV-RNA: Hepatitis C virus ribonucleic acid
HIV: Human immunodeficiency virus
HR: Hazard ratio
PCR: Polymerase chain reaction
PEG: Pegylated
PICOTS: Populations, Interventions, Comparators, Outcomes, Timing, and Setting
RR: Relative risk
SVR: Sustained virologic response
TEP: Technical Expert Panel
USPSTF: U.S. Preventive Services Task Force