# Results

## Introduction

This chapter is organized by Key Question (KQ) and grouped by medical condition(s) when possible. Briefly, we wanted to examine the comparative effectiveness of practice-based interventions for primary care patients with concomitant depression and chronic medical conditions; we focused on five main outcomes: mental health (KQ 1), chronic medical (KQ 2), harms of interventions (KQ 3), components of interventions (KQ 4), and characteristics of practice settings in which the interventions occurred (KQ 5). Our results pertain to the general adult population; no studies that met our inclusion criteria reported on young adults or pregnant women. Regarding older adults, one study61–65 selectively recruited for age 60 or older; however, participants across all studies in this review tended to be middle-aged or older (mean age, 59; range of means, 47 to 72) so we do not report results for older adults separately. Several studies reported on traditionally underrepresented populations, including women,66–68 Spanish speakers,66–72 and predominantly African-American male veterans with HIV;73 we report these results in the context of overall results by medical condition, not in separate categories.

## Results of Literature Searches

Results of our searches are presented in Figure 2. We ultimately included 24 published articles reporting on 10 randomized controlled trials (RCTs). We recorded the reason that each excluded full-text publication did not satisfy the eligibility criteria and compiled a comprehensive list of such studies (Appendix B). Evidence tables for included studies can be found in Appendix C.

Figure 2 Disposition of articles (PRISMA figure)

Source: Moher et al., 2009.47

^a^ This result includes the Improving Mood—Promoting Access to Collaborative Treatment (IMPACT) trial;5 it tested a collaborative care depression intervention in older adult primary care patients, including preplanned subgroups of patients with arthritis, cancer, and diabetes. For ease of interpretation, we consider each subgroup a unique “study” in the Results chapter. Thus, our results include data from 12 studies (9 stand-alone RCTs and 3 IMPACT subgroups).

Abbreviations: CINAHL = Cumulative Index to Nursing and Allied Health Literature; PICOTS = population, intervention, comparator, outcome, timing, setting; PRISMA = Preferred Reporting Items for Systematic Reviews and Meta-Analyses.

Figure 2 is titled “Disposition of articles.” The figure is a flow chart that summarizes the search and selection of articles: There were 1,947 citations of randomized trials identified by searching MEDLINE®, Embase, the Cochrane Library, CINAHL®, and PsycINFO®. In addition, 168 references were identified by searching reference lists of selected articles, searching clinicaltrials.gov, and by peer reviewer suggestion. After removal of duplicate citations, titles and abstracts of 1,903 references were screened for potential inclusion. Of these, 219 were deemed appropriate for full-text review in order to determine eligibility. After full-text review, 195 were excluded: 2 were in a language other than English; 57 were the wrong type of publication or wrong study design; 134 failed to meet at least one PICOTS element, and 2 were deemed poor quality. Twenty-four articles representing 12 studies are included in this report’s qualitative and quantitative syntheses.

## Description of Included Studies

In the 10 included trials, sample sizes ranged from 55 to 1,001, and study duration ranged from 6 to 60 months. Nine trials were conducted in the United States (1 of these in Puerto Rico72) and 1 in Scotland.74 All included studies characterized their respective intervention as a form of collaborative care, not another form of a practice-based intervention (such as integrated care). Similarly, all included studies specified depression as the targeted mental health condition; no studies specified anxiety as the condition of interest. The designated chronic medical conditions included arthritis,62, 65 cancer,61, 66, 68, 71, 74 diabetes,38, 40, 63, 64, 67, 69, 70, 75–78 heart disease,79 and HIV.73 Two studies selected patients with one or more active medical conditions.72, 80, 81

Five articles61–65 are secondary analyses from the Improving Mood—Promoting Access to Collaborative Treatment (IMPACT) trial;5 it tested a collaborative care depression intervention in older adult primary care patients, including preplanned subgroups of patients with arthritis, cancer, and diabetes. For ease of interpretation, we consider each subgroup a unique “study” in the Results chapter. Consequently, our results include data from 12 studies (9 stand-alone RCTs and 3 IMPACT subgroups). Six articles38, 40, 75–78 are from the Pathways trial, which tested a collaborative care intervention in primary care patients with diabetes and depression. The majority of all studies reported their funding source as the government, and in some cases “multiple sources,” including foundations. All studies reported their funding source, and no study identified an industry sponsor.

Because all KQs draw from the same universe of evidence, we present the trials in two ways here as context for reading the remainder of results. Tables 4 through 9 display the characteristics of trials for the specific chronic medical conditions. Table 10 summarizes the main elements of the trial interventions and control groups. For IMPACT,61–65 Bypassing the Blues,79 Symptom Management Research Trials (SMaRT) Oncology 1,^74^ HITIDES (HIV Implementation of Translating Initiatives for Depression into Effective Solutions),73 the Multifaceted Oncology Depression Program (MODP),66 and Vera et al.,72 the control condition was usual care, which consisted of informing patients of their depression status and advising them to share this information with their primary care provider (PCP). By contrast, ADAPt-C,68, 71 Pathways,38, 40, 75, 76, 78 TEAMcare,80–82 and the Multifaceted Diabetes and Depression Program (MDDP)67, 69, 70 compared collaborative care with enhanced usual care, which extended usual care by including some degree of additional communication between the research staff or diabetes care manager and the patient’s PCP and/or family about the patient’s depression status.

Table 4 Characteristics of included trials of patients with arthritis

Author, Year Study Name Country Setting | N Duration (mths) | Mean Age (y)^a^ | % Female^a^ % Nonwhite^a^ | Depression-Related Eligibility Requirement Baseline Depression Score^a,b^ | Quality^c^
Lin et al., 2003;^65^ Lin et al., 2006^62^ IMPACT U.S. PC | 1,001 24 | 72.0^d^ | 68.3 24 | Current DSM-IV diagnosis of MDD and/or dysthymia SCL-20: 1.7 | Fair

a Overall mean as reported, range of means for treatment groups, or overall mean calculated using mean age from each treatment group.

b See Table 11 for depression scale details.

c Quality assessment considers potential for biases including appropriate masking/blinding, attrition, and intent-to-treat analyses. In general terms, a “good” study has the least risk of bias and its results are considered to be valid. A “fair” study is susceptible to some bias but probably not sufficient to invalidate its results. For detailed quality assessment, see Appendix D.

d The IMPACT trial enrolled only people ≥60 years of age.

Abbreviations: DSM = Diagnostic and Statistical Manual; IMPACT = Improving Mood—Promoting Access to Collaborative Treatment; MDD = major depressive disorder; mths = months; PC = primary care;SCL-20 = Symptom Checklist—depression scale; U.S. = United States; y = years.

Table 5 Characteristics of included trials of patients with cancer

Author, Year Study Name Country Setting | N Duration (mths) | Mean Age (y)^a^ | % Female^a^ % Nonwhite^a^ | Depression-Related Eligibility Requirement Baseline Depression Score^a,b^ | Quality^c^
Dwight-Johnson et al., 2005^66^ MODP U.S. PC-like | 55 8 | 47.3 | NR^d^ | Major depression per PHQ-9 or dysthymia per PRIME-MD PHQ-9: 12.6–13.4 | Fair
Ell et al., 2008;^68^ Ell et al., 2011^71^ ADAPt-C U.S. PC-like | 472 24 | ~50^e^ | 84.5 87.9 | PHQ-9 ≥10 or dysthymia per DSM-IV SCI PHQ-9: 13.1 | Fair
Fann et al., 2009^61^ IMPACT U.S. PC | 215 24 | 71.8^f^ | 60 25 | Major depression or dysthymia per DSM-IV SCI SCL-20: 1.6 | Fair
Strong et al., 2008^74^ SMaRT Oncology 1 UK PC-like | 200 12 | 56.6 | 69–72 NR | HADS ≥15 and major depression per DSM-IV SCI and SCL-20 ≥1.75 SCL-20: 2.3–2.4 (median) | Fair

a Overall mean as reported, range of means for treatment groups, or overall mean calculated using mean age from each treatment group.

b See Table 11 for depression scale details.

c Quality assessment considers potential for biases including appropriate masking/blinding, attrition, and intent-to-treat analyses. In general terms, a “good” study has the least risk of bias and its results are considered to be valid. A “fair” study is susceptible to some bias but probably not sufficient to invalidate its results. For detailed quality assessment, see Appendix D.

d Race/ethnicity not reported, but 85–96 percent were Spanish-only speakers.

e Age only reported as percent ≥50 yrs.

f The IMPACT study enrolled only people ≥60 years old.

Abbreviations: ADAPt-C = Alleviating Depression Among Patients with Cancer; DSM = Diagnostic and Statistical Manual; HADS = Hospital Anxiety and Depression Scale; IMPACT = Improving Mood – Promoting Access to Collaborative Treatment; MODP = Multifaceted Oncology Depression Program; mths = months; NR = not reported; PC = primary care; PHQ-9 = Patient Health Questionnaire – depression module; PRIME-MD = Primary Care Evaluation of Mental Disorders; SCI = structured clinical interview; SCL-20 = Symptom Checklist – depression scale; SMaRT = Symptom Management Research Trials; UK = United Kingdom; U.S. = United States; y = years.

Table 6 Characteristics of included trials of patients with diabetes

Author, Year Study Name Country Setting | N Duration (mths) | Mean Age (y)^a^ | % Female^a^ % Nonwhite^a^ | Depression-Related Eligibility Requirement Baseline Depression Score^a,b^ | Quality^c^
Ell et al., 2010;^67^ Ell et al., 2011;^69^ Hay et al., 2012^70^ MDDP U.S. PC and PC-like | 387 24 | NR^d^ | 79.8–84.5 96.5 | PHQ-9 ≥10 SCL-20: 1.4–1.7 | Fair
Ciechanowski et al., 2006;^40^ Katon et al., 2008;^75^ Katon et al., 2004;^38^ Kinder et al., 2006;^76^ Lin et al., 2006;^77^ Simon et al., 2007;^78^ Pathways U.S. PC | 329 60 | 58.4 | 64.8–65.2 19.9–24.8 | PHQ-9 ≥10 and SCL-20 ≥1.1 SCL-20: 1.63–1.71 | Fair
Williams et al., 2004^64^; Katon et al., 2006^63^ IMPACT U.S. PC | 417 24 | 70.2^e^ | 53–54 35–37 | Major depression or dysthymia per DSM-IV SCI SCL-20: 1.67–1.72 | Fair

a Overall mean as reported, range of means for treatment groups, or overall mean calculated using mean age from each treatment group.

b See Table 11 for depression scale details.

c Quality assessment considers potential for biases including appropriate masking/blinding, attrition, and intent-to-treat analyses. In general terms, a “good” study has the least risk of bias and its results are considered to be valid. A “fair” study is susceptible to some bias but probably not sufficient to invalidate its results. For detailed quality assessment, see Appendix D.

d Age only reported as percent ≥50 yrs; 69 percent-75 percent were ≥50 yrs.

e The IMPACT study enrolled only people ≥60 years old.

Abbreviations: DSM = Diagnostic and Statistical Manual; IMPACT = Improving Mood – Promoting Access to Collaborative Treatment; MDDP = Multifaceted Diabetes and Depression Program; mths = months; NR = not reported; PC = primary care; PHQ-9 = Patient Health Questionnaire – depression module; SCI = structured clinical interview; SCL-20 = Symptom Checklist – depression scale; U.S. = United States; y = years.

Table 7 Characteristics of included trials of patients with heart disease

Author, Year Study Name Country Setting | N Duration (mths) | Mean Age (y)^a^ | % Female^a^ % Nonwhite^a^ | Depression-Related Eligibility Requirement Baseline Depression Score^a,b^ | Quality^c^
Rollman et al., 2009^79^ Bypassing the Blues U.S. Unclear^d^ | 302 8 | 64.0 | 37–46 7–12 | PHQ-9 ≥11 PHQ-9: 13.5–13.6 HRSD: 15.9–16.5 | Good

a Overall mean as reported, range of means for treatment groups, or overall mean calculated using mean age from each treatment group.

b See Table 11 for depression scale details.

c Quality assessment considers potential for biases including appropriate masking/blinding, attrition, and intent-to-treat analyses. In general terms, a “good” study has the least risk of bias and its results are considered to be valid. A “fair” study is susceptible to some bias but probably not sufficient to invalidate its results. For detailed quality assessment, see Appendix D.

d Patients were recruited before hospital discharge; intervention took place over the telephone.

Abbreviations: HRSD = Hamilton Rating Scale for Depression; mths = months; PHQ-9 = Patient Health Questionnaire – depression module; U.S. = United States; y = years.

Table 8 Characteristics of included trials of patients with HIV

Author, Year Study Name Country Setting | N Duration (mths) | Mean Age (y)^a^ | % Female^a^ % Nonwhite^a^ | Depression-Related Eligibility Requirement Baseline Depression Score^a,b^ | Quality^c^
Pyne et al., 2011^73^ HITIDES U.S. PC-like | 276 12 | 49.8 | 2.4–3.2 61.6–63.4 | PHQ-9 ≥10 PHQ-9: 15.7–16.0 SCL-20: 1.8–1.9 | Good

a Overall mean as reported, range of means for treatment groups, or overall mean calculated using mean age from each treatment group.

b See Table 11 for depression scale details.

c Quality assessment considers potential for biases including appropriate masking/blinding, attrition, and intent-to-treat analyses. In general terms, a “good” study has the least risk of bias and its results are considered to be valid. A “fair” study is susceptible to some bias but probably not sufficient to invalidate its results. For detailed quality assessment, see Appendix D.

Abbreviations: HITIDES = HIV Implementation of Translating Initiatives for Depression into Effective Solutions; mths = months; PC = primary care; PHQ-9 = Patient Health Questionnaire – depression module; SCL-20 = Symptom Checklist – depression scale; U.S. = United States; y = years.

Table 9 Characteristics of included trials of patients with multiple conditions

Author, Year Study Name Country Setting | N Duration (mths) | Mean Age (y)^a^ | % Female^a^ % Nonwhite^a^ | Depression-Related Eligibility Requirement Baseline Depression Score^a,b^ | Quality^c^
Katon et al., 2010;^80^ Von Korff, 2011;^82^ Lin, 2012^81^ TEAMcare^d^ U.S. PC | 214 12 | 56.9 | 48–56 22–25 | PHQ-9 ≥10 PHQ-9: 13.9–14.7 SCL-20: 1.7 | Fair
Vera et al., 2010^72^ None U.S. (Puerto Rico) PC | 179 6 | 55.2 | 76 100 | PHQ-9 (cutoff NR) and SCL-20 >1.0 SCL-20: 2.2–2.3 | Good

a Overall mean as reported, range of means for treatment groups, or overall mean calculated using mean age from each treatment group.

b See Table 11 for depression scale details.

c Quality assessment considers potential for biases including appropriate masking/blinding, attrition, and intent-to-treat analyses. In general terms, a “good” study has the least risk of bias and its results are considered to be valid. A “fair” study is susceptible to some bias but probably not sufficient to invalidate its results. For detailed quality assessment, see Appendix D.

d Diabetes and/or heart disease.

Abbreviations: mths = months; PC = primary care; PHQ-9 = Patient Health Questionnaire—depression module; SCL-20 = Symptom Checklist—depression scale; U.S. = United States; y = years.

Table 10 Summary of collaborative care intervention trials

Author/Trial Name Disease | Intervention Summary | Delivery Method Delivered By Psychiatrist Supervision? | Control Condition^a^
Lin et al., 2003;^65^ Lin et al., 2006;^62^ Fann et al., 2009;^61^ Williams et al., 2004;^64^ Katon et al., 2006^63^ IMPACT Arthritis, cancer, diabetes | Care management based on stepped care treatment algorithm; patient preference for treatment: antidepressants or problem-solving therapy (6–8 sessions); monitoring of treatment response (“IMPACT model”) | In-person and telephone Depression care specialist (nurse or clinical psychologist) Yes | Usual care
Dwight-Johnson et al., 2005^66^ MODP Cancer | Described as being based on the IMPACT model | In-person and telephone Bilingual cancer depression care specialist (master’s level social worker) Yes | Usual care
Ell et al., 2008;^68^ Ell et al., 2011^71^ ADAPt-C Cancer | Described as being based on the IMPACT model | In-person and telephone Bilingual cancer depression care specialist (master’s level social worker) Yes | Enhanced usual care
Ell et al., 2010;^67^ Ell et al., 2011;^69^ Hay et al., 2012^70^ MDDP Diabetes | Described as being based on the IMPACT model | In-person and telephone Bilingual diabetes depression care specialist (master’s level social worker) Yes | Enhanced usual care
Ciechanowski et al., 2006;^40^ Katon et al., 2008;^75^ Katon et al., 2004;^38^ Kinder et al., 2006;^76^ Lin et al., 2006;^77^ Simon et al., 2007^78^ Pathways Diabetes | Described as being based on the IMPACT model | In-person and telephone Depression clinical specialist (nurse) Yes | Enhanced usual care
Katon et al., 2010;^80^ Von Korff, 2011;^82^ Lin, 2012^81^ TEAMcare Diabetes +/− heart disease | Support for self-care of depression (including pharmacotherapy) and individualized goal-setting; treat-to-target program for DM and/or CHD; motivational coaching; maintenance support | In-person and telephone Medically supervised nurse trained in diabetes education Yes | Enhanced usual care
Pyne et al., 2011^73^ HITIDES HIV | Stepped care approach; education/activation; recommendations for medications and/or mental specialty referral; web-based decision support | Telephone Off-site depression care team: nurse depression care manager, pharmacist, psychiatrist Yes | Usual care
Rollman et al., 2009^79^ Bypassing the Blues Heart disease | Education on depression and CHD; support to PCP on antidepressants; referral to mental health specialists as needed; phone monitoring for symptoms | Telephone Nurse care manager Yes | Usual care
Strong et al., 2008^79^ c SMaRT Oncology 1 Cancer | Manual-Based Depression Care for People with Cancer; up to 10 sessions of problem-solving treatment to address coping; progress monitored by telephone; advice on choice of antidepressant if requested | In-person and telephone Nurses with no psychiatry experience Yes | Usual care
Vera et al., 2010^72^ NA ≥1 of the following: diabetes, hypothyroidism, asthma, hypertension, chronic bronchitis, arthritis, heart disease, high cholesterol, stroke | Depression education; antidepressant medications and/or 13 sessions of cognitive behavioral therapy | In-person and telephone Master’s level counselor or psychologist Yes | Usual care

a Specific components of usual care and enhanced usual care are listed in Appendix C.

b Though IMPACT is a single randomized, controlled trial, several subgroups, including those with chronic medical conditions, were analyzed. For ease of interpretation throughout this report, we consider each of the three IMPACT subgroups (arthritis, cancer, and diabetes) a separate study.

c Study took place in the United Kingdom where both primary care and mental health specialty services are free at the point of delivery.

Abbreviations: ADAPt-C = Alleviating Depression Among Patients with Cancer; CHD = coronary heart disease; DM = diabetes mellitus; IMPACT = Improving Mood—Promoting Access to Collaborative Treatment; MDDP = Multifaceted Diabetes and Depression Program; PCP = primary care provider.

## Key Question 1a Among adults with chronic medical conditions and concomitant depression (such as patients with diabetes and depression) treated in the primary care setting, what is the comparative effectiveness of practice-based interventions aimed at improving depression or both depression and chronic medical conditions (when compared with similar interventions or usual care) on intermediate depression outcomes (e.g., symptom improvement)?

In the key points below, we summarize the main findings by outcome and report the strength of evidence (SOE) for each outcome.

### Key Points

- Collaborative care interventions achieved greater depression symptom improvement than usual care (standardized mean difference [SMD], 0.45; 95% CI, 0.29 to 0.61 at 6 months; seven studies; SMD 0.47, 95% CI, 0.29 to 0.65 at 12 months; six studies). Benefits were sustained through 24 months, but the magnitude of benefit was reduced (moderate SOE).
- Collaborative care interventions achieved higher rates of depression response (≥50 percent reduction in symptoms from baseline) than usual care, based on 10 studies (number needed to treat [NNT], 5 at 6 months; NNT, 6 at 12 months). Benefits persisted, but to a lesser degree, at 18 months (moderate SOE).
- Collaborative care interventions resulted in more depression-free days at 12 months than usual care in the five studies that measured the outcome (range of differences between intervention and control groups: 20 to 59 days (moderate SOE).
- Remission of depression favored collaborative care over usual care at 6 months and at 12 months (but less so) based on five studies (NNT, 8 at 6 months; NNT, 12.5 at 12 months). Benefits persisted at 18 months but showed no difference between groups at 24 months (moderate SOE).
- Only one study (of patients with cancer) addressed recurrence as an outcome, and showed no difference between group at 18 or 24 months (insufficient SOE).
- Evidence was insufficient to draw conclusions about the effect of collaborative care interventions on adherence to antidepressants.
- Collaborative care interventions received significantly higher ratings of patient satisfaction than usual care at 12 months as reported in four studies, including patients with diabetes, heart disease, and cancer. Benefits were sustained at 24 months (moderate SOE).

### Detailed Synthesis

#### Depression Symptom Improvement and Treatment Response

All included studies examined depression symptom improvement or depression treatment response (≥50 percent reduction in depression score), or both, at 6 and 12 months; three studies61, 67, 69, 71 reported on one or both of these outcomes at 18 months, and five studies61, 63, 64, 69, 71, 78 reported relevant 24-month data. Nine studies38, 61–65, 67, 72–74, 80 used the Symptom Checklist-20,^83^ two66, 68 used the Patient Health Questionnaire-9,^84^ and one79 used the Hamilton Rating Scale for Depression85 (Table 11).

Table 11 Instruments used to measure depressive symptoms, response, and remission

Abbreviated Name | Complete Name of Measure or Instrument | Range of Scores | Improvement Denoted by | Notes
HRSD17^a^ | Hamilton Rating Scale for Depression – 17 item | 0–52 | Decrease | Observer-rated
PHQ-9 | Patient Health Questionnaire – 9 item | 0–27 | Decrease | Self-rated
SCL-20 (HSCL-20) | (Hopkins) Symptom Checklist – 20 item | 0.0–4.0 | Decrease | Self-rated

a Also referred to as the HAM-D17 and the HDRS.17

Abbreviations: HAM-D = Hamilton Rating Scale for Depression; HDRS = Hamilton Depression Rating Scale; HSCL = Hopkins Symptom Checklist; HRSD = Hamilton Rating Scale for Depression; PHQ = Patient Health Questionnaire; SCL = Symptoms Checklist Depression.

Quantitative analyses and strength of evidence data are detailed in Appendix E and Appendix F, respectively.

For the intermediate outcome of improvement in depression symptoms, Table 12 reports results of meta-analyses from 6, 12, and 24 months. Results from studies that used the Symptoms Checklist Depression-20 (SCL-20) are reported using weighted mean differences (WMD). Results that include studies using any measure of depression symptoms are reported using standardized mean difference (SMD) values.

Table 12 Summary of meta-analyses for intermediate outcomes for practice-based interventions aimed at improving depression or both depression and chronic medical conditions compared with controls

Outcome | Timing | N Studies | Statistic | Effect Size | 95% CI | I^2^
Depression symptoms | 6 months | 5 | WMD | 0.38 | 0.24 to 0.51 | 66.94
Depression symptoms | 6 months | 7 | SMD | 0.45 | 0.29 to 0.61 | 64.52
Depression symptoms | 12 months | 5 | WMD | 0.38 | 0.30 to 0.46 | 1.09
Depression symptoms | 12 months | 6 | SMD | 0.47 | 0.29 to 0.65 | 68.55
Depression symptoms | 24 months | 3 | WMD | 0.18 | 0.10 to 0.26 | 0.00
Response^a^ | 6 months | 9 | RD | 0.20 | 0.14 to 0.26 | 54.66
Response^a^ | 12 months | 7 | RD | 0.17 | 0.12 to 0.23 | 50.95
Response^a^ | 18 months | 3 | RD | 0.12 | 0.02 to 0.22 | 53.51
Remission^b^ | 6 months | 3 | RD | 0.12 | 0.06 to 0.18 | 0.00
Remission^b^ | 12 months | 3 | RD | 0.08 | 0.02 to 0.14 | 0.00
Remission^c^ | 18 months | 3 | RD | 0.08 | 0.01 to 0.14 | 0.00
Remission^c^ | 24 months | 3 | RD | 0.05 | −0.02 to 0.11 | 0.00
Treatment satisfaction | 12 months | 4 | RD | 0.21 | 0.11 to 0.30 | 69.62
Treatment satisfaction | 24 months | 3 | RD | 0.14 | 0.06 to 0.21 | 29.65

a Response indicated by ≥ 50 percent reduction in symptom score.

b Remission indicated by a Symptom Checklist-20 score <0.5.

c Remission indicated by a Symptom Checklist-20 score <0.5, or a PHQ-9 <5

Abbreviations: CI = confidence interval; RD = risk difference; SMD = standardized mean difference; WMD = weighted mean difference.

Using the WMD method, patients receiving collaborative care interventions had a 0.38 greater improvement from baseline on the SCL-20 at both 6 and 12 months than those in control groups (five studies38, 61, 64, 74, 80). Given that the range of the SCL-20 is 0 to 4 (lower scores meaning less depression), this magnitude of change is generally considered a clinically important difference.86, 87

Using a 50 percent or greater reduction in depression symptom score to indicate response, we pooled data at 6, 12, and 18 months. At 6 months (nine studies38, 61, 65–68, 72, 79, 80), 20 percent more patients receiving collaborative care achieved response (50 percent reduction in mental health score) than did patients in control groups. The TEAMcare study80 reported a significantly higher percentage difference in those achieving response at 6 months than in those with usual care (0.36; 95% CI, 0.23 to 0.49); a sensitivity analysis removing that study slightly reduced that number to 17 percent more patients achieving response compared with patients in control groups. From these data, we calculated an NNT to achieve response at 12 months of six patients. Despite significantly greater improvement among intervention participants than among controls on measures of depression, a large proportion of patients remained symptomatic. For example, the range among intervention arms of patients reporting response at 6 months (≥50 percent reduction in depression score from baseline) was 37 percent to 59 percent (Appendix E).

For patients with diabetes in the Pathways trial,38 additional analyses showed that patients with two or more diabetic complications were significantly more likely than usual care patients to experience reductions in depressive symptoms; patients with fewer than two complications showed no difference between arms.76 When investigators stratified the participants in the Pathways trial by independent versus interactive relationship styles, depression outcomes improved more significantly compared with usual care in patients with an independent attachment style.40 These isolated analyses lend context for interpreting the findings in patients with diabetes, but they are insufficient to draw quantitative conclusions.

We were able to perform meta-analyses on treatment response at 18 months based on three studies61, 69, 71 (Table 12), revealing a smaller but still significant difference between groups favoring the intervention (NNT=8).

#### Depression-Free Days

Five studies reported depression-free days.38, 61–65, 67, 73 The cancer subgroup of IMPACT61 reported 51 more depression-free days in the intervention patients than in the usual care patients at 12 months (186 vs. 135, p<0.001); in the diabetes subgroup,63 patients receiving collaborative care had 59 more depression-free days at 1 year than controls (95% CI, 37 to 81). In the Pathways project,78 patients in the intervention arm had 20 more depression-free days at 12 months than controls (186 vs. 166; 95% CI, −2 to 42). The HIV study73 reported an adjusted mean difference of 19 days (95% CI, 11 to 28) at 12 months. A study in patients with diabetes67 reported an estimated difference between groups of 32.6 days (p<0.001).

#### Remission and Recurrence

##### 6- and 12-Month Data

We pooled data from three studies in meta-analyses of remission of depression in patients with diabetes, HIV, and cancer at 6 and 12 months (Table 12 and Appendix E).61, 68, 73 Defining remission as SCL-20 <0.5, by 6 months, 12 percent fewer patients in control groups than patients in intervention groups achieved remission (RD, 0.12; 95% CI, 0.06 to 0.18). From this, we calculated an NNT of 8 patients to achieve one remission. Although results continued to favor the intervention group at 12 months, the NNT to achieve one remission was 12.5.

Two additional trials were not amenable to meta-analysis owing to a different definition or measurement of remission. The ADAPt-C study of predominantly female Hispanic patients with cancer used the PHQ-9.^68^ Those investigators reported that 70 percent of intervention patients were in remission at 6 months, with remission defined as “no longer had major depression”; conclusions cannot be drawn in the absence of comparator data. In the arthritis subgroup of IMPACT, Lin and colleagues reported that 24 percent of intervention patients and 38 percent of usual care patients met DSM-IV criteria for depression at 6 months (t, −4.6; p<0.001).65

##### 18- and 24-Month Data

Three studies (two in patients with cancer61, 71 and one in patients with diabetes69) were amenable to meta-analyses at 18 and 24 months, based on remission defined as PHQ-9 < 5^69, 71^ or HSCL <0.5,^61^ revealing that the intervention group was favored by a small but significant margin at 18 but not 24 months (Table 12).

#### Recurrence

No trial examined recurrence of depression at 6 or 12 months. One study of patients with cancer71 showed that among patients remitted at 12 months (PHQ-9<5), there was no difference in recurrence between groups at 18 or 24 months (36 percent in the intervention group vs. 39 percent in the control group).

#### Satisfaction With Treatment

Six studies38, 61, 67–69, 71, 74, 80 addressed patient satisfaction with depression treatment, although two assessed only the intervention group.68, 74 The remaining four studies were suitable for meta-analysis at 12 months; all four favored the intervention group across patients with diabetes,64, 66 diabetes and/or heart disease,80 and cancer.61 Our meta-analysis found that 21 percent (95% CI, 0.11 to 0.30) more patients receiving collaborative care than controls were satisfied with treatment (Table 12 and Appendix E). In those trials, treatment satisfaction was defined as follows: care rated “satisfied” to “very satisfied” (MDDP67, 69); care rated “moderately satisfied” to “very satisfied” (Pathways38); care rated “very satisfied” to “extremely satisfied” (TEAMcare80); care rated “very good” or “excellent”74 and care rated “good” or “excellent” (IMPACT61). Meta-analysis of the three studies reporting satisfaction responses at 24 months61, 69, 71 were suitable for meta-analysis, favoring the intervention (RD 0.14; 95% CI, 0.06 to 0.21).

#### Treatment Adherence

Two trials73, 77 reported on the outcome of adherence to antidepressant medications; we could not draw meaningful conclusions from this small amount of evidence. The Pathways study of patients with diabetes showed significantly greater adherence to antidepressants in the collaborative care group, reporting a 6-month adjusted odds ratio (OR) of 2.29 (95% CI, 1.38 to 3.82) and a 12-month adjusted OR of 2.18 (95% CI, 1.32 to 3.62).38 The HITIDES (HIV)73 study showed no difference between treatment groups at 6 months, with an OR of 1.65 (95% CI, 0.75 to 3.62). At 12 months, the direction of effect was reversed but remained statistically insignificant (OR, 0.56; 95% CI, 0.20 to 1.57).73

We found no other measures of adherence relevant to intermediate mental health outcomes.

### Applicability

These findings are generally applicable to primary care patients with depression and at least one chronic medical condition, but they may not apply to patients with medical conditions not addressed in this report. The average age across studies was 59, an age group most likely to have chronic disease; thus, the relevance of these results to either young adults with chronic disease or more elderly patients who may have multiple disorders remains unclear. (IMPACT included only adults ≥60 years of age, but the average age was 71.^5^) People of Hispanic origin (predominantly female)66–68 and male veterans73 were represented and appeared to respond similarly across outcomes, but we had too few data on such patients to analyze separately.

Included trials used clinically meaningful measures and had study durations (at least 6 months) that provided a real-world context. Although these trials represented several types of settings, including primary care–like cancer and HIV clinics, they all had in common a care manager who directed the intervention. The intermediate mental health outcomes achieved here might, therefore, apply only to settings in which such services and personnel can be accommodated and afforded. Similarly, practices that agreed to participate in these trials may reflect a selection bias based on culture and willingness to collaborate.

## Key Question 1b Among adults with chronic medical conditions and concomitant depression (such as patients with diabetes and depression) treated in the primary care setting, what is the comparative effectiveness of practice-based interventions aimed at improving depression or both depression and chronic medical conditions (when compared with similar interventions or usual care) on other mental health outcomes (e.g., depression-related quality of life) and use of mental health-related services?

In the key points below, we summarize the main findings by outcome and report the SOE for each outcome. For this KQ, outcomes of interest include suicide, use of antidepressants, mental health–related quality of life, use of mental health care, sick days attributable to mental health, and employment stability.

### Key Points

- Evidence was insufficient to draw conclusions about suicide; one suicide was reported in a usual care group.
- Collaborative care interventions generally resulted in greater antidepressant use for collaborative care interventions than for usual care at 12 months (RD, 0.23; 95% CI, 0.15 to 0.30; 5 studies), but not 6 months (RD, 0.09; 95% CI, −0.02 to 0.20; 3 studies) (low SOE).
- Patients in collaborative care intervention arms achieved greater mental health–related quality of life than usual care at 6 and 12 months using the mental component of the Medical Outcomes Study Short Form (WMD, 2.98; 95% CI, 1.41 to 4.55 at 12 months; four studies) (moderate SOE).
- Eight studies reported on use of mental health services (other than medication alone); each showed greater use of any services at 6 and/or 12 months (40 percent to 97 percent vs. 16 percent to 57 percent for intervention and control groups, respectively). One as-treated sample of patients with cancer61 showed that this trend persisted at 18, but not 24 months (low SOE).
- Evidence was insufficient (no data from any trial) on sick days or employment stability.

### Detailed Synthesis

#### Suicide

Two studies reported suicide-related outcomes. Authors of the MODP reported that they were unaware of any attempted or completed suicides in either treatment group.68 Strong and colleagues reported one suicide in the usual care group.74 In a second trial, investigators reported that they were unaware of any attempted or completed suicides in either treatment group.68 Data were too sparse to permit conclusions for this outcome.

#### Use of Antidepressants

Meta-analysis from three studies61, 73, 79 showed no difference in antidepressant use between groups at 6 months; but there was moderate heterogeneity (I^2^, 55.22), with the two studies enrolling subjects with cancer or heart disease both finding a similar increase in antidepressant use, and one study enrolling subjects with HIV finding no difference (Appendix E).61, 73, 79 Six studies reported use of antidepressants at 12 months, including additional populations with cancer,71 diabetes,67 and arthritis.64 Our meta-analysis indicated greater use in the intervention arms, but heterogeneity was considerable (I^2^, 73.50) (Appendix E). The one study that did not find greater use of antidepressants for those in the intervention group was again the HIV study, HITIDES.73 Because patients with HIV may differ from patients with other chronic diseases in ways that could affect medication use, we ran a sensitivity analysis, removing the HITIDES results. This analysis resulted in less heterogeneity (I^2^, 55.24; RD, 0.23; 95% CI, 0.15 to 0.30) and an overall NNT of 4.5 (Appendix E).

#### Mental Health–Related Quality of Life

Five studies measured well-being using the mental component of Medical Outcomes Study Short Form.64, 67, 68, 73, 79 Four studies64, 67, 68, 73 used the 12-item instrument (Short Form Health Survey [SF-12]); and one used the 36-item (SF-36).79 We conducted a meta-analysis across conditions, combining studies of patients with depression and one chronic disorder (cancer, diabetes, heart disease, or HIV). Our meta-analysis favored collaborative care interventions over controls at both 6 and 12 months (Table 13 and Appendix E). Only the HIV study did not find a statistically significant difference between intervention and control groups at either time point, but point estimates favored the intervention group.73

Table 13 Summary of meta-analyses for other mental health–related outcomes

Outcome | Timing | N Studies | Statistic | Effect Size | 95% CI | I^2^
Use of antidepressants | 6 months | 3 | Risk difference | 0.09 | −0.02 to 0.20 | 54.22
Use of antidepressants | 12 months | 5^a^ | Risk difference | 0.23 | 0.15 to 0.30 | 55.24
Self-rated mental health-related QOL^b^ | 6 months | 4 | SMD | 0.31 | 0.16 to 0.45 | 35.31
Self-rated mental health-related QOL^c^ | 6 months | 3 | WMD | 3.62 | 1.30 to 5.94 | 61.53
Self-rated mental health-related QOL^c^ | 12 months | 4 | WMD | 2.98 | 1.41 to 4.55 | 41.77

a Results of the meta-analysis that excluded the HIV Implementation of Translating Initiatives for Depression into Effective Solutions (HITIDES) study because of high heterogeneity.

b Self-rated mental health was measured with the 12-item Short Form Survey from the RAND Medical Outcomes Study (SF-12) for all trials except Bypassing the Blues, which used the SF-36. The Bypassing the Blues data were from the 8-month endpoint.

c Self-rated mental health is measured with the 12-item Short Form Survey from the RAND Medical Outcomes Study (SF-12) for all trials.

Abbreviations: CI = confidence interval; QOL = quality of life; SMD = standardized mean difference; WMD = weighted mean difference.

#### Use of Mental Health Services

Eight studies38, 61, 62, 65–67, 69, 71, 72, 79 reported use of mental health care services other than antidepressants alone. Ell et al., in their sample of patients with diabetes, showed that intervention patients received any depression treatment more often than controls at 12 and 18 months (83.9 percent vs. 32.5 percent and 45.8 percent vs. 24.1 percent, respectively, both p<0.001).67 In the Puerto Rico trial of patients with one or more medical conditions, significantly more intervention patients received any depression treatment at 6 months (97 percent vs. 57 percent, p not reported).72 Data from the IMPACT trial showed that patients with arthritis in the intervention group were more likely to receive mental health services at 12 months than patients in the control group (47 percent vs. 16 percent, p<0.001);65 similarly for the sample with cancer,61 service use favored the intervention group at 6 and 12 months (percentage with any mental health visit in the past 3 months: 40 vs. 15 and 42 vs. 16, respectively, both p<0.001), but the difference was no longer statistically significant at 18 months (15 vs. 12, p=0.56). The ADAPt-C trial of patients with cancer71 reported in its as-treated sample that more intervention patients than usual care patients received any depression care at 12 and 18, but not 24, months (Appendix C). The association with more depression treatment in the intervention group was consistent across all trials that reported on this outcome at 6, 12, and 18 months.

#### Sick Days Related to Mental Health

No data on sick days related to mental health were reported.

#### Employment Stability

No data on employment stability were reported.

### Applicability

We refer to the applicability section in KQ 1a for the same consideration of constraints posed by these types of studies. In general, the results in this section apply to primary care patients with depression and one or more chronic medical conditions, receiving care in a setting where a care manager is available to coordinate care. These results must be considered in the context of heterogeneity across medical conditions and interventions.

## Key Question 2a Among adults with chronic medical conditions and concomitant depression (such as patients with diabetes and depression) treated in the primary care setting, what is the comparative effectiveness of practice-based interventions aimed at improving depression or both depression and chronic medical conditions (when compared with similar interventions or usual care) on intermediate chronic medical outcomes (e.g., hemoglobin [Hb]A1c for patients with diabetes)?

For this Key Question, we were interested in the effects of practice-based interventions on medical outcomes related to the specified chronic medical condition(s). Of the trials that met our inclusion criteria, the medical conditions included arthritis, diabetes, cancer, heart disease, HIV, and one or more conditions. Outcomes of interest include symptom improvement, response to treatment, treatment adherence, and satisfaction with care. We summarize the main findings by medical condition and report the strength of evidence (SOE) for each outcome.

### Key Points

- Few studies reported specifically on symptom improvement; data were reported for people with arthritis (between group difference at 12 but not 6 months)62, 65, 67 and HIV (between-group difference at 6 but not 12 months).73 Evidence was insufficient to reach conclusions for this outcome.
- Hemoglobin A1c (HbA1c) was reported as a measure of response in four studies of patients with diabetes, though only three64, 67, 80 were reported in a way suitable for meta-analysis. Our meta-analysis found no between-group differences for change in HbA1c at 6 months (weighted mean difference [WMD], 0.13; 95% CI, −0.22 to 0.48; three studies) or 12 months (WMD, 0.24; 95% CI, −0.14 to 0.62; three studies). A single study69 showed no difference between groups at 18 and 24 months (low SOE).
  ○ The TEAMcare trial may serve as an exception because of its design and because it was the only study to use HbA1c as a predefined outcome measure;80 it reported significant differences in HbA1c (intervention vs. control): 8.14 versus 8.04 at baseline; 7.42 versus 7.87 at 6 months; and 7.33 versus 7.81 at 12 months; overall p<0.001. At 12 months, 37 intervention patients versus 18 controls achieved a ≥1.0 percent improvement (response) in HbA1c (p=0.006).
- Treatment adherence was reported for cancer,66 diabetes,64, 77, 80 and HIV,73 but only diabetes provided data from more than one study.
  ○ Diabetes and diet: Patients receiving the collaborative care intervention were no more likely than controls to adhere to a generally healthy diet in three of three trials64, 77, 80(moderate SOE).
  ○ Diabetes and exercise: Patients receiving the collaborative care intervention were no more likely than controls to adhere to an exercise program in three of three trials at 6 months and two of three trials at 12 months 64, 77, 80 (low SOE).
  ○ Diabetes and medications: Based on mixed results from three studies,64, 77, 82 evidence was insufficient to draw a conclusion.
  ○ A summary score of diabetes self-care and a mean number of diabetic complications were reported by one study67, 69 and showed no difference between groups for either outcome at 12,18, or 24 months.
- Evidence was insufficient to draw conclusions about treatment satisfaction.

### Detailed Synthesis

#### Symptom Improvement

##### Arthritis

One study, the IMPACT subgroup analysis of patients with arthritis,65 reported data on arthritis pain based on a 10-point severity scale (10 being worse). The intervention group reported a lower pain score compared with the control group at 6 months (−0.21; 95% CI, −0.6 to 0.19) and at 12 months (−0.53; 95% CI, −0.92 to −0.14), but arguably did not reflect clinically meaningful change at less than a 1-point difference. In a separate analysis,62 baseline pain severity showed significant interactions with the intervention on 12-month pain severity (p=0.04), revealing that the intervention was more effective than usual care in decreasing pain severity only in those with lower initial pain severity, but the difference between groups at 12 months was modest (intervention=4.54; control=5.41; change scores from baseline in each group not reported).

##### Cancer

No trial reported on cancer-related symptom improvement.

##### Cardiovascular Disease

No trial reported on heart disease–related symptom improvement.

##### Diabetes

The Ell et al. trial of predominantly Hispanic patients reported directly on diabetes symptoms using the Whitty-9 instrument,88 but it did not define a clinically meaningful important difference.67 Intervention patients had a lower symptom score at 6 months (1.65 vs. 1.79, p=0.07), but they were similar to controls at 12 months (1.66 vs. 1.69, p=0.18) and 18 months (1.79 vs. 1.74, p=0.85).

##### HIV

The HITIDES trial,73 in a population of predominantly male veterans, used the 20-item Symptoms Distress Module89 to measure the severity of common HIV symptoms. Bothersome symptoms were defined as scores of three or four on a Likert-type scale, and the total number of bothersome symptoms was reported. After removing 7 depression-related items due to overlap between the Symptoms Distress Module and the SCL-20, the authors reported significant adjusted intervention effects versus controls at 6 months (beta, −0.62; 95% CI, −1.2 to −0.08; p=0.03) but not 12 months (beta, −0.09, 95% CI, −1.58 to 1.40, p=0.88).

#### Response

##### Arthritis

No trial reported on response to arthritis treatment, other than the study assessing pain severity described in the previous section on symptoms.

##### Cancer

No trial reported on cancer response.

##### Cardiovascular Disease

The TEAMcare trial of patients with depression and diabetes and/or heart disease reported that intervention patients had a greater reduction in low-density lipoprotein (LDL, or “bad” cholesterol) than usual care patients at 12 months (intervention at baseline=107, at 12 months=92; control at baseline=109, at 12 months=101; mean difference at 12 months=−9.1; 95% CI, −17.5 to −0.8).80 The investigators also reported that intervention patients had a 4.6-point (95% CI, 1.9 to 7.3) greater reduction in systolic blood pressure (SBP) than usual care patients at 12 months (baseline SBP=136 and 132 in the intervention and control groups, respectively). Response was defined as an SBP ≥ 10 mm Hg decrease from baseline. At 12 months, 41 intervention patients and 25 controls achieved response (p=0.016) from an overall sample of 214.

##### Diabetes

The TEAMcare trial80 defined response for HbA1c as a reduction of ≥1 percent from baseline.80 At 12 months, 37 intervention patients and 18 controls achieved response (p=0.006) from an overall sample of 214. They also reported a greater percentage of intervention patients than controls reaching American Diabetes Association guideline targets for HbA1c, LDL, and SBP at 12 months (16.3 vs. 12.5, p not reported).

Our meta-analysis using three of the four trials reporting HbA1c64, 67, 80 revealed no significant difference between intervention and control groups at 6 and 12 months (Table 14 and Appendix E). Among these, the TEAMcare study80 was the only study to report statistically significant differences in HbA1c for intervention patients compared with control patients: 8.14 versus 8.04 at baseline; 7.42 versus 7.87 at 6 months; and 7.33 versus 7.81 at 12 months; overall p<0.001.^80^ Importantly, the nature and design of this trial differed from others in this comparative effectiveness review because the investigators set out to provide coordinated care management and “treat-to-target” principles for patients with poorly controlled diabetes, coronary heart disease, or both, and coexisting depression. None of the other trials intended to use HbA1c as a primary outcome. We could not include the Pathways study in our meta-analyses because it lacked sufficient data on differences between arms, but the investigators reported no statistically significant group differences at baseline or 6 or 12 months.38 They did report that HbA1c levels decreased over time across groups: mean=7.99 percent (standard deviation [SD], 1.47 percent) at baseline; mean=7.58 percent (SD, 1.47 percent) at 6 months; and mean=7.64 percent (SD, 1.57 percent) at 12 months.

Table 14 Summary of meta-analyses for intermediate chronic medical outcomes

Outcome | Timing | N Studies | Statistic | Effect Size | 95% CI | I^2^
Change in HbA1c | 6 months | 3 | WMD | 0.13 | −0.22 to 0.48 | 45.52
Change in HbA1c | 12 months | 3 | WMD | 0.24 | −0.14 to 0.62 | 67.79

Abbreviations: CI = confidence interval; HbA1c = hemoglobin A1c; WMD = weighted mean difference.

Ell and colleagues69 reported 18- and 24-month data on HbA1c, showing no difference between groups, with an overall mean difference at 24 months of 0.23 (95% CI, −0.34 to 0.81).

##### HIV

No trial reported on response.

#### Treatment Adherence

##### Arthritis

No trial reported on adherence to arthritis treatment.

##### Cancer

Of the three included trials involving cancer patients, only the MODP program66 reported on adherence; the investigators defined this as “completing all doctor-recommended treatment or follow-up visits.” Intervention patients (89 percent) were more likely than usual care patients (70 percent) to be adherent at 8 months (OR 3.51; 95% CI, 0.82 to 15.03).

##### Diabetes

Three trials reported in different ways on adherence to diet and exercise,64, 77, 80 and two reported on adherence to standard diabetes medications64, 77 (Appendix C). One study reported a summary of diabetes self-care based on a measure of overall self-reported adherence and showed no difference between groups at 12,18, or 24 months.69 They similarly showed no difference between groups in diabetic complications for the same time frame. Other measures of self-care were reported infrequently (such as foot care) and are detailed in the evidence tables (Appendix C).

###### Diet

A further analysis from the Pathways study reported the number of days in 1 week that the patient followed a generally healthy diet;77 by 12 months this outcome had risen by nearly 1 day in both groups (baseline mean 3.7 days/week for both groups). The two groups did not differ at 6 or 12 months (12-month mean 4.5 days/week for both groups). TEAMcare investigators reported the percentage adhering to a general diet plan ≥ 2 days per week; this outcome also showed no statistical difference at 12 months (68 percent intervention vs. 63 percent control, p=0.37).80 The IMPACT diabetes analysis revealed a similar trend for patients reporting how well they followed their diet plan (ranked from 1 [always] to 5 [never]); scores were 2.57 (intervention) and 2.54 (control) at 12 months (mean adjusted difference −0.26, 95% CI, −0.65 to 0.12).64

###### Exercise

From the Pathways cohort, Lin et al. reported no difference at any time points for the number of days in the last week spent exercising 30 or more minutes (Appendix C) and no significant improvement from baseline in either group (2.6 vs. 2.3 days at baseline; 2.7 vs. 2.6 at 12 months).77 TEAMcare researchers reported that 54 percent of intervention patients versus 44 percent of controls adhered to a specific exercise routine ≥ 2 days per week (p=0.21).80 In the IMPACT diabetes sample,64 patients in the intervention group performed significantly more exercise than those in the control group at 12 months (mean difference 0.50 day; p=0.01).

###### Medications

The Pathways researchers evaluated a subsample of participants77 for medication nonadherence to oral hypoglycemic medications, lipid-lowering agents, and angiotensin-converting enzyme inhibitors based on computerized records of pharmacy refills. Baseline and follow-up data revealed rates of nonadherence that ranged from 20 percent to 30 percent overall; these rates did not significantly change, nor did they differ, among treatment groups for lipid-lowering agents and angiotensin-converting enzyme inhibitors at 12 months (Appendix C). Interestingly, the rate of nonadherence to oral hypoglycemics was significantly higher in the intervention group than the control group at 12 months (28.2 vs. 24 percent, p<0.03).

The IMPACT investigators asked how often participants took their prescribed medications, scored on a scale from 1 [always] to 5 [never].64 They reported no significant difference over time and no differences between groups at any time points. At 12 months, the scores were 1.16 for the intervention group and 1.19 for the control group.

##### HIV

The HITIDES study defined patients as adherent to the HIV medication regimen when the number of pills taken over the past 4 days divided by the number prescribed was ≥95 percent.73 The groups did not differ at either 6 months (74 percent vs. 72 percent, p=0.65) or 12 months (68 percent vs. 64 percent, p=0.89) (Appendix C).

#### Satisfaction With Care

TEAMcare asked patients about their satisfaction with care of diabetes, heart disease, or both. At 12 months, 86 percent and 70 percent of patients in the intervention and control groups, respectively, reported being satisfied with their care.80

### Applicability

We refer to the applicability section in KQ 1a for the same consideration of constraints posed by these types of studies, specifically the required presence of a care manager to carry out the intervention. In general, the results in this section apply to a primary care population with depression and one of the chronic medical conditions discussed here, mostly patients with diabetes. Relatively few data were available on outcomes for patients with arthritis, cancer, heart disease, and HIV.

## Key Question 2b Among adults with chronic medical conditions and concomitant depression (such as patients with diabetes and depression) treated in the primary care setting, what is the comparative effectiveness of practice-based interventions aimed at improving depression or both depression and chronic medical conditions (when compared with similar interventions or usual care) on general and other health outcomes (e.g., diabetes-related morbidity, use of general health-related services, costs)?

For this Key Question, we were interested in the effects of the collaborative care intervention on general health outcomes and costs of the intervention. General health outcomes of interest include condition-specific morbidity, mortality, health care utilization, and quality of life. We summarize the main findings by outcome and report the strength of evidence for each outcome.

### Key Points

- Evidence was insufficient to draw conclusions about morbidity related to the medical condition. In one arthritis study,62, 65 the intervention group had less arthritis interference (between-group difference −0.56; 95% CI, −0.96 to −0.16 at 6 months, and −0.59; 95% CI, −1.00 to −0.19 at 12 months). In one trial of post–coronary artery bypass graft (CABG) patients,79 the intervention group had greater cardiac-related functioning (overall difference 4.6; 95% CI, 1.9 to 7.3; p=0.001; when stratified by sex, significant only in men).
- All but one study72 reported on mortality. Few deaths were reported overall (most in cancer studies). Intervention and control patients did not differ in mortality at 6 months (risk difference=0.00; 95% CI, −0.02 to 0.02; seven studies) or 12 months (risk difference, −0.00; 95% CI, −0.02 to 0.01; seven studies) (moderate SOE for no difference).
- Evidence was insufficient to draw conclusions about use of health care services. Hospitalizations were reported in two trials. In one of post-CABG patients79 at 8 months, overall, 33 percent of intervention patients, 32 percent of controls, and 25 percent of a nondepressed comparison group required hospitalization. In a trial of patients with diabetes and/or heart disease,80 27 intervention patients versus 23 controls were hospitalized at 12 months.
- Patients receiving the collaborative care intervention generally experienced greater quality of life than control patients at 6 and 12 months, based on several different measures (moderate SOE).
- Six trials, using various methods, reported costs of the intervention. Using a crude measure based on varying factors and time frames, the average cost of the intervention per patient was $705.00. Individual studies measured other aspects of cost that are detailed in Appendix C, but were not amenable to pooling.

### Detailed Synthesis

#### Morbidity Related to Chronic Medical Condition

The IMPACT arthritis subgroup reported on daily pain interference, using a scale ranging from 0=no interference to 10=unable to perform any activities.62, 65 Intervention patients had significantly less pain interference than control patients at 6 months (4.08 vs. 4.65; between-group difference −0.56; 95% CI, −0.96 to −0.16) and 12 months (4.40 vs. 4.99; between-group difference −0.59; 95% CI, −1.00 to −0.19).

The Bypassing the Blues study79 used a heart disease–specific measure of physical functioning, the Duke Activity Status Index (DASI);90 in this, a change of 3 or more points has been considered the minimal clinically important difference.90, 91 The investigators reported that patients in the collaborative care group had better scores on this measure than controls at 8 months (between-group difference 4.6; 95% CI, 1.9 to 7.3; p=0.001);79 both arms of the trial showed an overall improvement over time. Analyses by sex showed that the significantly better scores among intervention patients were found only among males (between-group difference for men, 6.1; 95% CI, 2.7 to 9.6; p<0.001; for women, 3.1; 95% CI, −1.1 to 7.3).

The Bypassing the Blues study of post-CABG patients also examined hospitalizations for cardiovascular causes (intervention=85 vs. control=68).79 Total hospitalizations are reported under health care utilization and in Appendix C.

#### Mortality

All-cause mortality was reported in 11 of the 12 studies (Appendix C). Unsurprisingly, it was higher among cancer patients than those with other chronic conditions. In 1 small (N=55) 8-month study of cancer patients,66 no deaths occurred in the intervention arm, and eight patients (30 percent) in the control arm died (OR 0.04; 95% CI, 0.002 to 0.74). In the other 2 studies of cancer patients,61, 68 mortality was similar across treatment arms at all time points.

In our meta-analyses, we detected no difference in mortality between groups at 6 months or 12 months (Table 15), with few events overall. The Pathways study75 reported deaths at 5 years (intervention=10.3 percent vs. control=12.8 percent); these data were not included in the pooled analyses.

Table 15 Summary of meta-analyses for general health outcomes

Outcome | Timing | N Studies | Statistic | Effect Size | 95% CI | I^2^
All cause mortality | 6 months | 7 | RD | 0.00 | −0.02 to 0.02 | 62.9
All cause mortality | 12 months | 7 | RD | 0.00 | −0.02 to 0.01 | 0.00
Self-rated physical health | 6 months | 4 | SMD | 0.19 | 0.08 to 0.31 | 0.00
Self-rated physical health | 6 months | 3 | WMD | 2.12 | 0.75 to 3.49 | 0.00
Self-rated physical health | 12 months | 3 | WMD | 1.25 | −0.45 to 2.95 | 27.21
Functional impairment^a^ | 12 months | 4 | WMD | 0.93 | 0.68 to 1.19 | 0.00

Abbreviations: CI = confidence interval; RD = risk difference; SMD = standardized mean difference; WMD = weighted mean difference.

a Sheehan Disability Scale of Functional Impairment92

#### Use of Health Care Services

Two studies reported hospitalizations. We reported cardiac-related rehospitalization in the study of post-CABG patients79 under condition-specific morbidity as noted above. That same study gave the total number of hospitalization in 8 months; overall, 33 percent of intervention patients, 32 percent of controls, and 25 percent of a nondepressed comparison group, required hospitalization. The TEAMcare trial (patients with diabetes and/or heart disease)80 reported that 27 (25.5 percent) of intervention patients and 23 control patients (21.3 percent) were hospitalized at some point during the previous 12 months.

We found no other reports of nonmental or overall health care utilization.

#### Physical Health Quality of Life

Five studies64, 67, 68, 73, 79 measured self-reported quality of life using the physical component of SF-12^64, 67, 68, 73^ or 36 (SF-36).79 We conducted meta-analyses for these outcomes, using WMD where measures were similar (all SF-12), and SMD to include the trial using the SF-36, at 6 and 12 months (Table 15). Our findings show that patients in the collaborative care groups had higher self-rated physical health status than controls at 6 months. At 12 months the WMD did not show a difference between groups (1.25; 95% CI, −0.45 to 2.95; three studies). Ell and colleagues69 similarly showed no difference between groups at 18 and 24 months. For context, 3 points is suggested as the minimally important clinical difference on the SF-36.^93^

Four studies61, 65, 67, 80 used the Sheehan Disability Scale of Functional Impairment92, which asks the extent to which health interferes with work, family, or social life on a 0–10 scale (0= not at all; 10 = unable to carry on activities). A meta-analysis of these data at the 12-month time point showed a difference in means that favored the intervention group (0.93; 95% CI, 0.68 to 1.19).

Similar to the more condition-specific DASI reported under morbidity outcomes above, the post-CABG study showed no between-group difference overall at 8 months on the SF-36 (1.6; 95% CI, −0.5 to 3.8).79 When the analyses were done by sex, men in the intervention group had significantly higher scores than men in the control group (3.6; 95% CI, 0.8 to 6.3).

The HIV study also collected the Quality of Well-Being Self-Administered Scale (QWB-SA), which ranges from death (0.0) to perfect health (1.0); the investigators reported no between-group differences at 6 months (−0.03; 95% CI, −0.01 to 0.06) or 12 months (−0.01; 95% CI, −0.05 to 0.03).73

Williams et al., in their sample of patients with diabetes,64 used a self-rated measure of health-related functioning (0=no problem to 10=unable to function). They showed that intervention patients reported significantly better functioning than controls at 6 months (4.37 vs. 4.63) and 12 months (3.91 vs. 4.90).

The arthritis subgroup analysis from IMPACT reported self-rated general health status on a scale ranging from 1 (excellent) to 5 (poor).62, 65 The investigators showed that intervention participants gave a significantly better rating than controls at 12 months (3.3 vs. 3.6, p<0.001). The same study also asked participants to rate their overall quality of life in the past month on a scale of 0 to 10 (zero=your situation is about as bad as dying); this measure also favored the intervention group at 12 months (6.4 vs. 6.0, p=0.005). The same scale was reported in the IMPACT cancer cohort;61 intervention patients gave better scores than controls at 12 months (6.7 vs. 6.0, p=0.04) but not 6 months (6.3 vs. 5.7, p=0.86).

Despite negative results in the HIV study, the general trends (including meta-analysis at 6 months with HIV included) across studies and measures suggest that patients receiving the collaborative care intervention experienced greater quality of life than control patients at both 6 and 12 months.

#### Costs of Intervention

Table 16 details costs of interventions in the trials that reported them. In some cases, the costs are per person or per service; in others, they are combined or total costs. Some investigators reported intervention (total) costs over a specified time period; others did not. Using a crude estimate because of such heterogeneity, for the six trials that reported data, the average cost of the intervention per patient was $705.00 Individual studies measured other aspects of cost that are detailed in Appendix C, but were not amenable to pooling.

Table 16 Costs of interventions

Author, Year Study Name Chronic Condition Quality | Costs
Ell et al., 2008^68^ ADAPt-C Cancer Fair | $524 per intervention patient over 12 months^a^
Strong et al., 2008^74^ SMaRT Oncology 1 Cancer Fair | $523 per patient over the 6-month intervention period^b^
Ell et al., 2010^67^ MDDP Diabetes Fair | $820 per patient over the 12-month intervention period^c^
Katon et al., 2008^75^ Pathways Diabetes Fair | $543 per patient from baseline through 12 months^d^
Katon et al., 2006^63^ IMPACT (secondary analyses) Diabetes Fair | $597 per patient over 24 months^e^
Katon et al., 2010^80^ TEAMcare Diabetes and/or heart disease Fair | $1,224 per patient over the 12-month intervention period^f^

a Inclusive of costs for intervention provider and patient navigation services, telephone and in-person supervision, evaluation and prescription by study psychiatrist, and intervention materials.

b Direct cost of nurse time + psychiatrist time, exclusive of nurse training and screening time.

c Assumptions: $71 per 90-minute visit, $35 per 45-minute telephone followup, $10 per 10- to 15-minute patient navigation call, $10 for relaxation tape, $136 for interventionist communication with PCP, $21 for clinical supervision. A later publication70 calculated average cost per patient to be $515.

d Unspecified “intervention visit” costs; assumptions: $79 per 30-minute in-person nurse visit, $31 for each 10- to 15-minute telephone contact, $57 for supervision and information system support.

e Inclusive of in-person and telephone contacts, overhead costs, supervision, and intervention materials.

f Inclusive of nurse contacts, physician supervision, and information systems support; mean of 10.0 in-person and 10.8 telephone visits; assumptions: $79 per 30-minute in-person nurse visit, $31 per 10- to 15-minute telephone nurse contact, $100 fixed costs per patient for supervision and information systems support.

Abbreviations: ADAPt-C = Alleviating Depression Among Patients with Cancer; CI = confidence interval; IMPACT = Improving Mood—Promoting Access to Collaborative Treatment; SD = standard deviation; SMaRT = Symptom Management Research Trials.

### Applicability

We refer to the applicability section in KQ 1a for the same consideration of constraints posed by these types of studies, specifically the required presence of a care manager to carry out the intervention. In general, the results in this section apply to a primary care population with depression and one of the chronic medical conditions discussed here. Some data were available on outcomes for patients with arthritis, cancer, diabetes, heart disease, and HIV, but they were too sparse to generalize to the population level based on condition. These studies did, however, include patients with significant medical morbidity, and as such they reflect real-world circumstances.

## Key Question 3 What harms are associated with practice-based interventions for primary care patients with chronic medical conditions and concomitant depression?

All the studies that met our eligibility criteria characterized their intervention as a form of collaborative care. We examined the body of evidence for any reported adverse events (AEs), but we recognized that potential harms reported as a direct effect of this type of intervention are rare.

### Key Points

- Very few data on harms were reported.
- The trial that specifically reported AEs,80 such as medication side effects or emergency room visits for chest pain or neurologic symptoms, found overall rates to be higher among intervention patients than controls.
- More frequent medication adjustments and monitoring of self-reported patient outcomes in the collaborative care arm may have contributed to the higher reported rate of AEs in that single trial.

### Detailed Synthesis

We reported deaths and hospitalizations in KQs 1 and 2. One trial, in patients with depression and diabetes and/or heart disease,80 considered the following to be mild and moderate AEs: falls, medication side effects, extremely high laboratory values, and emergency room visits for chest pain or neurologic symptoms. Mild and moderate AEs were self-reported, and the severity was based on a study clinician’s judgment. Two patients (1.9 percent) in the collaborative care arm experienced at least one mild AE; no patient in the control arm had any mild AE. At least one moderate AE was experienced by 17 percent of intervention patients and 3 percent of control patients.

The higher rate of mild and moderate AEs in the intervention arm may be attributable to increased rates of medication adjustment. Additionally, patients in the intervention arm had more frequent contacts with the care manager and thus had more opportunities to report adverse events, so findings might be the result of detection bias.

### Applicability

Given the factors related to applicability noted in KQs 1 and 2, these results must be considered in the context of heterogeneity across medical conditions and interventions. Collaborative care is a complex intervention, and harms of the intervention itself may be difficult to assess. These results may also not apply to patients with fewer symptoms of depression.

## Key Question 4 What are the characteristics of the practice-based interventions addressing concomitant depression and chronic medical conditions used in the primary care setting with regard to specific components and/or intensity (e.g., visit frequency, total number of contacts, provider discipline, use of self-management)?

This question was addressed in the context of studies that met criteria for KQs 1 and 2. The populations for the included studies all identified depression as the mental health condition. All interventions were described as collaborative care interventions; we found no studies with other types of practice-based interventions meeting our inclusion/exclusion criteria. The purpose of this key question is to compare and contrast characteristics of the collaborative care intervention.

### Key Points

- Components of the Intervention
  ○ Team Composition. Care teams were diverse and included various combinations of nurses (6 studies), psychologists or counselors (3 studies), social workers (3 studies), supervising psychiatrists (11 studies), independent physicians (4 studies), and a pharmacist (1 study).
  ○ Main Intervention Provider. The collaborative care intervention was typically delivered by a care manager alone or in concert with another member of the research team. In most cases the care manager was a nurse (six studies), a master’s or doctoral-level psychologist or counselor (three studies), or a social worker (three studies); most had received formal depression care training that focused on diagnosis, pharmacotherapy, and problem-solving treatment.
  ○ Approach and Mode of Delivery. Across studies, the collaborative care intervention incorporated some degree of personalized care, usually in the early stages of the intervention, along with some combination of telephone alone or telephone plus face-to-face sessions. Care often was implemented using a stepped approach, allowing for patient preferences and following established guidelines.
  ○ Self-management. The collaborative care intervention typically featured some degree of self-management education and monitoring.
- Intensity of the Intervention
  ○ Session Frequency. After an initial information and education session, care providers talked with or met participants face-to-face for multiple sessions across a period of time ranging from weeks to months. The number of sessions depended sometimes on the study design and sometimes on the pace at which the individual patient responded to treatment. Two studies were solely telephone based.
  ○ Session Duration. Across studies that reported session duration, the initial information/education session was typically longer than follow-up sessions. The latter varied in length from 5 to 45 minutes.

### Detailed Synthesis

Data were abstracted from all twelve studies to address this key question.38, 40, 61–68, 72–80 Components of the interventions that differed across studies included the composition of the treatment team members, type of provider who delivered the intervention, mode of delivery of the intervention, and the intensity (frequency and duration) of treatment sessions. All studies had in common some degree of personalizing the intervention for the individual patient and use of a stepped care approach, although the specific nature of the stepped care approach differed in complexity and evidence base across studies.

Also common across studies were other core components, many of which were based on the model of the IMPACT trial. These components included (1) a depression care specialist or manager who was typically responsible for patient education, brief problem-solving counseling, symptom monitoring, and follow-up telephone calls to facilitate relapse prevention; (2) a consulting psychiatrist on the collaborative care team who supervised the care manager and communicated directly with primary care providers of patients who did not respond adequately to treatment; and (3) use of a validated instrument to document change in depressive symptoms over the course of treatment. We could not develop any summary statistics relevant to this question or grade strength of evidence.

Some similarities as well as differences emerged across studies in terms of how and by whom the intervention was delivered (Table 17). In Bypassing the Blues,79 HITIDES,73 Pathways,38, 40, 75–78 SMaRT Oncology 1,^74^ and TEAMcare,80 the collaborative care intervention was delivered by a nurse, who was described as being part of the research staff with the exception of one study in which the nurse’s relation to the study team was unclear.74 In the remaining studies, the intervention was delivered by a trained counselor;72 a social worker;66–68 or, using a hybrid approach (IMPACT), either a nurse or psychologist.61–65 In the majority of studies the nurse,38, 40, 73, 75–78 social worker,66, 67 or psychologist61–63, 65 was a formally trained depression care specialist.

Table 17 Summary of service-level characteristics of included studies

| ADAPt-C68 | Bypassing the Blues79 | HITIDES73 | IMPACT61–65 | MDDP67 | MODP66 | Pathways38, 40, 75–78 | SMaRT Oncology 1^74^ | TEAMcare80 | Vera et al. 72
Care provider
Nurse | | X | X | X | | | X | X | X
Psychologist/counselor | | | | X | | | | | X | X
Social worker | X | | | | X | X
Supervisory team
Psychiatrist | X | X | X | X | X | X | X | X | | X
Physician | | X | | X | | | X | | X
Pharmacist | | | X
Stepped approach
IMPACT algorithm | | | | X
Modified IMPACT | X | | | | X | X | X
Other | | X | X | | | | | | X | X
None | | | | | | | | X
Self-management
Pleasant life events | X | X | X | X | | | X
Healthy lifestyle | | X | X | | X | | X
Coping | | | | | X | | | X
Medication/treatment adherence | X | | | | X | X | | | X

Abbreviations: ADAPt-C = Alleviating Depression Among Patients with Cancer; HITIDES = HIV Implementation of Translating Initiatives for Depression into Effective Solutions; IMPACT = Improving Mood—Promoting Access to Collaborative Treatment; MDDP = Multifaceted Diabetes and Depression Program; MODP = Multifaceted Oncology Depression Program; SMaRT = Symptom Management Research Trials.

The individual responsible for providing direct patient management (e.g., the depression care specialist) was part of a larger care team. This team included a psychiatrist in all studies, as well as another physician in some trials.38, 40, 61–65, 75–80 One trial was unique in including a pharmacist as part of the supervisory team.73

All trials provided some degree of personalized care, usually during the initial stages of treatment planning; all typically had a structure that included multiple contacts between the care team provider and the patient. Early in treatment, the intervention was personalized by allowing the patient some degree of autonomy in selecting to begin treatment with medication, psychotherapy, or both. Thereafter, treatment recommendations were adjusted according to a patient’s symptom response, including increasing the medication dose or contact with the care provider (or both). Two trials relied solely on telephone contact to deliver the intervention;73, 79 the others used some combination of weekly,66 twice per month,38, 40, 73, 75–80 or variable frequency61–65, 67, 68, 72, 74 face-to-face sessions and follow-up telephone calls. The Pathways38, 40, 75, 76, 78 and IMPACT61–65 trials described the initial information and education session as lasting 1 hour, whereas other studies were less descriptive. Session length varied from 5 minutes61–63, 65 to 30 minutes38, 40, 75, 76, 78 to 45 minutes61–63, 65, 74 or was unspecified.66, 68, 72, 73, 79, 80

The actual number of treatment sessions differed considerably across trials. In one case it was capped at 10.^74^ In the others, it varied over a predetermined length of followup according to the patients’ needs (i.e., if response to treatment was unsatisfactory, more frequent followup sessions were allowed).38, 40, 61–63, 65, 68, 75, 76, 78–80

Self-management training and reinforcement were integral to the collaborative care interventions. For example, patients received advice and skill-building opportunities regarding sleep hygiene, appropriate levels of physical activity or other pleasant life events, healthy nutrition, and tobacco and alcohol use;38, 40, 75, 76, 78, 79 scheduling pleasant life events;61–65 coping behaviors;74 and medication adherence.80 In some instances, these behaviors and activities were tracked during the trial and included as study outcomes.

### Applicability

The majority of trials hired research staff, many with special training in depression or diabetes care, to work directly with patients. For that reason, these findings may not generalize to settings that do not have (or cannot afford) a care manager. This limitation may be most relevant to community health centers and departments and small specialty practices (e.g., obstetrics and gynecology). This collection of trials focused on five major concomitant medical conditions: arthritis, cancer, diabetes, heart disease, and HIV. Missing from this literature are studies that focused on patients with chronic pulmonary disease, chronic pain, or stroke or on the frail elderly. Four trials focused almost exclusively on Hispanic or Latino participants,66–68, 72 whereas other trials had percentages of minority participants that were reflective of their presence in the general U.S. population.38, 40, 61–65, 73, 75, 76, 78, 80 No studies, however, were designed a priori to evaluate racial or ethnic differences in outcomes or in acceptability of, or barriers to, treatment. Thus, specific applicability to racial or ethnic subgroups is unclear.

## Key Question 5 What are the specific characteristics of the practice setting where the interventions were delivered with regard to such variables as organizational characteristics (e.g., decision support, level of integration, information technology, electronic medical records, presence of mental health services on site, payer and service mix, practice size, and practice location/setting) or the relationship between elements of the system in which the practice operates (e.g., coordination, financing of care, payment arrangements)?

### Key Points

- Overall, practice setting characteristics (e.g., geographic location, practice type and size, open/closed system, level of integration, payer mix and payer type, service mix, information technology) and system characteristics (e.g., financing of care and payment arrangements) were rarely reported.
- Nine trials were conducted in the United States (one in Puerto Rico) and one in the United Kingdom (Scotland).
- None of the trials explicitly reported on whether it was conducted in an open (no membership or eligibility required) or closed system, although the IMPACT trial61–65 was conducted in a mix of systems that included primary care clinics in a large health maintenance organization (HMO) as well as the Department of Veterans Affairs (VA) system. Three studies were presumed to be conducted in closed systems.38, 40, 73, 75–78, 80 Closed systems included Group Health Cooperative and the VA system.

### Detailed Synthesis

#### Characteristics of the Practice Setting

##### Geographic Location

Eleven studies were conducted in the United States (one in Puerto Rico72);38, 40, 61–68, 72, 73, 75–80 one trial was conducted in the United Kingdom.74

No trial explicitly reported whether the practice setting was urban, rural, or mixed. Three could be presumed to be urban based on information provided in the articles,66–68 and one could be presumed as mixed setting based on information provided by authors.72 The IMPACT trial subgroup analyses61–65 were presumed to be mixed setting based on information provided in an article by Unutzer and colleagues.5 For the remaining four trials, rural versus urban setting was not noted clearly nor could be inferred based on information in the articles.38, 40, 67, 73–78, 80 One trial was telephone delivered;79 hence, urban or rural setting was not deemed relevant for reporting.

##### Practice Type and Size

Eleven of the 12 studies were conducted in primary care or primary care–like settings. Intervention was conducted by telephone in 2 trials.73, 79

The majority of trials did not report practice size, and, when they did, the reporting was inconsistent. One trial was conducted in a cancer center that served 1.5 million people.74 Another trial reported HMO size (500,000) and number of patients (9,063) that met case identification based on the HMO’s population-based diabetes registry, but it did not mention practice size.38, 40, 75–78

##### Open Versus Closed System

System was categorized as open (no membership or eligibility required) in six trials,66–68, 72, 74, 79 and three were perceived to be closed.38, 40, 73, 75–78, 80 Closed systems were generally self-contained; in this evidence base, they included Group Health Cooperative and the VA system, in which an array of services was accessible to patients who were members of these organizations. The IMPACT trial subgroup analyses61–65 enrolled patients from a mix of settings, including some perceived as closed, such as a large HMO.5 None of the trials explicitly reported on this variable.

##### Level of Integration: Presence of Mental Health Services On-Site

We defined the level of integration by whether mental health services were available on-site (see Appendix C for trial-specific data), because these trials did not give other descriptors of integration. On-site mental health providers in primary care clinics were described in four trials.38, 40, 66, 68, 74–78 One trial reported that part-time registered nurses with experience in diabetes education collaborated with primary care providers to implement the intervention.80 One trial reported that mental health providers for primary care–like settings were located off-site,73 and another noted that the study team—including care managers, mental health specialist, and psychiatrist—was separate from the primary care practice.72 For the IMPACT trial subgroup analyses,5, 61–65 we could infer that depression care managers (nurses) were physically present in three primary care clinics; in another three clinics, some mental health care practitioner was available on-site whereas in the rest of 12 clinics, none were present on-site. Two trials did not report any information regarding the location of mental health services.67, 79

##### Payer Mix and Payer Type

We defined payer mix as the type of insurance plan. Payer mix or type was not reported for four trials.66, 68, 72, 79 Two trials described participants as members of Group Health Cooperative, a mixed-model prepaid health plan.38, 40, 75–78, 80 One group reported that participants were either enrolled in Medicaid/Medicare, a county-funded program, or had no health insurance.67 In one trial, all participants were covered by VA benefits.73 For the IMPACT trial subgroups,61–65 based on information provided in an article by Unutzer and colleagues,5 a considerable majority of patients had Medicare coverage (77%) and prescription drug coverage (90%). This trial was conducted in 18 primary care clinics, which included patients from 9 HMO/Independent Provider Association practices, 3 VA practices, 5 academic group-practice practices, and 1 private group practice.

##### Service Mix

Service mix referred to the types of services available at each intervention site. No trial reported service mix.

##### Information Technology

We defined information technology (IT) to include electronic medical records (EMRs) and how well they were integrated for the intervention and decision support. Decision support included computer-based prompts and/or algorithm triggers related to the disease of interest used as part of the intervention.

Included trials gave limited descriptions of whether and how they used information technology. Half of the trials did not mention health IT or EMRs.66–68, 72, 74 Another four trials mentioned health IT or EMR,38, 40, 61–65, 73, 75–78, 80 but two of these did not describe in detail the specific IT features that the intervention employed. See Appendix C for trial-specific details on use of information technology for concomitant care interventions in these four trials. Finally, although one trial79 did not report use of IT system or EMRs for delivery of concomitant care, it did report that data and safety monitoring was done electronically. The EMR was searched for an increase of 25 percent or more in a Hamilton Rating Scale for Depression (HRSD) score; this triggered a written letter to the treating physician and an offer to identify local mental health specialists and provide additional treatment advice.

#### Relationship Between Elements of the System in Which the Practice Operates

##### Financing of Care

Financing of care was not reported for six studies.38, 40, 61–65, 67, 73, 75–80 Two trials66, 72 reported that the study itself covered treatment costs, including medication and therapy. One trial reported that participants were reimbursed for time spent completing outcome interviews and for transportation and copays for antidepressant medications if applicable.68 One trial reported that medical treatments for patients were financed through the U.K. (Scotland) National Health Service.74

##### Payment Arrangements

Payment arrangements include financial arrangements between primary care providers and mental health providers and may include financial resource sharing or incentives. No trial described payment arrangements.

### Applicability

These findings generally apply to patients with depression and one or more medical conditions who are receiving care in settings that provide care management. Most trials occurred in the United States, so findings cannot be extended to other countries in general. Even though the systems of care were not well characterized, they likely differed considerably. How such infrastructure influences the delivery of collaborative care is not clear from our findings, and results should be considered with that in mind.