# References

1 World Health Organization. Integrating mental health into primary care - a global perspective. Geneva. World Health Organization. 2008. www.who.int/mental_health/policy/services/mentalhealthintoprimarycare/en/. Accessed October 13 2010.
2 Unutzer J, Schoenbaum M, Druss BG, et al. Transforming mental health care at the interface with general medicine: report for the presidents commission. Psychiatr Serv. Jan. 2006;57(1):37-47. [pmid: 16399961].
3 Schulberg HC, Katon WJ, Simon GE, et al. Best clinical practice: guidelines for managing major depression in primary medical care. J Clin Psychiatry. 1999;60(Suppl 7):19-26. [pmid: 10326871].
4 Katon W, Unutzer J, Wells K, et al. Collaborative depression care: history, evolution and ways to enhance dissemination and sustainability. Gen Hosp Psychiatry. Sep–Oct. 2010;32(5):456-64. [pmid: 20851265].
5 Unutzer J, Katon W, Callahan CM, et al. Collaborative care management of late-life depression in the primary care setting: a randomized controlled trial. JAMA. Dec. 2002;288(22):2836-45. [pmid: 12472325].
6 A new direction in depression treatment in Minnesota: DIAMOND program, Institute for Clinical Systems Improvement, Bloomington, Minnesota. Psychiatr Serv. Oct. 2010;61(10):1042-4. [pmid: 20889647].
7 Bogner HR, de Vries HF. Integrating type 2 diabetes mellitus and depression treatment among African Americans: a randomized controlled pilot trial. Diabetes Educ. Mar–Apr. 2010;36(2):284-92. [pmid: 20040705].
8 Schneider KM, O’Donnell BE, Dean D. Prevalence of multiple chronic conditions in the United States’ Medicare population. Health Qual Life Outcomes. 2009;7:82. [pmid: 19737412].
9 Kroenke K, Spitzer RL, Williams JB, et al. Anxiety disorders in primary care: prevalence, impairment, comorbidity, and detection. Ann Intern Med. Mar. 6. 2007;146(5):317-25. [pmid: 17339617].
10 Wang PS, Lane M, Olfson M, et al. Twelve-month use of mental health services in the United States: results from the National Comorbidity Survey Replication. Arch Gen Psychiatry. Jun. 2005;62(6):629-40. [pmid: 15939840].
11 Mertens JR, Weisner C, Ray GT, et al. Hazardous drinkers and drug users in HMO primary care: prevalence, medical conditions, and costs. Alcohol Clin Exp Res. Jun. 2005;29(6):989-98. [pmid: 15976525].
12 Olfson M, Lewis-Fernandez R, Weissman MM, et al. Psychotic symptoms in an urban general medicine practice. Am J Psychiatry. Aug. 2002;159(8):1412-9. [pmid: 12153836].
13 Ustun TB, Ayuso-Mateos JL, Chatterji S, et al. Global burden of depressive disorders in the year 2000. Br J Psychiatry. May. 2004;184:386-92. [pmid: 15123501].
14 Mathers CD, Loncar D. Projections of global mortality and burden of disease from 2002 to 2030. PLoS medicine. Nov. 2006;3(11):e442. [pmid: 17132052].
15 World Health Organization. The global burden of disease: 2004 update. Geneva. World Health Organization. 2004. www.who.int/healthinfo/global_burden_disease/2004_report_update/en/index.html. Accessed October 25 2010.
16 Greenberg PE, Kessler RC, Birnbaum HG, et al. The economic burden of depression in the United States: how did it change between 1990 and 2000?. J Clin Psychiatry. Dec. 2003;64(12):1465-75. [pmid: 14728109].
17 Partnership for Solutions National Program Office Chronic Conditions: Making the Case for Ongoing Care. Partnership for Solutions, Johns Hopkins University. 2004. www.partnershipforsolutions.org/DMS/files/chronicbook2004.pdf. Accessed September 26, 2011.
18 Centers for Disease Control and Prevention. National diabetes fact sheet, 2007. Atlanta, GA. Centers for Disease Control and Prevention. 2008. www.cdc.gov/diabetes/pubs/factsheet07.htm. Accessed January 11 2011.
19 National Heart Lung and Blood Institute. Morbidity & mortality: 2009 chart book on cardiovascular, lung, and blood diseases. Bethesda, MD. National Institutes of Health. 2009. www.nhlbi.nih.gov/resources/docs/2009_ChartBook.pdf. Accessed January 11 2011.
20 Culpepper L. Generalized anxiety disorder and medical illness. J Clin Psychiatry. 2009;70(Suppl 2):20-4. [pmid: 19371503].
21 Honda K, Goodwin RD. Cancer and mental disorders in a national community sample: findings from the national comorbidity survey. Psychother Psychosom. Jul–Aug. 2004;73(4):235-42. [pmid: 15184718].
22 Stein MB, Cox BJ, Afifi TO, et al. Does co-morbid depressive illness magnify the impact of chronic physical illness? A population-based perspective. Psychol Med. May. 2006;36(5):587-96. [pmid: 16608557].
23 Sherbourne CD, Jackson CA, Meredith LS, et al. Prevalence of comorbid anxiety disorders in primary care outpatients. Arch Fam Med. Jan. 1996;5(1):27-34. [pmid: 8542051].
24 Creed F. Psychological disorders in rheumatoid arthritis: a growing consensus?. Ann Rheum Dis. Oct. 1990;49(10):808-12. [pmid: 2241274].
25 Creed F, Murphy S, Jayson MV. Measurement of psychiatric disorder in rheumatoid arthritis. J Psychosom Res. 1990;34(1):79-87. [pmid: 2313615].
26 Rosemann T, Laux G, Szecsenyi J. Osteoarthritis: quality of life, comorbidities, medication and health service utilization assessed in a large sample of primary care patients. Journal of orthopaedic surgery and research. 2007;2:12. [pmid: 17603902].
27 Bush DE, Ziegelstein RC, Patel UV, et al. Post-myocardial infarction depression. Evidence report/technology assessment. May. 2005;(123):1-8. [pmid: 15989376].
28 Carney RM, Rich MW, Tevelde A, et al. Major depressive disorder in coronary artery disease. Am J Cardiol. Dec. 1. 1987;60(16):1273-5. [pmid: 3687779].
29 Gonzalez MB, Snyderman TB, Colket JT, et al. Depression in patients with coronary artery disease. Depression. 1996;4(2):57-62. [pmid: 9160641].
30 Anderson RJ, Freedland KE, Clouse RE, et al. The prevalence of comorbid depression in adults with diabetes: a meta-analysis. Diabetes Care. Jun. 2001;24(6):1069-78. [pmid: 11375373].
31 Ali S, Stone MA, Peters JL, et al. The prevalence of co-morbid depression in adults with Type 2 diabetes: a systematic review and meta-analysis. Diabet Med. Nov. 2006;23(11):1165-73. [pmid: 17054590].
32 Schneider A, Lowe B, Meyer FJ, et al. Depression and panic disorder as predictors of health outcomes for patients with asthma in primary care. Respir Med. Mar. 2008;102(3):359-66. [pmid: 18061424].
33 Chavannes NH, Huibers MJ, Schermer TR, et al. Associations of depressive symptoms with gender, body mass index and dyspnea in primary care COPD patients. Fam Pract. Dec. 2005;22(6):604-7. [pmid: 16024555].
34 Pasquini M, Biondi M. Depression in cancer patients: a critical review. Clin Pract Epidemiol Ment Health. 2007;3:2. [pmid: 17288583].
35 Butler M, Kane RL, McAlpine D, et al. Integration of Mental Health/Substance Abuse and Primary Care, Evidence Report/Technology Assessment No. 173. (Prepared by the Minnesota Evidence-based Practice Center under Contract No. 290-02-0009). Rockville, MD. Agency for Healthcare Research and Quality. October. 2008. AHRQ Publication No. 09-E003.
36 National Institute for Health and Clinical Excellence. National Clinical Practice Guideline Number 91: Depression in Adults with a Chronic Physical Health Problem: treatment and management. London. National Institute for Health and Clinical Excellence. 2009. www.nice.org.uk/nicemedia/live/12327/45909/45909.pdf. Accessed October 13 2010.
37 Gilbody S, Bower P, Fletcher J, et al. Collaborative care for depression: a cumulative meta-analysis and review of longer-term outcomes. Arch Intern Med. Nov. 27. 2006;166(21):2314-21. [pmid: 17130383].
38 Katon WJ, Von Korff M, Lin EH, et al. The Pathways Study: a randomized trial of collaborative care in patients with diabetes and depression. Arch Gen Psychiatry. Oct. 2004;61(10):1042-9. [pmid: 15466678].
39 Bogner HR, Morales KH, Post EP, et al. Diabetes, depression, and death: a randomized controlled trial of a depression treatment program for older adults based in primary care (PROSPECT). Diabetes Care. Dec. 2007;30(12):3005-10. [pmid: 17717284].
40 Ciechanowski PS, Russo JE, Katon WJ, et al. The association of patient relationship style and outcomes in collaborative care treatment for depression in patients with diabetes. Med Care. Mar. 2006;44(3):283-91. [pmid: 16501401].
41 Bower P, Gilbody S, Richards D, et al. Collaborative care for depression in primary care. Making sense of a complex intervention: systematic review and meta-regression (Structured abstract). Br J Psychiatry. 2006;(6):484-93. [pmid: 17139031].
42 Centers for Medicare & Medicaid Services, Department of Health and Human Services. Summary of Proposed Rule Provisions for Accountable Care Organizations Under the medicare Shared Savings Program. 2011. www.ftc.gov/opp/aco/cms-proposedrule.PDF. Accessed December 12, 2011.
43 National Committee for Quality Assurance. Patient-Centered Medical Home. 2011. www.ncqa.org/tabid/631/default.aspx. Accessed Nov 7, 2011.
44 Solberg LI, Crain AL, Sperl-Hillen JM, et al. Care quality and implementation of the Chronic Care Model: a quantitative study. Ann Fam Med. 2006;4(4):310-6. [pmid: 16868234].
45 Nutting PA, Rost K, Dickinson M, et al. Barriers to initiating depression treatment in primary care practice. J Gen Intern Med. Feb. 2002;17(2):103-11. [pmid: 11841525].
46 Institute of Medicine. Crossing the Quality Chasm: A New Health System for the 21st Century. Washington, DC. National Academy Press. 2001.
47 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLoS medicine. Jul. 21. 2009;6(7):e1000097. [pmid: 19621072].
48 Agency for Healthcare Research and Quality Web site. List of Priority Conditions for Research under Medicare Modernization Act Released. Press Release. December. 15. 2004. archive.ahrq.gov/news/press/pr2004/mmapr.htm. Accessed December 12 2011.
49 Adams K, Corrigan JM, editors. Priority areas for national action: transforming health care quality. Washington, DC. National Academies Press. 2003.
50 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
51 Centre for Reviews and Dissemination. Systematic reviews: CRD’s guidance for undertaking reviews in healthcare. York, England. University of York. 2009.
52 West SL, Gartlehner G, Mansfield AJ, et al. Comparative Effectiveness Review Methods: Clinical Heterogeneity. Methods Research Report. (Prepared by RTI International -- University of North Carolina Evidence-based Practice Center under Contract No. 290-2007-10056-I. Agency for Healthcare Research and Quality. Rockville, MD. September. 2010. www.ncbi.nlm.nih.gov/entrez/query.fcgi?cmd=Retrieve&db=PubMed&dopt=Citation&list_uids=21433337. 10-EHC070-EF.
53 Follmann D, Elliott P, Suh I, et al. Variance imputation for overviews of clinical trials with continuous response. J Clin Epidemiol. Jul. 1992;45(7):769-73. [pmid: 1619456].
54 Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions: The Cochrane Collaboration. 2011. Version 5.1.0 [updated March 2011]. Available from www.cochrane-handbook.org.
55 Sutton AJ, Abrams KR, Jones DR, et al. Methods for Meta-Analysis in Medical Research. (Wiley Series in Probability and Statistics - Applied Probability and Statistics Section). London. Wiley. 2000.
56 Lewis S, Clarke M. Forest plots: trying to see the wood and the trees. BMJ. Jun. 16. 2001;322(7300):1479-80. [pmid: 11408310].
57 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. Jun. 15. 2002;21(11):1539-58. [pmid: 12111919].
58 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-60. [pmid: 12958120].
59 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
60 Atkins D, Chang S, Gartlehner G, et al. Chapter 6: Assessing the Applicability of Studies When Comparing Medical Interventions. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. March. 2011. AHRQ Publication No. 11-EHC019-EF.
61 Fann JR, Fan MY, Unutzer J. Improving primary care for older adults with cancer and depression. J Gen Intern Med. Nov. 2009;24(Suppl 2):S417-24. [pmid: 19838842].
62 Lin EH, Tang L, Katon W, et al. Arthritis pain and disability: response to collaborative depression care. Gen Hosp Psychiatry. Nov–Dec. 2006;28(6):482-6. [pmid: 17088163].
63 Katon W, Unutzer J, Fan MY, et al. Cost-effectiveness and net benefit of enhanced treatment of depression for older adults with diabetes and depression. Diabetes Care. Feb. 2006;29(2):265-70. [pmid: 16443871].
64 Williams JW Jr, Katon W, Lin EH, et al. The effectiveness of depression care management on diabetes-related outcomes in older patients. Ann Intern Med. Jun. 15. 2004;140(12):1015-24. [pmid: 15197019].
65 Lin EH, Katon W, Von Korff M, et al. Effect of improving depression care on pain and functional outcomes among older adults with arthritis: a randomized controlled trial. JAMA. Nov. 12. 2003;290(18):2428-9. [pmid: 14612479].
66 Dwight-Johnson M, Ell K, Lee PJ. Can collaborative care address the needs of low-income Latinas with comorbid depression and cancer? Results from a randomized pilot study. Psychosomatics. May–Jun. 2005;46(3):224-32. [pmid: 15883143].
67 Ell K, Katon W, Xie B, et al. Collaborative care management of major depression among low-income, predominantly Hispanic subjects with diabetes: a randomized controlled trial. Diabetes Care. Apr. 2010;33(4):706-13. [pmid: 20097780].
68 Ell K, Xie B, Quon B, et al. Randomized controlled trial of collaborative care management of depression among low-income patients with cancer. J Clin Oncol. Sep. 20. 2008;26(27):4488-96. [pmid: 18802161].
69 Ell K, Katon W, Xie B, et al. One-year postcollaborative depression care trial outcomes among predominantly Hispanic diabetes safety net patients. Gen Hosp Psychiatry. 2011;33(5):436-42. [pmid: 21774987].
70 Hay JW, Katon WJ, Ell K, et al. Cost effectiveness anlysis of collaborative comanagement of major depression among low-income, predominantly Hispanics with diabetes. J Ment Health Policy Econ. Mar. 2011;14:S11-S.
71 Ell K, Xie B, Kapetanovic S, et al. One-year follow-up of collaborative depression care for low-income, predominantly Hispanic patients with cancer. Psychiatr Serv. 2011;(2):162-70. [pmid: 21285094].
72 Vera M, Perez-Pedrogo C, Huertas SE, et al. Collaborative care for depressed patients with chronic medical conditions: a randomized trial in Puerto Rico. Psychiatr Serv. Feb. 2010;61(2):144-50. [pmid: 20123819].
73 Pyne JM, Fortney JC, Curran GM, et al. Effectiveness of collaborative care for depression in human immunodeficiency virus clinics. Arch Intern Med. 2011;(1):23-31. [pmid: 21220657].
74 Strong V, Waters R, Hibberd C, et al. Management of depression for people with cancer (SMaRT oncology 1): a randomised trial. Lancet. Jul. 5. 2008;372(9632):40-8. [pmid: 18603157].
75 Katon WJ, Russo JE, Von Korff M, et al. Long-term effects on medical costs of improving depression outcomes in patients with depression and diabetes. Diabetes Care. Jun. 2008;31(6):1155-9. [pmid: 18332158].
76 Kinder LS, Katon WJ, Ludman E, et al. Improving depression care in patients with diabetes and multiple complications. J Gen Intern Med. Oct. 2006;21(10):1036-41. [pmid: 16836628].
77 Lin EH, Katon W, Rutter C, et al. Effects of enhanced depression treatment on diabetes self-care. Ann Fam Med. Jan–Feb. 2006;4(1):46-53. [pmid: 16449396].
78 Simon GE, Katon WJ, Lin EH, et al. Cost-effectiveness of systematic depression treatment among people with diabetes mellitus. Arch Gen Psychiatry. Jan. 2007;64(1):65-72. [pmid: 17199056].
79 Rollman BL, Belnap BH, LeMenager MS, et al. Telephone-delivered collaborative care for treating post-CABG depression: a randomized controlled trial. JAMA. Nov. 18. 2009;302(19):2095-103. [pmid: 19918088].
80 Katon WJ, Lin EH, Von Korff M, et al. Collaborative care for patients with depression and chronic illnesses. N Engl J Med. Dec. 30. 2010;363(27):2611-20. [pmid: 21190455].
81 Lin EH, Von Korff M, Ciechanowski P, et al. Treatment adjustment and medication adherence for complex patients with diabetes, heart disease, and depression: a randomized controlled trial. Ann Fam Med. Jan–Feb. 2012;10(1):6-14. [pmid: 22230825].
82 Von Korff M, Katon WJ, Lin EHB, et al. Functional outcomes of multi-condition collaborative care and successful ageing: Results of randomised trial. BMJ. 2011;343(7833):1083.
83 Derogatis LR, Lipman RS, Covi L. SCL-90: an outpatient psychiatric rating scale--preliminary report. Psychopharmacol Bull. Jan. 1973;9(1):13-28. [pmid: 4682398].
84 Lowe B, Unutzer J, Callahan CM, et al. Monitoring depression treatment outcomes with the patient health questionnaire-9. Med Care. Dec. 2004;42(12):1194-201. [pmid: 15550799].
85 Hamilton M. Development of a rating scale for primary depressive illness. Br J Soc Clin Psychol. Dec. 1967;6(4):278-96. [pmid: 6080235].
86 Derogatis LR, Lipman RS, Rickels K, et al. The Hopkins Symptom Checklist (HSCL). A measure of primary symptom dimensions. Mod Probl Pharmacopsychiatry. 1974;7(0):79-110. [pmid: 4607278].
87 Dobscha SK, Corson K, Hickam DH, et al. Depression decision support in primary care: a cluster randomized trial. Ann Intern Med. Oct. 3. 2006;145(7):477-87. [pmid: 17015865].
88 Whitty P, Steen N, Eccles M, et al. A new self-completion outcome measure for diabetes: is it responsive to change?. Qual Life Res. Jul. 1997;6(5):407-13. [pmid: 9290307].
89 Justice AC, Holmes W, Gifford AL, et al. Development and validation of a self-completed HIV symptom index. J Clin Epidemiol. Dec. 2001;54(Suppl 1):S77-90. [pmid: 11750213].
90 Hlatky MA, Boineau RE, Higginbotham MB, et al. A brief self-administered questionnaire to determine functional capacity (the Duke Activity Status Index). Am J Cardiol. Sep. 15. 1989;64(10):651-4. [pmid: 2782256].
91 Hays RD, Woolley JM. The concept of clinically meaningful difference in health-related quality-of-life research. How meaningful is it?. Pharmacoeconomics. Nov. 2000;18(5):419-23. [pmid: 11151395].
92 Leon AC, Olfson M, Portera L, et al. Assessing psychiatric impairment in primary care with the Sheehan Disability Scale. Int J Psychiatry Med. 1997;27(2):93-105. [pmid: 9565717].
93 Ware JE, Kosinski M. Interpreting SF-36 summary health measures: a response. Qual Life Res. 2001;10(5):405-13. discussion 15–20. [pmid: 11763203].
94 Katon WJ. Clinical and health services relationships between major depression, depressive symptoms, and general medical illness. Biol Psychiatry. Aug. 1. 2003;54(3):216-26. [pmid: 12893098].
95 Joynt KE, Whellan DJ, O’Connor CM. Depression and cardiovascular disease: mechanisms of interaction. Biol Psychiatry. Aug. 1. 2003;54(3):248-61. [pmid: 12893101].
96 Bogner HR, Morales KH, de Vries HF, et al. Integrated management of type 2 diabetes mellitus and depression treatment to improve medication adherence: a randomized controlled trial. Ann Fam Med. Jan–Feb. 2012;10(1):15-22. [pmid: 22230826].
97 Piette JD, Richardson C, Himle J, et al. A randomized trial of telephonic counseling plus walking for depressed diabetes patients. Med Care. Jul. 2011;49(7):641-8. [pmid: 21478777].
98 Davidson KW, Rieckmann N, Clemow L, et al. Enhanced depression care for patients with acute coronary syndrome and persistent depressive symptoms: coronary psychosocial evaluation studies randomized controlled trial. Arch Intern Med. Apr. 12. 2010;170(7):600-8. [pmid: 20386003].
99 Berkman LF, Blumenthal J, Burg M, et al. Effects of treating depression and low perceived social support on clinical events after myocardial infarction: the Enhancing Recovery in Coronary Heart Disease Patients (ENRICHD) Randomized Trial. JAMA. Jun. 18. 2003;289(23):3106-16. [pmid: 12813116].
100 New Freedom Commission on Mental Health: achieving the promise: transforming mental health care in America, Final Report. Rockville, MD. Department of Health and Human Resources. 2003. DHHS pub no SMA-03-3832.
101 Solberg LI, Trangle MA, Wineman AP. Follow-up and follow-through of depressed patients in primary care: the critical missing components of quality care. J Am Board Fam Pract. Nov–Dec. 2005;18(6):520-7. [pmid: 16322414].
102 Brazeau CMLR, Rovi S, Yick C, et al. Collaboration Between Mental Health Professionals and Family Physicians: A Survey of New Jersey Family Physicians. Prim Care Companion. J Clin Psychiatry. 2005;7(1):12-4.
103 Roy-Byrne P, Craske MG, Sullivan G, et al. Delivery of evidence-based treatment for multiple anxiety disorders in primary care: a randomized controlled trial. JAMA. May. 19. 2010;303(19):1921-8. [pmid: 20483968].
104 Institute for Clinical Systems Improvement. Health Care Redesign: DIAMOND. Updated 2010. www.icsi.org/health_care_redesign_/diamond_35953/. Accessed 4 April 2012.
105 Gunderson JG. Clinical practice. Borderline personality disorder. N Engl J Med. May. 26. 2011;364(21):2037-42. [pmid: 21612472].
106 Alexopoulos GS, Meyers BS, Young RC, et al. Clinically defined vascular depression. Am J Psychiatry. Apr. 1997;154(4):562-5. [pmid: 9090349].
107 Mast BT, Azar AR, Murrell SA. The vascular depression hypothesis: the influence of age on the relationship between cerebrovascular risk factors and depressive symptoms in community dwelling elders. Aging Ment Health. Mar. 2005;9(2):146-52. [pmid: 15804632].
108 Gaynes BN, DeVeaugh-Geiss J, Weir S, et al. Feasibility and diagnostic validity of the M-3 checklist: a brief, self-rated screen for depressive, bipolar, anxiety, and post-traumatic stress disorders in primary care. Ann Fam Med. Mar–Apr. 2010;8(2):160-9. [pmid: 20212303].
109 Saha S, Chant D, McGrath J. A systematic review of mortality in schizophrenia: is the differential mortality gap worsening over time?. Arch Gen Psychiatry. Oct. 2007;64(10):1123-31. [pmid: 17909124].
110 Goff DC, Cather C, Evins AE, et al. Medical morbidity and mortality in schizophrenia: guidelines for psychiatrists. J Clin Psychiatry. Feb. 2005;66(2):183-94. quiz 47. 273. 4. [pmid: 15705003].