# Methods

The methods for this comparative effectiveness review (CER) follow the methods suggested in the Agency for Healthcare Research and Quality (ARHQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews (www.effectivehealthcare.ahrq.gov/methodsguide.cfm). The main sections in this chapter reflect the elements of the protocol established for this CER; certain methods map to the Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) checklist.47

## Topic Refinement and Review Protocol

During the topic development and refinement processes, we generated an analytic framework, preliminary Key Questions (KQs), and preliminary inclusion/exclusion criteria in the form of PICOTS (Population, Intervention, Comparator, Outcome, Timing, Setting), and study design. The processes were guided by the information provided by the topic nominator, a scan of the literature, methods and content experts, and Key Informants. We worked with five Key Informants during the topic refinement, and five members of our Technical Expert Panel (TEP); (one individual participated in both). Key Informants and TEP members participated in conference calls and discussions through email to review the analytic framework, KQs, and PICOTS at the beginning of the project; TEP members also discussed the preliminary assessment of the literature, including inclusion/exclusion criteria and review of the protocol, and provided input on the information and categories included in evidence tables.

To achieve an appropriate scope for the review, we prioritized conditions and interventions that were most clinically relevant. Preliminary evidence reviews casting a wide net for mental health conditions revealed insufficient data on mental health conditions other than depression and anxiety, and the latter ultimately yielded no qualified studies. With input from our Key Informants, we selected the following chronic medical conditions identified as priority conditions by AHRQ48 and the Institute of Medicine:49 arthritis; diabetes; asthma or chronic obstructive pulmonary disease (COPD); cancer; chronic pain; stroke; HIV/AIDS; heart disease, heart failure, myocardial ischemia, coronary artery bypass graft, postmyocardial infarction, and coronary artery disease; “complex” patients with multiple comorbidities; and frailty due to old age.

Our KQs were posted for public comment on AHRQ’s Effective Health Care Web site from March 18, 2011, through April 15, 2011; we put them into final form after review of the comments and discussion with the TEP.

## Literature Search Strategy

### Search Strategy

To identify articles relevant to each KQ, we searched MEDLINE^®^, Embase^®^, the Cochrane Library, CINAHL^®^, and PsycINFO^®^. The full search strategy is presented in Appendix A. We used Medical Subject Headings (MeSH or MH) as search terms when available or key words when appropriate, focusing on terms to describe the relevant population and the interventions of interest. We reviewed our search strategy with the TEP members and incorporated their input into our search strategy.

We limited the electronic searches to English-language publications (because of time and other resources) and humans. Sources were searched from the inception of each database through May 23, 2011. We used the National Library of Medicine publication type tags to identify reviews, randomized controlled trials, and meta-analyses.

We manually searched reference lists of pertinent reviews, included trials, and background articles on this topic, including the 2008 AHRQ report on integration of care,35 to look for any relevant citations that might have been missed by our searches. We imported all citations into an electronic database (EndNote^®^ X4). We also searched for unpublished studies relevant to this review using ClinicalTrials.gov and the World Health Organization’s International Clinical Trials Registry Platform.

We conducted an updated literature search (of the same databases searched initially) through December 19, 2011. Literature suggested by Peer Reviewers or from the public were investigated and, if appropriate, incorporated into the final review. Appropriateness was determined by the same methods listed above.

### Inclusion and Exclusion Criteria

We developed eligibility (inclusion and exclusion) criteria with respect to patient PICOTS, and study designs and durations for each KQ (Table 2). Appendix B contains the list of studies that were reviewed at the full-text stage but failed to meet all inclusion criteria.

Table 2 Study eligibility criteria

Criteria | Definition
Population(s) | Adults (age 18 or older) with depression^a^ and one or more of the following chronic medical conditions: arthritis; diabetes; asthma or chronic obstructive pulmonary disease; cancer; chronic pain; stroke; HIV / AIDS; heart disease, heart failure, myocardial ischemia, coronary artery bypass graft, post-myocardial infarction, or coronary artery disease; “complex” patients with multiple comorbidities; and frailty due to old age. The inclusion criteria require a level of depression that exceeds generally accepted cut points for major depression on common instruments, but were not necessarily confirmed by gold standard evaluations. We use the term depression throughout the report to reflect this definition.
Interventions | Practice-based interventions aimed at improving depression or both depression and the chronic medical condition. Practice-based is understood to mean any intervention that (1) targets the care process within a system of care and (2) aims to improve depression or both depression and chronic medical conditions. Examples of practice-based interventions include but are not limited to coordinated care, integrated care, and collaborative care; they often involve a care manager. Each of these terms has varying, and possibly overlapping definitions, and is not specifically defined for the purposes of this report. In general, we perceive them broadly to mean primary care providers and mental health providers working together to address the comprehensive needs of the patient.
Comparators | Different combinations, approaches, and modalities for the above interventions Usual care (as defined by the study, representing, however, a particular practice or setting is providing care for patients who do not receive an intervention)
Outcomes | [underlined: Intermediate depression outcomes:]; - symptom improvement, response rates, and remission and/or recurrence as measured by scores on reliable and valid instruments (to include self-rated instruments) ;; - treatment adherence; and; - satisfaction with care.; [underlined: Intermediate chronic medical condition outcomes:]; - symptom improvement, remission, and remediation;; - response to treatment (e.g., HbA1c);; - treatment adherence; and; - satisfaction with care.; [underlined: Other depression–related outcomes:]; - disease-related mortality,; - disease-related morbidity,; - disease-related functional status,; - mental health–related quality of life,; - sick days related to mental health,; - mental health care utilization, and; - employment stability.; [underlined: Other chronic medical and general health outcomes:]; - all-cause mortality,; - disease-related mortality,; - disease-related morbidity,; - disease-related functional status,; - general health–related quality of life,; - disease-specific outcomes,; - general health care utilization,; - total sick days and sick days due to general health condition,; - employment stability, and; - costs of intervention delivery.; [underlined: Potential adverse effects of interventions:]; - adverse effects of pharmacotherapy and; - other harms as reported.
Timing | Outcome assessment at least 6 months after randomization (or from receipt of the intervention for nonrandomized controlled trials)
Settings | Traditional primary-care settings; settings with a primary care-type relationship that may be applicable to traditional primary care settings (e.g., infectious disease clinics for people with HIV, oncology clinics for people with cancer). No geographic limits.
Study designs | Randomized controlled trials, nonrandomized trials with concurrent eligible controls, and recent systematic reviews with or without meta-analyses. We chose to exclude studies without comparison groups owing to the potential risk of bias in such studies (especially the risk of selection bias and confounding). No sample size limits.

a Our original framework and search strategy included both depression and anxiety; since our searches yielded no studies of the latter, we have removed it from this figure for clarity.

Abbreviations: HbA1c = hemoglobin A1c.

### Data Extraction

For studies that met our inclusion criteria, we abstracted important information into evidence tables. We designed and used structured data abstraction forms to gather pertinent information from each article, including characteristics of study populations, settings, interventions, comparators, study designs, methods, and results. Trained reviewers extracted the relevant data from each included article into the evidence tables. A second member of the team reviewed all data abstractions against the original article for completeness and accuracy. We recorded intention-to-treat results if available. All data abstraction was performed using Microsoft Excel^®^ software. Data abstraction forms were almost identical to the evidence tables containing abstracted data (Appendix C).

## Quality Assessment of Individual Studies

To assess the quality (internal validity) of studies, we used predefined criteria based on those developed by the U.S. Preventive Services Task Force (ratings: good, fair, poor)50 and the University of York Centre for Reviews and Dissemination.51 These criteria assess for the adequacy of randomization, allocation concealment, similarity of groups at baseline, masking, attrition, and whether intention to treat analysis was used. In general terms, a “good” study has the least risk of bias and its results are considered to be valid. To be rated “good” for the purpose of this review, a study must have fulfilled all or all but one of the following criteria: adequate randomization of patients; adequate allocation concealment; blinded outcome assessors; similar baseline characteristics across treatment arms; overall attrition less than 20 percent; differential attrition less than 15 percent (i.e., there is less than a 15 percentage point difference between attrition in one group and attrition in another); intention-to-treat analysis; and use of equivalent, valid, and reliable outcome measures. A “fair” study is susceptible to some bias but probably not sufficient to invalidate its results. A “poor” study has significant risk of bias (e.g., stemming from serious errors in design or analysis) that may invalidate its results. We gave poor quality ratings to studies that had a fatal flaw (defined as a methodological shortcoming that leads to a very high risk of bias) in one or more categories, and we excluded them from our analyses.

Two independent reviewers assigned quality ratings for each study. Disagreements between the two reviewers were resolved by discussion and consensus or by consulting a third member of the team. Appendix D details the criteria used for evaluating the quality of all included studies as well as comments on the studies rated “poor” and excluded from analysis.

## Data Synthesis

### Overall Approach

The research team determined prioritization and/or categorization of outcomes with input from TEP members. Quantitative analyses were conducted using meta-analyses of outcomes reported by a sufficient number of studies that were homogeneous enough that combining their results could be justified. To determine whether quantitative analyses were appropriate, we assessed the clinical and methodological heterogeneity of the studies under consideration following established guidance.52 We did this by qualitatively assessing the PICOTS of the included studies, looking for similarities and differences. When quantitative analyses were not appropriate (e.g., because of heterogeneity, insufficient numbers of similar studies, or insufficiency or variation in outcome reporting), we synthesized the data qualitatively.

### Statistical Analyses

We ran meta-analyses for outcomes with sufficient data, including depression symptom improvement, reduction of depression symptoms, remission of depression, mental health treatment satisfaction, mental health status, prescription antidepressant use, change in hemoglobin A1c (HbA1c), change in physical health status, and all-cause mortality. For continuous outcomes of mean score change between baseline and endpoint, many studies did not report a variance measure of the mean change but did include variance information at baseline and 12 months. In these cases, we assumed a correlation of 0.5 to estimate the mean change variance53 and conducted sensitivity analyses with assumed correlations of 0.3 and 0.7 to confirm that this assumption did not significantly change our results. However, in cases in which the final mean value was adjusted for baseline via regression or analysis of covariance, we used this endpoint value instead of assuming a correlation because it is the most efficient and least-biased statistic.54 Separate analyses were run for studies reporting 6- and 12-month outcomes.

We used random-effects models to estimate pooled effects.55 For continuous outcomes, the effect measure was the weighted mean difference or, if the measurement scale differed among trials, the standardized mean difference was calculated. For most dichotomous outcomes, we report risk differences. For all-cause mortality at 6 or 12 months, the comparison between intervention and control was calculated as a risk ratio. Forest plots graphically summarize results of individual studies and of the pooled analysis (Appendix E).56

The chi-squared statistic and the I^2^ statistic (the proportion of variation in study estimates attributable to heterogeneity) were calculated to assess heterogeneity in effects between studies.57, 58 An I^2^ from 0 to 40 percent might not be important, 30 to 60 percent may represent moderate heterogeneity, 50 to 90 percent may represent substantial heterogeneity, and ≥75 percent represents considerable heterogeneity.54 The importance of the observed value of I^2^ depends on the magnitude and direction of effects and on the strength of evidence for heterogeneity (e.g., p value from the chi-squared test, or a confidence interval for I^2^). Whenever including a meta-analysis with considerable statistical heterogeneity in this report, we provide an explanation for doing so, considering the magnitude and direction of effects.54 We conducted sensitivity analyses for all analyses where considerable heterogeneity was present (i.e., I^2^ statistic greater than 75 percent). Quantitative analyses were conducted using Stata^®^ version 11.1 (StataCorp LP, College Station, TX) and Comprehensive Meta Analysis^®^ version 2.2.055 (BioStat, Inc., Englewood, NJ).

## Strength of the Body of Evidence

We graded the strength of evidence based on the guidance established for the Evidence-based Practice Center Program.59 Developed to grade the overall strength of a body of evidence, this approach incorporates four key domains: risk of bias (includes study design and aggregate quality), consistency, directness, and precision of the evidence. It also considers other optional domains that may be relevant for some scenarios, such as a dose-response association, plausible confounding that would decrease the observed effect, strength of association (magnitude of effect), and publication bias.

Table 3 describes the grades of evidence that can be assigned. We graded the strength of evidence for mental health outcomes (KQ 1), chronic medical condition outcomes (KQ 2), and harms (KQ 3). Two reviewers assessed each domain for each key outcome and differences were resolved by consensus.

Table 3 Definitions of the grades of overall strength of evidence

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

* Owens et al., 2010^59^

## Applicability

We assessed applicability of the evidence following guidance from the Methods Guide for Effectiveness and Comparative Effectiveness Reviews.60 We used the PICOTS framework to explore factors that affect applicability. Some factors identified a priori that may limit the applicability of evidence included the following: ethnicity of enrolled populations, type of practice setting (open vs. closed), and use of interventions that may be difficult to incorporate into routine practice for many providers (e.g., they require substantial resources or time, or they may be delivered by research staff rather than existing staff in the practice).

## Peer Review and Public Commentary

Experts in the field and individuals representing stakeholder and user communities were invited to provide external peer review of this CER. They were charged with commenting on the content, structure, and format of the evidence report, providing additional relevant citations, and pointing out issues related to how we conceptualized the topic and analyzed the evidence. Our Peer Reviewers (listed in the front matter) gave us permission to acknowledge their review of the draft. AHRQ staff and an associate editor also provided comments. In addition, the Scientific Resource Center posted the draft report on the AHRQ Web site (effectivehealthcare.ahrq.gov/) for 4 weeks to elicit public comment. We addressed all reviewer comments, revising the text as appropriate, and documented everything in a “disposition of comments report” that will be made available 3 months after the Agency posts the final CER on the AHRQ Web site.