# Introduction

## Background

The World Health Organization has identified the integration of mental health into primary care as the most salient means of addressing the burden of mental health conditions, noting its “urgent importance.”1 In the United States, half of the care for common mental health disorders is delivered in general medical settings,2 emphasizing the vital role that primary care providers play in the diagnosis and treatment of these disorders.

Common mental health conditions, such as depression and anxiety, are found in up to 10 percent of primary care patients,3 and these conditions often coexist with chronic medical conditions. Accordingly, considerable interest has been expressed in improving the recognition and management of mental health conditions, especially depression, within primary care.4–6 Specifically, interest is emerging about whether treatment of common mental health conditions in primary care can improve both mental health and chronic medical outcomes. The arena of mental health and primary care is moving from consideration of single conditions and their outcomes to more real-world, complex-care paradigms.2, 7 However, to date, no synthesis of the evidence on practice-based interventions accounts for the primary care patient with “multiple chronic conditions”8 and examines both mental health and chronic medical outcomes simultaneously.

Despite the prevalence and importance of other mental health conditions in the primary care setting, especially anxiety,9, 10 substance use,11 and psychotic disorders,12 our preliminary review of the literature revealed that only depression has the evidence base necessary to meet eligibility criteria for a comparative effectiveness review.

The purpose of this report, therefore, is to summarize the available evidence on the effectiveness of practice-based interventions aimed at adult primary care patients with concomitant depression and chronic medical diagnoses. We believe this will add to the literature by (1) synthesizing data on mental health outcomes among people with defined chronic medical conditions, and (2) synthesizing data on chronic medical outcomes among these same people.

### Depression and Chronic Medical Conditions

Of all mental health conditions, depression contributes the greatest societal burden as measured by social and economic costs.13 Indeed, by 2030, depression itself is projected to be the single leading cause of overall disease burden in high-income countries.14 Worldwide, depression makes a large contribution to the burden of disease, ranking third worldwide, eighth in low-income countries, and first in middle- and high-income countries.15 In 2000, the U.S. economic burden of depressive disorders was estimated to be $83.1 billion.16 More than 30 percent of these costs were attributable to direct medical expenses.16

Half of all Americans live with a chronic medical condition.17 An estimated 23.6 million people (7.8 percent of the U.S. population) have diabetes.18 Roughly 24 million U.S. adults have chronic obstructive pulmonary disease, and an additional 23 million have asthma.19 Up to one-quarter of people living with chronic medical conditions have limitations in daily activity.17 Living with chronic disease also takes a personal and emotional toll on patients and their families, owing to significant reductions in quality of life.17

Chronic medical conditions commonly associated with depression include arthritis, heart disease, diabetes, asthma, lung disease, and cancer.20, 21 (Table 1). Depression among people with chronic physical illness has been linked to an increase in health care utilization, disability, and work absenteeism when compared with those without depression, even after controlling for the varying burden of the physical health condition.22, 23

Table 1 Prevalence of depression in chronic medical conditions

Chronic Condition | Prevalence of Depression
Arthritis
Rheumatoid arthritis | 13% to 20%^24, 25^
Osteoarthritis | 19.4%^26^
Heart disease
Post-myocardial infarction | 10% to 47%^27^
Coronary artery disease | 15%^28^ to 23%^29^
Diabetes | 11% to 15%^30^ (MDD specifically)
| 17.6%^31^ to 31.0%^30^ (any depressive disorder)
Pulmonary disease
Asthma | 26.6%^32^
Chronic obstructive pulmonary disease | 27.2%^33^
Cancer | 9% to 24%^34^ (MDD)
| 20% to 50% 34 (any depressive disorder)

Abbreviations: MDD = major depressive disorder.

### Treating Depression in Primary Care

Repeated evidence reviews show the benefits of integrated and collaborative care models, as compared with usual care, on the outcomes of depression in the general health setting without consideration of coexisting mental health conditions.4, 35–37 An emerging literature addresses whether better treatment of depression in primary care can also improve chronic medical outcomes, such as for diabetes.38–40 A review of similar studies will help address the clinical uncertainty about whether such interventions can make a difference in more than one disease outcome and inform policy decisions about the potential benefit of adopting such guidance.

### Scope and Key Questions

#### Previous Reports

Two recent reports have particular relevance to this topic: a 2008 Agency for Healthcare Research and Quality (AHRQ) report examining the integration of mental health/substance abuse and primary care35 and a 2009 National Institute for Health and Clinical Excellence (NICE) guideline for depression in adults with a chronic physical health problem.36 The AHRQ report required trials to include patients with a mental health condition seen in primary or specialty care, but did not require the presence of a chronic medical condition. The NICE report neither specified primary care as the setting of interest nor examined disease-specific chronic medical outcomes. This review is therefore distinct.

#### Scope of the Review

As we conceptualized the approach to this report through the topic nomination and refinement process, preliminary evidence reviews revealed insufficient data on mental health conditions other than depression that met all eligibility criteria. We specifically searched for evidence in patients with anxiety, but no studies met final eligibility criteria. The exclusion of mental health conditions other than depression does not reflect a belief that they are less important, but that the literature is not mature enough to answer the questions set forth.

This review therefore summarizes the body of evidence that examines the effectiveness of practice-based interventions aimed at improving depression or both depression and chronic medical conditions in adult primary care patients with depression and chronic medical condition(s) at baseline. The inclusion criteria require a level of depression that exceeds generally accepted cut points for major depression on common instruments, but were not necessarily confirmed by gold standard evaluations. We use the term depression throughout the report to reflect this definition. In an effort to address the inherent heterogeneity of complex interventions,41 this report also compares the specific characteristics of the interventions and the practice settings in which they are delivered.

These results should be of interest to multiple stakeholders, including patients, providers, and policymakers. A family physician nominated this topic because he wanted to know whether concomitantly treating mental health and general health conditions in the primary care setting could improve overall health outcomes. As we move to consider shared savings programs, such as accountable care organizations,42 and the patient-centered medical home,43 consumers and payers are eager to identify interventions and processes that can streamline care for multiple conditions and improve the quality and efficiency of care. In fact, the PCMH has been defined as being accountable for “meeting the vast majority of each patient’s physical and mental health care needs.” [pcmh.ahrq.gov/portal/server.pt/community/pcmh__home/1483/PCMH_Defining%20the%20PCMH_v2] Numerous barriers, many financial, have hindered implementation of collaborative depression treatment in primary care despite its considerable evidence base.4, 44, 45 This report aims to provide new data about the common and costly problem of primary care patients with concomitant depression and chronic medical conditions. Understanding how depression care influences a broad range of health outcomes can inform clinical decisionmaking as well as potential reimbursement and coverage strategies.

##### Population

The focus of this review is on adults with one or more diagnosed chronic medical condition and a diagnosis of depression, being treated in a primary care setting. An example is patients with diabetes and depression. The inclusion criteria require a level of depression that exceeds generally accepted cut points for major depression on common instruments. The purpose is to include patients with a level of severity known to benefit from treatment and to be associated with poor outcomes.

##### Interventions

For this review we use the term “practice-based” to define the interventions of interest. This term reflects an explicit effort to be inclusive of a wide range of interventions while also requiring the primary care site to be the nucleus of activity. Our rationale is to honor the spirit of the original nomination by acknowledging the crucial role of primary care, where most patients receive care, and from which care can be coordinated.46

Practice-based is understood to mean any intervention that (1) targets the care process within a system of care and (2) aims to improve depression or both depression and chronic medical conditions. Examples of practice-based interventions include but are not limited to coordinated care, integrated care, and collaborative care; they often involve a care manager. Because of the dual focus on (1) concurrent management of both depression and the chronic medical condition within primary care and (2) systematic changes that can improve the delivery of care (rather than testing specific interventions), we exclude medication-only, device, and psychotherapy-only clinical trials (e.g., efficacy studies comparing a medication with a placebo) from this review. Practice-based interventions can include person-level components such as problem-solving therapy and antidepressant medications, but they must be delivered as part of a broader systematic strategy to improve care.

##### Comparators

Potential comparators include different combinations, approaches, and modalities of practice-based interventions. A comparator of usual care, or enhanced usual care, is defined by each study.

##### Outcomes

We focused on five main outcomes: depression (Key Question [KQ] 1), chronic medical (KQ 2), harms of interventions (KQ 3), components of interventions (KQ 4), and characteristics of practice settings in which the interventions occurred (KQ 5). All KQs draw from the same universe of studies, such that KQs 3, 4, and 5 are subsidiary to KQs 1 and 2.

##### Settings

Settings include traditional primary care (e.g., family medicine, internal medicine, obstetrics/gynecology, and geriatrics) and settings with a primary care–type relationship (e.g., oncology clinics for those with cancer, infectious disease clinics for those with HIV).

#### Key Questions

- KQ 1a: Among adults with chronic medical conditions and concomitant depression (such as patients with diabetes and depression) treated in the primary care setting, what is the comparative effectiveness of practice-based interventions aimed at improving depression or both depression and chronic medical conditions (when compared with similar interventions or usual care) on intermediate depression outcomes (e.g., symptom improvement)?
- KQ 1b: Among adults with chronic medical conditions and concomitant depression (such as patients with diabetes and depression) treated in the primary care setting, what is the comparative effectiveness of practice-based interventions aimed at improving depression or both depression and chronic medical conditions (when compared with similar interventions or usual care) on other mental health outcomes (e.g., depression-related quality of life) and use of mental health-related services?
- KQ 2a: Among adults with chronic medical conditions and concomitant depression (such as patients with diabetes and depression) treated in the primary care setting, what is the comparative effectiveness of practice-based interventions aimed at improving depression or both depression and chronic medical conditions (when compared with similar interventions or usual care) on intermediate chronic medical outcomes (e.g., hemoglobin [Hb]A1c for patients with diabetes)?
- KQ 2b: Among adults with chronic medical conditions and concomitant depression (such as patients with diabetes and depression) treated in the primary care setting, what is the comparative effectiveness of practice-based interventions aimed at improving depression or both depression and chronic medical conditions (when compared with similar interventions or usual care) on general and other health outcomes (e.g., diabetes-related morbidity, general health-related utilization, costs)?
- KQ 3: What harms are associated with practice-based interventions for primary care patients with chronic medical conditions and concomitant depression?
- KQ 4: What are the characteristics of the practice-based interventions addressing concomitant depression and chronic medical conditions used in the primary care setting with regard to specific components and/or intensity (e.g., visit frequency, total number of contacts, provider discipline, use of self-management)?
- KQ 5: What are the specific characteristics of the practice setting where the interventions were delivered with regard to such variables as organizational characteristics (e.g., decision support, level of integration, information technology, electronic medical records, presence of mental health services on site, payer and service mix, practice size, and practice location/setting) or the relationship between elements of the system in which the practice operates (e.g., coordination, financing of care, payment arrangements)?

#### Analytic Framework

We developed an analytic framework to guide the systematic review process (Figure 1). KQ 1 addresses the effectiveness of practice-based interventions for improving depression outcomes—1a addresses intermediate clinical outcomes related to depression, such as symptom response, and 1b addresses other outcomes related to mental health, such as depression-related quality of life, and mental health care utilization. KQ 2 addresses the effectiveness of practice-based interventions for improving chronic medical condition outcomes—KQ 2a addresses intermediate clinical outcomes, such as pain severity scores for patients with chronic pain, and 2b addresses other important chronic medical outcomes, such as disease-related quality of life, and general health-related utilization. KQ 3 addresses the potential harms of practice-based interventions. KQs 4 and 5 assess the characteristics of the interventions and practice settings, respectively.

Figure 1 Analytic framework for interventions addressing concomitant depression^a^ a Our original framework and search strategy included both depression and anxiety; since our searches yielded no studies of the latter, we have removed it from this figure for clarity. and chronic medical conditions in primary care

b Chronic medical conditions are considered broadly and include the AHRQ priority conditions and IOM priority conditions, including diabetes, arthritis, and chronic pain, among others.

Abbreviations: CM = chronic medical; MH = mental health.

Figure 1 is titled “Analytic framework for interventions addressing concomitant depression and chronic medical conditions in primary care.” There is a footnote at the end of the title that reads “Our original framework and search strategy included both depression and anxiety; since our searches yielded no studies of the latter, we have removed it from this figure for clarity.” The framework begins on the left with our patient population of interest: adults with chronic medical conditions and concomitant depression. There is a footnote for chronic medical conditions that reads “Chronic medical conditions are considered broadly and include the AHRQ priority conditions and IOM priority conditions, including diabetes, arthritis, and chronic pain, among others.” We also specify the following subgroups of interest: seniors (65+), veterans, racial/ethnic minorities, and men compared with women. An arrow with the word “intervention” starts from the population on the left and splits into four arrows, each leading to a box on the right. Each of these arrows has a specific KQ listed above it. The four boxes are labeled as: “Intermediate depression outcomes” (KQ 1a); “Intermediate chronic medical outcomes” (KQ 2a); “Depression-related outcomes” (KQ 1b); and “Chronic medical-related and general health outcomes” (KQ 2b). Within each box, outcomes are specified: intermediate depression and chronic medical condition outcomes are listed as symptom improvement, response and remission, treatment adherence, and satisfaction with care. Other depression-related and chronic medical condition-related outcomes are listed as morbidity, mortality, health care utilization, quality of life/health status, and costs of intervention delivery. A curvy arrow labeled “KQ 3” descends from the initial “intervention” arrow to an elliptical shape with the words “Harms of intervention” to illustrate the focus of KQ 3. A dashed line starts at the “Intermediate mental health outcomes” box and goes to the right, connecting to the “Other mental health outcomes” box. Similarly, a dashed line starts at the “Intermediate chronic medical outcomes” box and goes to the right, connecting to the “General health outcomes” box. A vertical dashed line connects the “Other mental health outcomes” and “General health outcomes” boxes. A diamond-shaped ‘kite’ containing the words “Characteristics of intervention” is located near the top of the figure and is connected to the main intervention arrow with two dashed vertical lines to illustrate the foci of KQs 4 (intervention components and intensity) and 5 (practice-setting factors).