# Discussion

In this report, we aimed to address the following overarching question: Among adults with chronic medical conditions and a concomitant mental health condition (such as patients with diabetes and depression) treated in the primary care setting, what is the comparative effectiveness of practice-based interventions aimed at improving the mental health condition or both the mental health and chronic medical conditions?

We broadly defined the scope of our review to include real-world scenarios and patients with clear diagnoses, representing common primary care populations. However, although studies we identified involved several coexisting medical conditions, included studies involved only a single mental health condition, depression. The variety of interventions was similarly limited. Indeed, despite an effort informed by our Technical Expert Panel to be inclusive of practice-based interventions (such as integrated care or telemedicine), the studies in our final analysis all defined their intervention as a form of collaborative care. No study compared its intervention with another intervention; rather, all did comparisons only with usual or enhanced usual care. Therefore, this discussion is based on a body of evidence comparing the effectiveness of collaborative care interventions with usual care for primary care patients with depression and one or more chronic medical conditions, and does not include any head-to-head trials.

Inclusive of a broad range of chronic medical conditions that the Agency for Healthcare Research and Quality (AHRQ) and the Institute of Medicine (IOM) have identified as being of high priority for research, we identified studies on arthritis, cancer, diabetes, heart disease, HIV, and one or more conditions. Nine studies were primary randomized controlled trials (RCTs); three studies were condition-specific subgroup analyses of a separate RCT, with the most data available on patients with diabetes. All trials except one80 were designed to measure mental health–related outcomes, rather than medical outcomes, as the primary outcome.

Our review focuses on five main groups of outcomes: mental health outcomes (KQ 1), chronic disease medical outcomes (KQ 2), harms of interventions (KQ 3), components of interventions (KQ 4), and characteristics of practice settings in which the interventions occurred (KQ 5).

## Key Findings and Strength of Evidence

### Key Question 1a Intermediate Mental Health Outcomes and Satisfaction With Care

We summarize findings and strength of evidence (SOE) for this question in Table 18. Evidence from 11 studies indicated that patients receiving a collaborative care intervention had greater improvement in depressive symptoms. Collaborative care interventions were also associated with greater depression treatment response (≥50 percent reduction in symptoms) than for those receiving usual care in 9 studies (moderate SOE). These results were consistent across medical conditions and reflect clinically meaningful changes on well-accepted measures of depression. The evidence showed that five patients would need to be treated to achieve one more depression response than would be seen with usual care at 6 months, with a number needed to treat [NNT] of six patients at 12 months. Benefits persisted, but to a lesser degree, at 18 months.

Table 18 Summary of results for collaborative care interventions compared with controls for people with depression and one or more chronic medical conditions: intermediate mental health outcomes

Outcome | Summary of Results | Strength of Evidence
Symptom improvement | Greater symptom improvement scores in intervention groups at both 6 months (SMD, 0.45; 95% CI, 0.29 to 0.61; 7 studies) and 12 months (SMD, 0.47; 95% CI, 0.29 to 0.65; 6 studies) compared with control groups. Benefits were sustained through 24 months, but the magnitude of benefit was reduced (WMD, 0.18; 95% CI, 0.10 to 0.16; 3 studies). | Moderate
Depression- free days | More depression-free days at 12 months for those in intervention groups than usual care groups (5 studies, range of differences between intervention and control groups: 20 to 59 days). | Moderate
Response (≥50% reduction) | Higher rates of depression response in intervention groups than usual care, based on 10 studies(NNT, 5 at 6 months; NNT, 6 at 12 months). Benefits persisted, but to a lesser degree, at 18 months (RD 0.12; 95% CI, 0.02 to 0.22; 3 studies). | Moderate
Remission | Remission of depression favored intervention over usual care at 6 months and at 12 months based on 3 RCTs and 2 RCT subgroup analyses (NNT, 8 at 6 months; NNT, 12.5 at 12 months). Benefits persisted at 18 months, but showed no difference between groups at 24 months. | Moderate
Recurrence | Only 1 study (of patients with cancer) addressed recurrence as an outcome, and showed no difference between groups at 18 or 24 months. | Insufficient
Treatment adherence | Mixed results: 1 trial reported significantly greater adherence to antidepressants in the intervention arm at 6 and 12 months; the other reported no difference between groups at 6 and 12 months. | Insufficient
Treatment satisfaction | Greater satisfaction with care for intervention participants than controls at 12 months (RD, 0.21 (95% CI, 0.11 to 0.30; 4 studies)^a^; . Benefits were sustained at 24 months (RD, 0.14; 95% CI, 0.06 to 0.21; 3 studies). | Moderate

a Results are from meta-analysis of the 4 trials that reported satisfaction for both intervention and control arms. Two additional trials reported treatment satisfaction for the intervention arm but not the usual care arm.

Abbreviations: CI = confidence interval; NA = not applicable; RD = risk difference; SMD = standardized mean difference; WMD = weighted mean difference.

Although less frequently measured, patients receiving collaborative care also had more depression-free days (moderate SOE) and higher rates of depression remission (moderate SOE) compared with patients receiving usual care. Intervention patients similarly reported greater satisfaction with care (moderate SOE).

Evidence was insufficient to draw conclusions about adherence to antidepressants based on limited data and variable definitions. Of the two studies that provided adequate data on adherence, one showed significant differences between groups77 and one did not73. We found insufficient data to draw conclusions about recurrence of depression (only one study68, 71).

### Key Question 1b Morbidity, Mortality, Quality of Life, Function, and Utilization

This question looked at other mental health outcomes, including suicide, use of antidepressants, mental health–related quality of life, use of mental health care services, sick days related to mental health, and employment stability (Table 19). Only one suicide was reported, in the usual care arm of a cancer trial.74 In a second trial, investigators reported that they were unaware of any attempted or completed suicides in either treatment group.68 Meta-analyses from three studies61, 73, 79 at 6 months showed no difference in antidepressant use between groups, with a clear outlier in the HIV study (see Appendix E). Five studies61, 64, 65, 67, 68, 73 at 12 months showed that the use of antidepressants was greater in collaborative care arms than in control groups across populations with various chronic medical conditions; we removed the HIV study in sensitivity analysis (low SOE). Quality of life was measured in several ways but most frequently using the mental component of the Medical Outcomes Study Short-Form (SF-12), showing that collaborative care interventions achieved greater quality of life scores than usual care at 6 and 12 months (moderate SOE). Five studies38, 61, 62, 67–69, 71 reported on mental health care utilization; each showed greater use of any mental health services at 6 or 12 months (or both) by those receiving the collaborative care intervention, and one as-treated sample of patients with cancer61 showed that this trend persisted at 18, but not 24 months (low SOE). No data were available on sick days or employment stability (insufficient SOE).

Table 19 Summary of results for collaborative care interventions compared with controls for people with depression and one or more chronic medical conditions: other mental health outcomes

Outcome | Summary of Results | Strength of Evidence
Suicide | One study reported one suicide in the usual care group. | Insufficient
Use of anti-depressants | Greater antidepressant use for collaborative care interventions than for usual care at 12 months (RD, 0.23; 95% CI, 0.15 to 0.30; 5 studies^a^), but not 6 months (RD, 0.09; 95% CI, −0.02 to 0.20; 3 studies). | Low
MH-related quality of life | Greater mental health–related quality of life for patients in collaborative care intervention arms than usual care at 6 and 12 months using the mental component of the Medical Outcomes Study Short Form (WMD, 2.98; 95% CI, 1.41 to 4.56 at 12 months; 4 studies). | Moderate
MH care utilization | Greater use of any mental health services for collaborative care interventions than for usual care at 6 and/or 12 months (42% to 97% vs. 16% to 57% for intervention and control groups, respectively; based on 8studies). | Low
MH-related sick days | Not reported | Insufficient
MH-related employment stability | Not reported | Insufficient

a Results of the meta-analysis excluding the HITIDES data

Abbreviations: CI = confidence interval; HITIDES = HIV Implementation of Translating Initiatives for Depression; MH = mental health; mths = months; NA = not applicable; RD = risk difference; SMD = standardized mean difference; WMD = weighted mean difference.

### Key Question 2a Intermediate Chronic Medical Outcomes

For this question, we were interested in the effects of collaborative care interventions on intermediate outcomes for the specified chronic medical condition(s). For most chronic medical conditions of interest here, we found just one study (Table 20). We found multiple studies of people with diabetes and depression.

Table 20 Summary of results for collaborative care interventions compared with controls for people with depression and one or more chronic medical conditions: intermediate chronic medical outcomes

Outcome | Summary of Results | Strength of Evidence
Symptom improvement
Arthritis: pain | Insufficient evidence from 1 subgroup analysis to draw conclusions. | Insufficient
HIV: symptom severity | Insufficient evidence from 1 RCT to draw conclusions. | Insufficient
Response
Diabetes: HbA1c | Meta-analysis of 4 studies showed no between-group differences at 6 or 12 months. A single study69 showed no difference between groups at 18 and 24 months. | Moderate
Heart disease: ≥10 mmHg decrease in SBP | Insufficient evidence from 1 RCT to draw conclusions. | Insufficient
Adherence
Cancer: followed treatment | Insufficient evidence from 1 RCT to draw conclusions. | Insufficient
Diabetes: diet | Not calculated; no between-group difference at any time points in all studies examined. | Moderate
Diabetes: exercise | 3 of 3 trials found no difference between groups at 6 months; of these same trials, 2 of 3 found no difference at 12 months. | Low
Diabetes: medications | Insufficient evidence from 2 studies to draw conclusions. | Insufficient
HIV: medications | Insufficient evidence from 1 RCT to draw conclusions. | Insufficient
Satisfaction with care
Diabetes, heart disease, or both | Insufficient evidence from 1 RCT to draw conclusions. | Insufficient

Abbreviations: CI = confidence interval; mmHg = millimeters of mercury; OR = odds ratio; RCT = randomized controlled trial; SBP = systolic blood pressure; WMD = weighted mean difference.

HbA1c was reported as a measure of response in four studies of people with diabetes; baseline HbA1c ranged from 7.28 percent to 9.03 percent. Our meta-analyses found no significant differences between intervention and control groups (weighted mean difference [WMD], 0.13; 95% CI, −0.55 to 0.41 at 6 months; three studies; WMD, 0.24; 95% CI, −0.14 to 0.62 at 12 months; three studies). In the single study that measured it (Ell 2011), the finding of no difference between groups persisted at 18 and 24 months (moderate SOE). However, the only study to use HbA1c as a predefined outcome measure, the TEAMcare study,80 reported significant differences in HbA1c. The figures were as follows for intervention versus control groups: 8.14 versus 8.04 at baseline; 7.42 versus 7.87 at 6 months; and 7.33 versus 7.81 at 12 months (overall p<0.001). Ell and colleagues69 reported 18- and 24-month data on HbA1c, showing no difference between groups, with an overall mean difference at 24 months of 0.23 (95% CI, −0.34 to 0.81).

Three studies reported on adherence to recommended treatment.64, 77, 80 Patients in the collaborative care intervention were no more likely than controls to adhere to a generally healthy diet (moderate SOE), and they were no more likely to adhere to an exercise program in two of three studies64, 77, 80 (low SOE). For rates of adherence to an overall regimen (including oral hypoglycemics, lipid-lowering agents, and angiotensin-converting enzyme inhibitors), evidence was insufficient to draw conclusions. A summary of diabetes self-care based on a measure of overall self-reported adherence was reported by one study, and showed no difference between groups at 12,18, or 24 months.67, 69 They similarly showed no difference between groups in diabetic complications for these same time frames.

Data were insufficient to draw conclusions about treatment satisfaction with care for chronic medical conditions.

### Key Question 2b General Health Outcomes and Costs

General health outcomes of interest included condition-specific morbidity, mortality, health care utilization, and quality of life. All evidence was insufficient to draw conclusions other than for mortality and quality of life (Table 21).

Table 21 Strength of evidence for collaborative care interventions for people with depression and one or more chronic medical conditions: KQ 2b, general health outcomes and costs

Outcome | Summary of Results | Strength of Evidence
Condition-specific morbidity | Insufficient evidence from 1 RCT (post-CABG) and 1 subgroup analysis (arthritis) to draw conclusions. | Insufficient
Mortality | 8 studies reported no difference between groups, with few overall events; 6 months: RD, 0.00 (95% CI, −0.02 to 0.02); 12 months: RD, 0.00 (95% CI, −0.02 to 0.01). | Moderate
Health care utilization | Data were insufficient to draw conclusions about use of health care services. | Insufficient
Quality of life | Greater quality of life for those receiving collaborative care at 6 and 12 months, based on several different measures. | Moderate
Cost of intervention | Data were insufficient because of heterogeneity in the ways in which cost was reported. Using a crude estimate because of such heterogeneity, for the 6 trials that reported data, the average cost of the intervention per patient was $705.00. Individual studies measured other aspects of cost that are detailed in Appendix C, but were not amenable to pooling. | Insufficient

Abbreviations: CABG = coronary artery bypass graft; CI = confidence interval; RCT = randomized controlled trial; RD = risk difference.

All but one study72 reported on mortality and few deaths were reported overall. Most were in studies of people with cancer. Intervention and control patients did not differ in mortality at 6 months (risk difference [RD], 0.00; 95% CI, −0.02 to 0.02; seven studies) or 12 months (RD, 0.00; 95% CI, −0.02 to 0.01; seven studies) (moderate SOE). Patients receiving collaborative care interventions generally experienced greater quality of life than control patients at 6 and 12 months, based on several different measures from six studies (moderate SOE).

### Key Question 3 Harms

Very few data were reported on harms, leaving insufficient evidence to draw conclusions. Only the TEAMcare study, in patients with depression, diabetes, and/or heart disease,80 defined adverse events (AEs); the investigators reported higher rates of mild AEs (e.g., medication side effects) and of moderate AEs (e.g., falls) in the intervention arm. These could be attributed to increased rates of medication adjustment related to the collaborative care intervention. Additionally, patients in the intervention arm had more frequent contacts with the care manager and thus had more opportunities to report AEs, so findings might be the result of detection bias.

### Key Question 4 Characteristics of Service Interventions

All interventions were described as collaborative care interventions; we found no study with any other types of practice-based interventions that met our inclusion/exclusion criteria.

The summary finding was that collaborative care hinged on the role of care manager, whose training and expertise varied widely. A physician (11 of 12 were psychiatrists) supervised care; a form of stepped care, patient preferences for treatment, and self-management were central to most interventions. Table 17 (in the Results chapter presentation above for KQ 4) shows the detailed comparisons.

The TEAMcare study80 was the most original in its design. Its investigators had a goal not just of reducing depression, but also controlling risk factors for various diseases simultaneously using a nurse to support guideline-concordant care.

### Key Question 5 Characteristics of the Practice Setting

Given that characteristics of the practice setting often determine the feasibility of implementing interventions, we were interested in assessing similarities and differences. Eleven of 12 studies were conducted in the United States (1 of those in Puerto Rico); 1^74^ took place in the United Kingdom. Overall, practice setting characteristics (e.g., location, practice type and size, open/closed system, level of integration, payer mix and payer type, service mix, information technology) and system characteristics (e.g., financing of care and payment arrangements) were rarely reported. We categorized the system as open (no membership or eligibility required) in 6 trials 66–68, 72, 74, 79 and closed in 3 trials.38, 40, 73, 75–78, 80 Closed systems were generally self-contained; in this evidence base, they included Group Health Cooperative and the VA system, where an array of services was accessible to patients who were members of these organizations. This latter factor may be important for applicability because of the nature of collaborative care and its focus on coordination, which is arguably easier in a closed than in an open system of care.

## Findings in Relationship to What Is Already Known

Our findings reinforce the evidence for the effectiveness of collaborative care interventions for treating depression in primary care.37 Moreover, they add a level of detail that had previously not been systematically reviewed. We selected trials that required the diagnosis of one or more chronic medical conditions (rather than generic primary care samples), and we reported on both the depression and the chronic medical outcomes. This review also extended the parameters of primary care to include settings in which certain patients with chronic disease receive the majority of their care. We found that recipients of collaborative care had significantly greater improvement in depression outcomes as compared with patients receiving usual care, for people with arthritis, cancer, diabetes, heart disease, and HIV.

Although the relationship between depression and chronic disease is established,30, 94, 95 the extent to which successful treatment of depression improves chronic medical conditions remains unknown. Our review shows that investigators are beginning to examine these outcomes, particularly in diabetes, although largely as secondary outcomes and with negative or inconclusive data at present. We excluded some relevant studies because of short duration of followup96 or because the treatment occurred outside the purview of a primary care–like setting.97–99 However, our inability to answer the basic question posed by a primary care provider “Will treating my patient’s depression (with an evidence-based collaborative care program) improve their medical conditions?” was both surprising and disappointing.

One study in the review, TEAMcare,80 is an exception because it identified markers of disease risk for multiple conditions as primary outcomes. Using a guideline-based “treat-to-target” approach delivered by a medically trained nurse, these investigators targeted patients with poorly controlled diabetes, coronary artery disease, or both and coexisting depression; their aim was to reduce overall risk factors. This approach is a detour from the traditional model, in which the focus is on collaborative care of depression, presumably in the hope that treating depression will improve overall health. Perhaps partly because of the benefits of having an integrated health care system, TEAMcare recipients showed clear improvements not only in depression, but also in reducing HbA1c and systolic blood pressure to target goals.

### Implementation, Dissemination, and Role of Decisionmakers

Despite evidence for the use of collaborative depression care in primary care settings, and a recommendation from the President’s New Freedom Commission on Mental Health,100 uptake of such interventions has been poor. Although financial and system barriers have been identified,101 it is still unclear why decisionmakers have not advocated for the dissemination of collaborative depression care. One reason may be that in our current system, primary care providers have little incentive to find and treat mental health problems. Should a model of accountable care42 be adopted, in which one bundled payment must suffice for the breadth of necessary care, a focus on concomitant mental health conditions will align incentives in a way that gives priority to dissemination of proven programs. Once incentivized to keep people well, primary care providers may also find new motivation for gaining proficiency in mental health care.102 Inherent in any new model of payment will be the discussion of both absolute costs and the cost-effectiveness of such interventions—neither of which topics had comprehensive data or were a central focus of this report.

This review adds further evidence supporting the effectiveness of collaborative care interventions. We show that patients with multiple and specific medical conditions can achieve improvement in depression (moderate SOE), satisfaction with care (moderate SOE), and mental and physical quality of life (moderate SOE).

Stakeholders for improving the quality of primary care can apply the findings in this review from several perspectives. One way these data might be used and further disseminated is in measuring quality, for instance, to meet new standards for the Patient-Centered Medical Home.43

### Applicability

Our findings are generally applicable to primary care patients with depression and at least one chronic medical condition, but they may not apply to patients with multiple chronic conditions. The average age across studies was 59, an age group likely to have chronic disease. For that reason, we cannot speak directly to the relevance of these results to young adults with chronic disease. People of Hispanic origin (predominantly female)66–68 and male veterans73 were represented and appeared to respond similarly across outcomes, but there were too few data to analyze separately. Reported studies used clinically meaningful measures and had study durations (at least 6 months) that provided a real-world context.

Although these trials represented several settings, including primary care–like cancer and HIV clinics, they all had in common a care manager who directed the intervention. The intermediate mental health outcomes achieved might, therefore, apply only to settings that can accommodate and afford to provide such services. Although we did not attempt, as others have, to identify “key ingredients” of collaborative care such as training background of team members,41 our report suggests that the complexion of teams and their types of training may afford some flexibility.

### Limitations of the Comparative Effectiveness Review Process

Outlining the scope of this evidence review posed a challenge in regard to defining the interventions of interest. With input from our Key Informants and members of our Technical Expert Panel, we ultimately arrived at the term “practice-based” to differentiate interventions relative to this review from person-level interventions such as medications or stand-alone psychotherapies. We did not find the term practice-based in the literature, but we used other eligibility criteria and some known interventions to inform our searches. Even though we also added the terms “collaborative care,” “integrated care,” and “telemedicine” to guide our search, we may have missed relevant interventions that are not indexed in these categories. However, we included a general intervention term (see Appendix A) that should have identified studies that were not found using the more specific terms.

We also recognize that limiting the eligibility to trials of patients with clear medical diagnoses may have missed some potentially relevant work. One example is a recent RCT of a novel intervention for patients with anxiety conducted in the primary care setting;103 the trial did not require a coexisting medical condition.

We chose to exclude studies without comparison groups because of the potential risk of bias in such studies (especially the risk of selection bias and confounding). We recognize that studies without comparison groups can sometimes identify important information, but for the purposes of our questions we generally consider such studies to provide hypothesis-generating information, rather than valid evidence to answer our questions. The purpose of this review was not to uncover hypothesis-generating information, but rather to find evidence with sufficiently low risk of bias to provide more definitive answers to the KQs. The number of potential known confounders is substantial for the questions we addressed in this review (and there may always be additional unknown confounders). Thus, we believe that the risk of bias in studies without comparison groups is too high to provide reliable evidence to answer our KQs. Note, however, that important and innovative systems efforts in the fields of mental health and primary care104 may be overlooked using these methods.

### Limitations of the Evidence Base

Few relevant trials reported medical outcomes specifically. We also acknowledge significant heterogeneity among conditions (e.g., cancer is different from diabetes). Only 1 of our 12 studies80 was specifically designed to answer KQ 2a about intermediate medical outcomes. The remainder aimed to look at mental health outcomes in patients with different medical conditions.

We had no head-to-head trials in our report; this meant that we could make comparisons only with usual or enhanced usual care. We had only one study from outside the United States, highlighting the lack of similar literature from other countries. Although we characterized the components of the interventions, we could not evaluate quantitatively the determinants of effectiveness (i.e., “active ingredients”41). This was not the intention of the review but highlights the difficulty in synthesizing data on complex interventions.

Also, note that studies did not necessarily screen for mental health comorbidities (such as substance abuse), which may have negatively influenced medical outcomes, particularly related to self-care activities. A completely unexplored area is personality disorders, which are pervasive by nature and can prove a barrier to achieving therapeutic goals.105

## Research Gaps

### Depression Treatment and Outcomes of Chronic Disease

Depression can negatively affect general medical illness, but we do not know whether the effective treatment of depression in the primary care setting can alter the course of chronic disease. Is it that treating depression isn’t enough to improve medical outcomes, or that we need more innovative interventions that do not just focus on depression? The TEAMcare approach offers an example, in which treatment goals included targets for all relevant diseases and individualized approaches to reach these targets. Designing, implementing, and sustaining such approaches will not be without considerable challenge, and studies will require larger sample sizes, longer time frames, and, optimally, higher levels of joint funding from multiple institutes more used to focusing on one disease.

Our report identified outcomes mostly for single medical conditions, which does not necessarily reflect real-world primary care patients that may have multiple comorbidities. Trials involving other medical conditions not represented here, such as lung disease or pain syndromes, could be informative as an incremental approach, but perhaps what the field needs most to understand is what models of care work best for patients with common clusters of disease in primary care. One possible cluster could be diabetes, hypertension, and obesity, concomitant with depression; this group may be particularly salient given the probable role of vascular disease in late-onset depression.106, 107 More generally, the bidirectional aspect of depression and medical illness needs further exploration. For example, investigators could usefully explore whether effectively improving vascular risk factors reduces depression.

### Other Mental Health Conditions

This report did not identify relevant evidence for practice-based interventions targeting common disorders known to be prevalent and problematic in primary care, including anxiety spectrum, psychotic disorders, substance disorders, and cognitive disorders. It is unclear whether interventions for each of these needs to be studied in isolation with related medical conditions, or perhaps a more broad-based approach might make sense. Instead of the current reductionist approach of screening for one mental health condition at a time, it might be possible to screen broadly108 and develop and tailor an intervention accordingly, with a core set of features that could be adapted as necessary. Psychotic disorders such as schizophrenia deserve special attention owing to the significant early mortality seen in this group,109 although many patients with such disorders do not come to primary care. Reverse “co-location,”110 in which a primary care doctor comes to a mental health setting, may be a preferred arrangement and should be explored. Such studies should focus on prevention and early intervention for medical conditions, to help discern whether downstream morbidity can be avoided.

### Head-to-Head Trials

It is noteworthy that we identified no studies of co-location or integrated care in this review, and disappointing that we found no-head-head trials of various approaches. Head-to-head trials of practice-based interventions should be considered; these might include collaborative care versus mental health co-location, or another model of integrated care versus collaborative care. Given the desire to find the active ingredients of practice-based care,41 we should test variations of existing efficacious models. Certain components of the collaborative care model may be more salient than others, and future studies that explicitly compare intervention components within the collaborative care model may help address this issue. For example, head-to-head comparisons of telephone-based versus face-to-face approaches might be useful. Examining session frequency and/or study intensity (i.e., frequency plus duration) as a predictor of outcome within these two approaches may also prove fruitful.

Exploring the extent to which mental health and physical health outcomes are related to the intervention provider’s training is another important issue; that could entail determining whether, for instance, outcomes improve by having a depression care specialist deliver the intervention rather than a provider not trained in mental health.

Answering some of these basic design questions in ways that facilitate comparisons with true interventions, and not simply usual care, will eventually facilitate translation and implementation of these approaches on a broader scale.

## Conclusions

In primary care patients with depression and one or more specific chronic medical condition, collaborative care interventions achieved improvement in depression symptoms, response, remission, and depression-free days (moderate SOE); satisfaction with care (moderate SOE); and mental and physical quality of life (moderate SOE). These improvements were consistent across different common chronic medical conditions. Patients with diabetes receiving collaborative care had no difference in HbA1c (low SOE). To determine the relative benefit of implementing collaborative care programs for depression (or other mental health conditions) on overall health, we need studies designed to measure the effectiveness of practice-based interventions on medical outcomes. Future investigations should compare variations of such interventions in head-to-head trials to discern best models of care. They should also move from addressing single medical conditions to common clusters of disease and, similarly, broaden the net for mental health conditions beyond depression.