# Strength of Evidence

Table F-1 Strength of Evidence for collaborative care interventions for people with depression and one or more chronic medical conditions: KQ1a

Outcome | Number of Studies; Subjects | Risk of bias; Design; Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI)^a^ | Strength of Evidence
Symptom improvement | 11; 3,868 | Low; 9 RCTs, 2 subgroup analyses from an RCT; 3 good, 8 fair | Consistent | Indirect | Precise | 6 mths: SMD = 0.45 (0.29 to 0.61; 7 studies) 12 mths: SMD = 0.47 (0.29 to 0.65; 6 studies) 24 mths: WMD=0.18 (0.10 to 0.16; 4 studies) | Moderate
Depression- free days | 5; 1,624 | Low; 3 RCTs, 2 subgroup analyses from an RCT; 1 good, 4 fair | Consistent | Indirect | Imprecise | Not calculated; intervention always favored | Moderate
Response (at least 50% reduction) | 10; 3,430 | Low; 8 RCTs, 2 subgroup analyses from an RCT; 3 good, 7 fair | Consistent | Indirect | Precise | 6 mths: RD = 0.20 (0.14 to 0.26; 9 studies) 12 mths: RD = 0.17 (0.12 to 0.23; 7 studies) 18 mths: RD=0.12 (0.02 to 0.22; 3 studies) | Moderate
Remission | 5; 2,351 | Low 3 RCTs, 2 subgroup analyses from an RCT; 1 good, 4 fair | Consistent | Indirect | Precise | 6 mths: RD = 0.12 (0.06 to 0.18; 3 studies) 12 mths: RD = 0.08 (0.02 to 0.14) 18 mths: RD=0.08 (0.01 to 0.14; 3 studies) 24 mths: RD=0.05 (−0.02 to 0.11; 3 studies) | Moderate
Recurrence | 1; 472 | Low 1 RCT; 1 Fair | Unknown (single study) | Indirect | Unknown (single study) | No significant difference between groups | Insufficient
Treatment adherence | 2; 605 | Low; 2 RCTs; 1 good, 1 fair | Inconsistent | Indirect | Imprecise | Mixed results^b^ | Insufficient
Treatment satisfaction | 4; 1,145^c^ | Low; 3 RCTs, 1 subgroup analysis from an RCT; 4 fair | Consistent | Indirect | Precise | 6 mths: RD = 0.21 (0.11 to 0.30; 4 studies) 12 mths: RD=0.14 (0.06 to 0.21; 3 studies) | Moderate

a All of the effect sizes reported in this Table favor collaborative care over controls. Effect sizes and confidence intervals are rounded to the nearest hundredth.

b One trial reported significantly greater adherence to antidepressants in the intervention arm at six and 12 months; the other reported no difference between groups at six and 12 months.

c Two additional trials reported treatment satisfaction for the intervention arm but not the usual care arm.

Abbreviations: CI = confidence interval; mths = months; NA = not applicable; RCT = randomized controlled trial; RD = risk difference; SMD = standardized mean difference; WMD = weighted mean difference

Table F-2 Strength of Evidence for collaborative care interventions for people with depression and one or more chronic medical conditions: KQ 1b

Outcome | Number of Studies; Subjects | Risk of bias; Design; Quality | Consistency | Directness | Precision | Summary effect Size (95% CI) | Strength of Evidence
Suicide | 2; 255 | Low; 1 RCT; 1 fair | Inconsistent | Direct | Imprecise | Not calculated^a^ | Insufficient
Use of anti-depressants | 10; 3,813 | Low; 7 RCTs, 3 subgroup analyses from an RCT; 2 good, 8 fair | Inconsistent | Direct | Imprecise | 6 mths: RD = 0.09 (−0.02 to 0.20; 3 studies) 12 mths: RD = 0.23 (0.15 to 0.30; 5 studies)^b^ | Low
MH-related quality of life | 5; 1,854 | Low; 4 RCTs, 1 subgroup analysis from an RCT; 2 good; 3 fair | Consistent | Direct | Imprecise | 6 mths: SMD = 0.31 (0.16 to 0.45; 4 studies) 12 mths: WMD = 2.98 (1.41 to 4.56; 4 studies) | Moderate
MH care utilization | 8; 2940 | Low; 6 RCTs, 2 subgroup analyses from an RCT; 2 good; 6 fair | Consistent | Direct | Imprecise | Not calculated | Low
MH-related sick days | 0;0 | N/A | N/A | N/A | N/A | N/A | Insufficient
MH-related employment stability | 0;0 | N/A | N/A | N/A | N/A | N/A | Insufficient

Note: IMPACT trial is divided by condition (arthritis, cancer, diabetes) and each condition is considered a “study” in this table.

a One study reported one suicide in the usual care group; another reported that they were unaware of any attempted or completed suicides in either group.

b Results of the meta-analysis excluding the HITIDES data

Abbreviations: CI = confidence interval; MH = mental health; mths = months; N/A = not applicable; RCT = randomized controlled trial; RD = risk difference; SMD = standardized mean difference; WMD = weighted mean difference

Table F-3 Strength of Evidence for collaborative care interventions for people with depression and one or more chronic medical conditions: KQ 2a

Outcome | Number of Studies; Subjects | Risk of bias; Design; Quality | Consistency | Directness | Precision | Summary effect size (95% CI) | Strength of Evidence
Symptom improvement
Arthritis: pain | 1; 1,001 | Medium; 1 subgroup analysis of an RCT; 1 Fair | N/A | Indirect | Imprecise | Change in pain score (0–10 scale, higher = worse) 6 mths: −0.21( −0.55 to 0.13) 12 mths: −0.53 (−0.92 to −0.14) | Insufficient
HIV: symptom severity | 1; 276 | Low; 1 RCT; 1 Good | N/A | Indirect | Imprecise | 6 mths: Beta = −0.62 (−1.2 to −0.08) 12 mths: Beta = −0.09 (−1.58 to 1.40) | Insufficient
Response
Diabetes: HbA1c | 4; 1,347^a^ | Medium, 3 RCTs, 1 subgroup analysis of an RCT; 4 Fair | Inconsistent | Indirect | Imprecise | 6 mths: WMD = 0.13 (−0.55 to 0.41; 3 studies) 12 mths: WMD = 0.24 (−0.14 to 0.62; 3 studies) | Low
Heart disease: ≥ 10 mg Hg decrease in SBP | 1; 214^a^ | Medium; 1 RCT; 1 Fair | N/A | Indirect | Precise | At 12 mths, 41 intervention subjects vs. 25 controls achieved response (p=0.016) | Insufficient
Adherence
Cancer: followed treatment | 1; 55 | Medium; 1 RCT; 1 Fair | N/A | Indirect | Precise | 12 mths: OR = 3.51 (0.82 to 15.03) | Insufficient
Diabetes: diet | 3; 960^a^ | Medium; 2 RCTs, 1 subgroup analysis from an RCT; 3 Fair | Consistent | Indirect | Precise | Not calculated; no between group difference at any time points in all studies examined | Moderate
Diabetes: exercise | 3; 960^a^ | Medium; 2 RCTs, 1 subgroup analysis from an RCT; 3 Fair | Inconsistent | Indirect | Imprecise | Not calculated; 2 studies favored intervention, 1 study found no difference | Low
Diabetes: medications | 2; 746 | Medium; 1 RCT, 1 subgroup analysis from an RCT; 2 Fair | Inconsistent | Indirect | Imprecise | Not calculated; 1 study found no difference in adherence to lipid-lowering agents or ACE inhibitors but a higher rate of non-adherence to oral hypoglycemics in the intervention group at 12 mths; the other found no difference in general medication adherence at any time point. | Insufficient
HIV: medications | 1; 276 | Low; 1 RCT; 1 Good | N/A | Indirect | Imprecise | Not calculated; no between-group differences at 6 and 12 months | Insufficient
Satisfaction with care
Diabetes, heart disease or both | 1; 214 | Medium; 1 RCT; 1 Fair | N/A | Indirect | Imprecise | Mean improvement from baseline was 16% in the intervention vs. 2% in control (p<0.001) | Insufficient

Note: IMPACT trial is divided by condition (arthritis, cancer, diabetes) and each condition is considered a “study” in this table.

a Total number includes patients from the TEAMcare study who had diabetes, heart disease, or both.

Abbreviations: CI = confidence interval; N/A = not applicable; OR = odds ratio; RCT = randomized controlled trial; RD = risk difference; SMD = standardized mean difference; WMD = weighted mean difference

Table F-4 Strength of Evidence for collaborative care interventions for people with depression and one or more chronic medical conditions: KQ 2b, general health outcomes and costs

Outcome | Number of Studies; Subjects | Risk of bias; Design; Quality | Consistency | Directness | Precision | Summary effect Size (95% CI) | Strength of Evidence
Condition-specific morbidity | 2; 1,303 | Medium; 1 RCT, 1 subgroup analysis from an RCT; 1 Good, 1 Fair | Inconsistent | Direct | Imprecise | Not calculated | Insufficient
Mortality | 11; 3,868 | Low; 8 RCTs, 3 subgroup analyses from an RCT; 2 Good; 9 Fair | Consistent | Direct | Precise | 6 mths: RD = 0.00 (−0.02 to 0.02; 7 studies) 12 mths: RD = 0.00 (0.02 to 0.01; 7 studies) | Moderate
Health care utilization | 2; 516 | Low; 2 RCTs; 1 Good; 1 Fair | Inconsistent | Direct | Imprecise | Not calculated | Insufficient
Quality of life | 6; 2,768 | Medium; 3 RCTs, 3 subgroup analyses from an RCT; 1 Good, 5 Fair | Consistent | Direct | Imprecise | Not calculated;^a^ Intervention favored across measures. | Moderate
Cost of intervention | 6; 2,019 | High; 5 RCT, 1 subgroup analysis from an RCT; 6 Fair | N/A | Direct | N/A | $705 per patient^b^ | Insufficient

Note: IMPACT trial is divided by condition (arthritis, cancer, diabetes) and each condition is considered a “study” in this table.

a Not calculated because of highly variable measures used by the studies to measure quality of life.

b Crude estimate of average cost of intervention.

Abbreviations: CI = confidence interval; mths = months; RD = risk difference; WMD = weighted mean difference