# Meta-Analyses

Depression Symptom Improvement at Months

Note: All trials measured depressive symptoms with the Hopkins Symptom Checklist (HSCL).

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
12.101 | 4 | 0.017 | 66.944

Depression Symptom Improvement at 6 Months - WMD

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | WMD | Lower Limit | Upper Limit | p-Value
| SMaRT Oncology 1 (Strong, 2008) | Cancer | 0.334 | 0.203 | 0.464 | 0.000
| IMPACT (Fann, 2009) | Cancer | 0.392 | 0.219 | 0.566 | 0.000
| Pathways (Katon, 2004) | Diabetes | 0.428 | 0.308 | 0.548 | 0.000
| IMPACT (Williams, 2004) | Diabetes | 0.393 | 0.206 | 0.579 | 0.000
| TEAMcare (Katon, 2010) | Diabetes +/− Heart Disease | 0.346 | 0.194 | 0.498 | 0.000
Random | | | 0.378 | 0.241 | 0.515 | 0.000

Depression Symptom Improvement at 6 Months

Notes: The ADAPt-C trial measured depressive symptoms with the Patient Health Questionnaire (PHQ-9); the Bypassing the Blues trial used the Hamilton Rating Scale for depression (HAM-D); all other trials used the Hopkins Symptom Checklist (HSCL). The Bypassing the Blues data are from the 8-month endpoint.

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
16.912 | 6 | 0.010 | 64.522

Depression Symptom Improvement at 6 Months - SMD

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | SMD | Lower Limit | Upper Limit | p-Value
| ADAPt-C (Ell, 2008) | Cancer | 0.494 | 0.338 | 0.651 | 0.000
| SMaRT Oncology 1 (Strong, 2008) | Cancer | 0.404 | 0.256 | 0.551 | 0.000
| IMPACT (Fann, 2009) | Cancer | 0.452 | 0.272 | 0.632 | 0.000
| Pathways (Katon, 2004) | Diabetes | 0.491 | 0.328 | 0.655 | 0.000
| IMPACT (Williams, 2004) | Diabetes | 0.449 | 0.259 | 0.638 | 0.000
| TEAMcare (Katon, 2010) | Diabetes +/− Heart Disease | 0.408 | 0.256 | 0.561 | 0.000
| Bypassing the Blues (Rollman, 2009) | Heart Disease | 0.457 | 0.273 | 0.640 | 0.000
Random | | | 0.450 | 0.295 | 0.605 | 0.000

Depression Symptom Improvement at 12 Months

Note: All trials measured depressive symptoms with the Hopkins Symptom Checklist (HSCL).

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
4.044 | 4 | 0.400 | 1.094

Depression Symptom Improvement at 12 Months - WMD

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | WMD | Lower Limit | Upper Limit | p-Value
| SMaRT Oncology 1 (Strong, 2008) | Cancer | 0.374 | 0.281 | 0.466 | 0.000
| IMPACT (Fann, 2009) | Cancer | 0.373 | 0.274 | 0.472 | 0.000
| Pathways (Katon, 2004) | Diabetes | 0.416 | 0.333 | 0.500 | 0.000
| IMPACT (Williams, 2004) | Diabetes | 0.360 | 0.262 | 0.457 | 0.000
| TEAMcare (Katon, 2010) | Diabetes +/− Heart Disease | 0.368 | 0.265 | 0.471 | 0.000
Random | | | 0.381 | 0.304 | 0.458 | 0.000

Depression Symptom Improvement at 12 Months

Note: The ADAPt-C trial measured depressive symptoms with the Patient Health Questionnaire (PHQ-9); all other trials used the Hopkins Symptom Checklist (HSCL).

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
15.898 | 5 | 0.007 | 68.549

Depression Symptom Improvement at 12 Months - SMD

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | SMD | Lower Limit | Upper Limit | p-Value
| ADAPt-C (Ell, 2008) | Cancer | 0.523 | 0.345 | 0.702 | 0.000
| SMaRT Oncology 1 (Strong, 2008) | Cancer | 0.468 | 0.251 | 0.685 | 0.000
| IMPACT (Fann, 2009) | Cancer | 0.453 | 0.238 | 0.667 | 0.000
| Pathways (Katon, 2004) | Diabetes | 0.516 | 0.323 | 0.710 | 0.000
| IMPACT (Williams, 2004) | Diabetes | 0.435 | 0.225 | 0.645 | 0.000
| TEAMcare (Katon, 2010) | Diabetes +/− Heart Disease | 0.411 | 0.236 | 0.585 | 0.000
Random | | | 0.467 | 0.286 | 0.649 | 0.000

Depression Symptom Improvement at 24 Months

Note: All trials measured depressive symptoms with the Hopkins Symptom Checklist (HSCL).

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
1.820 | 2 | 0.403 | 0.000

Depression Symptom Improvement at 24 Months - WMD

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-value
Model | Study Name | Chronic Medical Condition | WMD | Lower Limit | Upper Limit | p-value
| IMPACT (Fann, 2009) | Cancer | 0.166 | 0.069 | 0.264 | 0.001
| MDDP (Ell, 2010) | Diabetes | 0.159 | 0.042 | 0.276 | 0.008
| Pathways (Katon, 2004) | Diabetes | 0.229 | 0.120 | 0.338 | 0.000
Random | | | 0.179 | 0.099 | 0.259 | 0.000

Reduction (at least 50%) in Mental Health Score at 6 Months

Notes: The ADAPt-C and MDDP (Dwight-Johnson, 2005) trials measured depressive symptoms with the Patient Health Questionnaire (PHQ-9); the Bypassing the Blues trial used the Hamilton Rating Scale for depression (HAM-D); all other trials used the Hopkins Symptom Checklist (HSCL). The Bypassing the Blues and MDDP (Dwight-Johnson, 2005) data are from 8-month endpoints.

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
17.644 | 8 | 0.024 | 54.659

Reduction (at least 50%) in Mental Health Score at 6 Months

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | RD | Lower Limit | Upper Limit | p-Value
| ADAPt-C (Ell, 2008) | Cancer | 0.211 | 0.151 | 0.270 | 0.000
| IMPACT (Fann, 2009) | Cancer | 0.194 | 0.128 | 0.261 | 0.000
| MDDP (Dwight-Johnson, 2005) | Diabetes | 0.193 | 0.129 | 0.256 | 0.000
| MDDP (Ell, 2010) | Diabetes | 0.195 | 0.127 | 0.263 | 0.000
| Pathways (Katon, 2004) | Diabetes | 0.211 | 0.152 | 0.271 | 0.000
| TEAMcare (Katon, 2010) | Diabetes +/− Heart Disease | 0.173 | 0.122 | 0.223 | 0.000
| Bypassing the Blues (Rollman, 2009) | Heart Disease | 0.195 | 0.127 | 0.264 | 0.000
| HITIDES (Pyne, 2011) | HIV | 0.202 | 0.133 | 0.270 | 0.000
| Vera, 2010 | Multiple Conditions | 0.185 | 0.123 | 0.247 | 0.000
Random | | | 0.195 | 0.136 | 0.255 | 0.000

Reduction (at least 50%) in Mental Health Score at 6 Months

Sensitivity Analysis: Removing TEAMcare (Katon, 2010)

Measures of Heterogeneity

Q-value | df (Q) | p-Value | I-squared
10.111 | 7 | 0.182 | 30.771

Notes: The ADAPt-C and MDDP (Dwight-Johnson, 2005) trials measured depressive symptoms with the Patient Health Questionnaire (PHQ-9); the Bypassing the Blues trial used the Hamilton Rating Scale for depression (HAM-D); all other trials used the Hopkins Symptom Checklist (HSCL). The Bypassing the Blues and MDDP (Dwight-Johnson, 2005) data are from 8-month endpoints.

Reduction (at least 50%) in Mental Health Score at 6 Months - Sensitivity Analysis Removing TEAMcare (Katon, 2010)

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | RD | Lower Limit | Upper Limit | p-Value
| ADAPt-C (Ell, 2008) | Cancer | 0.186 | 0.137 | 0.235 | 0.000
| IMPACT (Fann, 2009) | Cancer | 0.169 | 0.113 | 0.225 | 0.000
| MDDP (Dwight-Johnson, 2005) | Diabetes | 0.169 | 0.116 | 0.223 | 0.000
| MDDP (Ell, 2010) | Diabetes | 0.168 | 0.111 | 0.226 | 0.000
| Pathways (Katon, 2004) | Diabetes | 0.188 | 0.139 | 0.237 | 0.000
| Bypassing the Blues (Rollman, 2009) | Heart Disease | 0.169 | 0.111 | 0.227 | 0.000
| HITIDES (Pyne, 2011) | HIV | 0.177 | 0.117 | 0.236 | 0.000
| Vera, 2010 | Multiple Conditions | 0.157 | 0.110 | 0.204 | 0.000
Random | | | 0.173 | 0.122 | 0.223 | 0.000

Reduction (at least 50%) in Mental Health Score at 12 Months

Note: The ADAPt-C trial measured depressive symptoms with the Patient Health Questionnaire (PHQ-9); all other trials used the Hopkins Symptom Checklist (HSCL).

Measures of Heterogeneity

Q-Value | Df (Q) | p-Value | I-Squared
12.232 | 6 | 0.057 | 50.947

Reduction (at least 50%) in Mental Health Score at 12 Months

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | RD | Lower limit | Upper limit | p-Value
| IMPACT (Lin, 2003) | Arthritis | 0.155 | 0.095 | 0.216 | 0.000
| ADAPt-C (Ell, 2008) | Cancer | 0.179 | 0.115 | 0.242 | 0.000
| IMPACT (Fann, 2009) | Cancer | 0.171 | 0.105 | 0.236 | 0.000
| MDDP (Ell, 2010) | Diabetes | 0.169 | 0.102 | 0.235 | 0.000
| Pathways (Katon, 2004) | Diabetes | 0.189 | 0.132 | 0.245 | 0.000
| TEAMcare (Katon, 2010) | Diabetes +/− Heart Disease | 0.159 | 0.102 | 0.217 | 0.000
| HITIDES (Pyne, 2011) | HIV | 0.189 | 0.134 | 0.243 | 0.000
Random | | | 0.173 | 0.116 | 0.230 | 0.000

Reduction (at least 50%) in Mental Health Score at 12 Months

Sensitivity Analysis: Removing TEAMcare (Katon, 2010)

Note: The ADAPt-C trial measured depressive symptoms with the Patient Health Questionnaire (PHQ-9); all other trials used the Hopkins Symptom Checklist (HSCL).

Measures of Heterogeneity

Q-value | df (Q) | p-Value | I-squared
9.742 | 5 | 0.083 | 48.677

Reduction (at least 50%) in Mental Health Score at 12 Months - Sensitivity Analysis Removing TEAMcare (Katon, 2010)

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | RD | Lower Limit | Upper Limit | p-Value
| IMPACT (Lin, 2003) | Arthritis | 0.132 | 0.081 | 0.184 | 0.000
| ADAPt-C (Ell, 2008) | Cancer | 0.162 | 0.096 | 0.229 | 0.000
| IMPACT (Fann, 2009) | Cancer | 0.153 | 0.085 | 0.222 | 0.000
| MDDP (Ell, 2010) | Diabetes | 0.151 | 0.082 | 0.220 | 0.000
| Pathways (Katon, 2004) | Diabetes | 0.176 | 0.117 | 0.234 | 0.000
| HITIDES (Pyne, 2011) | HIV | 0.176 | 0.121 | 0.232 | 0.000
Random | | | 0.159 | 0.102 | 0.217 | 0.000

Reduction (at least 50%) in Mental Health Score at 18 Months

Notes: The ADAPt-C and MDDP (Dwight-Johnson, 2005) trials measured depressive symptoms with the Patient Health Questionnaire (PHQ-9); the IMPACT (Fann, 2009) trial used the Hopkins Symptom Checklist (HSCL).

Measures of Heterogeneity

Q-value | df (Q) | p-Value | I-squared
4.302 | 2 | 0.116 | 53.509

Reduction (at least 50%) in Mental Health Score at 18 Months - RD

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | RD | Lower Limit | Upper Limit | p-Value
| IMPACT (Fann, 2009) | Cancer | 0.163 | 0.080 | 0.247 | 0.000
| MDDP (Ell, 2010) | Diabetes | 0.076 | −0.021 | 0.173 | 0.123
| Pathways (Katon, 2004) | Diabetes | 0.116 | −0.062 | 0.293 | 0.201
Random | | | 0.118 | 0.017 | 0.219 | 0.022

Remission of Depression at 6 Months

Note: All included studies defined remission as SCL-20 < 0.5.

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
0.860 | 2 | 0.650 | 0.000

Remission of Depression at 6 Months

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | RD | Lower Limit | Upper Limit | p-Value
| IMPACT (Fann, 2009) | Cancer | 0.107 | 0.037 | 0.176 | 0.003
| MDDP (Ell, 2010) | Diabetes | 0.128 | 0.056 | 0.199 | 0.000
| HITIDES (Pyne, 2011) | HIV | 0.139 | 0.062 | 0.216 | 0.000
Random | | | 0.123 | 0.064 | 0.183 | 0.000

Remission of Depression at 12 Months

Note: All included studies defined remission as SCL-20 < 0.5.

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
1.218 | 2 | 0.544 | 0.000

Remission of Depression at 12 Months

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | RD | Lower Limit | Upper Limit | p-Value
| IMPACT (Fann, 2009) | Cancer | 0.053 | −0.022 | 0.127 | 0.164
| MDDP (Ell, 2010) | Diabetes | 0.090 | 0.019 | 0.161 | 0.013
| HITIDES (Pyne, 2011) | HIV | 0.086 | 0.007 | 0.164 | 0.032
Random | | | 0.077 | 0.016 | 0.137 | 0.013

Remission of Depression at 18 Months

Notes: The ADAPt-C and MDDP (Dwight-Johnson, 2005) trials measured depressive symptoms with the Patient Health Questionnaire (PHQ-9); the IMPACT (Fann, 2009) trial used the Hopkins Symptom Checklist (HSCL).

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
0.761 | 2 | 0.683 | 0.000

Remission of Depression at 18 Months - RD

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | RD | Lower Limit | Upper Limit | p-Value
| ADAPt-C (Ell, 2008) | Cancer | 0.077 | 0.006 | 0.149 | 0.034
| IMPACT (Fann, 2009) | Cancer | 0.053 | −0.029 | 0.134 | 0.205
| MDDP (Ell, 2010) | Diabetes | 0.090 | 0.016 | 0.164 | 0.017
Random | | | 0.075 | 0.013 | 0.136 | 0.017

Remission of Depression at 24 Months

Notes: The ADAPt-C and MDDP (Dwight-Johnson, 2005) trials measured depressive symptoms with the Patient Health Questionnaire (PHQ-9); the IMPACT (Fann, 2009) trial used the Hopkins Symptom Checklist (HSCL).

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
2.783 | 2 | 0.249 | 28.139

Remission of Depression at 24 Months – RD

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | RD | Lower Limit | Upper Limit | p-Value
| ADAPt-C (Ell, 2008) | Cancer | 0.052 | −0.058 | 0.163 | 0.351
| IMPACT (Fann, 2009) | Cancer | 0.009 | −0.066 | 0.083 | 0.821
| MDDP (Ell, 2010) | Diabetes | 0.068 | −0.011 | 0.148 | 0.091
Random | | | 0.045 | −0.023 | 0.113 | 0.191

Mental Health Treatment Satisfaction at 12 Months

Note: Treatment satisfaction was measured as follows:

MDDP: care was rated “satisfied” to “very satisfied”

Pathways: care was rated “moderately satisfied” to “very satisfied”

TEAMcare: care was rated “very satisfied” to “extremely satisfied”

IMPACT: care was rated “good” or “excellent”

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
9.878 | 3 | 0.020 | 69.629

Mental Health Treatment Satisfaction at 12 Months

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | RD | Lower Limit | Upper Limit | p-Value
| IMPACT (Fann, 2009) | Cancer | 0.213 | 0.080 | 0.346 | 0.002
| MDDP (Ell, 2010) | Diabetes | 0.239 | 0.138 | 0.340 | 0.000
| Pathways (Katon, 2004) | Diabetes | 0.214 | 0.084 | 0.343 | 0.001
| TEAMcare (Katon, 2010) | Diabetes +/− Heart Disease | 0.157 | 0.101 | 0.214 | 0.000
Random | | | 0.205 | 0.112 | 0.299 | 0.000

Mental Health Treatment Satisfaction at 24 Months

Note: Treatment satisfaction was measured as follows: ADAPt-C and MDDP: emotional care was rated “satisfied” to “very satisfied;” IMPACT: depression care was rated “good” or “excellent.”

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
2.843 | 2 | 0.241 | 29.648

Mental Health Treatment Satisfaction at 24 Months – RD

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | RD | Lower Limit | Upper Limit | p-Value
| ADAPt-C (Ell, 2008) | Cancer | 0.133 | −0.005 | 0.270 | 0.059
| IMPACT (Fann, 2009) | Cancer | 0.160 | 0.094 | 0.227 | 0.000
| MDDP (Ell, 2010) | Diabetes | 0.107 | 0.033 | 0.182 | 0.005
Random | | | 0.137 | 0.065 | 0.209 | 0.000

Mental Health Status at 6 Months

Notes: Mental health status was measured with the 12-Item Short Form Survey from the RAND Medical Outcomes Study (SF-12) for all trials.

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
5.199 | 2 | 0.074 | 61.531

Mental Health Status at 6 Months - WMD

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | WMD | Lower Limit | Upper Limit | p-Value
| ADAPt-C (Ell, 2008) | Cancer | 4.041 | 0.275 | 7.807 | 0.035
| MDDP (Ell, 2010) | Diabetes | 2.486 | 0.714 | 4.258 | 0.006
| HITIDES (Pyne, 2011) | HIV | 4.273 | 1.236 | 7.311 | 0.006
Random | | | 3.619 | 1.303 | 5.935 | 0.002

Mental Health Status at 6 Months

Notes: Mental health status was measured with the 12-Item Short Form Survey from the RAND Medical Outcomes Study (SF-12) for all trials except Bypassing the Blues, which used the SF-36. The Bypassing the Blues data are from the 8-month endpoint.

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
4.638 | 3 | 0.200 | 35.313

Mental Health Status at 6 Months - SMD

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | SMD | Lower Limit | Upper Limit | p-Value
| ADAPt-C (Ell, 2008) | Cancer | 0.319 | 0.115 | 0.522 | 0.002
| MDDP (Ell, 2010) | Diabetes | 0.240 | 0.106 | 0.373 | 0.000
| Bypassing the Blues (Rollman, 2009) | Heart Disease | 0.322 | 0.123 | 0.522 | 0.002
| HITIDES (Pyne, 2011) | HIV | 0.350 | 0.190 | 0.510 | 0.000
Random | | | 0.308 | 0.165 | 0.452 | 0.000

Mental Health Status at 12 Months

Note: Mental health status was measured with the 12-Item Short Form Survey from the RAND Medical Outcomes Study (SF-12) for all trials.

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
5.152 | 3 | 0.161 | 41.772

Mental Health Status at 12 Months

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | WMD | Lower Limit | Upper Limit | p-Value
| ADAPt-C (Ell, 2008) | Cancer | 3.261 | 1.088 | 5.433 | 0.003
| MDDP (Ell, 2010) | Diabetes | 2.272 | 1.005 | 3.538 | 0.000
| IMPACT (Williams, 2004) | Diabetes | 3.249 | 0.848 | 5.650 | 0.008
| HITIDES (Pyne, 2011) | HIV | 3.250 | 1.342 | 5.159 | 0.001
Random | | | 2.983 | 1.413 | 4.553 | 0.000

Prescription Antidepressant Use at 6 Months

Note: The Bypassing the Blues data are from the 8-month endpoint.

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
4.368 | 2 | 0.113 | 54.216

Prescription Antidepressant Use at 6 Months

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | RD | Lower Limit | Upper Limit | p-Value
| IMPACT (Fann, 2009) | Cancer | 0.059 | −0.079 | 0.197 | 0.402
| Bypassing the Blues (Rollman, 2009) | Heart Disease | 0.071 | −0.096 | 0.239 | 0.404
| HITIDES (Pyne, 2011) | HIV | 0.143 | 0.055 | 0.232 | 0.002
Random | | | 0.090 | −0.015 | 0.195 | 0.092

Prescription Antidepressant Use at 12 Months

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
18.867 | 5 | 0.002 | 73.498

Prescription Antidepressant Use at 12 Months

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | RD | Lower Limit | Upper Limit | p-Value
| IMPACT (Lin, 2003) | Arthritis | 0.203 | 0.082 | 0.324 | 0.001
| ADAPt-C (Ell, 2008) | Cancer | 0.182 | 0.079 | 0.285 | 0.001
| IMPACT (Fann, 2009) | Cancer | 0.185 | 0.080 | 0.290 | 0.001
| MDDP (Ell, 2010) | Diabetes | 0.160 | 0.073 | 0.247 | 0.000
| IMPACT (Williams, 2004) | Diabetes | 0.178 | 0.073 | 0.283 | 0.001
| HITIDES (Pyne, 2011) | HIV | 0.225 | 0.148 | 0.301 | 0.000
Random | | | 0.189 | 0.099 | 0.280 | 0.000

Prescription Antidepressant Use at 12 Months

Sensitivity Analysis: Removing HITIDES (Pyne, 2011)

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
8.936 | 4 | 0.063 | 55.236

Prescription Antidepressant Use at 12 Months – Sensitivity Analysis

Model | Study name | Chronic Medical Condition | Statistics with study removed | | | p-Value
Model | Study name | Chronic Medical Condition | RD | Lower limit | Upper limit | p-Value
| IMPACT (Lin, 2003) | Arthritis | 0.267 | 0.201 | 0.333 | 0.000
| ADAPt-C (Ell, 2008) | Cancer | 0.224 | 0.133 | 0.315 | 0.000
| IMPACT (Fann, 2009) | Cancer | 0.228 | 0.135 | 0.322 | 0.000
| MDDP (Ell, 2010) | Diabetes | 0.183 | 0.125 | 0.242 | 0.000
| IMPACT (Williams, 2004) | Diabetes | 0.221 | 0.127 | 0.315 | 0.000
Random | | | 0.225 | 0.148 | 0.301 | 0.000

Change in HbA1C Levels at 6 Months

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
3.671 | 2 | 0.160 | 45.524

Change in HbA1C Levels at 6 Months

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | WMD | Lower Limit | Upper Limit | p-Value
| MDDP (Ell, 2010) | Diabetes | 0.242 | −0.293 | 0.777 | 0.375
| TEAMcare (Katon, 2010) | Diabetes | −0.026 | −0.313 | 0.262 | 0.862
| IMPACT (Williams, 2004) | Diabetes | 0.231 | −0.376 | 0.838 | 0.456
Random | | | 0.132 | −0.217 | 0.482 | 0.458

Change in HbA1C Levels at 12 Months

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
6.208 | 2 | 0.045 | 67.785

Change in HbA1C Levels at 12 Months

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | WMD | Lower Limit | Upper Limit | p-Value
| MDDP (Ell, 2010) | Diabetes | 0.312 | −0.197 | 0.821 | 0.230
| TEAMcare (Katon, 2010) | Diabetes | 0.037 | −0.257 | 0.331 | 0.807
| IMPACT (Williams, 2004) | Diabetes | 0.337 | −0.175 | 0.850 | 0.197
Random | | | 0.239 | −0.143 | 0.622 | 0.220

Change in Physical Health Status at 6 Months

Notes: Physical health status was measured with the 12-Item Short Form Survey from the RAND Medical Outcomes Study (SF-12) for all trials.

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
1.505 | 2 | 0.471 | 0.000

Change in Physical Health Status at 6 Months - WMD

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | WMD | Lower Limit | Upper Limit | p-Value
| ADAPt-C (Ell, 2008) | Cancer | 2.729 | 0.916 | 4.542 | 0.003
| MDDP (Ell, 2010) | Diabetes | 1.509 | −0.195 | 3.212 | 0.083
| HITIDES (Pyne, 2011) | HIV | 2.212 | 0.325 | 4.099 | 0.022
Random | | | 2.120 | 0.750 | 3.490 | 0.002

Change in Physical Health Status at 6 Months

Notes: Physical health status was measured with the 12-Item Short Form Survey from the RAND Medical Outcomes Study (SF-12) for all trials except Bypassing the Blues, which used the SF-36. The Bypassing the Blues data are from the 8-month endpoint.

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
1.101 | 3 | 0.777 | 0.000

Change in Physical Health Status at 6 Months - SMD

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | SMD | Lower Limit | Upper Limit | p-Value
| ADAPt-C (Ell, 2008) | Cancer | 0.210 | 0.076 | 0.345 | 0.002
| MDDP (Ell, 2010) | Diabetes | 0.155 | 0.022 | 0.288 | 0.023
| Bypassing the Blues (Rollman, 2009) | Heart Disease | 0.198 | 0.065 | 0.332 | 0.004
| HITIDES (Pyne, 2011) | HIV | 0.199 | 0.069 | 0.328 | 0.003
Random | | | 0.191 | 0.076 | 0.305 | 0.001

Change in Physical Health Status at 12 Months

Note: Physical health status was measured with the 12-Item Short Form Survey from the RAND Medical Outcomes Study (SF-12) for all trials.

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
2.748 | 2 | 0.253 | 27.212

Change in Physical Health Status at 12 Months - WMD

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | WMD | Lower Limit | Upper Limit | p-Value
| ADAPt-C (Ell, 2008) | Cancer | 0.311 | −1.540 | 2.162 | 0.742
| MDDP (Ell, 2010) | Diabetes | 1.803 | −0.420 | 4.026 | 0.112
| HITIDES (Pyne, 2011) | HIV | 1.515 | −1.052 | 4.082 | 0.247
Random | | | 1.251 | −0.446 | 2.948 | 0.149

Change in Physical Health Status at 12 Months

Note: Change in functional impairment was measured with the Sheehan Disability Scale of Functional Impairment.

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
2.726 | 3 | 0.436 | 0.000

Change in Functional Impairment at 12 Months - WMD

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed | | | p-Value
Model | Study Name | Chronic Medical Condition | WMD | Lower Limit | Upper Limit | p-Value
| IMPACT (Linn, 2003) | Arthritis | 1.067 | 0.688 | 1.446 | 0.000
| IMPACT ( Fann, 2009) | Cancer | 0.859 | 0.586 | 1.131 | 0.000
| MDDP (Ell, 2010) | Diabetes | 0.970 | 0.614 | 1.327 | 0.000
| TEAMcare (Katon, 2010) | Diabetes | 0.983 | 0.620 | 1.347 | 0.000
Random | | | 0.934 | 0.677 | 1.190 | 0.000

Risk of All-Cause Mortality at 6 Months

Note: The Bypassing the Blues and MDDP data are from 8-month endpoints.

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
16.194 | 6 | 0.013 | 62.949

Risk of All-Cause Mortality at 6 Months

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed
Model | Study Name | Chronic Medical Condition | RD | Lower Limit | Upper Limit | p-Value
| IMPACT (Lin, 2003) | Arthritis | 0.008 | −0.020 | 0.035 | 0.582
| ADAPt-C (Ell, 2008) | Cancer | 0.001 | −0.019 | 0.021 | 0.923
| IMPACT (Fann, 2009) | Cancer | 0.005 | −0.016 | 0.026 | 0.630
| MDDP (Dwight-Johnson, 2005) | Diabetes | −0.003 | −0.013 | 0.007 | 0.519
| IMPACT (Williams, 2004) | Diabetes | −0.002 | −0.022 | 0.018 | 0.846
| Bypassing the Blues (Rollman, 2009) | Heart Disease | 0.008 | −0.018 | 0.034 | 0.562
| HITIDES (Pyne, 2011) | HIV | 0.008 | −0.015 | 0.031 | 0.507
Random | | | 0.003 | −0.016 | 0.022 | 0.785

Risk of All-Cause Mortality at 12 Months

Measures of Heterogeneity

Q-Value | df (Q) | p-Value | I-Squared
3.325 | 6 | 0.767 | 0.000

Risk of All-Cause Mortality at 12 Months

Model | Study Name | Chronic Medical Condition | Statistics With Study Removed
Model | Study Name | Chronic Medical Condition | RD | Lower Limit | Upper Limit | p-Value
| IMPACT (Lin, 2003) | Arthritis | 0.009 | −0.011 | 0.028 | 0.374
| ADAPt-C (Ell, 2008) | Cancer | −0.002 | −0.018 | 0.013 | 0.780
| IMPACT (Fann, 2009) | Cancer | 0.000 | −0.015 | 0.015 | 0.983
| SMaRT Oncology 1 (Strong, 2008) | Cancer | −0.001 | −0.017 | 0.014 | 0.869
| IMPACT (Williams, 2004) | Diabetes | 0.000 | −0.016 | 0.016 | 0.997
| TEAMcare (Katon, 2010) | Diabetes +/− Heart Disease | −0.003 | −0.020 | 0.014 | 0.732
| HITIDES (Pyne, 2011) | HIV | −0.001 | −0.017 | 0.015 | 0.870
Random | | | 0.000 | −0.015 | 0.015 | 0.974