# Quality Assessment

This appendix describes the criteria relating to internal validity and the procedures that topic teams follow for all updates and new assessments in making these judgments.

All topic teams use initial “filters” to select studies for review that deal most directly with the question at issue and that are applicable to the population at issue. Thus, studies of any design that use outdated technology or that use technology that is not feasible for primary care practice may be filtered out before the abstraction stage, depending on the topic and the decisions of the topic team. The teams justify such exclusion decisions if there could be reasonable disagreement about this step. The criteria below are meant for those studies that pass this initial filter.

Presented below are a set of minimal criteria for each study design and then a general definition of three categories: “good,” “fair,” and “poor,” based on those criteria. These specifications are not meant to be rigid rules but rather are intended to be general guidelines, and individual exceptions, when explicitly explained and justified, can be made. In general terms, a “good” study has the least risk of bias and its results are considered to be valid. A “fair” study is susceptible to some bias but probably not sufficient to invalidate its results. A “poor” study has significant risk of bias (e.g., stemming from serious errors in design or analysis) that may invalidate its results.

Two independent reviewers assigned quality ratings for each study. For each article, one of the two reviewers was always an experienced/senior investigator (LW). Disagreements between the two reviewers were resolved by discussion and consensus or by consulting a third member of the team. We gave good quality ratings to studies that met all, or all but one, criteria. We gave poor quality ratings to studies that had a fatal flaw (defined as a methodological shortcoming that leads to a very high risk of bias) in one or more categories, and we excluded them from our analyses.

## Randomized Controlled Trials

### Criteria

- Initial assembly of comparable groups: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination)
- Important differential loss to follow-up or overall high loss to follow-up
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies, or intention to treat analysis.

### Definition of Ratings Based on Above Criteria

Good: Meets all or all but one of the following criteria: Comparable groups are assembled initially and maintained throughout the study (follow-up at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, for RCTs, intention to treat analysis is used.

Fair: Studies will be graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred with follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention to treat analysis is done for RCTs.

Poor: Studies will be graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. For RCTs, intention to treat analysis is lacking.

Table D-1 Quality ratings for efficacy/effectiveness trials

First author, year Trial name | Was randomization adequate? | Was allocation concealment adequate? | Were groups similar at baseline? | Were outcome assessors masked? | Were care providers masked? | Were patients masked? | Was overall attrition ≥20%? | Was differential attrition ≥15%? | Did the study use ITT analyses? | Were outcome measures equal, valid, and reliable? | Efficacy/Effectiveness quality rating
Dwight-Johnson, 2005^1^ MODP | Yes | Yes | Yes | Yes | No | No | Yes^a^ | Yes | Modified ITT | Yes | Fair
Ell, 2008^2^ Ell, 2011^3^ ADAPt-C | Yes | Yes | Yes | Yes | No | No | Yes^a^ | No | Modified ITT | Yes | Fair
Ell, 2010^4^ Ell, 2011^5^ Hay, 2011^6^ MDDP | Yes | Yes | No | Unclear/NR | No | No | Yes | No | No | Yes | Fair
Katon, 2004^7^ Katon, 2008^8^ Simon, 2007^9^ Kinder, 2006^10^ Ciechanowski, 2006^11^ Lin, 2006^12^ Pathways | Yes | Yes | Yes | Yes | No | No | No | No | Varied by outcome | Yes | Fair
Katon, 2010^13^ Von Korff, 2011^14^ TEAMcare | Yes | Yes | Yes | Yes | No | No | No | No | No | Yes | Fair
Pyne, 2011^15^ HITIDES | Yes | Yes | Yes | Yes | No | No | No | No | Yes | Yes | Good
Rollman, 2009^16^ Bypassing the Blues | Yes | Yes | Yes | Yes | No | No | No | No | Yes | Yes | Good
Strong, 2008^17^ SMaRT Oncology 1 | Yes | Yes | Yes | Yes | No | No | No | No | Modified ITT | Yes | Fair
Vera, 2010^18^ NA | Yes | Yes | Yes | Yes | No | No | No | No | Yes | Yes | Good
Williams, 2004^19^ Fann, 2009^20^ Lin, 2006^21^ Katon, 2006^22^ Lin, 2003^23^ IMPACT (secondary analyses) | No^b^ | Yes | Yes | Yes | No | No | No | No | Modified ITT | Yes | Fair

a Although attrition rate was high, the study population was patients with cancer – a population known to experience higher dropout rates for multiple reasons;

b Although randomization effect was lost by conducting post-randomization subgroup analyses, baseline characteristics were well-match between intervention and control arms. Quality rating was performed for each chronic condition subset, and the results did not vary.

Abbreviations: ADAPt-C = Alleviating Depression Among Patients with Cancer; HITIDES = HIV Implementation of Translating Initiatives for Depression into Effective Solutions; IMPACT = Improving Mood – Promoting Access to Collaborative Treatment; ITT = intent to treat; MDDP = Multifaceted Diabetes and Depression program; MODP = Multifaceted Oncology Depression Program; NA = not applicable; NR = not reported; SMaRT = Symptom Management Research Trials

Comments on efficacy/effectiveness trials rated “poor” (high risk of bias):

Bogner HR, Morales KH, Post EP, et al. Diabetes, depression, and death: a randomized controlled trial of a depression treatment program for older adults based in primary care (PROSPECT). Diabetes Care. 2007 Dec;30(12):3005–10. PMID: 17717284.

- Although the analysis describes adequate strategy for survival analysis, the initial variables chosen for possible confounding are not described and there are baseline differences in medical conditions – thus introducing a high risk for bias in this now observational add-on study

Sriwattanakomen R, Mazumdar S, Belnap B, et al. The effect of comorbid anxiety on post-CABG depressed patients' mental health related quality of life. Journal of General Internal Medicine. 2010 June;25 SUPPL. 3:S401.

-
- This was an abstract of a submission accepted for presentation at a Society of General Internal Medicine meeting. Although it is a subgroup analysis from a trial we have included (Bypassing the Blues), we feel that the risk of bias in this analysis is high due to unbalanced subgroup sizes and several significant differences at baseline.

## References

1 Dwight-Johnson M, Ell K, Lee PJ. Can collaborative care address the needs of low-income Latinas with comorbid depression and cancer? Results from a randomized pilot study. Psychosomatics. May–Jun. 2005;46(3):224-32. [pmid: 15883143].
2 Ell K, Xie B, Quon B, et al. Randomized controlled trial of collaborative care management of depression among low-income patients with cancer. J Clin Oncol. Sep. 20. 2008;26(27):4488-96. [pmid: 18802161].
3 Ell K, Xie B, Kapetanovic S, et al. One-year follow-up of collaborative depression care for low-income, predominantly Hispanic patients with cancer. Psychiatr Serv. 2011;(2):162-70. [pmid: 21285094].
4 Ell K, Katon W, Xie B, et al. Collaborative care management of major depression among low-income, predominantly Hispanic subjects with diabetes: a randomized controlled trial. Diabetes Care. Apr. 2010;33(4):706-13. [pmid: 20097780].
5 Ell K, Katon W, Xie B, et al. One-year postcollaborative depression care trial outcomes among predominantly Hispanic diabetes safety net patients. Gen Hosp Psychiatry. 2011;33(5):436-42. [pmid: 21774987].
6 Hay JW, Katon WJ, Ell K, et al. Cost Effectiveness Analysis of Collaborative Care Management of Major Depression among Low-Income, Predominantly Hispanics with Diabetes. J Ment Health Policy Econ. Mar. 2011;14:S11-S.
7 Katon WJ, Von Korff M, Lin EH, et al. The Pathways Study: a randomized trial of collaborative care in patients with diabetes and depression. Arch Gen Psychiatry. Oct. 2004;61(10):1042-9. [pmid: 15466678].
8 Katon WJ, Russo JE, Von Korff M, et al. Long-term effects on medical costs of improving depression outcomes in patients with depression and diabetes. Diabetes Care. Jun. 2008;31(6):1155-9. [pmid: 18332158].
9 Simon GE, Katon WJ, Lin EH, et al. Cost-effectiveness of systematic depression treatment among people with diabetes mellitus. Arch Gen Psychiatry. Jan. 2007;64(1):65-72. [pmid: 17199056].
10 Kinder LS, Katon WJ, Ludman E, et al. Improving depression care in patients with diabetes and multiple complications. J Gen Intern Med. Oct. 2006;21(10):1036-41. [pmid: 16836628].
11 Ciechanowski PS, Russo JE, Katon WJ, et al. The association of patient relationship style and outcomes in collaborative care treatment for depression in patients with diabetes. Med Care. Mar. 2006;44(3):283-91. [pmid: 16501401].
12 Lin EH, Katon W, Rutter C, et al. Effects of enhanced depression treatment on diabetes self-care. Ann Fam Med. Jan–Feb. 2006;4(1):46-53. [pmid: 16449396].
13 Katon WJ, Lin EH, Von Korff M, et al. Collaborative care for patients with depression and chronic illnesses. N Engl J Med. Dec. 30. 2010;363(27):2611-20. [pmid: 21190455].
14 Von Korff M, Katon WJ, Lin EHB, et al. Functional outcomes of multi-condition collaborative care and successful ageing: Results of randomised trial. BMJ. 2011;343(7833):1083.
15 Pyne JM, Fortney JC, Curran GM, et al. Effectiveness of collaborative care for depression in human immunodeficiency virus clinics. Arch Intern Med. 2011;(1):23-31. [pmid: 21220657].
16 Rollman BL, Belnap BH, LeMenager MS, et al. Telephone-delivered collaborative care for treating post-CABG depression: a randomized controlled trial. JAMA. Nov. 18. 2009;302(19):2095-103. [pmid: 19918088].
17 Strong V, Waters R, Hibberd C, et al. Management of depression for people with cancer (SMaRT oncology 1): a randomised trial. Lancet. Jul. 5. 2008;372(9632):40-8. [pmid: 18603157].
18 Vera M, Perez-Pedrogo C, Huertas SE, et al. Collaborative care for depressed patients with chronic medical conditions: a randomized trial in Puerto Rico. Psychiatr Serv. Feb. 2010;61(2):144-50. [pmid: 20123819].
19 Williams JW Jr, Katon W, Lin EH, et al. The effectiveness of depression care management on diabetes-related outcomes in older patients. Ann Intern Med. Jun. 15. 2004;140(12):1015-24. [pmid: 15197019].
20 Fann JR, Fan MY, Unutzer J. Improving primary care for older adults with cancer and depression. J Gen Intern Med. Nov. 2009;24(Suppl 2):S417-24. [pmid: 19838842].
21 Lin EH, Tang L, Katon W, et al. Arthritis pain and disability: response to collaborative depression care. Gen Hosp Psychiatry. Nov–Dec. 2006;28(6):482-6. [pmid: 17088163].
22 Katon W, Unutzer J, Fan MY, et al. Cost-effectiveness and net benefit of enhanced treatment of depression for older adults with diabetes and depression. Diabetes Care. Feb. 2006;29(2):265-70. [pmid: 16443871].
23 Lin EH, Katon W, Von Korff M, et al. Effect of improving depression care on pain and functional outcomes among older adults with arthritis: a randomized controlled trial. JAMA. Nov. 12. 2003;290(18):2428-9. [pmid: 14612479].