# Evidence Tables

Evidence Table 1 Characteristics of included studies

Evidence Table 2 Characteristics of study populations

Evidence Table 3 Intervention components

Evidence Table 4 Intervention logistics

Evidence Table 5 Mental health outcomes: symptom improvement, response rate, remission and/or recurrence

Evidence Table 6 Mental health outcomes: treatment adherence and treatment satisfaction

Evidence Table 7 Mental health outcomes: morbidity, mortality, self-reported health status, and quality of life

Evidence Table 8 Mental health outcomes: health care utilization and intervention costs

Evidence Table 9 Chronic medical condition outcomes: symptom improvement and response

Evidence Table 10 Chronic medical condition outcomes: treatment adherence and treatment satisfaction

Evidence Table 11 Chronic medical condition outcomes: self-reported health status, quality of life, and mortality

Evidence Table 12 Chronic medical condition outcomes: health care utilization and other outcomes, including harms

Evidence Table 13 System factors

## References

1 Dwight-Johnson M, Ell K, Lee PJ. Can collaborative care address the needs of low-income Latinas with comorbid depression and cancer? Results from a randomized pilot study. Psychosomatics. May–Jun. 2005;46(3):224-32. [pmid: 15883143].
2 Ell K, Xie B, Quon B, et al. Randomized controlled trial of collaborative care management of depression among low-income patients with cancer. J Clin Oncol. Sep. 20. 2008;26(27):4488-96. [pmid: 18802161].
3 Ell K, Xie B, Kapetanovic S, et al. One-year follow-up of collaborative depression care for low-income, predominantly Hispanic patients with cancer. Psychiatr Serv. 2011;(2):162-70. [pmid: 21285094].
4 Ell K, Katon W, Xie B, et al. Collaborative care management of major depression among low-income, predominantly Hispanic subjects with diabetes: a randomized controlled trial. Diabetes Care. Apr. 2010;33(4):706-13. [pmid: 20097780].
5 Ell K, Katon W, Xie B, et al. One-year postcollaborative depression care trial outcomes among predominantly Hispanic diabetes safety net patients. Gen Hosp Psychiatry. 2011;33(5):436-42. [pmid: 21774987].
6 Hay JW, Katon WJ, Ell K, et al. Cost Effectiveness Analysis of Collaborative Care Management of Major Depression among Low-Income, Predominantly Hispanics with Diabetes. J Ment Health Policy Econ. Mar. 2011;14:S11-S.
7 Katon WJ, Von Korff M, Lin EH, et al. The Pathways Study: a randomized trial of collaborative care in patients with diabetes and depression. Arch Gen Psychiatry. Oct. 2004;61(10):1042-9. [pmid: 15466678].
8 Katon WJ, Russo JE, Von Korff M, et al. Long-term effects on medical costs of improving depression outcomes in patients with depression and diabetes. Diabetes Care. Jun. 2008;31(6):1155-9. [pmid: 18332158].
9 Simon GE, Katon WJ, Lin EH, et al. Cost-effectiveness of systematic depression treatment among people with diabetes mellitus. Arch Gen Psychiatry. Jan. 2007;64(1):65-72. [pmid: 17199056].
10 Kinder LS, Katon WJ, Ludman E, et al. Improving depression care in patients with diabetes and multiple complications. J Gen Intern Med. Oct. 2006;21(10):1036-41. [pmid: 16836628].
11 Ciechanowski PS, Russo JE, Katon WJ, et al. The association of patient relationship style and outcomes in collaborative care treatment for depression in patients with diabetes. Med Care. Mar. 2006;44(3):283-91. [pmid: 16501401].
12 Lin EH, Katon W, Rutter C, et al. Effects of enhanced depression treatment on diabetes self-care. Ann Fam Med. Jan–Feb. 2006;4(1):46-53. [pmid: 16449396].
13 Katon WJ, Lin EH, Von Korff M, et al. Collaborative care for patients with depression and chronic illnesses. N Engl J Med. Dec. 30. 2010;363(27):2611-20. [pmid: 21190455].
14 Von Korff M, Katon WJ, Lin EHB, et al. Functional outcomes of multi-condition collaborative care and successful ageing: Results of randomised trial. BMJ. 2011;343(7833):1083.
15 Lin EH, Von Korff M, Ciechanowski P, et al. Treatment adjustment and medication adherence for complex patients with diabetes, heart disease, and depression: a randomized controlled trial. Ann Fam Med. Jan–Feb. 2012;10(1):6-14. [pmid: 22230825].
16 Pyne JM, Fortney JC, Curran GM, et al. Effectiveness of collaborative care for depression in human immunodeficiency virus clinics. Arch Intern Med. 2011;(1):23-31. [pmid: 21220657].
17 Rollman BL, Belnap BH, LeMenager MS, et al. Telephone-delivered collaborative care for treating post-CABG depression: a randomized controlled trial. JAMA. Nov. 18. 2009;302(19):2095-103. [pmid: 19918088].
18 Strong V, Waters R, Hibberd C, et al. Management of depression for people with cancer (SMaRT oncology 1): a randomised trial. Lancet. Jul. 5. 2008;372(9632):40-8. [pmid: 18603157].
19 Vera M, Perez-Pedrogo C, Huertas SE, et al. Collaborative care for depressed patients with chronic medical conditions: a randomized trial in Puerto Rico. Psychiatr Serv. Feb. 2010;61(2):144-50. [pmid: 20123819].
20 Lin EH, Tang L, Katon W, et al. Arthritis pain and disability: response to collaborative depression care. Gen Hosp Psychiatry. Nov–Dec. 2006;28(6):482-6. [pmid: 17088163].
21 Lin EH, Katon W, Von Korff M, et al. Effect of improving depression care on pain and functional outcomes among older adults with arthritis: a randomized controlled trial. JAMA. Nov. 12. 2003;290(18):2428-9. [pmid: 14612479].
22 Fann JR, Fan MY, Unutzer J. Improving primary care for older adults with cancer and depression. J Gen Intern Med. Nov. Suppl 2. 2009;24:S417-24. [pmid: 19838842].
23 Williams JW Jr, Katon W, Lin EH, et al. The effectiveness of depression care management on diabetes-related outcomes in older patients. Ann Intern Med. Jun. 15. 2004;140(12):1015-24. [pmid: 15197019].
24 Katon W, Unutzer J, Fan MY, et al. Cost-effectiveness and net benefit of enhanced treatment of depression for older adults with diabetes and depression. Diabetes Care. Feb. 2006;29(2):265-70. [pmid: 16443871].