# Excluded Studies

## Wrong language

Boni F, Corsonello A, Panuccio D. COPD and depression/anxiety. ORIGINAL (NON-ENGLISH) TITLE. BPCO e depressione/ansia. Italian Journal of Medicine. March. 2011;5(1 SUPPL 1):S81-S90.
Hermanns N. Structured depression management in the therapy of comorbid depressive disorders in the case of diabetes. ORIGINAL (NON-ENGLISH) TITLE. Strukturiertes Depressionsmanagement in der Therapie komorbider depressiver Storungen bei Diabetes. Diabetologe. June. 2010;6(4):297-8.

## Wrong publication type or study design

Adili F, Larijani B, Haghighatpanah M. Diabetic patients: Psychological aspects. Ann N Y Acad Sci. Nov. 2006;1084:329-49. [pmid: 17151313].
Agius M, Zaman R, Klepacka K. Developing guidelines for the treatment of resistant unipolar depression across primary and secondary care. Journal of Cancer Education. 2009. SUPPL 1. 2009;24:S428-S9.
Anderson D, Horton C, O’Toole ML, et al. Integrating depression care with diabetes care in real-world settings: lessons from the Robert Wood Johnson Foundation Diabetes Initiative. Diabetes Spectrum. 2007. Winter. 2007;20(1):10-6. Language: English. Entry Date: 20070511. Publication Type: journal article.
Antoni MH, Lutgendorf SK, Cole SW, et al. The influence of bio-behavioural factors on tumour biology: pathways and mechanisms. Nat Rev Cancer. Mar. 2006;6(3):240-8. [pmid: 16498446].
Bartels SJ. Caring for the whole person: Integrated health care for older adults with severe mental illness and medical comorbidity. Journal of the American Geriatrics Society. December. 2004;52(SUPPL 12):S249-S57. MEDLINE 15541165. (www.ncbi.nlm.nih.gov/pubmed/15541165). [pmid: 15541165].
Bland P. Is collaborative care best for depression in chronic disease?. The Practitioner. Jan. 2011;255(1736):5.
Block SD. Diagnosis and treatment of depression in patients with advanced illness. Epidemiol Psichiatr Soc. Apr–Jun. 2010;19(2):103-9. [pmid: 20815292].
Bloom JR, Kessler L. Risk and timing of counseling and support interventions for younger women with breast cancer. J Natl Cancer Inst Monogr. 1994;(16):199-206. [pmid: 7999465].
Carlsen K, Jensen AB, Jacobsen E, et al. Psychosocial aspects of lung cancer. Lung Cancer. Mar. 2005;47(3):293-300. [pmid: 15713512].
Carlson LE, Bultz BD. Benefits of psychosocial oncology care: improved quality of life and medical cost offset. Health Qual Life Outcomes. 2003;1:8. [pmid: 12756059].
Carney RM, Blumenthal JA, Catellier D, et al. Depression as a risk factor for mortality after acute myocardial infarction. Am J Cardiol. Dec. 1. 2003;92(11):1277-81. [pmid: 14636903].
Chan R, Webster J, Bennett L. Effects and feasibility of a multi-disciplinary orientation program for newly registered cancer patients: design of a randomised controlled trial. BMC Health Serv Res. 2009;9:203. [pmid: 19906312].
Cheok F, Schrader G, Banham D, et al. Identification, course, and treatment of depression after admission for a cardiac condition: rationale and patient characteristics for the Identifying Depression As a Comorbid Condition (IDACC) project. Am Heart J. Dec. 2003;146(6):978-84. [pmid: 14660988].
Cole SA, Farber NC, Weiner JS, et al. Double-disease management or one care manager for two chronic conditions: pilot feasibility study of nurse telephonic disease management for depression and congestive heart failure. Dis Manag. Oct. 2006;9(5):266-76. [pmid: 17044760].
Davidson MB, Echeverry D. Collaborative care for depression and chronic illnesses. N Engl J Med. Mar. 31. 2011;364(13):1278. author reply -9. [pmid: 21449795].
de Ridder D, Schreurs K. Developing interventions for chronically ill patients: is coping a helpful concept? (Structured abstract). Clinical Psychology Review. 2001:205-40. [pmid: 11293366].
Dickens C, McGowan L, Percival C, et al. Depression is a risk factor for mortality after myocardial infarction: fact or artifact?. J Am Coll Cardiol. May. 8. 2007;49(18):1834-40. [pmid: 17481442].
Dobscha SK, Corson K, Leibowitz RQ, et al. Rationale, design, and baseline findings from a randomized trial of collaborative care for chronic musculoskeletal pain in primary care. Pain Med. Nov. 2008;9(8):1050-64. [pmid: 18565008].
Echols MR, Jiang W. Clinical trial evidence for treatment of depression in heart failure. Heart Fail Clin. Jan. 2011;7(1):81-8. [pmid: 21109211].
Egede LE. Disease-focused or integrated treatment: diabetes and depression. Med Clin North Am. Jul. 2006;90(4):627-46. [pmid: 16843766].
Ell K, Aranda MP, Xie B, et al. Collaborative depression treatment in older and younger adults with physical illness: Pooled comparative analysis of three randomized clinical trials. American Journal of Geriatric Psychiatry. June. 2010;18(6):520-30. [pmid: 20220588].
Ell K, Quon B, Quinn DI, et al. Improving treatment of depression among low-income patients with cancer: the design of the ADAPt-C study. Gen Hosp Psychiatry. May–Jun. 2007;29(3):223-31. [pmid: 17484939].
Fenton WS, Stover ES. Mood disorders: cardiovascular and diabetes comorbidity. Curr Opin Psychiatry. Jul. 2006;19(4):421-7. [pmid: 16721175].
Gallagher R. Telephone-delivered collaborative care for post-CABG depression is more effective than usual care for improving quality of life related to mental health. Evidence-Based Nursing. 2010;13(2):37. [pmid: 20436137].
Ganz P. Institute of medicine report: Recognizing psychological health needs to treat the whole patient. Journal of Oncology Practice. 2008;4(3):128-30. [pmid: 20856616].
George PP, Molina JAD, Cheah J, et al. The evolving role of the community pharmacist in chronic disease management - A literature review. Annals of the Academy of Medicine Singapore. November. 2010;39(11):861-7. MEDLINE 21165527. (www.ncbi.nlm.nih.gov/pubmed/21165527).
Georgiades A, Zucker N, Friedman KE, et al. Changes in depressive symptoms and glycemic control in diabetes mellitus. Psychosom Med. Apr. 2007;69(3):235-41. [pmid: 17420441].
Handford C, Tynan A-M, Rackal Julia M, et al. Setting and organization of care for persons living with HIV/AIDS, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2006.
Harris M, Smith B, Veale A. Printed patient education interventions to facilitate shared management of chronic disease: a literature review (Structured abstract). Internal Medicine Journal. 2005:711-6. [pmid: 16313546].
Heron KE, Smyth JM. Ecological momentary interventions: incorporating mobile technology into psychosocial and health behaviour treatments. Br J Health Psychol. Feb. 2010;15(Pt 1):1-39. [pmid: 19646331].
Johri M, Beland F, Bergman H. International experiments in integrated care for the elderly: a synthesis of the evidence (Structured abstract). International Journal of Geriatric Psychiatry. 2003;(3):222-35. [pmid: 12642892].
Katon WJ, Seelig M. Population-based care of depression: team care approaches to improving outcomes. J Occup Environ Med. Apr. 2008;50(4):459-67. [pmid: 18404019].
Konstam V, Moser DK, De Jong MJ. Depression and anxiety in heart failure. J Card Fail. Aug. 2005;11(6):455-63. [pmid: 16105637].
Krumholz HM, Currie PM, Riegel B, et al. A taxonomy for disease management: a scientific statement from the American Heart Association Disease Management Taxonomy Writing Group. Circulation. 2006;114(13):1432-45. Corporate Author: American Heart Association. Disease Management Taxonomy Writing Group. Language: English. Entry Date: 20070831. Revision Date: 20101231. Publication Type: journal article. [pmid: 16952985].
Mast BT, Vedrody S. Poststroke depression: a biopsychosocial approach. Curr Psychiatry Rep. Feb. 2006;8(1):25-33. [pmid: 16513040].
McGregor M, Lin EH, Katon WJ. TEAMcare: an integrated multicondition collaborative care program for chronic illnesses and depression. J Ambul Care Manage. Apr–Jun. 2011;34(2):152-62. [pmid: 21415613].
Newport DJ, Nemeroff CB. Assessment and treatment of depression in the cancer patient. J Psychosom Res. Sep. 1998;45(3):215-37. [pmid: 9776368].
Opolski M, Wilson I. Asthma and depression: A pragmatic review of the literature and recommendations for future research. Clinical Practice and Epidemiology in Mental Health. 2005;1(18).
Patel KJ, Dwamena F. Impact of collaborative care management of depression among patients with cancer. Journal of Clinical Oncology. 2009;1;27(10):1730. MEDLINE 19255305. (www.ncbi.nlm.nih.gov/pubmed/19255305).
Peters-Klimm F, Muller-Tasch T, Schellberg D, et al. Rationale, design and conduct of a randomised controlled trial evaluating a primary care-based complex intervention to improve the quality of life of heart failure patients: HICMan (Heidelberg Integrated Case Management). BMC Cardiovasc Disord. 2007;7:25. [pmid: 17716364].
Pirl WF. Evidence report on the occurrence, assessment, and treatment of depression in cancer patients. J Natl Cancer Inst Monogr. 2004;(32):32-9. [pmid: 15263039].
Price J. Collaborative care improves health outcomes in older people with depression and arthritis. Evidence-Based Mental Health. 2004;7(2):45. [pmid: 15107341].
Rollman BL, Herbeck Belnap B. The Bypassing the Blues trial: collaborative care for post-CABG depression and implications for future research. Cleve Clin J Med. Aug. Suppl 1. 2011;78:S4-12. [pmid: 21972329].
Ross L, Boesen EH, Dalton SO, et al. Mind and cancer: does psychosocial intervention improve survival and psychological well-being?. Eur J Cancer. Jul. 2002;38(11):1447-57. [pmid: 12110489].
Schrader GD, Cheok F, Beltrame JF. Collaborative care for post-CABG depression. JAMA: Journal of the American Medical Association. 2010;303(13):1252-3.
Sharpe M, Strong V, Allen K, et al. Management of major depression in outpatients attending a cancer centre: a preliminary evaluation of a multicomponent cancer nurse-delivered intervention. Br J Cancer. Jan. 26. 2004;90(2):310-3. [pmid: 14735169].
Shemesh E, Koren-Michowitz M, Yehuda R, et al. Symptoms of posttraumatic stress disorder in patients who have had a myocardial infarction. Psychosomatics. May–Jun. 2006;47(3):231-9. [pmid: 16684940].
Thomas SA. Care management for poststroke depression. Stroke. March. 2007;38(3):850-1. MEDLINE 17303770. (www.ncbi.nlm.nih.gov/pubmed/17303770). [pmid: 17303770].
Tully PJ. Randomised controlled trial: telephone-delivered collaborative care for post-CABG depression is more effective than usual care for improving mental-health-related quality of life. Evidence Based Medicine. 2010;15(2):57-8. Language: English. Entry Date: 20100709. Revision Date: 20100709. Publication Type: journal article. [pmid: 20436129].
Van Der Feltz-Cornelis C. Treatment of depression and diabetes when co-morbid. European Psychiatry. 2010;25(1):2010-02.
Vieweg WV, Julius DA, Fernandez A, et al. Treatment of depression in patients with coronary heart disease. Am J Med. Jul. 2006;119(7):567-73. [pmid: 16828625].
Vilela LD, Nicolau B, Mahmud S, et al. Comparison of psychosocial outcomes in head and neck cancer patients receiving a coping strategies intervention and control subjects receiving no intervention. J Otolaryngol. Apr. 2006;35(2):88-96. [pmid: 16527026].
Villarreal SS. A comparative study of selected patient variables as risk factors in hospitalization for chronic headache. Headache. Jun. 1995;35(6):349-54. [pmid: 7635721].
Walker J, Cassidy J, Sharpe M. The third symptom management research trial in oncology (SMaRT oncology-3): a randomised trial to determine the efficacy of adding a complex intervention for major depressive disorder (depression care for people with lung cancer) to usual care, compared to usual care alone in patients with lung cancer. Trials. 2009;10:92. [pmid: 19793390].
Walker J, Sharpe M. Depression Care for People with Cancer: a collaborative care intervention. Gen Hosp Psychiatry. Sep–Oct. 2009;31(5):436-41. [pmid: 19703637].
Weinstein J School-Based Health Centers and the Primary Care Physician: an Opportunity for Collaborative Care Primary Care - Clinics in Office Practice 2006 June 33 2 305 15MEDLINE 16713764(www.ncbi.nlm.nih.gov/pubmed/16713764)
Yohannes AM, Willgoss TG, Baldwin RC, et al. Depression and anxiety in chronic heart failure and chronic obstructive pulmonary disease: prevalence, relevance, clinical implications and management principles. Int J Geriatr Psychiatry. Dec. 2010;25(12):1209-21. [pmid: 20033905].

## Wrong PICOTS element(s)

Addington-Hall JM, MacDonald LD, Anderson HR, et al. Randomised controlled trial of effects of coordinating care for terminally ill cancer patients. BMJ. Nov. 28. 1992;305(6865):1317-22. [pmid: 1483075].
Agius M, Murphy CL, Zaman R. Does shared care help in the treatment of depression?. Psychiatr Danub. Nov. Suppl 1. 2010;22:S18-22. [pmid: 21057395].
Allen D, Rixson L. How has the impact of 'care pathway technologies' on service integration in stroke care been measured and what is the strength of the evidence to support their effectiveness in this respect? (Structured abstract). International Journal of Evidence-Based Healthcare. 2008:78-110. [pmid: 21631815].
Allen M, Iezzoni LI, Huang A, et al. Improving patient-clinician communication about chronic conditions: description of an internet-based nurse E-coach intervention. Nurs Res. Mar–Apr. 2008;57(2):107-12. [pmid: 18347482].
Appels A, van Elderen T, Bar F, et al. Effects of a behavioural intervention on quality of life and related variables in angioplasty patients: results of the EXhaustion Intervention Trial. J Psychosom Res. Jul. 2006;61(1):1-7. discussion 9–10. [pmid: 16813838].
Arving C, Sjoden PO, Bergh J, et al. Individual psychosocial support for breast cancer patients: a randomized study of nurse versus psychologist interventions and standard care. Cancer Nurs. May–Jun. 2007;30(3):E10-9. [pmid: 17510577].
Badger TA, Braden CJ, Mishel MH. Depression burden, self-help interventions, and side effect experience in women receiving treatment for breast cancer. Oncol Nurs Forum. Apr. 2001;28(3):567-74. [pmid: 11338763].
Banerjee S, Shamash K, Macdonald AJ, et al. Randomised controlled trial of effect of intervention by psychogeriatric team on depression in frail elderly people at home. BMJ. Oct. 26. 1996;313(7064):1058-61. [pmid: 8898601].
Barsevick AM, Sweeney C, Haney E, et al. A systematic qualitative analysis of psychoeducational interventions for depression in patients with cancer. Oncol Nurs Forum. Jan–Feb. 2002;29(1):73-84. quiz 5–7. [pmid: 11817494].
Beale IL. Scholarly literature review: Efficacy of psychological interventions for pediatric chronic illnesses. J Pediatr Psychol. Jun. 2006;31(5):437-51. [pmid: 16162841].
Benfari RC, McIntyre K, Eaker E, et al. The psychological effects of differential treatment of a high risk sample in a randomized clinical trial. Am J Public Health. Oct. 1979;69(10):996-1000. [pmid: 484765].
Bogner HR, de Vries HF. Integrating type 2 diabetes mellitus and depression treatment among African Americans: a randomized controlled pilot trial. Diabetes Educ. Mar–Apr. 2010;36(2):284-92. [pmid: 20040705].
Bogner HR, Morales KH, de Vries HF, et al. Integrated management of type 2 diabetes mellitus and depression treatment to improve medication adherence: a randomized controlled trial. Ann Fam Med. Jan–Feb. 2012;10(1):15-22. [pmid: 22230826].
Bond GE, Burr RL, Wolf FM, et al. The effects of a web-based intervention on psychosocial well-being among adults aged 60 and older with diabetes: a randomized trial. Diabetes Educ. May–Jun. 2010;36(3):446-56. [pmid: 20375351].
Boult C, Reider L, Leff B, et al. The effect of guided care teams on the use of health services: results from a cluster-randomized controlled trial. Arch Intern Med. Mar. 14. 2011;171(5):460-6. [pmid: 21403043].
Bower P, Gilbody S, Richards D, et al. Collaborative care for depression in primary care. Making sense of a complex intervention: systematic review and meta-regression (Structured abstract). British Journal of Psychiatry. 2006;(6):484-93. [pmid: 17139031].
Boyes A, Newell S, Girgis A, et al. Does routine assessment and real-time feedback improve cancer patients' psychosocial well-being?. Eur J Cancer Care (Engl). May. 2006;15(2):163-71. [pmid: 16643264].
Burg MM, Lesperance F, Rieckmann N, et al. Treating persistent depressive symptoms in post-ACS patients: the project COPES phase-I randomized controlled trial. Contemp Clin Trials. Mar. 2008;29(2):231-40. [pmid: 17904917].
Campbell NC, Thain J, Deans HG, et al. Secondary prevention clinics for coronary heart disease: randomised trial of effect on health. BMJ. May. 9. 1998;316(7142):1434-7. [pmid: 9572758].
Christian AH, Cheema AF, Smith SC, et al. Predictors of quality of life among women with coronary heart disease. Qual Life Res. Apr. 2007;16(3):363-73. [pmid: 17091358].
Cimpean D, Drake RE. Treating co-morbid chronic medical conditions and anxiety/depression. Epidemiol Psychiatr Sci. Jun. 2011;20(2):141-50. [pmid: 21714361].
Cowan MJ, Freedland KE, Burg MM, et al. Predictors of treatment response for depression and inadequate social support--the ENRICHD randomized clinical trial. Psychother Psychosom. 2008;77(1):27-37. [pmid: 18087205].
Crotty M, Prendergast J, Battersby MW, et al. Self-management and peer support among people with arthritis on a hospital joint replacement waiting list: a randomised controlled trial. Osteoarthritis Cartilage. Nov. 2009;17(11):1428-33. [pmid: 19486959].
Davidson KW, Rieckmann N, Clemow L, et al. Enhanced depression care for patients with acute coronary syndrome and persistent depressive symptoms: coronary psychosocial evaluation studies randomized controlled trial. Arch Intern Med. Apr. 12. 2010;170(7):600-8. [pmid: 20386003].
de Blok BM, de Greef MH, ten Hacken NH, et al. The effects of a lifestyle physical activity counseling program with feedback of a pedometer during pulmonary rehabilitation in patients with COPD: a pilot study. Patient Educ Couns. Apr. 2006;61(1):48-55. [pmid: 16455222].
de Boer AG, Taskila T, Tamminga SJ, et al. Interventions to enhance return-to-work for cancer patients, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2011.
de Man-van Ginkel JM, Gooskens F, Schuurmans MJ, et al. A systematic review of therapeutic interventions for poststroke depression and the role of nurses. J Clin Nurs. Dec. 2010;19(23–24):3274-90. [pmid: 21083778].
Dickinson KC, Sharma R, Duckart JP, et al. VA healthcare costs of a collaborative intervention for chronic pain in primary care. Medical Care. January. 2010;48(1):38-44. MEDLINE 19952802. (www.ncbi.nlm.nih.gov/pubmed/19952802). [pmid: 19952802].
Dobscha SK, Corson K, Perrin NA, et al. Collaborative care for chronic pain in primary care: a cluster randomized trial. JAMA. Mar. 25. 2009;301(12):1242-52. [pmid: 19318652].
Doorenbos A, Given B, Given C, et al. Physical functioning: effect of behavioral intervention for symptoms among individuals with cancer. Nurs Res. May–Jun. 2006;55(3):161-71. [pmid: 16708040].
Drummond N, Abdall M, Buckingham JK, et al. Integrated care for asthma: a clinical, social, and economic evaluation (Structured abstract). BMJ. 1994:559-64.
Duffy SA, Ronis DL, Valenstein M, et al. A tailored smoking, alcohol, and depression intervention for head and neck cancer patients. Cancer Epidemiol Biomarkers Prev. Nov. 2006;15(11):2203-8. [pmid: 17119047].
Dumrongpakapakorn P, Hopkins K, Sherwood P, et al. Computer-mediated patient education: opportunities and challenges for supporting women with ovarian cancer. Nurs Clin North Am. Sep. 2009;44(3):339-54. [pmid: 19683095].
Eakin EG, Bull SS, Glasgow RE, et al. Reaching those most in need: a review of diabetes self-management interventions in disadvantaged populations (Structured abstract). Diabetes/Metabolism Research and Reviews. 2002:26-35. [pmid: 11921415].
Edwards AG, Hulbert-Williams N, Neal RD. Psychological interventions for women with metastatic breast cancer, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2008.
Efficace F, Kemmler G, Vignetti M, et al. Health-related quality of life assessment and reported outcomes in leukaemia randomised controlled trials - A systematic review to evaluate the added value in supporting clinical decision making. European Journal of Cancer. July. 2008;44(11):1497-506. MEDLINE 18555682. (www.ncbi.nlm.nih.gov/pubmed/18555682). [pmid: 18555682].
Ellis G, Mant J, Langhorne P, et al. Stroke liaison workers for stroke patients and carers: an individual patient data meta-analysis. Cochrane Database Syst Rev. 2010;(5):CD005066. [pmid: 20464736].
Foy R, Hempel S, Rubenstein L, et al. Meta-analysis: effect of interactive communication between collaborating primary care physicians and specialists (Structured abstract). Annals of Internal Medicine. 2010:247-58. [pmid: 20157139].
Frasure-Smith N, Lesperance F, Gravel G, et al. Long-term survival differences among low-anxious, high-anxious and repressive copers enrolled in the Montreal heart attack readjustment trial. Psychosom Med. Jul–Aug. 2002;64(4):571-9. [pmid: 12140346].
Gallo JJ, Bogner HR, Morales KH, et al. The effect of a primary care practice-based depression intervention on mortality in older adults: a randomized trial. Ann Intern Med. May. 15. 2007;146(10):689-98. [pmid: 17502629].
Gatchel RJ, Stowell AW, Wildenstein L, et al. Efficacy of an early intervention for patients with acute temporomandibular disorder-related pain: a one-year outcome study. J Am Dent Assoc. Mar. 2006;137(3):339-47. [pmid: 16570467].
Gilden JL, Hendryx MS, Clar S, et al. Diabetes support groups improve health care of older diabetic patients. J Am Geriatr Soc. Feb. 1992;40(2):147-50. [pmid: 1740599].
Girgis A, Breen S, Stacey F, et al. Impact of two supportive care interventions on anxiety, depression, quality of life, and unmet needs in patients with nonlocalized breast and colorectal cancers. J Clin Oncol. Dec. 20. 2009;27(36):6180-90. [pmid: 19917842].
Gruen RL, Weeramanthri TS, Knight SS, et al. Specialist outreach clinics in primary care and rural hospital settings, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2003.
Hansen RA, Dusetzina SB, Song L, et al. Depression affects adherence measurement but not the effectiveness of an adherence intervention in heart failure patients. J Am Pharm Assoc. 2009. Nov–Dec. 2003;49(6):760-8. [pmid: 19926556].
Helgeson VS, Lepore SJ, Eton DT. Moderators of the benefits of psychoeducational interventions for men with prostate cancer. Health Psychol. May. 2006;25(3):348-54. [pmid: 16719606].
Huang CQ, Dong BR, Lu ZC, et al. Collaborative care interventions for depression in the elderly: a systematic review of randomized controlled trials (Structured abstract). Journal of Investigative Medicine. 2009;(2):446-55. [pmid: 19174704].
Iconomou G, Viha A, Koutras A, et al. Impact of providing booklets about chemotherapy to newly presenting patients with cancer: a randomized controlled trial. Ann Oncol. Mar. 2006;17(3):515-20. [pmid: 16344276].
Jackson CL, Bolen S, Brancati FL, et al. A systematic review of interactive computer-assisted technology in diabetes care: interactive information technology in diabetes care (Structured abstract). Journal of General Internal Medicine. 2006:105-10. [pmid: 16390512].
Johansson P, Dahlstrom U, Brostrom A. Factors and interventions influencing health-related quality of life in patients with heart failure: a review of the literature. Eur J Cardiovasc Nurs. Mar. 2006;5(1):5-15. [pmid: 15967727].
Johns SA, Kroenke K, Theobald DE, et al. Telecare management of pain and depression in patients with cancer: patient satisfaction and predictors of use. J Ambul Care Manage. Apr–Jun. 2011;34(2):126-39. [pmid: 21415611].
Jonkers CC, Lamers F, Evers SM, et al. Economic evaluation of a minimal psychological intervention in chronically ill elderly patients with minor or mild to moderate depression: a randomized trial (the DELTA-study). Int J Technol Assess Health Care. Oct. 2009;25(4):497-504. [pmid: 19845979].
Joubert J, Joubert L, Reid C, et al. The positive effect of integrated care on depressive symptoms in stroke survivors. Cerebrovasc Dis. 2008;26(2):199-205. [pmid: 18628619].
Joubert J, Reid C, Joubert L, et al. Risk factor management and depression post-stroke: the value of an integrated model of care. J Clin Neurosci. Jan. 2006;13(1):84-90. [pmid: 16410202].
Katon W, Unutzer J, Russo J. Major depression: the importance of clinical characteristics and treatment response to prognosis. Depress Anxiety. 2010;27(1):19-26. [pmid: 19798766].
Kroenke K, Theobald D, Wu J, et al. Effect of telecare management on pain and depression in patients with cancer: a randomized trial. JAMA. Jul. 14. 2010;304(2):163-71. [pmid: 20628129].
Lamers F, Jonkers CC, Bosma H, et al. Improving quality of life in depressed COPD patients: effectiveness of a minimal psychological intervention. COPD. Oct. 2010;7(5):315-22. [pmid: 20854045].
Landis SE, Gaynes BN, Morrissey JP, et al. Generalist care managers for the treatment of depressed medicaid patients in North Carolina: a pilot study. BMC Fam Pract. 2007;8:7. [pmid: 17338822].
Lane DA, Chong AY, Lip GY. Psychological interventions for depression in heart failure. Cochrane Database Syst Rev. 2005;(1):CD003329. [pmid: 15674906].
Lee V, Robin Cohen S, Edgar L, et al. Meaning-making intervention during breast or colorectal cancer treatment improves self-esteem, optimism, and self-efficacy. Soc Sci Med. Jun. 2006;62(12):3133-45. [pmid: 16413644].
Lenze EJ, Rogers JC, Martire LM, et al. The association of late-life depression and anxiety with physical disability: a review of the literature and prospectus for future research. Am J Geriatr Psychiatry. Spring. 2001;9(2):113-35. [pmid: 11316616].
Lett HS, Blumenthal JA, Babyak MA, et al. Depression as a risk factor for coronary artery disease: evidence, mechanisms, and treatment. Psychosom Med. May–Jun. 2004;66(3):305-15. [pmid: 15184688].
Lett HS, Blumenthal JA, Babyak MA, et al. Social support and prognosis in patients at increased psychosocial risk recovering from myocardial infarction. Health Psychol. Jul. 2007;26(4):418-27. [pmid: 17605561].
Lie I, Arnesen H, Sandvik L, et al. Effects of a home-based intervention program on anxiety and depression 6 months after coronary artery bypass grafting: a randomized controlled trial. J Psychosom Res. Apr. 2007;62(4):411-8. [pmid: 17383492].
Linton SJ, Bradley LA, Jensen I, et al. The secondary prevention of low back pain: a controlled study with follow-up. Pain. Feb. 1989;36(2):197-207. [pmid: 2521930].
Livingston PM, White VM, Hayman J, et al. The psychological impact of a specialist referral and telephone intervention on male cancer patients: a randomised controlled trial. Psychooncology. Jun. 2010;19(6):617-25. [pmid: 19673008].
Llewellyn CD, McGurk M, Weinman J. Are psycho-social and behavioural factors related to health related-quality of life in patients with head and neck cancer? A systematic review. Oral Oncol. May. 2005;41(5):440-54. [pmid: 15878748].
Lustman PJ, Freedland KE, Griffith LS, et al. Predicting response to cognitive behavior therapy of depression in type 2 diabetes. Gen Hosp Psychiatry. Sep. 1998;20(5):302-6. [pmid: 9788030].
Lustman PJ, Griffith LS, Freedland KE, et al. Cognitive behavior therapy for depression in type 2 diabetes mellitus. A randomized, controlled trial. Ann Intern Med. Oct. 15. 1998;129(8):613-21. [pmid: 9786808].
MacMahon KM, Lip GY. Psychological factors in heart failure: a review of the literature. Arch Intern Med. Mar. 11. 2002;162(5):509-16. [pmid: 11871918].
Mancuso CA, Sayles W, Allegrante JP. Randomized trial of self-management education in asthmatic patients and effects of depressive symptoms. Ann Allergy Asthma Immunol. Jul. 2010;105(1):12-9. [pmid: 20642198].
Martensson J, Stromberg A, Dahlstrom U, et al. Patients with heart failure in primary health care: effects of a nurse-led intervention on health-related quality of life and depression. Eur J Heart Fail. Mar. 16. 2005;7(3):393-403. [pmid: 15718180].
McArdle JM, George WD, McArdle CS, et al. Psychological support for patients undergoing breast cancer surgery: a randomised study. BMJ. Mar. 30. 1996;312(7034):813-6. [pmid: 8608288].
McLachlan SA, Allenby A, Matthews J, et al. Randomized trial of coordinated psychosocial interventions based on patient self-assessments versus standard care to improve the psychosocial functioning of patients with cancer. J Clin Oncol. Nov. 1. 2001;19(21):4117-25. [pmid: 11689579].
McQuellon RP, Wells M, Hoffman S, et al. Reducing distress in cancer patients with an orientation program. Psychooncology. May–Jun. 1998;7(3):207-17. [pmid: 9638782].
Mendes de Leon CF, Czajkowski SM, Freedland KE, et al. The effect of a psychosocial intervention and quality of life after acute myocardial infarction: the Enhancing Recovery in Coronary Heart Disease (ENRICHD) clinical trial. J Cardiopulm Rehabil. Jan–Feb. 2006;26(1):9-13. quiz 4–5. [pmid: 16617220].
Merrill RM, Taylor P, Aldana SG. Coronary Health Improvement Project (CHIP) is associated with improved nutrient intake and decreased depression. Nutrition. Apr. 2008;24(4):314-21. [pmid: 18296026].
Michalsen A, Grossman P, Lehmann N, et al. Psychological and quality-of-life outcomes from a comprehensive stress reduction and lifestyle program in patients with coronary artery disease: results of a randomized trial. Psychother Psychosom. 2005;74(6):344-52. [pmid: 16244510].
Midtgaard J, Rorth M, Stelter R, et al. The impact of a multidimensional exercise program on self-reported anxiety and depression in cancer patients undergoing chemotherapy: a phase II study. Palliat Support Care. Sep. 2005;3(3):197-208. [pmid: 16594459].
Miller DK, Chibnall JT, Videen SD, et al. Supportive-affective group experience for persons with life-threatening illness: reducing spiritual, psychological, and death-related distress in dying patients. J Palliat Med. Apr. 2005;8(2):333-43. [pmid: 15890044].
Mitchell PH, Veith RC, Becker KJ, et al. Brief psychosocial–behavioral intervention with antidepressant reduces poststroke depression significantly more than usual care with antidepressant: living well with stroke: randomized, controlled trial. Stroke. Sep. 2009;40(9):3073-8. [pmid: 19661478].
Molloy AR, Nicholas MK, Asghari A, et al. Does a combination of intensive cognitive-behavioral pain management and a spinal implantable device confer any advantage? A preliminary examination. Pain Pract. Jun. 2006;6(2):96-103. [pmid: 17309716].
Morone NE, Weiner DK, Belnap BH, et al. The impact of pain and depression on recovery after coronary artery bypass grafting. Psychosom Med. Sep. 2010;72(7):620-5. [pmid: 20562371].
Oh H, Seo W. Decreasing pain and depression in a health promotion program for people with rheumatoid arthritis. J Nurs Scholarsh. 2003;35(2):127-32. [pmid: 12854292].
Osborn RL, Demoncada AC, Feuerstein M. Psychosocial interventions for depression, anxiety, and quality of life in cancer survivors: meta-analyses. Int J Psychiatry Med. 2006;36(1):13-34. [pmid: 16927576].
Ouwens M, Hulscher M, Hermens R, et al. Implementation of integrated care for patients with cancer: a systematic review of interventions and effects (Structured abstract). International Journal for Quality in Health Care. 2009:137-44. [pmid: 19147593].
Pariser D, O'Hanlon A. Effects of telephone intervention on arthritis self-efficacy, depression, pain, and fatigue in older adults with arthritis. J Geriatr Phys Ther. 2005;28(3):67-73. [pmid: 16386168].
Parker JC, Smarr KL, Slaughter JR, et al. Management of depression in rheumatoid arthritis: a combined pharmacologic and cognitive-behavioral approach. Arthritis Rheum. Dec. 15. 2003;49(6):766-77. [pmid: 14673962].
Perestelo-Perez L, Perez-Ramos J, Gonzalez-Lorenzo M, et al. Decision aids for patients facing health treatment decisions in Spain: preliminary results. Patient Educ Couns. Sep. 2010;80(3):364-71. [pmid: 20598470].
Pincus T, Burton AK, Vogel S, et al. A systematic review of psychological factors as predictors of chronicity/disability in prospective cohorts of low back pain. Spine (Phila Pa 1976). Mar. 1. 2002;27(5):E109-20. [pmid: 11880847].
Pols RG, Battersby MW. Coordinated care in the management of patients with unexplained physical symptoms: depression is a key issue. Med J Aust. Jun. 16. 2008;188(12 Suppl):S133-7. [pmid: 18558914].
Porter LS, Keefe FJ, Garst J, et al. Caregiver-assisted coping skills training for lung cancer: Results of a randomized clinical trial. Journal of Pain and Symptom Management. January. 2011;41(1):1-13.
Preyde M, Synnott E. Psychosocial intervention for adults with cancer: a meta-analysis. J Evid Based Soc Work. Oct. 2009;6(4):321-47. [pmid: 20183681].
Ream EK, Richardson A, Wiseman T, et al. Telephone interventions for symptom management in adults with cancer. Cochrane Database of Systematic Reviews. 2009;1.
Rose C, Wallace L, Dickson R, et al. The most effective psychologically-based treatments to reduce anxiety and panic in patients with chronic obstructive pulmonary disease (COPD): a systematic review. Patient Educ Couns. Aug. 2002;47(4):311-8. [pmid: 12135822].
Rutledge T, Reis VA, Linke SE, et al. Depression in heart failure a meta-analytic review of prevalence, intervention effects, and associations with clinical outcomes. J Am Coll Cardiol. Oct. 17. 2006;48(8):1527-37. [pmid: 17045884].
Salminen M, Isoaho R, Vahlberg T, et al. Effects of a health advocacy, counselling, and activation programme on depressive symptoms in older coronary heart disease patients. Int J Geriatr Psychiatry. Jun. 2005;20(6):552-8. [pmid: 15920714].
Salter K, Foley N, Teasell R. Social support interventions and mood status post stroke: a review. Int J Nurs Stud. May. 2010;47(5):616-25. [pmid: 20053402].
Sarna L. Effectiveness of structured nursing assessment of symptom distress in advanced lung cancer. Oncol Nurs Forum. Jul. 1998;25(6):1041-8. [pmid: 9679262].
Scheier MF, Helgeson VS, Schulz R, et al. Moderators of interventions designed to enhance physical and psychological functioning among younger women with early-stage breast cancer. J Clin Oncol. Dec. 20. 2007;25(36):5710-4. [pmid: 17998547].
Schneider S, Moyer A, Knapp-Oliver S, et al. Pre-intervention distress moderates the efficacy of psychosocial treatment for cancer patients: a meta-analysis. J Behav Med. Feb. 2010;33(1):1-14. [pmid: 19784868].
Schulberg HC, Belnap BH, Houck PR, et al. Treating post-CABG depression with telephone-delivered collaborative care: Does patient age affect treatment and outcome?. American Journal of Geriatric Psychiatry. 2011;21.
Schwarz KA, Mion LC, Hudock D, et al. Telemonitoring of heart failure patients and their caregivers: a pilot randomized controlled trial. Prog Cardiovasc Nurs. Winter. 2008;23(1):18-26. [pmid: 18326990].
Sheard T, Maguire P. The effect of psychological interventions on anxiety and depression in cancer patients: results of two meta-analyses. Br J Cancer. Aug. 1999;80(11):1770-80. [pmid: 10468295].
Simpson JS, Carlson LE, Beck CA, et al. Effects of a brief intervention on social support and psychiatric morbidity in breast cancer patients. Psychooncology. Jul–Aug. 2002;11(4):282-94. [pmid: 12203742].
Smeeding SJ, Bradshaw DH, Kumpfer K, et al. Outcome evaluation of the Veterans Affairs Salt Lake City Integrative Health Clinic for chronic pain and stress-related depression, anxiety, and post-traumatic stress disorder. Journal of Alternative & Complementary Medicine. 2010;16(8):823-35.
Smeets RJ, Vlaeyen JW, Kester AD, et al. Reduction of pain catastrophizing mediates the outcome of both physical and cognitive-behavioral treatment in chronic low back pain. J Pain. Apr. 2006;7(4):261-71. [pmid: 16618470].
Smith J, Forster A, Young J. A randomized trial to evaluate an education programme for patients and carers after stroke. Clin Rehabil. Nov. 2004;18(7):726-36. [pmid: 15573828].
Smith SM, Allwright S, O'Dowd T. Does sharing care across the primary-specialty interface improve outcomes in chronic disease? A systematic review. American Journal of Managed Care. April. 2008;14(4):213-24. MEDLINE 18402514. (www.ncbi.nlm.nih.gov/pubmed/18402514). [pmid: 18402514].
Snoek FJ, Skinner TC. Psychological counselling in problematic diabetes: does it help?. Diabet Med. Apr. 2002;19(4):265-73. [pmid: 11942996].
Steed L, Cooke D, Newman S. A systematic review of psychosocial outcomes following education, self-management and psychological interventions in diabetes mellitus. Patient Educ Couns. Sep. 2003;51(1):5-15. [pmid: 12915275].
Stiefel F, Zdrojewski C, Bel Hadj F, et al. Effects of a multifaceted psychiatric intervention targeted for the complex medically ill: a randomized controlled trial. Psychother Psychosom. 2008;77(4):247-56. [pmid: 18443391].
Summers KM, Martin KE, Watson K. Impact and clinical management of depression in patients with coronary artery disease. Pharmacotherapy. Mar. 2010;30(3):304-22. [pmid: 20180613].
Thielke SM, Fan MY, Sullivan M, et al. Pain limits the effectiveness of collaborative care for depression. American Journal of Geriatric Psychiatry. August. 2007;15(8):699-707. MEDLINE 17670998. (www.ncbi.nlm.nih.gov/pubmed/17670998). [pmid: 17670998].
Thomas JJ. Reducing anxiety during phase I cardiac rehabilitation. J Psychosom Res. Apr. 1995;39(3):295-304. [pmid: 7636773].
Thoolen BJ, de Ridder DT, Bensing JM, et al. Psychological outcomes of patients with screen-detected type 2 diabetes: the influence of time since diagnosis and treatment intensity. Diabetes Care. Oct. 2006;29(10):2257-62. [pmid: 17003303].
Trask PC, Paterson AG, Griffith KA, et al. Cognitive-behavioral intervention for distress in patients with melanoma: comparison with standard medical care and impact on quality of life. Cancer. Aug. 15. 2003;98(4):854-64. [pmid: 12910531].
Tsai AC, Morton SC, Mangione CM, et al. A meta-analysis of interventions to improve care for chronic illnesses (Structured abstract). American Journal of Managed Care. 2005;11(8):478-88. [pmid: 16095434].
Turk DC, Audette J, Levy RM, et al. Assessment and treatment of psychosocial comorbidities in patients with neuropathic pain. Mayo Clin Proc. Mar. 2010;85(3 Suppl):S42-50. [pmid: 20194148].
Turner JA, Holtzman S, Mancl L. Mediators, moderators, and predictors of therapeutic change in cognitive-behavioral therapy for chronic pain. Pain. Feb. 2007;127(3):276-86. [pmid: 17071000].
Turner JA, Mancl L, Aaron LA. Short- and long-term efficacy of brief cognitive-behavioral therapy for patients with chronic temporomandibular disorder pain: a randomized, controlled trial. Pain. Apr. 2006;121(3):181-94. [pmid: 16495014].
van Bastelaar KM, Pouwer F, Cuijpers P, et al. Web-based cognitive behavioural therapy (W-CBT) for diabetes patients with co-morbid depression: design of a randomised controlled trial. BMC Psychiatry. 2008;8:9. [pmid: 18284670].
van Bastelaar KM, Pouwer F, Cuijpers P, et al. Web-based depression treatment for type 1 and type 2 diabetic patients: a randomized, controlled trial. Diabetes Care. Feb. 2011;34(2):320-5. [pmid: 21216855].
van der Feltz-Cornelis CM, Nuyen J, Stoop C, et al. Effect of interventions for major depressive disorder and significant depressive symptoms in patients with diabetes mellitus: a systematic review and meta-analysis. Gen Hosp Psychiatry. Jul–Aug. 2010;32(4):380-95. [pmid: 20633742].
van Elderen-van Kemenade T, Maes S, van den Broek Y. Effects of a health education programme with telephone follow-up during cardiac rehabilitation. Br J Clin Psychol. Sep. 1994;33(Pt 3):367-78. [pmid: 7994223].
Vizza J, Neatrour DM, Felton PM, et al. Improvement in psychosocial functioning during an intensive cardiovascular lifestyle modification program. J Cardiopulm Rehabil Prev. Nov–Dec. 2007;27(6):376-83. quiz 84–5. [pmid: 18197071].
Wang MY, Tsai PS, Chou KR, et al. A systematic review of the efficacy of non-pharmacological treatments for depression on glycaemic control in type 2 diabetics. J Clin Nurs. Oct. 2008;17(19):2524-30. [pmid: 18808619].
Weinstock RS, Brooks G, Palmas W, et al. Lessened decline in physical activity and impairment of older adults with diabetes with telemedicine and pedometer use: results from the IDEATel study. Age Ageing. Jan. 2011;40(1):98-105. [pmid: 21081539].
Wells ME, McQuellon RP, Hinkle JS, et al. Reducing anxiety in newly diagnosed cancer patients: a pilot program. Cancer Pract. Mar–Apr. 1995;3(2):100-4. [pmid: 7704066].
Wells-Federman C, Arnstein P, Caudill M. Nurse-led pain management program: effect on self-efficacy, pain intensity, pain-related disability, and depressive symptoms in chronic pain patients. Pain Manag Nurs. Dec. 2002;3(4):131-40. [pmid: 12454805].
Whang W, Shimbo D, Kronish IM, et al. Depressive symptoms and all-cause mortality in unstable angina pectoris (from the Coronary Psychosocial Evaluation Studies [COPES]). Am J Cardiol. Oct. 15. 2010;106(8):1104-7. [pmid: 20920647].
Williams LS, Kroenke K, Bakas T, et al. Care management of poststroke depression: a randomized, controlled trial. Stroke. Mar. 2007;38(3):998-1003. [pmid: 17303771].
Williams S, Dale J. The effectiveness of treatment for depression/depressive symptoms in adults with cancer: a systematic review. Br J Cancer. Feb. 13. 2006;94(3):372-90. [pmid: 16465173].
Yohannes AM, Caton S. Management of depression in older people with osteoarthritis: A systematic review. Aging Ment Health. Aug. 2010;14(6):637-51. [pmid: 20686976].

## Poor quality

Bogner HR, Morales KH, Post EP, et al. Diabetes, depression, and death: a randomized controlled trial of a depression treatment program for older adults based in primary care (PROSPECT). Diabetes Care. Dec. 2007;30(12):3005-10. [pmid: 17717284].
Sriwattanakomen R, Mazumdar S, Belnap B, et al. The effect of comorbid anxiety on post-CABG depressed patients' mental health related quality of life. Journal of General Internal Medicine. June. SUPPL 3. 2010;25:S401.