# Search Strategy

Initial Searches performed 23 May 2011

MEDLINE^®^

Search | Most Recent Queries | Result
#1 | Search “depressive disorder”[MeSH Terms] OR “depressive disorder”[tiab] OR “depression”[MeSH Terms] | 127175
#2 | Search “anxiety disorders”[MeSH Terms] OR “anxiety disorders”[tiab] OR “anxiety disorder”[tiab] OR “anxiety”[MeSH Terms] | 101286
#3 | Search #1 OR #2 | 203606
#4 | Search #3 Limits: Humans, English | 164381
#5 | Search “arthritis”[MeSH Terms] | 177086
#6 | Search #4 AND #5 | 853
#7 | Search “diabetes mellitus”[MeSH Terms] OR “diabetes”[tiab] | 354545
#8 | Search #4 AND #7 | 2313
#9 | Search (chronic[tiab] AND “pain”[MeSH Terms]) OR “chronic pain”[tiab] | 35695
#10 | Search #4 AND #9 | 1988
#11 | Search “cancer”[tiab] | 813675
#12 | Search #4 AND #11 | 4187
#13 | Search “asthma”[MeSH Terms] OR “asthma”[tiab] OR “pulmonary disease, chronic obstructive”[MeSH Terms] OR “chronic obstructive pulmonary disease”[tiab] OR “COPD”[tiab] | 142817
#14 | Search #4 AND #13 | 1190
#15 | Search “stroke”[MeSH Terms] | 63078
#16 | Search #4 AND #15 | 1050
#17 | Search “HIV”[MeSH Terms] | 69536
#18 | Search #4 AND #17 | 111
#19 | Search “heart failure”[MeSH Terms] OR “heart failure”[tiab] | 113507
#20 | Search #4 AND #19 | 669
#21 | Search “myocardial ischaemia”[tiab] OR “myocardial ischemia”[MeSH Terms] OR “myocardial ischemia”[tiab] | 320571
#22 | Search #4 AND #21 | 2328
#23 | Search “coronary artery bypass”[tiab] OR “CABG”[tiab] | 28137
#24 | Search #4 AND #23 | 246
#25 | Search “status post” AND myocardial | 29
#26 | Search #4 AND #25 | 2
#27 | Search “frail elderly”[MeSH Terms] OR “frail elderly”[All Fields] | 5867
#28 | Search #4 AND #27 | 280
#29 | Search complex patient* | 890
#30 | Search #4 AND #29 | 10
#31 | Search #6 OR #8 OR #10 OR #12 OR #14 OR #16 OR #18 OR #20 OR #22 OR #24 OR #26 OR #28 OR #30 | 14022
#32 | Search “Intervention Studies”[MeSH Terms] OR intervention*[tiab] | 409254
#33 | Search “collaborative care”[tiab] | 642
#34 | Search “integrated treatment”[tiab] OR “clinical integration”[tiab] OR “integrated services”[tiab] OR “integrated care”[tiab] OR “integrated health care”[tiab] | 2743
#35 | Search “integrated”[tiab] and “behavioral model”[tiab] | 16
#36 | Search “service coordination” | 105
#37 | Search “chronic disease management” | 711
#38 | Search “coordinated care” | 447
#39 | Search #32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 | 412959
#40 | Search #31 AND #39 | 2206
#41 | Search (“Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[MeSH]) OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] | 446111
#42 | Search #40 AND #41 | 598
#43 | Search “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 47698
#44 | Search #40 AND #43 | 39
#45 | Search “review”[Publication Type] OR “review literature as topic”[MeSH Terms] OR “systematic review”[All Fields] | 1604853
#46 | Search #40 AND #45 | 379
#47 | Search “Comparative Study”[Publication Type] | 1512315
#48 | Search #40 AND #47 | 234
#49 | Search #42 OR #44 OR #46 OR #48” | 1078
#51 | Search #40 Limits: Clinical Trial, Meta-Analysis, Randomized Controlled Trial, Clinical Trial, Phase I, Clinical Trial, Phase II, Clinical Trial, Phase III, Clinical Trial, Phase IV, Comparative Study, Evaluation Studies, Multicenter Study | 870
#52 | Search #49 OR #51 | 1235

Cochrane Library

ID | Search | Hits
#1 | “depressive disorder”[MeSH Terms] OR “depressive disorder”[tiab] OR “depression”[MeSH Terms] | 27842
#2 | “anxiety disorders”[MeSH Terms] OR “anxiety disorders”[tiab] OR “anxiety disorder”[tiab] OR “anxiety”[MeSH Terms] | 17159
#3 | (#1 OR #2) | 38401
#4 | “arthritis”[MeSH Terms] | 8026
#5 | “diabetes mellitus”[MeSH Terms] OR “diabetes”[tiab] | 21190
#6 | (chronic[tiab] AND “pain”[MeSH Terms]) OR “chronic pain”[tiab] | 7478
#7 | “cancer”[tiab] | 63095
#8 | “asthma”[MeSH Terms] OR “asthma”[tiab] OR “pulmonary disease, chronic obstructive”[MeSH Terms] OR “chronic obstructive pulmonary disease”[tiab] OR “COPD”[tiab] | 26210
#9 | “stroke”[MeSH Terms] | 25211
#10 | “HIV”[MeSH Terms] | 9517
#11 | “heart failure”[MeSH Terms] OR “heart failure”[tiab] | 9329
#12 | “myocardial ischaemia”[tiab] OR “myocardial ischemia”[MeSH Terms] OR “myocardial ischemia”[tiab] | 2932
#13 | “coronary artery bypass”[tiab] OR “CABG”[tiab] | 6474
#14 | “status post” AND myocardial | 5
#15 | “frail elderly”[MeSH Terms] OR “frail elderly”[All Fields] | 605
#16 | (#4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15) | 168623
#17 | (#3 AND #16) | 5834
#18 | “Intervention Studies”[MeSH Terms] | 2571
#19 | “collaborative care”[tiab] | 194
#20 | “integrated treatment”[tiab] OR “clinical integration”[tiab] OR “integrated services”[tiab] OR “integrated care”[tiab] OR “integrated health care”[tiab] | 291
#21 | “integrated”[tiab] and “behavioral model”[tiab] | 0
#22 | “service coordination” | 6
#23 | “chronic disease management” | 79
#24 | “coordinated care” | 43
#25 | (#18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24) | 3145
#26 | (#17 AND #25) | 209
#27 | (“Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[MeSH]) OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] | 341441
#28 | “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 17038
#29 | “review”[Publication Type] OR “review literature as topic”[MeSH Terms] OR “systematic review”[All Fields] | 94139
#30 | “Comparative Study”[Publication Type] | 135576
#31 | (#27 OR #28 OR #29 OR #30) | 438947
#32 | (#26 AND #31) | 204
#33 | “Humans”[MeSH] | 424963
#34 | (#32 AND #33) | 175

EMBASE

ID | Search | Results
1 | ‘anxiety disorder’/exp OR ‘anxiety’/exp OR ‘depression’/exp | 382806
2 | ‘arthritis’/exp OR ‘diabetes mellitus’/exp OR ‘chronic pain’/exp OR ‘neoplasm’/exp OR ‘asthma’/exp OR ‘chronic obstructive lung disease’/exp OR ‘stroke’/exp OR ‘human immunodeficiency virus’/exp OR ‘heart failure’/exp OR ‘heart muscle ischemia’/exp OR ‘coronary artery bypass graft’/exp OR ‘frail elderly’/exp OR ‘complex patient’ OR (‘status post’ AND myocardial) | 4346558
3 | #1 AND #2 | 43721
4 | ‘intervention study’/exp OR ‘collaborative care’ OR ‘integrated treatment’ OR ‘clinical integration’ OR ‘integrated services’ OR ‘integrated health care’ OR ‘integrated care’ OR ‘integrated behavioral model’ OR ‘patient care planning’/exp | 43591
5 | #3 AND #4 | 354
6 | #5 AND [humans]/lim AND [english]/lim AND ([embase]/lim OR [embase classic]/lim) | 250

PsycINFO & CINAHL

# | Query | Last Run Via | Results
S1 | (MH “Anxiety+”) OR (MH “Anxiety Disorders+”) OR (MH “Depression+”) OR “depressive disorder” | Interface - EBSCOhost Search Screen - Advanced Search Database - PsycINFO;CINAHL with Full Text | 60953
S2 | (MH “Arthritis+”) OR (MH “Chronic Pain”) OR (MH “Neoplasms+”) OR (MH “Diabetes Mellitus+”) OR (MH “Asthma+”) OR (MH “Pulmonary Disease, Chronic Obstructive+”) OR (MH “Stroke”) OR (MH “Human Immunodeficiency Virus+”) OR (MH “Heart Failure+”) OR (MH “Myocardial Ischemia+”) OR (MH “Coronary Artery Bypass+”) OR (MH “Frail Elderly”) OR “frail elderly” OR “complex patient” | Interface - EBSCOhost Search Screen - Advanced Search Database - PsycINFO;CINAHL with Full Text | 305296
S3 | S1 and S2 | Interface - EBSCOhost Search Screen - Advanced Search Database - PsycINFO;CINAHL with Full Text | 6787
S4 | “intervention studies” OR “collaborative care” OR “integrated treatment” OR “clinical integration” OR “integrated services” OR (MH “Health Care Delivery, Integrated”) OR (MH “Integrative Medicine”) OR “integrated care” OR “integrated behavioral model” OR “integratd health care” OR (MH “Patient Care”) | Interface - EBSCOhost Search Screen - Advanced Search Database - PsycINFO;CINAHL with Full Text | 17848
S5 | S3 and S4 | Interface - EBSCOhost Search Screen - Advanced Search Database - PsycINFO;CINAHL with Full Text | 83

Total number of records before duplicates removed: 1743

Search of clinicaltrials.gov performed 13 December 2011

Collaborative care \| interventional studies \| “Anxiety Disorders” | 16
Collaborative care \| interventional studies \| “Depression” | 59
Integrated treatment \| interventional studies \| “Depression” | 6
Clinical integration\| interventional studies \| “Depression” | 0
Integrated services \| interventional studies \| “Depression” | 3
Integrated care \| interventional studies \| “Depression” | 1
Integrated health care \| interventional studies \| “Depression” | 0
Integrated \| interventional studies \| “Depression” | 37
Behavioral model\| interventional studies \| “Depression” | 0
Service coordination \| interventional studies \| “Depression” | 0
Chronic disease management \| interventional studies \| “Depression” | 0
Coordinated care \| interventional studies \| “Depression” | 1
Total, including duplicates | 123
Total, minus duplicates | 100

The following update searches were performed on 19 December 2011

MEDLINE^®^

Search | Query | Items found
#1 | Search “depressive disorder”[MeSH Terms] OR “depressive disorder”[tiab] OR “depression”[MeSH Terms] | 131868
#2 | Search “anxiety disorders”[MeSH Terms] OR “anxiety disorders”[tiab] OR “anxiety disorder”[tiab] OR “anxiety”[MeSH Terms] | 105172
#3 | Search #1 OR #2 | 210976
#4 | Search #3 Limits: Humans, English | 170496
#5 | Search “arthritis”[MeSH Terms] | 181036
#6 | Search #4 AND #5 | 892
#7 | Search “diabetes mellitus”[MeSH Terms] OR “diabetes”[tiab] | 368549
#8 | Search #4 AND #7 | 2457
#9 | Search (chronic[tiab] AND “pain”[MeSH Terms]) OR “chronic pain”[tiab] | 37227
#10 | Search #4 AND #9 | 2091
#11 | Search “cancer”[tiab] | 852198
#12 | Search #4 AND #11 | 4434
#13 | Search “asthma”[MeSH Terms] OR “asthma”[tiab] OR “pulmonary disease, chronic obstructive”[MeSH Terms] OR “chronic obstructive pulmonary disease”[tiab] OR “COPD”[tiab] | 147430
#14 | Search #4 AND #13 | 1254
#15 | Search “stroke”[MeSH Terms] | 66379
#16 | Search #4 AND #15 | 1111
#17 | Search “HIV”[MeSH Terms] | 71832
#18 | Search #4 AND #17 | 113
#19 | Search “heart failure”[MeSH Terms] OR “heart failure”[tiab] | 117943
#20 | Search #4 AND #19 | 706
#21 | Search “myocardial ischaemia”[tiab] OR “myocardial ischemia”[MeSH Terms] OR “myocardial ischemia”[tiab] | 327670
#22 | Search #4 AND #21 | 2431
#23 | Search “coronary artery bypass”[tiab] OR “CABG”[tiab] | 29033
#24 | Search #4 AND #23 | 261
#25 | Search “status post” AND myocardial | 31
#26 | Search #4 AND #25 | 2
#27 | Search “frail elderly”[MeSH Terms] OR “frail elderly”[All Fields] | 6165
#28 | Search #4 AND #27 | 289
#29 | Search complex patient* | 964
#30 | Search #4 AND #29 | 12
#31 | Search #6 OR #8 OR #10 OR #12 OR #14 OR #16 OR #18 OR #20 OR #22 OR #24 OR #26 OR #28 OR #30 | 14766
#32 | Search “Intervention Studies”[MeSH Terms] OR intervention*[tiab] | 433876
#33 | Search “collaborative care”[tiab] | 712
#34 | Search “integrated treatment”[tiab] OR “clinical integration”[tiab] OR “integrated services”[tiab] OR “integrated care”[tiab] OR “integrated health care”[tiab] | 2927
#35 | Search “integrated”[tiab] and “behavioral model”[tiab] | 17
#36 | Search “service coordination” | 109
#37 | Search “chronic disease management” | 778
#38 | Search “coordinated care” | 479
#39 | Search #32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 | 437827
#40 | Search #31 AND #39 | 2373
#41 | Search (“Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[MeSH]) OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] | 463648
#42 | Search #40 AND #41 | 645
#43 | Search “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 51984
#44 | Search #40 AND #43 | 48
#45 | Search “review”[Publication Type] OR “review literature as topic”[MeSH Terms] OR “systematic review”[All Fields] | 1655861
#46 | Search #40 AND #45 | 404
#47 | Search “Comparative Study”[Publication Type] | 1545102
#48 | Search #40 AND #47 | 241
#49 | Search #42 OR #44 OR #46 OR #48 | 1152
#50 | Search #40 Limits: Clinical Trial, Meta-Analysis, Randomized Controlled Trial, Clinical Trial, Phase I, Clinical Trial, Phase II, Clinical Trial, Phase III, Clinical Trial, Phase IV, Comparative Study, Evaluation Studies, Multicenter Study | 932
#51 | Search #49 OR #50 | 1320
#52 | Search (“2011/03/01”[Date - Entrez] : “3000”[Date - Entrez]) AND #51 | 59

Cochrane Library

ID | Search | Hits
#1 | “depressive disorder”[MeSH Terms] OR “depressive disorder”[tiab] OR “depression”[MeSH Terms] | 28481
#2 | “anxiety disorders”[MeSH Terms] OR “anxiety disorders”[tiab] OR “anxiety disorder”[tiab] OR “anxiety”[MeSH Terms] | 17664
#3 | (#1 OR #2) | 39261
#4 | “arthritis”[MeSH Terms] | 8019
#5 | “diabetes mellitus”[MeSH Terms] OR “diabetes”[tiab] | 21797
#6 | (chronic[tiab] AND “pain”[MeSH Terms]) OR “chronic pain”[tiab] | 7913
#7 | “cancer”[tiab] | 63979
#8 | “asthma”[MeSH Terms] OR “asthma”[tiab] OR “pulmonary disease, chronic obstructive”[MeSH Terms] OR “chronic obstructive pulmonary disease”[tiab] OR “COPD”[tiab] | 26579
#9 | “stroke”[MeSH Terms] | 25845
#10 | “HIV”[MeSH Terms] | 9681
#11 | “heart failure”[MeSH Terms] OR “heart failure”[tiab] | 9484
#12 | “myocardial ischaemia”[tiab] OR “myocardial ischemia”[MeSH Terms] OR “myocardial ischemia”[tiab] | 2952
#13 | “coronary artery bypass”[tiab] OR “CABG”[tiab] | 6519
#14 | “status post” AND myocardial | 7
#15 | “frail elderly”[MeSH Terms] OR “frail elderly”[All Fields] | 588
#16 | (#4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15) | 170814
#17 | (#3 AND #16) | 6180
#18 | “Intervention Studies”[MeSH Terms] | 2728
#19 | “collaborative care”[tiab] | 218
#20 | “integrated treatment”[tiab] OR “clinical integration”[tiab] OR “integrated services”[tiab] OR “integrated care”[tiab] OR “integrated health care”[tiab] | 323
#21 | “integrated”[tiab] and “behavioral model”[tiab] | 1
#22 | “service coordination” | 7
#23 | “chronic disease management” | 96
#24 | “coordinated care” | 51
#25 | (#18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24) | 3353
#26 | (#17 AND #25) | 280
#27 | (“Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[MeSH]) OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] | 350583
#28 | “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 18223
#29 | “review”[Publication Type] OR “review literature as topic”[MeSH Terms] OR “systematic review”[All Fields] | 100203
#30 | “Comparative Study”[Publication Type] | 138150
#31 | (#27 OR #28 OR #29 OR #30) | 452959
#32 | (#26 AND #31) | 274
#33 | “Humans”[MeSH] | 419855
#34 | (#32 AND #33) | 245
#35 | (#34), in 2011 | 65

EMBASE

ID | Search | Results
1 | ‘anxiety disorder’/exp OR ‘anxiety’/exp OR ‘depression’/exp | 404,850
2 | ‘arthritis’/exp OR ‘diabetes mellitus’/exp OR ‘chronic pain’/exp OR ‘neoplasm’/exp OR ‘asthma’/exp OR ‘chronic obstructive lung disease’/exp OR ‘stroke’/exp OR ‘human immunodeficiency virus’/exp OR ‘heart failure’/exp OR ‘heart muscle ischemia’/exp OR ‘coronary artery bypass graft’/exp OR ‘frail elderly’/exp OR ‘complex patient’ OR (‘status post’ AND myocardial) | 4,581,284
3 | #1 AND #2 | 47,583
4 | ‘intervention study’/exp OR ‘collaborative care’ OR ‘integrated treatment’ OR ‘clinical integration’ OR ‘integrated services’ OR ‘integrated health care’ OR ‘integrated care’ OR ‘integrated behavioral model’ OR ‘patient care planning’/exp | 46,634
5 | #3 AND #4 | 423
6 | #5 AND [humans]/lim AND [english]/lim AND ([embase]/lim OR [embase classic]/lim) AND [1-3-2011]/sd NOT [31-12-2011]/sd | 75

PsycINFO & CINAHL

# | Query | Results
S1 | (MH “Anxiety+”) OR (MH “Anxiety Disorders+”) OR (MH “Depression+”) OR “depressive disorder” | 65947
S2 | (MH “Arthritis+”) OR (MH “Chronic Pain”) OR (MH “Neoplasms+”) OR (MH “Diabetes Mellitus+”) OR (MH “Asthma+”) OR (MH “Pulmonary Disease, Chronic Obstructive+”) OR (MH “Stroke”) OR (MH “Human Immunodeficiency Virus+”) OR (MH “Heart Failure+”) OR (MH “Myocardial Ischemia+”) OR (MH “Coronary Artery Bypass+”) OR (MH “Frail Elderly”) OR “frail elderly” OR “complex patient” | 327543
S3 | S1 and S2 | 7365
S4 | “intervention studies” OR “collaborative care” OR “integrated treatment” OR “clinical integration” OR “integrated services” OR (MH “Health Care Delivery, Integrated”) OR (MH “Integrative Medicine”) OR “integrated care” OR “integrated behavioral model” OR “integratd health care” OR (MH “Patient Care”) | 19346
S5 | S3 and S4 Limiters - Published Date from: 20110301-20120131 | 5

Total number of records before duplicates removed: 204

Handsearches of the following references yielded 111 additional records
- Bower P, Gilbody S, Richards D, et al. Collaborative care for depression in primary care. Making sense of a complex intervention: systematic review and meta-regression (Structured abstract). British Journal of Psychiatry. 2006;(6):484-93. [pmid: 17139031].
- Katon WJ, Seelig M. Population-based care of depression: team care approaches to improving outcomes. J Occup Environ Med. Apr. 2008;50(4):459-67. [pmid: 18404019].
- van der Feltz-Cornelis CM, Nuyen J, Stoop C, et al. Effect of interventions for major depressive disorder and significant depressive symptoms in patients with diabetes mellitus: a systematic review and meta-analysis. Gen Hosp Psychiatry. Jul–Aug. 2010;32(4):380-95. [pmid: 20633742].

Peer Reviewers suggested the following additional references
- Bogner HR, Morales KH, de Vries HF, Cappola AR. Integrated management of type 2 diabetes mellitus and depression treatment to improve medication adherence: a randomized controlled trial. Ann Fam Med. 2012;10(1):15-22. [pmid: 22230826].
- Lin EH, Von Korff M, Ciechanowski P, et al. Treatment adjustment and medication adherence for complex patients with diabetes, heart disease, and depression: a randomized controlled trial. Ann Fam Med. 2012;10(1):6-14. [pmid: 22230825].
- Rollman BL, Belnap BH. The Bypassing the Blues trial: Collaborative care for post-CABG depression and implications for future research. Cleveland Clinic J Med. 2011;78(Suppl 1):S4-S12.
- Boult C, Reider L, Leff B, Frick KD, Boyd CM, Wolff JL, Frey K, et al. The effect of guided care teams on the use of health services: results from a cluster-randomized controlled trial. Arch Intern Med. 2011;171(5):460-6. [pmid: 21403043].

Total references from main and update searches, handsearches and Peer Reviewer suggestions, and the clinicaltrials.gov search, minus duplicates = 1,903

In response to Peer Reviewer comments, we performed two supplemental searches, each using a different intervention term.

In the first, we searched for any of the following (combined with our non-intervention search terms:

- “Decision Support Systems, Clinical”[MeSH]
- “Registry”[MeSH]
- “decision support” (anywhere in record)
- reminder system(s) (anywhere in record)
- “patient care management” (anywhere in record)

Those searches yielded 45 citations of which 15 had been identified during our review. The remaining 30 abstracts were reviewed and none met our inclusion criteria.

Second, we performed a search using “disease management” rather than “chronic disease management,” and the additional yield was 66 abstracts. Upon review, none of those met all of our inclusion criteria.