# Results

We identified 417 nonduplicate publications through the search process, with 178 proceeding to full text review (Figure 2). Seventy articles were included in the review, representing 63 distinct study populations: 28 RCTs, four clinical trials, 14 cohort studies, eight case-series, six case-control studies, and three cross-sectional studies. The most common reasons for exclusion were irrelevance to the topic and ineligible study size. Forty-six articles pertain to Key Question (KQ) 1, 52 articles to KQ2, 19 articles to KQ3, 52 articles to KQ4, 18 articles to KQ5, and 11 articles to KQ6. Table 3 provides a summary of the progestogen interventions represented in this review in reverse chronologic order. The progestogen interventions include 31 distinct combinations of formulations, route, and dose.

Figure 2 Disposition of articles identified by the search strategy

KQ=Key Question

* The number of articles addressing KQs and those excluded exceed the total number of articles in each category because some articles fit multiple exclusion categories or addressed more than one KQ.

Figure 2 is a flow chart that summarized the selection of articles. There were 326 citations identified by search Medline and EMBASE and another 91 articles were identified by reference lists of these articles. Of these, 239 were excluded at abstract review. The remaining 178 full-text articles were retrieved. 108 were excluded for the following reasons: not related to the use of progestogens to prevent preterm birth, did not address study questions, not original research, or were an ineligible study size. Seventy studies were included in this review.

Table 3 Summary of progestogen interventions

Study Country Total N | Progestogen | Form | Dose & Interval | Target EGA, start; end (weeks) | Indication
Mason et al.27 2010 U.S. N=253 | 17OHP | NR | NR | ≤ 28 6/7; NR | Prior PTB
Harper et al.28 2010 U.S. N=852 | 17OHP | IM | 250 mg q 7d | 16–21.9; 36.9 | Prior PTB
Gonzalez-Quintero et al.29 2010 U.S. N=4,238 | 17OHP | IM | 250 mg q 7d | ≤ 26; 36 | Prior PTB
Combs et al.30 2010 U.S. N=89 | 17OHP | IM | 250 mg q 7d | 16–22; 34 | Triplets
Cetingoz et al.31 2010 Turkey N=160 | Progesterone^†^ | Vaginal Supp | 100 mg qd | 24; 34 | Varied risk factors
Berghella et al.32 2010 U.S. N=300 | 17OHP | IM | 250 mg q 7d | 16; 36 | Varied risk factors
Rittenberg et al33. 2009 U.S. N=770 | 17OHP | IM | 250 mg q 7–10d | < 21 (80.4%); 36 | Prior PTB
Rai et al.34 2009 India N=150 | Progesterone^†^ | Oral | 100 mg b.i.d. | 18–24; 36 | Prior PTB
Norman et al.35 2009 UK N=500 | Progesterone | Vaginal Gel | 90 mg qd | 24; 34 | Twins
Majhi et al.36 2009 India N=100 | Progesterone^†^ | Vaginal Cap | 100 mg qd | 20–24; 36 | Prior PTB
Keeler et al.37 2009 U.S. N=91 | 17OHP | IM | 250 mg q 7d | 16–24; 36 | Varied risk factors
Gyamfi et al.38 2009 U.S. N=1,094 | 17OHP | IM | 250 mg q 7d | 16–20.9; 34–36 | Prior PTB Twins
Durnwald et al.39 2009 U.S. N=200 | 17OHP | IM | NR | 15.0 ± 4.1; 36 | Prior PTB
Caritis et al.40 2009 U.S. N=134 | 17OHP | IM | 250 mg q 7d | 16–21; 35 | Triplets
Briery et al.41 2009 U.S. N=30 | 17OHP | IM | 250 mg q 7d | 20–30; NR | Twins
Ventolini et al.42 2008 U.S. N=606 | 17OHP | IM | 250 mg q 7d | 16–20.9; NR | Prior PTB
Rittenberg et al.43 2008 U.S. N=166 | 17OHP | IM | 250 mg q 7d | 16–26; NR | Prior PTB
Rebarber et al.44 2008 U.S. N=1,882 | 17OHP | IM | 250 mg q 7d | 16–29; NR | Prior PTB
Mason et al.45 2008 U.S. N=104 | 17OHP | IM | 250 mg q 7d | 16–21 or > 21; NR | Prior PTB
Facchinetti et al.46 2008 Italy N=45 | 17OHP | IM | 341 mg q 4d | 25–34; 36 | PTL
Borna et al.47 2008 Iran N=70 | Progesterone^†^ | Vaginal Supp | 400 mg qd | 24–34; NR | PTL
Rouse et al.48 2007 U.S. N=661 | 17OHP | IM | 250 mg q 7d | 16–20; 36 | Twins
Rittenberg et al.49 2007 U.S. N=2,159 | 17OHP | IM | 250 mg q 7d | 16–20.9 (56.5%); NR | Health system
Rebarber et al.50 2007 U.S. N=2,081 | 17OHP | IM | 250 mg q 7d | 16–20.9; NR | Health system
Rebarber et al.51 2007 U.S. N=481 | 17OHP | IM | 250 mg q 7–10 d | 16–20.9; 37 | Health system
O’Brien et al.52 2007 Multinational N=669 | Progesterone | Vaginal Gel | 90 mg qd | 16–23; 37 | Prior PTB
How et al.53 2007 U.S. N=906 | 17OHP | IM | Unknown q 7d | 16–20.9 (66%); NR | Prior PTB
Gonzalez-Quintero et al.54 2007 U.S. N=515 | 17OHP | IM | Unknown q 7d | 16–20.9 (56.7%); NR | Prior PTB
Fonseca et al.55 2007 Multinational N=250 | Progesterone^†^ | Vaginal Cap | 200 mg qd | 24; 34 | Short cervix
Facchinetti et al.56 2007 Italy N=60 | 17OHP | IM | 341 mg q 4d | 25–34; 36 | PTL
Bailit et al.57 2007 U.S. N=502 | Progesterone | IM, Vaginal | NR | NR | Health system
Dudas et al.58 2006 Hungary N=60,994 | 17OHP | IM | 250 mg qd | NR | Varied risk factors
Mason et al.59 2005 U.S. N=38 | 17OHP | IM | 250 mg q 7d | 16–21; 36 | Health system
Meis et al.60 2003 U.S. N=463 | 17OHP | IM | 250 mg q 7d | 16–21; 36 | Prior PTB
da Fonseca et al.61 2003 Brazil N=157 | Progesterone | Vaginal Supp | 100 mg qd | 24; 34 | Varied risk factors
Corrado et al.62 2002 Italy N=584 | Progesterone | IM | 200 mg qd for 3 d after amniocentesis | 16.7 ± 0.8 at amniocentesis; NR | Other
Corrado et al.62 2002 Italy N=584 | 17OHP | IM | 340 mg twice a week until 2^nd^ week after amniocentesis | 16.7 ± 0.8 at amniocentesis; NR | Other
Bacq et al.63 1997 France N=100 | Progesterone^†^ (68.0%) | Oral | 200–1,000 mg qd | NR | Other
Hobel et al.64 1994 U.S. N=3,459 | Provera | Oral | 20 mg (NR) | > 20; NR | Varied risk factors
Noblot et al.65 1991 France N=44 | Ritodrine | IV drip | 0.2 mg/min for 1h | NR | PTL
Noblot et al.65 1991 France N=44 | Progesterone^†^ | Oral | 4× 100 mg q6h for 24h; 4× 100 mg q8h for 24h; 3 100 mg q8h | NR | PTL
Suvonnakote66 1986 Thailand N=75 | 17OHP | IM | 250 mg q 7d | 16–20; 38 | Varied risk factors
Erny et al.67 1986 France N=7 | Progesterone^†^ | Oral | 4, 100 mg capsules (NR) | 30–36; NR | PTL
Yemini et al.68 1985 Israel N=80 | 17OHP | IM | 250–12,500 mg over 36 wks (NR) | 12.2 ± 3.3; 37 | Varied risk factors
Resseguie et al.69 1985 U.S. N=4,719 | 17OHP | NR | NR | 8.6 (median); NR | Other
Resseguie et al.69 1985 U.S. N=4,719 | Progesterone | NR | NR | 8.5 (median); NR | Other
Kester et al.70 1984 U.S. N=50 | 17OHP | IM | 250 mg q 7d | 4–24; NR | Other
Szekeres-Bartho et al.71 1983 Hungary N=33 | 17OHP | IM | 250 mg q 7d | 27–30; 34 | PTL
Hauth et al.72 1983 U.S. N=246 | 17OHP | IM | 1,000 mg q 7d | 16–20; 36 | Varied risk factors
Kauppila et al.73 1980 Finland N=48 | 17OHP | IM | 250 mg day 1 and 3; 250 mg q 7d | 27–36; 37 | PTL
Hartikainen-Sorri et al.74 1980 Finland N=77 | 17OHP | IM | 250 mg q 7d | 28–33; 36 | Twins
Cortes-Prieto et al.75 1980 Spain N=415 | Allylestrenol | Oral | 10–40 mg qd | NR; 1–2 before term | Varied risk factors
Kester et al.13 1980 U.S. N=62 | DES | NR | 50–14,000 mg (NR) | 6, 36 | Other
Kester et al.13 1980 U.S. N=62 | DES; Progesterone | NR | 56–14,215 mg (NR); 100–1,890 mg (NR) | 6, 36 | Other
Kester et al.13 1980 U.S. N=62 | Natural Progesterone | NR | 25–1,955 mg (NR) | 6, 36 | Other
Kester et al.13 1980 U.S. N=62 | Synthetic Progesterone | NR | 125–2,198 mg (NR) | 6, 36 | Other
Johnson et al.76 1979 U.S. N=21 | 17OHP | IM | 250 mg q 7d | 16; 36 | Varied risk factors
Breart et al.77 1979 France N=211 | 17OHP | IM | 500 mg 2x/wk | 20–34; 37 | PTL
Breart et al.77 1979 France N=211 | Chlormadinone acetate | Oral | 25 mg qd | 20–34; 37 | PTL
Reinisch & Karrow78 1977 U.S. N=141 | Unspecified progestin | NR | Total: 478–10,650 mg (NR) | 4.0; 36.1 | Other
Meyer-Bahlburg et al.15 1977 U.S. N=204 | Unspecified | NR | NR | NR | Other
Johnson et al.79 1975 U.S. N=50 | 17OHP | IM | 250 mg q 7d | < 24; 37 | Prior PTB
Hill et al.80 1975 U.S. N=73 | 17OHP | NR | 250–7,500 mg (NR) | 13.6; NR | Other
Hill et al.80 1975 U.S. N=73 | Progesterone | IM | 100 mg (NR) | 13.6; NR | Other
Øvlisen & Iversen16 1963 Denmark N=63 | 6α-methyl-17α-acetoxy-progesterone | NR | 180 mg qd for 3 d, then 60 mg qd for 4 d | NR | PTL
Fuchs & Stakemann14 1960 Denmark N=126 | Progesterone | NR | 200 mg qd for 3 d, then 150 mg for 2 d, & then 100 mg qd | NR | PTL

† Micronized progesterone

17OHP = 17 alpha-hydroxyprogesterone caproate; Cap = capsule; IM = intramuscular; mg = milligrams; NR = not reported; PTB = preterm birth; PTL = preterm labor; q = every; qd = every day; Supp = suppository; wk = week.

## KQ1 Maternal, Fetal, and Neonatal Health Outcomes

In this section we provide an overview of the content of the literature focused on the types of studies, settings, and study populations that make up the current state of the science. Then in turn, we summarize the evidence that relates progestogen use to antenatal and maternal outcomes, risk of preterm birth, and fetal and neonatal outcomes. Within each of these outcome categories we have organized the research findings by the risk factors that made the study participants eligible for progestogen treatment. These indications included prior preterm birth, multiple gestations, symptomatic preterm labor, short cervix, and treatment of those women with multiple risk factors. We organized outcomes by the risk factors of the study populations, since applicability is a central question for women, clinicians, and payers who want to know: does this research apply in this situation? Is this intervention likely to provide benefit if used for an individual with specific characteristics that make her at higher risk of preterm birth? Where a sufficient number of studies with some common elements allowed, we have provided aggregate estimates of effects from meta-analyses.

### Content of the Literature

Forty-six publications address maternal, fetal, and neonatal health outcomes of progestogen treatment for prevention of preterm birth. They represent 41 unique study populations. These 41 studies include 26 RCTs;14, 30–32, 34–37, 39, 41, 46–48, 52, 55–56, 60–62, 64–65, 67–68, 72, 77, 79 four clinical trials;66, 71, 73–74 and eleven observational studies, including seven retrospective cohort studies,27, 29, 33, 39, 44, 59, 80 two prospective cohort studies,75–76 one prospective case series;16 and one case-control study.58 Of the 41, 18 were conducted in the United States, 15 in Europe, three in Asia, three in the Middle East, one in South America, and one on multiple continents including U.S. centers.

The preterm birth risk factor prompting progestogen treatment varied. Ten studies focused on women with a history of preterm birth;27, 29, 33–34, 36, 39, 44, 52, 59–60 ten on preterm labor;14, 16, 46–47, 56, 65, 67, 71, 73, 77 six on multiple gestations (four studies of twin pregnancies35, 41, 48, 74 and two with triplets);40, 81 eleven studies enrolled populations with a variety of risk factors;31–32, 37, 58, 61, 64, 66, 68, 75–76, 79 one focused on asymptomatic women with a short cervix on midgestation ultrasound;55 one on active-duty military personnel;72 one on abdominal surgery during but unrelated to the pregnancy;80 and one on midtrimester amniocentesis.62 Studies of populations with varied risk factors included previously mentioned indications, such as history of preterm birth, as well as other conditions, such as previous spontaneous abortion, threatened spontaneous abortion, uterine anomaly, short cervical length and incompetent cervix.

The 41 studies include 23 unique combinations of progestogen formulation, route, and dose. The intramuscular route was most common with 25 studies using intramuscular 17OHP, one using crystalline progesterone, and one using a combination of natural progesterone and 17OHP injections. Seven studies used vaginal progestogens including three with suppositories, two with gel, and two with capsules. Six studies administered oral progestogens including micronized progesterone in three, medroxyprogesterone acetate (trade names Provera® and Perlutex®) in two, and allylestrenol in one. One study compared two progestogens, intramuscular 17OHP and oral chlormadinone acetate.

### Maternal Health Outcomes

Preterm birth is associated with significant maternal morbidity and health care utilization. Progestogen treatment is aimed at not only preventing preterm birth and its associated fetal and neonatal health outcomes, but also improving maternal health outcomes. Thirty-two studies reported maternal health outcomes other than preterm birth (studies for which preterm birth is the only maternal health outcome reported can be found below in the discussion of preterm birth findings). The most clinically significant and frequently reported outcomes for complications during pregnancy and mode of birth are presented in Tables 4–7, of note each of these is mediated by the care provider as part of the process of care; none are patient reported or longer term. Within each table, studies are grouped by progestogen route (intramuscular, vaginal, and oral). Within each route, RCTs are listed first followed by clinical trials and observational studies, and each group of study types is in reverse chronological order.

Table 4 Maternal outcomes for women with a history of preterm birth

Author Year Study Type | Intervention (N) | Antenatal Admission (%) | Preterm Labor (%) | Tocolysis (%) | PPROM (%) | Cesarean Birth (%)
Meis et al.60 2003 RCT | IM (305) | 16.0 | NR | 17.3 | NR | 25.2
Meis et al.60 2003 RCT | Placebo (153) | 13.8 | NR | 15.9 | NR | 26.8
González-Quintero et al.29 2010 Retrospective cohort | IM (2,978) | NR | NR | 13.9^*^ | NR | NR
González-Quintero et al.29 2010 Retrospective cohort | Daily outpatient nursing contact (1,260) | NR | NR | 75.0 | NR | NR
Rittenberg et al.33 2009 Retrospective cohort | IM (342) | 12.6^*^ | 39.2^*^ | 12.9^*^ | 7.3 | NR
Rittenberg et al.33 2009 Retrospective cohort | Daily outpatient nursing contact (342) | 43.0 | 60.8 | 49.7 | 8.5 | NR
Rebarber et al.44 2008 Retrospective cohort | IM (232) | 45.7^*^ | 45.7^*^ | NR | 8.6 | NR
Rebarber et al.44 2008 Retrospective cohort | Daily outpatient nursing contact (1,650) | 70.8 | 70.8 | NR | 8.1 | NR
Majhi et al.36 2009 RCT | Vaginal (50) | 2.0 | NR | NR | NR | 8.0
Majhi et al.36 2009 RCT | None (50) | 6.0 | NR | NR | NR | 14.0
O’Brien et al.52 2007 RCT | Vaginal (309) | 25.6 | NR | 11.3 | 12.0 | 29.0
O’Brien et al.52 2007 RCT | Placebo (302) | 24.8 | NR | 10.3 | 12.6 | 27.8
Rai et al.34 2009 RCT | Oral (74) | NR | NR | 20.3 | NR | NR
Rai et al.34 2009 RCT | Placebo (74) | NR | NR | 27.0 | NR | NR

* Findings are statistically significant across treatment and placebo groups.

IM = intramuscular; NR = not reported; PPROM = preterm premature rupture of membranes; RCT = randomized control trial.

Table 5 Maternal outcomes for women with preterm labor

Author Year Study Type | Intervention (N) | Antenatal Admission (d) | PTL Recurrence (%) | Tocolysis (%) | PPROM (%) | Latency From PTL to Birth Days ± SD | Cesarean Birth (%)
Facchinetti et al.56 2007 RCT | IM (30) | NR | NR | NR | NR | 35.3 ± 19.1^*^ | NR
Facchinetti et al.56 2007 RCT | None (30) | NR | NR | NR | NR | 25.5 ± 15.1 | NR
Bréart et al.77 1979 RCT | IM (105) | NR | NR | 37.0 | NR | NR | NR
Bréart et al.77 1979 RCT | Oral (106) | NR | NR | 35.0 | NR | NR | NR
Kauppila et al.73 1980 CT | IM (24) | NR | NR | 0 | NR | 38.1 ± 4.3 | NR
Kauppila et al.73 1980 CT | Ritodrine (24) | NR | NR | 100 | NR | 35.9 ± 5.7 | NR
Borna et al.47 2008 RCT | Vaginal (33) | NR | 35.1 | NR | NR | 36.1 ± 17.9 | NR
Borna et al.47 2008 RCT | None (37) | NR | 57.6 | NR | NR | 24.5 ± 27.2 | NR
Noblot et al.65 1991 RCT | Oral with Ritodrine (22) | 13.6 (n=21)^*^ | NR | 100 | 4.5 | 42 | NR
Noblot et al.65 1991 RCT | Placebo with Ritodrine (22) | 17.8 (n=18) | NR | 100 | 13.6 | 45 | NR

* Findings are statistically significant.

CT = clinical trial; IM = intramuscular; NR = not reported; PPROM = preterm premature rupture of membranes; PTL = preterm labor; RCT = randomized control trial; SD = standard deviation.

Table 6 Maternal outcomes for women with multiple gestation

Author Year Study Type | Intervention (N) | Antenatal Admission (%) | Preterm Labor (%) | Tocolysis (%) | PPROM (%) | Cesarean Birth (%)
Combs et al.30 2010 RCT | IM (56, triplets) | NR | NR | 78.6 | NR | 92.9
Combs et al.30 2010 RCT | Placebo (25, triplets) | NR | NR | 68.0 | NR | 100
Briery et al.41 2009 RCT | IM (16, twins) | NR | 45.0 | 45.0 | 6.0 | NR
Briery et al.41 2009 RCT | Placebo (14, twins) | NR | 35.0 | 35.0 | 7.0 | NR
Caritis et al.40 2009 RCT | IM (71, triplets) | NR | NR | 47.0 | 8.0 | 100
Caritis et al.40 2009 RCT | Placebo (63, triplets) | NR | NR | 44.0 | 11.0 | 98.0
Rouse et al.48 2007 RCT | IM (325, twins) | NR | NR | 21.9 | NR | 61.7
Rouse et al.48 2007 RCT | Placebo (330, twins) | NR | NR | 29.4 | NR | 62.2
Hartikainen-Sorri et al.74 1980 CT | IM (39, twins) | 94.9 | NR | NR | NR | NR
Hartikainen-Sorri et al.74 1980 CT | Placebo (38, twins) | 89.5 | NR | NR | NR | NR
Norman et al.35 2009 UK RCT | Vaginal (250, twins) | NR | NR | NR | NR | 59.2^*^
Norman et al.35 2009 UK RCT | Placebo (250, twins) | NR | NR | NR | NR | 64.4

* Findings are statistically significant.

CT = clinical trial; IM = intramuscular; NR = not reported; PPROM = preterm premature rupture of membranes; RCT = randomized control trial.

Table 7 Maternal outcomes for study populations with varied risk factors

Author Year Study Type | Intervention (N) | Antenatal Admission (%) | Preterm Labor (%) | Tocolysis (%) | PPROM (%) | Cesarean Birth (%)
Keeler et al.37 2010 RCT | IM (37) | NR | NR | NR | 37.1 | NR
Keeler et al.37 2010 RCT | Cerclage (42) | NR | NR | NR | 32.5 | NR
Yemini et al.68 1985 RCT | IM (39) | NR | 29.0^*^ | NR | 6.4 | NR
Yemini et al.68 1985 RCT | Placebo (40) | NR | 59.4 | NR | 8.1 | NR
Cetingoz et al.31 2010 RCT | Vaginal (70) | 25.0^*^ | NR | NR | 3.8 | NR
Cetingoz et al.31 2010 RCT | Placebo (80) | 45.7 | NR | NR | 2.9 | NR
da Fonseca et al.61 2003 RCT | Vaginal (72) | 19.4 | NR | NR | NR | NR
da Fonseca et al.61 2003 RCT | Placebo (70) | 31.4 | NR | NR | NR | NR

* Findings are statistically significant.

IM = intramuscular; NR = not reported; PPROM = preterm premature rupture of membranes; RCT = randomized control trial.

In addition to those presented in Tables 4–7, other reported maternal health outcomes include spontaneous abortion;60, 62, 68 changes in cervical length;39, 46, 56 cerclage placement;37, 40, 48, 79 contraction frequency in women diagnosed with preterm labor;61, 65, 67 details of tocolysis use, such as timing, quantity, and duration;65, 77 use of antenatal steroids;30, 40–41, 48, 52, 60 hypertensive disorders;30, 40, 48, 72 gestational diabetes;30 placental abruption;37 premature rupture of membranes;62 chorioamnionitis;30, 35, 37, 40, 48, 60 sepsis;30 timing of birth in relation to treatment using categorical measures for time;14, 16 duration of labor stages;35 postpartum endometritis;30 and postterm pregnancy.72

History of preterm birth. Among studies reporting maternal health outcomes, eight examined progestogen treatment in women with a history of preterm birth, including four RCTs34, 36, 52, 60 and four observational studies.29, 33, 39, 44 Seven of these studies reported maternal outcomes presented in Table 4, and one reported maternal outcomes not presented in the table.39 Of the seven studies presented in Table 4, the intervention was intramuscular 17OHP in four,29, 33, 44, 60 a vaginal micronized progesterone capsule in one,36 vaginal progesterone gel in one,52 and oral micronized progesterone in one.34 Three of the RCTs had a placebo arm,34, 52, 60 and the fourth had a no-treatment arm.36 In the three retrospective cohort studies,29, 33, 44 the women not receiving progesterone had daily nursing surveillance.

Five studies reported antenatal hospitalizations. Three RCTs did not find a significant difference in antenatal hospitalizations with progestogen treatment compared to no treatment.36, 52, 60 One of these trials36 found the rate of antenatal hospitalizations was lower with vaginal progesterone compared to no treatment (2% vs. 6%, p=0.30). The other two trials found a higher rate of antenatal hospitalizations with progestogens, including one60 with intramuscular 17OHP versus placebo (16.0% vs. 13.8%; risk ratio (RR)=1.14; 95% confidence interval (CI): 0.72, 1.86) and another52 with vaginal progesterone versus placebo (25.6% vs. 24.8%; RR=1.14; 95% CI: 0.38, 3.37). The two retrospective cohort studies33, 44 that compared progesterone with daily nursing surveillance did find a significantly lower rate of antenatal hospitalizations in women treated with intramuscular 17OHP (p < 0.001 in both). One study44 found a 45.7 percent hospitalization rate in the 17OHP group compared to 70.8 percent in the control group, and the other study33 had a 12.6 percent hospitalization rate in the 17OHP group compared to 43.0 percent in the control group.

These two retrospective cohort studies33, 44 also found a significantly lower rate of preterm labor in women treated with intramuscular 17OHP versus daily nursing surveillance (p < 0.001 for both). One study44 found a 45.7 percent rate of preterm labor in the 17OHP group compared to 70.8 percent in the control group, and the other study33 had a 39.2 percent preterm labor rate in the 17OHP group compared to 60.8 percent in the control group. None of the other studies reported preterm labor rates.

Five studies reported the rates of tocolysis. Three RCTs did not report a significant difference in tocolysis when women received progestogens.34, 52, 60 The rate of tocolysis was higher with progestogen treatment in a trial60 comparing intramuscular 17OHP to placebo (17.3% vs. 15.9%; RR=1.09; 95% CI: 0.70, 1.69) and a trial52 comparing vaginal progesterone to placebo (11.3% vs. 10.3%; odds ratio (OR)=1.12; 95% CI: 0.67, 1.86). The third RCT with nonsignificant findings34 found a lower rate of tocolysis with oral progesterone compared to placebo (20.3% vs. 27. 0%, p=0.686). Two of the retrospective cohort studies29, 33 found a significantly lower rate of tocolysis in women treated with intramuscular 17OHP compared to those who received daily nursing surveillance (12.9% vs. 49.7%, p < 0.001^33^ and 13.9% vs. 75.0%, p<0.001).29

Three studies reported PPROM rates,33, 44, 52 and did not find a significant difference. The PPROM rate was minimally higher in one study44 comparing intramuscular 17OHP to placebo (8.6% vs. 8.1%, p=0.770). The other studies found a lower PPROM rate with progestogen treatment, including one study52 with vaginal progesterone versus placebo (12.0% vs. 12.6%; OR=0.95; 95% CI: 0.58, 1.53) and another study33 with intramuscular 17OHP versus outpatient nursing surveillance (7.3% vs. 8.5%, p=0.677).

Three studies reported cesarean rates36, 52, 60 and did not find a significant difference. One study52 found a higher cesarean rate with vaginal progesterone compared to placebo (29.0% vs. 27.8%; OR=1.06; 95% CI: 0.75, 1.51). The other studies found a lower rate of cesarean with progestogen treatment, including one study36 with vaginal progesterone versus no treatment (8% vs. 14%; p=0.33) and another study60 with intramuscular 17OHP versus placebo (25.2% vs. 26.8%; RR=0.94; 95% CI: 0.68, 1.30).

Preterm labor. Preterm labor was the indication for progestogen treatment in nine studies reporting maternal health outcomes, including seven RCTs,14, 46–47, 56, 65, 67, 77 one clinical trial,73 and one observational study.16 Five of these studies reported maternal outcomes presented in Table 5, and four reported maternal outcomes not presented in the table.14, 16, 46, 67, 71 Enrollment sizes for studies not included in Table 5 ranged from 45 to 126 participants. Each the five trials in Table 5 used a different dose and route of progestogens. The second trial arm was placebo in one trial;65 no treatment in two trials;47, 56 and a different intervention in two trials, including a different progestogen in one77 and a tocolytic73 in the other.

One trial65 reported on antenatal hospitalizations by mean days hospitalized and found a significantly shorter duration in women treated with oral micronized progesterone and Ritodrine versus placebo and Ritodrine (13.6 days vs. 17.8 days, p < 0.05). One trial47 evaluated the recurrence rate of preterm labor and found it was lower with vaginal progesterone compared to no treatment (35.1% vs. 57.6%), but this difference was not statistically significant (p=0.092). Tocolysis could not be assessed as an outcome in two trials, because it was part of the intervention65 or second arm.73 The other trial77 with tocolysis data analyzed rates in women receiving two progestogens (oral chlormadinone acetate vs. intramuscular 17OHP) and found a nonsignificant difference between the two treatments (35% for oral vs. 37% for intramuscular, p-value not reported). One trial65 reported rates of PPROM and found a nonsignificant difference between groups treated with oral micronized progesterone and Ritodrine versus placebo and Ritodrine (4.5% vs. 13.6%, p-value not reported).

Four trials reported on the latency period from preterm labor treatment to birth. In two trials, the latency period was significantly longer in women treated with progestogens, including one47 with vaginal progesterone versus no treatment (36.1 ± 17.9 days vs. 24.5 ± 27.2 days, p=0.037) and another56 with intramuscular 17OHP versus no treatment (35.3 ± 19.1 days vs. 25.5 ± 15.1 days, p=0.003).56 These two trials had a significant risk of bias; they did not have a placebo control, the event numbers were small, and the confidence intervals were wide. The other two trials found nonsignificant differences in the latency period (p-values not reported) with a longer latency period in the progestogen group (38.1 ± 4.3 days vs. 35.9 ± 5.7 days) in one trial73 and in the placebo group (6.0 weeks with progestogen vs. 6.4 weeks with placebo) in the other trial.65

Multiple gestation. Multiple gestation was the indication for progestogen treatment in six studies, including five RCTs30, 35, 40–41, 48 and one clinical trial,74 all of which reported maternal health outcomes presented in Table 6. Four trials included twin gestations,35, 41, 48, 74 and two trials included triplet gestations.30, 40 The intervention was intramuscular 17OHP 250 mg weekly in five trials30, 40–41, 48, 74 and vaginal progesterone gel 90 mg in one trial.35 All of the trials included a placebo arm.

One trial of twin pregnancies74 reported antenatal admission rates and duration of hospitalization. More women treated with intramuscular 17OHP (94.9%) than placebo (89.5%) were hospitalized, but the length of stay was shorter for the 17OHP group (23.5 ± 10.9 days) than the placebo group (31.2 ± 16.0 days). A test of statistical significance was not reported for the admission rates, but the difference for hospitalization duration was significant (p < 0.01).

One RCT of twin pregnancies41 reported rates of preterm labor and found a higher, but not statistically significant difference, in women treated with intramuscular 17OHP compared to placebo (45% vs. 35%, p=0.98). Four multiple gestation trials reported tocolysis rates.30, 40–41, 48 Two RCTs of triplet pregnancies30, 40 found a higher rate of tocolysis with intramuscular 17OHP compared to placebo (47% vs. 44%; RR=1.0; 95% CI: 0.7, 1.5 and 79% vs. 68%; OR=1.73; 90% CI: 0.51, 5.55) as did a RCT of twin pregnancies41 comparing intramuscular 17OHP to placebo (45% vs. 35%, p=0.98). The third RCT reporting tocolysis rates48 found a lower rate of tocolysis with intramuscular 17OHP in twin pregnancies compared to placebo (21.9% vs. 29.4%; RR=0.7; 95% CI: 0.6, 1.0).

Two trials reported rates of PPROM40–41 and both found a slightly lower rate with progestogen treatment, including a RCT of triplet pregnancies40 comparing intramuscular 17OHP to placebo (8% vs. 11%; RR=0.8; 95% CI: 0.3, 2.1) and a RCT of twin pregnancies41 comparing intramuscular 17OHP to placebo (6% vs. 7%, p=0.525). Four trials reported cesarean birth rates.30, 35, 40, 44 One RCT35 found significantly lower cesarean birth rates with treatment with vaginal progesterone gel versus placebo (59.2% vs. 64.4%, p=0.006). The other three trials that reported cesarean birth rates did not find a significant difference with progestogen treatment, including two RCTs of triplet pregnancies30, 40 comparing intramuscular 17OHP to placebo (100% vs. 98%; RR=1.0; 95% CI: 1.0, 1.1 and 93% vs. 100%; p > 0.99) and a RCT of twin pregnancies48 comparing intramuscular 17OHP to placebo (61.7% vs. 62.2%; RR=1.0; 95% CI: 0.9, 1.1).

Study populations with varied risk factors. Among studies reporting maternal outcomes other than preterm birth, five examined progestogen treatment in populations with varied risk factors (a variety of indications within a single study). Four were RCTs31, 37, 61, 68 that included outcomes presented in Table 7, and one was an observational study (n=50) that reported maternal outcomes not presented in the table.79 Of the trials presented in Table 7, two used a vaginal progesterone suppository,31, 61 two used intramuscular 17OHP,37, 67 three had a placebo arm, and one had a cerclage arm.37

Two trials analyzed the rate of antenatal hospitalizations among women receiving vaginal progesterone suppositories. One trial31 found they were significantly lower among women who received progesterone than those who received placebo (25% vs. 45.7%; OR=2.5; 95% CI: 1.27, 5.04), and the other trial61 found no significant difference between women who received progesterone and placebo (19.4% vs. 31.4%, p-value not reported). One trial67 evaluated preterm labor rates and found they were significantly lower among women treated with intramuscular 17OHP compared to those who received placebo (29.0% vs. 59.4%, p < 0.025). Three trials31, 37, 68 reported PPROM rates and did not find a significant difference between treatment and placebo or cerclage arms. One trial68 compared intramuscular 17OHP and placebo (6.4% vs. 8.1%, p-value not reported), and the other trial31 compared vaginal progesterone suppositories and placebo (3.8% vs. 2.9%, p > 0.05).

Active-duty military personnel. In the one study (n=246)72 in which intramuscular 17OHP was given to active-duty military personnel, the only maternal health outcome reported was preterm labor rates. There was no significant difference between treatment and placebo groups (6.3% vs. 5.7%, p-value not reported).

Abdominal surgery unrelated to pregnancy. In the one study (n=73)80 in which intramuscular 17OHP was given to women who had abdominal surgery unrelated to pregnancy, the only maternal health outcome reported was preterm labor rates. The rate was lower in the treatment group than placebo, 2.9 percent versus 8.6 percent respectively, but no test of statistical significance was provided.

### Preterm Birth Outcomes

Thirty-three studies reported preterm birth outcomes by gestational age. In some, a continuous outcome of mean gestational age birth was reported. Most reported the mean gestational age for all births; a few studies differentiated mean gestational age for preterm and term births. Others reported categorical outcomes by various cut points of gestational age. A number of cut points were used including 37, 36, 35, 34, 32, 30, 28, and 24 weeks. Specific cut points varied slightly depending on whether the day of the cut point was or was not included (for example, ≤ 35 weeks vs. < 35 weeks). A few studies reported categories by a range of gestational age (e.g., 32–34 weeks). The majority of studies reported the total preterm birth rate while a few differentiated spontaneous preterm births from preterm births for which there was an indication.

Preterm birth findings are presented in Tables 8–11. For 34, 32, and 28 weeks’ gestation, cut points have been combined when studies did or did not include the day of the cut point (e.g., ≤ 34 weeks includes studies who reported by ≤ 34 weeks and < 34 weeks). All of the outcomes are for total preterm births, including spontaneous and indicated, unless otherwise noted. Within each table, studies are grouped by progestogen route (intramuscular, vaginal, and oral). Within each route, RCTs are listed first followed by clinical trials and observational studies, and each group of study types is in reverse chronological order.

Table 8 Preterm birth outcomes for women with a history of preterm birth

Author Year Study Type | Intervention (N) | Mean GA ± SD (weeks) | PTB < 37 wk (%) | PTB < 35 wk (%) | PTB ≤ 34 wk (%) | PTB ≤ 32 wk (%) | PTB ≤ 28 wk (%)
Meis et al.60 2003 RCT | IM (306) | NR | 36.3^*^ | 20.6^*^ | NR | 11.4^*^ | NR
Meis et al.60 2003 RCT | Placebo (153) | NR | 54.9 | 30.7 | NR | 19.6 | NR
Mason et al.27 2010 Retrospective cohort | IM (193) | NR | 46.6 | 26.4^*^ | NR | 13.5 | NR
Mason et al.27 2010 Retrospective cohort | No treatment or OB case management (60) | NR | 51.7 | 41.7 | NR | 21.7 | NR
Durnwald et al.39 2009 Retrospective cohort | IM (105) | NR | 42.9 | NR | NR | NR | NR
Durnwald et al.39 2009 Retrospective cohort | None (95) | NR | 35.8 | NR | NR | NR | NR
Rittenberg et al.33 2009 Retrospective cohort | IM (342) | 36.6 ± 3.0 | 45.9 | 12.0^†^ | NR | 3.8^†^ | NR
Rittenberg et al.33 2009 Retrospective cohort | Daily perinatal nursing surveillance (342) | 36.7 ± 2.9 | 42.7 | 10.8 | NR | 5.0 | NR
Rebarber et al.44 2008 Retrospective cohort | IM (232) | 35.4 ± 4.7 | 40.5^†^ | 25.9^†^ | NR | 13.4^*,†^ | NR
Rebarber et al.44 2008 Retrospective cohort | Daily outpatient nursing surveillance (1,650) | 36.0 ± 3.0 | 46.2 | 21.5 | NR | 7.9 | NR
Majhi et al.36 2009 RCT | Vaginal (50) | NR | 12.0^*^ | NR | 4.0 | NR | NR
Majhi et al.36 2009 RCT | None (50) | NR | 38.0 | NR | 6.0 | NR | NR
O’Brien et al.52 2007 RCT | Vaginal (309) | 36.6 ± 3.8 | 41.7 | 22.7 | NR | 10.0 | 3.2
O’Brien et al.52 2007 RCT | Placebo (302) | 36.6 ± 4.2 | 40.7 | 26.5 | NR | 11.3 | 3.0
Rai et al.34 2009 RCT | Oral (74) | 36.1 ± 2.6^*^ | 39.2^*^ | NR | 27.0 | 2.7^*^ | 0
Rai et al.34 2009 RCT | Placebo (74) | 34.0 ± 3.25 | 59.5 | NR | 25.7 | 20.3 | 4.0

* Findings are statistically significant.

GA = gestational age <weeks>; IM = intramuscular; NR = not reported; OB = obstetrical; PTB = preterm birth; RCD = randomized control trial; SD = standard deviation.

† Includes only spontaneous preterm births, total preterm birth rate not reported

Table 9 Preterm birth outcomes for women with preterm labor

Author Year Study Type | Intervention (N) | Mean GA ± SD (weeks) | PTB < 37 wk (%) | PTB < 35 wk (%) | PTB ≤ 34 wk (%) | PTB ≤ 32 wk (%) | PTB ≤ 28 wk (%)
Facchinetti et al.46 2008 RCT | IM (23) | NR | 22.0^*^ | NR | NR | NR | NR
Facchinetti et al.46 2008 RCT | None (22) | NR | 54.0 | NR | NR | NR | NR
Facchinetti et al.56 2007 RCT | IM (30) | NR | 16.0^*^ | 10.0 | NR | NR | NR
Facchinetti et al.56 2007 RCT | None (30) | NR | 57.0 | 23.0 | NR | NR | NR
Kauppila et al.73 1980 CT | IM (24) | 39.1 ± 0.3^*^ | NR | NR | NR | NR | NR
Kauppila et al.73 1980 CT | Ritodrine (24) | 37.7 ± 0.4 | NR | NR | NR | NR | NR
Borna et al.47 2008 RCT | Vaginal | 36.7 ± 1.5^*^ | NR | NR | NR | NR | NR
Borna et al.47 2008 RCT | None (33) | 34.5 ± 1.2 | NR | NR | NR | NR | NR
Noblot et al.65 1991 RCT | Oral (22) | NR | 27.3 | NR | NR | NR | NR
Noblot et al.65 1991 RCT | Placebo plus Ritodrine (22) | NR | 36.4 | NR | NR | NR | NR

* Findings are statistically significant.

† Includes only spontaneous preterm births, total preterm birth rate not reported.

CT = clinical trial; GA = gestational age <weeks>; IM = intramuscular; NR = not reported; PTB = preterm birth; RCT = randomized control trial; SD = standard deviation.

Table 10 Preterm birth outcomes for women with multiple gestation

Author Year Study Type | Intervention (N) | Mean GA ± SD (weeks) | PTB < 37 wk (%) | PTB < 35 wk (%) | PTB ≤ 34 wk (%) | PTB ≤ 32 wk (%) | PTB ≤ 28 wk (%)
Combs et al.30 2010 RCT | IM (56, triplets) | 31.9 ± 4.1 | NR | 76.8 | NR | 33.9 | 16.1
Combs et al.30 2010 RCT
Combs et al.30 2010 RCT | Placebo (25, triplets) | 31.8 ± 2.9 | NR | 84.0 | NR | 52.0 | 8.0
Briery et al.41 2009 RCT | IM (16, twins) | 33.9 ± 4.0 | NR | 44.0 | NR | NR | NR
Briery et al.41 2009 RCT
Briery et al.41 2009 RCT | Placebo (14, twins) | 33.1 ± 2.9 | NR | 79.0 | NR | NR | NR
Caritis et al.40 2009 RCT | IM (71, triplets) | 32.4 | NR | 83.1 | NR | 41.0 | 10.0
Caritis et al.40 2009 RCT
Caritis et al.40 2009 RCT | Placebo (63, triplets) | 33.0 | NR | 84.1 | NR | 30.0 | 11.0
Rouse et al.48 2007 RCT | IM (325, twins) | 34.6 ± 3.9 | 69.5 | 41.5 | NR | 16.9 | 8.0
Rouse et al.48 2007 RCT | Placebo (330, twins) | 34.9 ± 3.6 | 70.3 | 37.3 | NR | 14.5 | 6.1
Hartikainen-Sorri et al.74 1980 CT | IM (39, twins) | 36.9 ± 2.6 | 30.8^†^ | NR | NR | NR | NR
Hartikainen-Sorri et al.74 1980 CT
Hartikainen-Sorri et al.74 1980 CT | Placebo (38, twins) | 37.3 ± 2.4 | 23.7 | NR | NR | NR | NR
Norman et al.35 2009 RCT | Vaginal (250) | 35.4 ± 3.5 | NR | NR | 24.7 | NR | NR
Norman et al.35 2009 RCT
Norman et al.35 2009 RCT | Placebo (250, twins) | 35.7 ± 3.0 | NR | NR | 19.4 | NR | NR

† Includes only spontaneous preterm births, total preterm birth rate not reported.

CT = clinical trial; GA = gestational age <weeks>; IM = intramuscular; NR = not reported; PTB = preterm birth; RCT = randomized control trial; SD = standard deviation.

Table 11 Preterm birth outcomes for study populations with varied risk factors

Author Year Study Type | Intervention (N) | Mean GA ± SD (weeks) | PTB <37 wk (%) | PTB <35 wk (%) | PTB ≤34 wk (%) | PTB ≤32 wk (%) | PTB ≤28 wk (%)
Keeler et al.37 2010 RCT | IM (37) | 33.0 ± 5.9 | 59.4 | 43.2 | NR | 35.1 | 18.9
Keeler et al.37 2010 RCT | Cerclage (42) | 32.9 ± 6.4 | 52.4 | 38.1 | NR | 35.7 | 23.8
Johnson et al.79 1975 RCT | IM (18) | 38.6 ± 1.6^*^ | NR | NR | NR | NR | NR
Johnson et al.79 1975 RCT | Placebo (25) | 35.2 ± 6.7 | NR | NR | NR | NR | NR
Suvonnakote66 1986 CT | IM (35) | NR | 14.3^*^ | NR | 11.4 | NR | 0
Suvonnakote66 1986 CT | None (39) | NR | 48.7 | NR | 17.9 | NR | 5.1
Dudas et al.58 2006 Case-control | IM (433) | 38.8 ± 2.4^*^ | NR | NR | NR | NR | NR
Dudas et al.58 2006 Case-control | Controls (37,718) | 39.4 ± 2.0 | NR | NR | NR | NR | NR
Cetingoz et al.31 2010 RCT | Vaginal (70) | 36.9 ± 2.4^*^ | 40.0^*^ | NR | 8.8^*^ | NR | NR
Cetingoz et al.31 2010 RCT | Placebo (80) | 35.9 ± 3.3 | 57.2 | NR | 24.3 | NR | NR
da Fonseca et al.61 2003 RCT | Vaginal (72) | 37.0 ± 2.8 | 13.8^*^ | NR | 2.8^*^ | NR | NR
da Fonseca et al.61 2003 RCT | Placebo (70) | 36.0 ± 3.3 | 28.5 | NR | 18.6 | NR | NR
Hobel et al.64 1994 RCT | Oral (411) | NR | 11.2 | NR | NR | NR | NR
Hobel et al.64 1994 RCT | Placebo (412) | NR | 7.3 | NR | NR | NR | NR

* Findings are statistically significant

† Includes only spontaneous preterm births, total preterm birth rate not reported.

CT = clinical trial; GA = gestational age <weeks>; IM = intramuscular; NR = not reported; PTB = preterm birth; RCT = randomized control trial; SD = standard deviation.

History of preterm birth. Among studies reporting preterm birth outcomes, ten examined progestogen treatment in women with a history of preterm birth, including four RCTs34, 36, 52, 60 and six retrospective cohort studies.27, 29, 33, 39, 44, 59 Eight of these studies are presented in Table 8. One retrospective cohort study (n=38)59 is not included because gestational age data were incomplete for the women who received progestogen treatment, and no specific gestational age data were provided for controls. Another retrospective cohort study (n=4,238) is not included because gestational age data are provided according to gestational age at prior preterm birth rather than by progestogen treatment and comparison groups.29 Of the eight studies in Table 8, five used intramuscular 17OHP,27, 33, 39, 44, 60 one used a vaginal progesterone capsule,36 one used vaginal progesterone gel,52 and one used oral micronized progesterone.34 Three of the RCTs had a placebo arm,34, 52, 60 and the fourth had a no-treatment arm.36

Four studies33–34, 44, 52 reported mean gestational age at birth. One RCT52 found the mean gestational age to be virtually identical among women treated with vaginal progesterone compared to placebo (36.6 ± 3.8 weeks vs. 36.6 ± 4.2, mean difference=0.0). Two retrospective cohort studies found a minimally lower, and not statistically significant, mean gestational age in women given intramuscular 17OHP versus daily nursing surveillance with findings of 35.4 ± 4.7 weeks versus 36.0 ± 3.0 weeks (p=0.388) in one study44 and 36.6 ± 3.0 weeks versus 36.7 ± 2.9 weeks (p=0.842) in the other.33 One RCT34 found mean gestational age at birth was significantly higher in women who received oral progesterone versus placebo (36.1 ± 2.66 weeks vs. 34.0 ± 3.25 weeks, p < 0.001).

All eight studies reported the proportion of births at less than 37 weeks. Three RCTs found the rate was significantly lower among women who received progestogen treatment, including one36 comparing women using vaginal progesterone to no treatment (12% vs. 38%; RR=0.315; 95% CI: 0.14, 0.72; p=0.0027), one60 comparing intramuscular 17OHP to placebo (36.3% vs. 54.9%; RR=0.66; 95% CI: 0.54, 0.81; p=0.001), and one34 comparing oral progesterone to placebo (39.2% vs. 59.5%, p=0.002). Two retrospective cohort studies27, 44 also found a lower rate of preterm birth at less than 37 weeks. One compared intramuscular 17OHP to daily nursing surveillance (40.5% vs. 46.2%), and this difference was not significant (p=0.121).44 The second compared intramuscular 17OHP with either no treatment or obstetric case management (46.6% vs. 51.7%) and did not report a test of statistical significance.27 Three additional studies found a higher, but not statistically significant, rate of preterm birth at less than 37 weeks with progestogen treatment. One of these52 was a RCT comparing vaginal progesterone to placebo (41.7% vs. 40.7%; OR=1.08; 95% CI: 0.76, 1.52). The other two were retrospective cohort studies, including one33 comparing intramuscular 17OHP to daily nursing surveillance (45.9% vs. 42.7%, p=0.436) and another39 comparing women who did and did not receive intramuscular 17OHP (42.9% vs. 35.8%, p=0.31). The meta-estimate of the four RCTs reporting the proportion of births at less than 37 weeks is an OR of 0.66 (95% Bayesian credible interval (BCI): 0.53, 0.82). Among the trials in the meta-estimate, the risk of preterm birth was 46.6 percent among women in the placebo group and 37.2 percent among those receiving progestogens. Thus across studies, intervention is associated with a 9.4 percent overall reduction in preterm births.

Five studies27, 33, 44, 52, 60 reported the occurrence of preterm birth at less than 35 weeks, and one RCT60 found a significantly lower rate with intramuscular 17OHP compared to placebo (20.6% vs. 30.7%; RR=0.67; 95% CI: 0.48, 0.93; p=0.02). Another RCT52 also found a lower rate of preterm birth at less than 35 weeks in women who received vaginal progesterone compared to placebo (22.7% vs. 26.5%), but this difference was not statistically significant (OR=0.9; 95% CI: 0.61, 1.34). One retrospective cohort study27 found a significantly lower occurrence with intramuscular 17OHP compared to either no treatment or obstetric case management (26.4% vs. 41.7%, p=0.024). Two retrospective cohort studies found a higher, but not statistically significant, rate of preterm birth at less than 35 weeks with intramuscular 17OHP compared to daily nursing surveillance with rates of 25.9 percent vs. 21.5 percent (p=0.152) in one study44 and 12.0 percent vs. 10.8 percent (p=0.712) in the other study.33

Two RCTs34, 36 reported the rate of preterm birth at ≤ 34 weeks, and both found it was lower with progestogen treatment. One trial36 compared vaginal progesterone to no treatment (4 percent vs. 6 percent; RR=0.666; 95 percent CI: 0.116, 3.82; p=0.64), and the other trial34 compared oral progesterone to placebo (29.7% vs. 50%, no test of statistical significance reported).

Six studies27, 33–34, 44, 52, 60 reported the rate of preterm birth at ≤ 32 weeks. One RCT60 comparing intramuscular 17OHP to placebo found a significantly lower rate of preterm birth at ≤ 32 weeks with progestogen treatment (11.4% vs. 19.6%; RR=0.58; 95% CI: 0.37, 0.91; p=0.02). Four additional studies found a lower rate of preterm birth at ≤ 32 weeks that was not significant or did not have significance reported. These include a retrospective cohort study33 comparing intramuscular 17OHP to daily nursing surveillance (3.8% vs. 5.0%, p=0.584), a retrospective cohort27 study comparing intramuscular 17OHP to either no treatment or obstetric case management (13.5% vs. 21.7%, no test of statistical significance reported), a RCT52 comparing vaginal progesterone to placebo (10.0% vs. 11.3%; OR=0.9; 95% CI: 0.52, 1.56), and a RCT34 comparing oral progesterone to placebo (2.7% vs. 20.3%, no test of statistical significance reported). One retrospective cohort study44 found a significantly higher rate of preterm birth at less than 32 weeks among women treated with intramuscular 17OHP compared to those who did not receive 17OHP (13.4% vs. 7.9%, p=0.008). The authors attribute this to the fact that there was a higher incidence of pregnancy loss prior to 24 weeks’ gestation in women receiving 17OHP.

Two RCTs reported the rate of preterm birth at ≤ 28 weeks, and neither found a significant difference with progestogen treatment. One trial52 compared vaginal progesterone to placebo (3.2% vs. 3.0%; OR 1.07; 95% CI: 0.38, 2.96), and the other34 compared oral progesterone to placebo (0% vs. 4%, p=0.25).

Preterm labor. Preterm labor was the indication for progestogen treatment in seven studies reporting preterm birth outcomes, including five RCTs,46–47, 56, 65, 77 one controlled trial73 and one observational study.71, 73 Five of these studies are included in Table 9. Of these five studies, three used intramuscular 17OHP at varying doses and frequency.46, 56, 73 The other two used a vaginal progesterone suppository47 and oral progesterone.65 Three of the RCTs had a no-treatment arm, and the fourth used placebo treatment.

Two studies reported mean gestational age at birth, and both found it to be significantly higher among women who were treated with progestogen compared to those who were not. One was a RCT47 comparing a vaginal progesterone suppository to no treatment (36.7 ± 1.5 weeks versus 34.5 ± 1.2 weeks, p=0.041), and the other was a clinical trial73 in which women received intramuscular 17OHP or Ritodrine (39.1 ± 0.3 weeks vs. 37.7 ± 0.4 weeks, p < 0.01). Three RCTs reported the rate of preterm birth at less than 37 weeks.46, 56, 65 Two found a significantly lower rate of preterm birth at less than 37 weeks with intramuscular 17OHP compared to no treatment, with rates of 22 versus 54 percent (p=0.049) in one trial,46 and rates of 16 percent versus 57 percent (p=0.004) in another trial.56 The third trial65 found no statistically significant difference between women treated with oral progesterone and placebo (27.3% vs. 36.4%, p-value not reported). The meta-estimate combining these three trials is an odds ratio of 0.26 (95% BCI: 0.10, 0.49).46, 56, 65 Among 74 comparison group members not receiving progestogens 50.0 percent had preterm births compared to 21.3 percent of the 75 women receiving progestogens, an overall decrease of 28.7 percent. One study56 reported the rate of preterm birth at less than 35 weeks and did not find statistically significant differences at this cut point between women receiving intramuscular 17OHP or no treatment (10.0% vs. 23.3%, p-value not reported).

Two additional studies that reported preterm birth outcomes are not shown in Table 9 because no definition of preterm birth was provided, thus the gestational age cut point could not be determined. One of these studies (n=211)77 compared oral chlormadinone acetate to intramuscular 17OHP and did not find a statistically significant difference in the rate of preterm birth between the two progestogens (4% vs. 8% respectively, p-value not reported). The other study (n=33)71 found a significantly lower rate of preterm birth among women treated with beta-mimetic drugs plus intramuscular 17OHP compared to women treated only with beta-mimetic drugs (27.3% vs. 69.2%, p < 0.05).

Multiple gestation. Multiple gestation was the indication for progestogen treatment in six studies, including five RCTs30, 35, 40–41, 48 and one clinical trial74, all of which reported preterm birth outcomes presented in Table 10. Four trials included twin gestations,35, 41, 48, 74 and two trials included triplet gestations.30, 40 The intervention was intramuscular 17OHP 250 mg weekly in five trials30, 40–41, 48, 74 and vaginal progesterone gel 90 mg in one trial.35 All of the trials included a placebo arm.

None of the trials found any significant difference in preterm birth outcomes with progestogen treatment. All of the trials reported mean gestational age at birth. Mean gestational age was higher with intramuscular 17OHP than placebo (33.9 ± 4 weeks vs. 33.1 ± 2.9 weeks, p=0.190) in one trial of twins41 and another trial of triplets30 (31.9 ± 4.1 weeks vs. 31.8 ± 2.9 weeks, p=0.36). In the other four trials, mean gestational age was slightly lower with progestogen treatment compared to placebo with findings of 32.4 versus 33.0 weeks (p=0.527) in one trial,40 35.4 ± 3.5 weeks versus 35.7 ± 3 weeks (p=0.31) in one trial,35 34.6 + 3.9 weeks versus 34.9 ± 3.6 weeks (no test of statistical significance reported) in one trial,48 and 36.9 ± 2.6 weeks versus 37.3 ± 2.4 weeks (p-value not reported) in one trial.74

Two trials, one with adequate power, reported no difference in preterm births using a 37-week cutpoint.48, 74 Four trials30, 40–41, 48 reported the preterm birth risk at less than 35 weeks. Three trials found the rate of preterm birth at less than 35 weeks was lower with progestogen treatment, including one trial of twin pregnancies41 comparing intramuscular 17OHP to placebo (44% vs. 79%, p=0.117) and two trials of triplet pregnancies30, 40 also comparing intramuscular 17OHP to placebo (83.1% vs. 84.1%; RR=1.0; 95% CI: 0.9, 1.1 and 76.8% vs. 84.0%; RR=0.9; 95% CI: 0.7, 1.1). One trial48 found the rate of preterm birth at less than 35 weeks was higher with intramuscular 17OHP compared to placebo (41.5% vs. 37.3%; RR=1.1; 95% CI: 0.9, 1.3). The meta-estimate combining the two twin trials is an odds ratio of 1.07 (95% BCI: 0.80, 1.40) for preterm birth prior to 35 weeks.41, 48 Combining the two triplet trials produces an odds ratio of 4.40 (95% BCI: 0.32, 11.57).30, 40 When all twin and triplet trials are combined, the meta-estimate is 1.18 (95% BCI: 0.79, 1.39).30, 40–41, 48 Among the trials in the meta-estimate, the risk of preterm birth was 47.5 percent among women in the placebo group and 51.9 percent among those receiving progestogens. Thus across studies, intervention is associated with a 4.4% overall increase in preterm births.

One trial35 reported the rate of preterm birth at ≤ 34 weeks and found the rate was higher with vaginal progesterone compared to placebo (24.7% vs. 19.4%; OR=1.36; 95% CI: 0.89, 2.09; p=0.16). Three trials30, 40, 48 reported the preterm birth rate at ≤ 32 weeks, and two found it was higher with progestogen treatment. One trial40 compared intramuscular 17OHP and placebo in triplet pregnancies (41% vs. 30%; RR=1.4; 95% CI: 0.8, 2.2), and the other trial48 compared intramuscular 17OHP and placebo in twin pregnancies (16.9% vs. 14.5%; RR=1.2; 95% CI: 0.8, 1.7). The third trial30 compared intramuscular 17OHP and placebo in triplet pregnancies and found the preterm birth rate at ≤ 32 weeks was lower with progestogen treatment (33.9% vs. 52.0%; RR=0.7; 95% CI: 0.4, 1.1). Three trials30, 40, 48 reported the preterm birth rate at ≤ 28 weeks. A trial of triplet pregnancies40 found the rate was lower with intramuscular 17OHP compared to placebo (10% vs. 11%; RR=0.9; 95% CI: 0.3, 2.4). Two trials found the rate was higher with intramuscular 17OHP compared to placebo including one trial of twin pregnancies48 (8.0% vs. 6.1%; RR=1.3; 95% CI: 0.8, 2.3) and one trial of triplet pregnancies30 (16.1% vs. 8.0%; RR 2.0; 95% CI: 0.5, 8.6).

Study populations with varied risk factors. Among studies reporting preterm birth outcomes, ten examined progestogen treatment in study populations with varied risk factors (a variety of indications within a single study). Five RCTs,32, 37, 61, 64, 79 one clinical trial,66 and one case-control study58 included preterm birth outcomes presented in Table 11. Three additional studies32, 68, 76 are not included in the table but are discussed in the text at the end of this section. Of the seven studies included in Table 11, four used intramuscular 17OHP,37, 58, 66, 79 two used a vaginal progesterone suppository,31, 61 and one used an oral progestin.64

Five studies reported mean gestational age at birth.31, 37, 58, 61, 79 Two RCTs found a significantly higher gestational age at birth among women treated with progestogens, including one trial31 comparing vaginal progesterone to placebo (36w6d ± 2w3d vs. 35w6d ± 3w2d, p < 0.05) and one trial79 comparing intramuscular 17OHP to placebo (38.6 ± 1.4 weeks vs. 35.2 ± 6.2 weeks, p < 0.025). A third RCT found a higher, but not statistically significant gestational age among women using vaginal progesterone compared to placebo (37.0 ± 2.8 weeks vs. 26.0 ± 3.3 weeks, p=0.029).61 One RCT comparing intramuscular 17OHP to cerclage37 found a similar gestational age at birth (33.0 ± 5.9 weeks vs. 32.9 ± 6.4 weeks, p=0.96). A case-control study58 found a lower gestational age among women who received intramuscular 17OHP compared to women who did not (38.8 ± 2.4 weeks vs. 39.4 ± 2.0 weeks), and this result was significant in unadjusted and adjusted models (p < 0.0001 for both).

Five studies reported the rate of preterm birth at less than 37 weeks.31, 37, 61, 64, 66 The rate was significantly lower with progestogen treatment in two RCTs31 comparing vaginal progesterone to placebo, with rates of 40 percent versus 57.2 percent (OR=2.0; 95% CI: 1.04, 3.83; p=0.036) in one study31 and 13.8 percent versus 28.5 percent (p=0.03) in the other.61 The rate of preterm birth at less than 37 weeks was also significantly lower with progestogen treatment in a RCT66 comparing intramuscular 17OHP to no treatment (14.3% vs. 48.7%, p=0.0036). The RCT71 comparing intramuscular 17OHP to cerclage found the occurrence of preterm birth at less than 37 weeks was higher with progestogen treatment, but the difference was not significant (59.4% vs. 52.4%; RR=1.14; 95% CI: 0.77, 1.68). The fifth study64 found a nonsignificant but higher rate of preterm birth at less than 37 weeks among women who received an oral progestin (Provera) compared with placebo (11.2% vs. 7.3%). This difference was attributed to the fact that many women did not take the progestogen. Further analysis demonstrated the preterm birth rate was 17.6 percent among 182 women who did not take the medication and 6.1 percent among 228 women who did.

One RCT reported preterm births at less than 35 weeks.37 The rate was higher with intramuscular 17OHP than cerclage, but the difference was not statistically significant (43.2% vs. 38.1%; RR=1.14; 95% CI: 0.67, 1.93).

Three studies reported the preterm birth rate at ≤ 34 weeks.31, 61, 66 The rate was significantly higher in the placebo group in two RCTs31 comparing vaginal progesterone to placebo, with rates of 24.3 percent versus 8.8 percent (OR=3.35; 95% CI: 1.30, 8.63; p=0.010) in one study31 and 18.6 percent versus 2.8 percent (p=0.002) in the other.61 The third study66 reported a lower preterm birth rate at ≤ 34 weeks with intramuscular 17OHP compared to no treatment (11.43% vs. 17.95%) but did not report a statistical test result for this finding.

One RCT reported the preterm birth rate at less than 32 weeks.37 The rate was lower with intramuscular 17OHP than cerclage, but the difference was not statistically significant (35.1% vs. 35.7%; RR=0.98; 95% CI: 0.54, 1.79).

Two studies37, 66 reported the birth rate at ≤ 28 weeks. One found it was lower with intramuscular 17OHP compared to no treatment (0% vs. 5.13%) but did not report a statistical test result for this finding.66 The other found it was lower with intramuscular 17OHP than cerclage, but the difference was not statistically significant (18.9% vs. 23.8%; RR=0.79; 95% CI: 0.34, 1.88).37

One study (n=80)68 is not included in Table 11 because it used an uncommon cut point for preterm birth (less than 36 weeks). Among the 31 women in that study who received intramuscular 17OHP, 16.1 percent gave birth at less than 36 weeks compared to 37.8 percent who received placebo, which was statistically significant (p < 0.05). A second study (n=21)74 is a prospective cohort study that includes participants whose results are reported in a RCT79 included in Table 11. The data from the two studies are combined in a way that makes it impossible to confidently provide results for preterm birth outcomes specific to participants in the prospective cohort study who were not in the RCT. A third study (n=300)32 is a secondary analysis of a cerclage RCT in which there was an additional randomization stratum reflecting the patient’s stated intent to use 17OHP. Outcomes for progestogen treatment are reported by initial randomization to cerclage or no cerclage. Preterm birth rates at less than 37, 35, 32, and 28 weeks did not differ significantly with 17OHP or no 17OHP in both cerclage and no-cerclage groups.

Asymptomatic short cervix on midgestation ultrasound. In the one study (n=250)55 in which women who had an asymptomatic short cervix on midgestation ultrasound were given vaginal progesterone, the rate of preterm birth prior to 34 weeks was 20.8 percent in the progesterone group and 36.0 percent in the placebo group (RR=0.58; 95% CI: 0.38, 0.87; p=0.008 and adjusted relative risk (ARR)=0.60; 95% CI: 035, 0.94; p=0.02).

Midtrimester amniocentesis. In the one study (n=584)62 in which intramuscular natural progesterone and 17OHP were given to women who had midtrimester amniocentesis, there was no significant difference in the rate of preterm birth at less than 37 weeks in the treatment group compared to women who did not receive treatment (8.7% vs. 7.3%, p-value not reported).

### Fetal and Neonatal Health Outcomes

Thirty-two studies reported fetal and neonatal outcomes other than gestational age (studies for which gestational age was the only neonatal outcome reported can be found in the previous discussion on preterm birth). Intrauterine fetal death, neonatal death, infant birth weight, and neonatal intensive care unit (NICU) outcomes are presented in Tables 12–16. Outcomes for neonatal conditions associated with prematurity are presented in Table 13. Each of Tables 12 and 14–16 is for a specific indication, while Table 13 includes multiple indications that are organized by risk factor in the order the indications are discussed in the text. Within all of the tables, studies are grouped by progestogen route (intramuscular, vaginal, and oral). Within each route, RCTs are listed first followed by clinical trials and observational studies, and each group of study types is in reverse chronological order.

Table 12 Fetal and neonatal outcomes for women with a history of preterm birth

Author Year Study Type | Intervention (N) | IUFD (%) | Neonatal Death (%) | Weight, Mean g ± SD | LBW, % (<2500g) | NICU Admission (%) | NICU Days, Mean ± SD
Meis et al.60 2003 RCT | IM (306) | 2.0 | 2.6 | NR | 27.2^*^ | NR | NR
Meis et al.60 2003 RCT | Placebo (153) | 1.3 | 5.9 | NR | 41.1 | NR | NR
Mason et al.27 2010 Retrospective cohort | IM (193) | NR | NR | NR | NR | 33.7^*^ | NR
Mason et al.27 2010 Retrospective cohort | No treatment or OB case management (60) | NR | NR | NR | NR | 45.0 | NR
Mason et al.59 2005 Retrospective cohort | IM (24) | NR | NR | NR | NR | 8.3 | 149.0^*^
Mason et al.59 2005 Retrospective cohort | None (14) | NR | NR | NR | NR | 14.3 | 231.0
Majhi et al.36 2009 RCT | Vaginal (50) | NR | 0 | 2813.0 ± 501.0^*^ | NR | 0 | NR
Majhi et al.36 2009 RCT | None (50) | NR | 0 | 2599.0 ± 421.0 | NR | 8.0 | NR
O’Brien et al.52 2007 RCT | Vaginal (309) | 1.6 | 1.9 | 2680.0 ± 710.0 | NR | 17.5 | 14.2 ± 16.6
O’Brien et al.52 2007 RCT | Placebo (302) | 1.3 | 2.3 | 2661.0 ± 738.0 | NR | 21.5 | 20.5 ± 30.7
Rai et al.34 2009 RCT | Oral (74) | NR | 4.1 | 2400.0 ± 650.0^*^ | NR | 13.5 | NR
Rai et al.34 2009 RCT | Placebo (74) | NR | 9.5 | 1890.0 ± 560.0 | NR | 51.3 | NR

* Findings are statistically significant.

g = gram; IM = intramuscular; IUFD = intrauterine fetal death; LBW = low birth weight; NICU = neonatal intensive care unit; NR = not reported; OB = obstetrical; RCT = randomized clinical trial; SD = standard deviation

Table 13 Neonatal conditions associated with prematurity

Author Year Study Type Indication | Intervention (N) | RDS (%) | NEC (%) | IVH (%) | Sepsis (%) | Vent (%) | ROP (%)
Meis et al.60 2003 RCT History of PTB | IM (306) | 9.5 | 0^*^ | 1.3^*^ | 3.0 | 8.6 | 1.6
Meis et al.60 2003 RCT History of PTB | Placebo (153) | 15.1 | 2.6 | 5.2 | 2.6 | 14.6 | 3.3
Majhi et al.36 2009 RCT History of PTB | Vaginal (50) | NR | 0 | NR | 0 | NR | NR
Majhi et al.36 2009 RCT History of PTB | None (50) | NR | 2.0 | NR | 6.0 | NR | NR
O’Brien et al.52 2007 RCT History of PTB | Vaginal (309) | 11.0 | 1.0 | 1.9 | NR | NR | NR
O’Brien et al.52 2007 RCT History of PTB | Placebo (302) | 11.9 | 1.7 | 1.6 | NR | NR | NR
Borna et al.47 2008 RCT PTL | Vaginal (37) | 10.8^*^ | 0 | 0 | 18.2 | 18.2 | NR
Borna et al.47 2008 RCT PTL | None (33) | 36.4 | 0 | 0 | 5.4 | 5.4 | NR
Combs et al.30 2010 RCT Multiple gestation | IM (168, triplets) | 28.4 | 5.2 | 2.7 | 2.6 | NR | 2.8
Combs et al.30 2010 RCT Multiple gestation | Placebo (75, triplets) | 37.3 | 4.0 | 4.0 | 5.3 | NR | 6.5
Briery et al.41 2009 RCT Multiple gestation | IM (32, twins) | 31.0 | 3.0 | 9.0 | NR | NR | NR
Briery et al.41 2009 RCT Multiple gestation | Placebo (28, twins) | 32.0 | 0 | 14.0 | NR | NR | NR
Caritis et al.40 2009 RCT Multiple gestation | IM (212, triplets) | 31.0 | 0.9 | 0.9 | 9.0 | 33.0 | 0
Caritis et al.40 2009 RCT Multiple gestation | Placebo (183, triplets) | 27.0 | 3.0 | 2.0 | 7.0 | 31.0 | 0
Rouse et al.48 2007 RCT Multiple gestation | IM (632, twins) | 15.2 | 0.5 | 1.1 | 3.8 | 11.1 | 0
Rouse et al.48 2007 RCT Multiple gestation | Placebo (648, twins) | 13.4 | 0.6 | 0.9 | 4.0 | 11.9 | 0
Yemini et al.68 1985 RCT Various risk factors | IM (5) | 20.0 | NR | NR | 20.0 | NR | NR
Yemini et al.68 1985 RCT Various risk factors | Placebo (14) | 28.6 | NR | NR | 14.3 | NR | NR
Fonseca et al.55 2007 RCT Short cervix | Vaginal (125) | 8.1 | 0 | 0.7 | 2.2 | 11.8 | 1.5
Fonseca et al.55 2007 RCT Short cervix | Placebo (125) | 13.8 | 0.7 | 1.4 | 8.0 | 18.1 | 0

* Findings are statistically significant.

IM = intramuscular; IVH = intraventricular hemorrhage; NEC = necrotizing enterocolitis; NR = not reported; PTB = preterm birth; PTL = preterm labor; RCT = randomized control trial; RDS = respiratory distress syndrome; ROP = retinopathy; Vent = mechanical ventilator.

Table 14 Fetal and neonatal outcomes for women with preterm labor

Author Year Study Type | Intervention (N) | IUFD (%) | Neonatal Death (%) | Weight, Mean g ± SD | LBW, % (< 2500g) | NICU Admission (%) | NICU Days Mean ± SD
Facchinetti et al.56 2007 RCT | IM (30) | NR | NR | 3103.0 ± 468.0 | NR | NR | NR
Facchinetti et al.56 2007 RCT | None (30) | NR | NR | 2809.0 ± 317.0 | NR | NR | NR
Bréart et al.77 1979 RCT | IM (105) | NR | NR | 3156.0 | NR | NR | NR
Bréart et al.77 1979 RCT | Oral (106) | NR | NR | 3099.0 | NR | NR | NR
Fuchs & Stakemann14 1960 RCT | IM (63) | 0 | NR | NR | 55.6 | NR | NR
Fuchs & Stakemann14 1960 RCT | Placebo (63) | 3.2 | NR | NR | 55.6 | NR | NR
Kauppila et al.73 1980 CT | IM (24) | NR | 4.5 | 3460.0 ± 119.0^*^ | 8.3 | NR | NR
Kauppila et al.73 1980 CT | Ritodrine (24) | NR | 0 | 3106.0 ± 118.0 | 12.5 | NR | NR
Øvlisen et al.16 1963 Case series | IM (63) | NR | NR | NR | 55.6 | NR | NR
Øvlisen et al.16 1963 Case series | Oral (63) | NR | NR | NR | 61.9 | NR | NR
Øvlisen et al.16 1963 Case series | Placebo (63) | NR | NR | NR | 55.6 | NR | NR
Borna et al.47 2008 RCT | Vaginal (37) | NR | NR | 3101.5 ± 587.9 | 27.0^*^ | 24.3 | 3.4 ± 7.6
Borna et al.47 2008 RCT | None (33) | NR | NR | 2609.4 ± 662.9^*^ | 51.5 | 39.4 | 3.8 ± 8.2
Noblot et al.65 1991 RCT | Oral (22) | NR | NR | 3077.0 | NR | NR | NR
Noblot et al.65 1991 RCT | Placebo (22) | NR | NR | 2832.0 | NR | NR | NR

* Findings are statistically significant.

g = grams; IM = intramuscular; IUFD = intrauterine fetal death; LBW = low birth weight; NICU = neonatal intensive care unit; NR = not reported; RCT = randomized control trial; SD = standard deviation.

Table 15 Fetal and neonatal outcomes for women with multiple gestation

Author Year Study Type | Intervention (Maternal N/Fetal N) | IUFD (%) | Neonatal death (%) | Weight, Mean g ± SD | LBW, % (<2500g) | NICU Admission (%) | NICU Days, Mean ± SD
Combs et al.30 2010 RCT | IM (56/168) | 7.7^*,†^ | 3.9 | 1719.0 ± 554.0 | NR | NR | 16.0 ± 23.2
Combs et al.30 2010 RCT | Placebo (25/75) | 0 | 2.7 | 1609.0 ± 472.0 | NR | NR | 18.8 ± 30.1
Briery et al.41 2009 RCT | IM (16/32) | 0 | 6.0 | 1968.8 ± 679.0 | NR | NR | 18.4 ± 65.8
Briery et al.41 2009 RCT | Placebo (14/28) | 0 | 0 | 1934.7 ± 549.0 | NR | NR | 17.3 ± 29.8
Caritis et al.40 2009 RCT | IM (71/212) | 0.4 | 2.0 | 1650.0 ± 554.0 | 91.0 | NR | NR
Caritis et al.40 2009 RCT | Placebo (63/183) | 3.3 | 1.0 | 1754.0 ± 494.0 | 96.0 | NR | NR
Norman et al.35 2009 RCT | Vaginal (250/494) | 1.2 | 1.6 | NR | NR | 33.8 | 26.9 ± 33.5
Norman et al.35 2009 RCT | Placebo (250/494) | 0.8 | 1.2 | NR | NR | 32.0 | 23.6 ± 29.5
Rouse et al.48 2007 RCT | IM (325/632) | 3.7 | 3.1 | NR | 60.0 | NR | NR
Rouse et al.48 2007 RCT | Placebo (330/648) | 2.7 | 1.8 | NR | 64.0 | NR | NR
Hartikainen-Sorri et al.74 1980 CT | IM (39/78) | 1.3 | 3.8 | NR | NR | NR | NR
Hartikainen-Sorri et al.74 1980 CT | Placebo (38/76) | 1.3 | 1.3 | NR | NR | NR | NR

* Findings are statistically significant.

† Includes miscarriages.

CT = clinical trial; g = grams; IM = intramuscular; IUFD = intrauterine fetal death; LBW = low birth weight; NICU = neonatal intensive care unit; NR = not reported; RCT = randomized control trial; SD = standard deviation.

Table 16 Fetal and neonatal outcomes for study populations with varied risk factors

Author Year Study Type | Intervention (Maternal N/Fetal N) | IUFD (%) | Neonatal Death (%) | Weight, Mean g ± SD | LBW, % (<2500g) | NICU Admission (%) | NICU Days, Mean ± SD
Yemini et al.68 1985 RCT | IM (39) | 0 | 0 | 3111.9 ± 905.5^*^ | NR | NR | NR
Yemini et al.68 1985 RCT | Placebo (40) | 0 | 0 | 2680 ± 813.4 | NR | NR | NR
Johnson et al.79 1975 RCT | IM (18) | 0 | 0 | 2836.0 ± 412.0^*^ | NR | NR | NR
Johnson et al.79 1975 RCT | Placebo (22) | 22.7 | 9.0 | 2361.0 ± 108.0 | NR | NR | NR
Suvonnakote66 1986 CT | IM (35) | NR | NR | NR | 31.4 | NR | NR
Suvonnakote66 1986 CT | None (39) | NR | NR | NR | 48.7 | NR | NR
Dudas et al.58 2006 Case-control | IM (433) | NR | NR | 3194.0 ± 555.0 | 9.0 | NR | NR
Dudas et al.58 2006 Case-control | None (37,718) | NR | NR | 3277.0 ± 511.0 | 5.6 | NR | NR
Cetingoz et al.31 2010 RCT | Vaginal (80) | NR | 3.8 | NR | NR | 16.3^*^ | NR
Cetingoz et al.31 2010 RCT | Placebo (70) | NR | 4.3 | NR | NR | 37.1 | NR
Cortes-Prieto et al.75 1980 Prospective cohort | Oral (25) | NR | NR | 3455.0 | NR | NR | NR
Cortes-Prieto et al.75 1980 Prospective cohort | None (40) | NR | NR | 3186.0 | NR | NR | NR

* Findings are statistically significant.

CT = clinical trial; g = grams; IM = intramuscular; IUFD = intrauterine fetal death; LBW = low birth weight; NICU = neonatal intensive care unit; NR = not reported; RCT = randomized control trial; SD = standard deviation.

In addition to those presented in Tables 12–16, other reported neonatal characteristics include Apgar scores,35, 40–41, 48, 52, 62, 65, 73 cord pH,36 placenta weights,76 head circumference,30, 52 very low birth weight,40, 48, 55, 60 small for gestational age,40 birth weight differences across groups,76 neonatal age at birth per Ballard score,34 and total days of hospital stay.30 In addition, several studies present findings for a variety of neonatal health conditions, which may or may not be associated with prematurity, including transient tachypnea,60 need for supplemental oxygen,30, 60 bronchopulmonary dysplasia,40, 48, 60 pneumonia,30, 40, 48 pulmonary infection,74 respiratory problems (nonspecific),74 apnea/bradycardia,68 patent ductus arteriosus,40–41, 48, 60, 68 periventricular leukomalacia,30, 40, 48 asphyxia,30 seizures,40, 48 hyperbilirubinemia,36, 68, 74 phototherapy,55 blood transfusion,55 omphalitis,74 anemia,68 and the financial impact of the number of days in the NICU.59

History of preterm birth. Among studies reporting fetal and neonatal outcomes, six examined progestogen treatment in women with a history of preterm birth, including four RCTs34, 36, 52, 60 and two retrospective cohort studies.27, 59 All six of these studies are presented in Table 12, and three are included in Table 13. Three of the studies used intramuscular 17OHP,27, 59–60 one used a vaginal micronized progesterone capsule,36 one used vaginal progesterone gel,52 and one used oral micronized progesterone.34 Three of the RCTs had a placebo arm,34, 52, 60 and the fourth had a no-treatment arm.36

Two RCTs52, 60 reported intrauterine fetal death rates, and four RCTs34, 36, 52, 60 reported neonatal death rates. No significant differences were reported with progestogen treatment. The meta-estimate for neonatal death is an odds ratio of 0.52 (95% BCI: 0.25, 0.96). Among the trials in the meta-estimate, the risk of neonatal death was 4.0 percent among women in the placebo group and 2.3 percent among those receiving progestogens. Thus across studies, intervention is associated with a 1.7 percent overall reduction in neonatal mortality.

Three RCTs reported mean birth weight. Two of these34, 36 found a significantly higher birth weight in infants whose mothers received progestogens, including vaginal progesterone capsules (p=0.023) and oral progesterone (p < 0.001).The third52 used vaginal progesterone gel and did not find a significant difference. The meta-estimate of the change in mean birth weight is a mean difference of 239 g (95% CI: −44.5, 523.3).

One RCT60 found a significantly lower rate of low birth weight (< 2,500 gm) in infants whose mothers were treated with intramuscular 17OHP (RR=0.66; 95% CI: 0.51, 0.87). Five studies27, 34, 36, 52, 59 reported NICU admission rates, and two52, 59 reported mean days in NICU. The only significant finding from the NICU outcomes was a lower number of days in the retrospective cohort in which women were treated with intramuscular 17OHP (p < 0.000 [sic]).59 Three RCTs reported rates of neonatal conditions associated with prematurity, including respiratory distress syndrome,52, 60 necrotizing enterocolitis,36, 52, 60 intraventricular hemorrhage,52, 60 sepsis,36, 60 mechanical ventilation,60 and retinopathy.60 One trial60 found significantly lower rates of necrotizing enterocolitis (p=0.01) and intraventricular hemorrhage (RR=0.25; p < 0.05) in infants whose mothers received intramuscular 17OHP. None of the others reported significant findings related to neonatal conditions associated with prematurity.

Preterm labor. Preterm labor was the indication for progestogen treatment in seven studies reporting fetal and neonatal outcomes, including five RCTs14, 47, 56, 65, 77 and two observational studies.16, 73 All seven of these studies are included in Table 14, and one is included in Table 13. Each of these seven studies used a different type, dose, and route of progestogens.

One RCT14 reported the rate of intrauterine fetal death, and one clinical trial73 reported the rate of neonatal death. Neither reported if the difference in rate between intervention and placebo groups was significant. Five studies reported mean birthweight. Two studies found a significant difference in mean birth weight between infants whose mothers did and did not receive progestogens, p-values were 0.002 with vaginal progesterone suppositories47 and < 0.05 with intramuscular 17OHP.73 Two studies65, 77 found no significant difference in birth weight with progestogen treatment, and one56 did not report statistical findings for this outcome. Four studies analyzed the rate of low birth weight. One47 found a significant difference between infants whose mothers did (27.0%) and did not (51.5%) receive vaginal progesterone suppositories (p=0.040), one73 found the difference was not significant with intramuscular 17OHP (p-value not reported), and two14, 16 did not report statistical findings for this outcome. One study47 analyzed the rate of NICU admission and mean days of NICU stay, and found no significant differences in NICU outcomes with treatment with vaginal progesterone suppositories. One study47 reported rates of five conditions associated with prematurity, including respiratory distress syndrome, necrotizing enterocolitis, intraventricular hemorrhage, sepsis, and mechanical ventilation. Respiratory distress syndrome was the only condition for which there was a significantly lower rate (p=0.021) among infants whose mothers received vaginal progesterone suppositories.

Multiple gestation. Multiple gestation was the indication for progestogen treatment in six studies, including five RCTs30, 35, 40–41, 48 and one clinical trial,74 all of which reported fetal and neonatal health outcomes presented in Tables 13 and 15. Four trials included twin gestations,35, 41, 48, 74 and two trials included triplet gestations.30, 40 The intervention was intramuscular 17OHP 250 mg weekly in five trials30, 40–41, 48, 74 and vaginal progesterone gel 90 mg in one trial.35 All of the trials included a placebo arm.

All of the trials reported intrauterine fetal deaths and neonatal deaths. One RCT of triplet pregnancies30 comparing intramuscular 17OHP to placebo found a statistically significant higher rate of intrauterine fetal death with progestogen treatment (7.7% vs. zero%, p=0.01). In this study, the intrauterine fetal death rate was only reported in combination with the miscarriage rate. Thus the 7.7 percent result includes some miscarriages after 16 weeks’ gestation.30 The meta-estimate for neonatal death combining the three twin trials is an odds ratio of 1.64 (95% BCI: 0.83, 2.67). Combining the two triplet trials produces an odds ratio of 2.09 (95% BCI: 0.14, 5.66). When the twin and triplet trials are combined, the meta-estimate is 1.75 (95% BCI: 0.93, 2.80). Among the trials in the meta-estimate, the risk of neonatal death was 1.5 percent among women in the placebo group and 2.8 percent among those receiving progestogens. Thus across studies, intervention is associated with a 1.3 percent overall increase in neonatal mortality.

Three trials30, 40–41 reported mean birth weights, and two40, 48 reported the rate of low birth weight. One trial35 reported the rate of NICU admissions, and three30, 35, 41 reported the mean number of NICU days. Four trials30, 35, 41, 48 reported rates of respiratory distress syndrome, necrotizing enterocolitis, and intraventricular hemorrhage. Three trials30, 40, 48 reported rates of sepsis and retinopathy. Two trials40, 48 reported rates of mechanical ventilation. The only significant difference in fetal or neonatal outcomes with progestogen treatment was the higher rate of miscarriage and stillbirth among participants who received 17OHP in a RCT of triplet pregnancies.30

Study populations with varied risk factors. Among studies reporting fetal and neonatal health outcomes, seven examined progestogen treatment in populations with varied risk factors (a variety of indications within a single study). Three RCTs31, 68, 79 and three observational studies58, 66, 75 included outcomes presented in Tables 13 and 16. One observational study reported other neonatal outcomes.76 Two additional studies32, 37 are not included in the table but are discussed in the text at the end of this section. Of the studies in Tables 13 and 16, four used intramuscular 17OHP58, 66, 68, 79, one used a vaginal progesterone suppository,31 and one used oral allylestrenol.75

One RCT79 combined intrauterine fetal death and neonatal death rates to obtain a perinatal mortality rate and found this was significantly lower with intramuscular 17OHP compared to placebo (p < 0.05). There were no intrauterine fetal deaths or neonatal deaths in the other RCT reporting both these death rates.68 A third RCT31 only reported the neonatal death rate and did not find a significant difference with vaginal progesterone suppositories compared to no treatment (p=0.867). Two RCTs68, 79 found a significantly higher mean birth weight among infants whose mothers received intramuscular 17OHP (p < 0.025 and p < 0.05 respectively). One case-control study58 found lower mean birth weight in infants whose mothers were treated with intramuscular 17OHP, which was significant when unadjusted (p=0.002) but lost significance when adjusted (p=0.09). The fourth study with mean birth weight data was a clinical trial that reported no significant findings.75 Two studies reported the rate of low birth weight infants. One case-control study58 found a higher rate of low birth weight in infants whose mothers were treated with intramuscular 17OHP, which was significant when unadjusted (OR=1.7; 95% CI: 1.2, 2.3) but lost significance when adjusted (OR=1.4; 95% CI: 0.9, 2.0). The other study, which was a clinical trial,66 reported no significant findings with regard to with low birth weight. One RCT31 found NICU admission rates were three times higher in newborns whose mothers received placebo than those whose mothers received vaginal progesterone suppositories (OR=3.04; 95% CI: 1.41, 6.54; p=0.004). One RCT68 reported rates of neonatal conditions associated with prematurity, including respiratory distress syndrome and sepsis, with no significant findings when mothers received intramuscular 17OHP.

One RCT (n=79) only reported stratified neonatal morbidity and a perinatal death rate that combined intrauterine fetal deaths and neonatal deaths (10.8% with intramuscular 17OHP vs. 11.9% with cerclage, no test of statistical significance reported).37 Another study (n=300) is a secondary analysis of a cerclage RCT in which there was an additional randomization stratum reflecting the patient’s stated intent to use 17OHP.32 Outcomes for progestogen treatment are reported by initial randomization to cerclage or no cerclage. The perinatal death rate, which includes stillbirths and postnatal deaths prior to hospital discharge, was significantly lower with 17OHP compared to no 17OHP in the group randomized to no cerclage (4% vs. 23%; OR=0.14; 95% CI: 0.03, 0.61; p=0.0029). The perinatal death rate did not differ significantly with 17OHP compared to no 17OHP in the group randomized to no cerclage(6% vs. 10%; OR=0.62; 95% CI: 0.16, 2.37; p=0.76).

Asymptomatic short cervix on midgestation ultrasound. In the one study55 in which women who had an asymptomatic short cervix on midgestation ultrasound were given vaginal progesterone, there were no significant differences in treatment and placebo groups in rates of intrauterine fetal death (0.7% vs. 0.7%), neonatal death (1.5% vs. 5.1%), low birth weight (41.2% vs. 42.8%), respiratory distress syndrome (8.1% vs. 13.8%), necrotizing enterocolitis (0% vs. 0.7%), intraventricular hemorrhage (0.7% vs. 1.4%), sepsis (2.2% vs. 8.0%), mechanical ventilation (11.8% vs. 18.1%), and retinopathy (1.5% vs. 0%).

Active-duty military personnel. In the one study72 in which progesterone was given to active-duty military personnel, there was no significant difference in rates of intrauterine fetal death (1.3% vs. 3.4%), neonatal death (2.5% vs. 0%), or low birth weight (7.5% vs. 9.0%) with intramuscular 17OHP compared to placebo (p-values not reported).

Abdominal surgery unrelated to pregnancy. In the one study80 in which intramuscular 17OHP was given to women who had abdominal surgery unrelated to pregnancy, the intrauterine fetal death and neonatal death rates were lower in the treatment group than placebo, 2.9 percent versus 0 percent and 2.9 percent versus 8.6 percent respectively. No test of statistical significance was reported.

Midtrimester amniocentesis. In the one study62 in which intramuscular natural progesterone and 17OHP were given to women who had midtrimester amniocentesis, the intrauterine fetal death rate was lower (0.6% vs. 1.1%) and the mean birth weight was higher (3138.9 ± 665.9 gm vs. 3073.6 ± 618.9 gm) in the treatment group compared to women who did not receive treatment. The differences in these outcomes were not statistically significant (p-values not reported).

## KQ2 Harms of Progestogen Treatments

Surveillance for adverse effects (harms) of progestogens use varied widely across studies with few explicitly describing a universal approach to inquiring about or establishing operational definitions of harms. Fourteen treatment studies, six RCTs32, 46, 61, 64–65, 77 and eight other study types,27, 29, 33, 39, 43–45, 71 did not include any reporting of harms associated with therapy in the methods or results of their study. In RCTs that addressed harms, incidence of any harm ranged from zero to 69 percent for the treatment group and zero to 65 percent for the placebo groups (Table 17).14, 30–31, 34–36, 38, 40–41, 47–48, 52, 55–56, 60, 62, 67–68, 72, 79, 82–83 Harms were less likely to be reported by other types of studies and are especially challenging to compile in retrospective research. When reported, treatment groups had documented drug-related adverse events in zero to 13 percent of those treated compared to zero to 7 percent in comparison groups. Reported harms were generally mild and varied depending upon route of progestogen administrations (e.g., injection site reactions and vaginal irritation). In the RCTs, withdrawal due to drug or placebo treatment effects occurred in up to three percent and two percent of participants in the treatment and placebo arms respectively. In other studies, withdrawal occurred in up to 9.4 percent of participants in the treatment and comparison groups.

Table 17 Side effects and harms of progestogen treatment

| Placebo-Controlled RCT Arms | | | | Other Studies by Treatment
Range (Number of studies reporting) | Placebo (n=27) | Injection (n=15) | Vaginal (n=8) | Oral (n=4) | Comparison Group (n=16) | Injection (n=23) | Vaginal (n=0) | Oral (n=2)
Reaction/discomfort with suppository | 0–17% (3) | | 0–24% (3)
Injection site discomfort | 7.8–62.3% (3) | 17.2–61.6% (3) | | | | 58.6% (2)
Urticaria/pruritus | 1.2–2% (2) | 3.4% (1) | 4% (1) | | | | | 0 (1)
Nausea | 0–12% (3) | 1.6% (1) | 5% (1) | 0 (1) | | | | 0 (1)
Vaginal discharge | 9.2–24% (2) | | 8.4–32% (3)
Gestational diabetes | 6.9–12% (2) | 6.7–16% (2) | | | 4.9% (1) | 5.5–12.9% (2)
Hypertension (PIH) | 0–29% (5) | 12.5–21% (4) | | 0 (1) | | 4.8% (1)
Chorioamnionitis | 0–8% (5) | 1.4–9% (2) | 0–3.6% (3) | | 28.6% (1) | 21.6% (1)
Cesarean birth | 14–100%^a^ (7) | 93–100%^a^ (2) | 8–59.2%^a^ (5) | | 4% (1) | 12% (1)
Bleeding disorders postpartum (maternal) | 0–4% (3) | 0 (1) | 0.6 (1) | 0 (1) | | 12.5% (1)
Other complication in pregnancy (maternal) | 0–21% (7) | 5.3–7.5% (2) | 0–17% (3) | 0–6.8% (2) | 32.2 (1) | 33.8 (1) | | 0% (1)
Neonatal infection/sepsis | 2.6–18.2% (8) | 3.0–20% (5) | 0–5.4% (3) | | 5.3% (1) | 0.7–2.6% (2)
Fetal/neonatal death^b,d^ | 0–27% (16) | 0–11% (10) | 0–3.8% (5) | 4.1% (1) | 0–25% (5) | 1.5–10.8% (8) | | 3.8% (1)
Congenital anomalies | 0–12% (8) | 0.5–11% (5) | 0–0.6% (3) | | 0–8% (6) | 0–12% (6) | | 1.6% (1)
Reproductive teratogenic effects | 1.2% (1) | 2.1% (1) | | | 0–2.1%^c^ (2) | 3.4%^c^ (1) | | 0–1.6%^c^ (2)
Any adverse event | 64.4–65% (2) | 65.9–69% (2)
Withdrawals due to adverse events | 0.3–1.6% (4) | 0.6–3.2% (3) | 1.6% (1) | | 7.3% (1) | 8.3–9.4% (2)
Not reported * | 9 | 4 | 3 | 2 | 5 | 7

a Includes multiple gestation studies

b Fetal/Neonatal Deaths for all causes including complications of prematurity

c Includes fetuses exposed to progestogens in first trimester

d Includes participants with cervical length < 25 mm.

* One “other” study type did not report formulation or dosage information and is not included in the table

The most commonly reported progestogen-related harm in RCTs was injection site discomfort, in 17 to 62 percent of the treatment group and 8 to 62 percent of the placebo group;40, 48, 60 one prospective study reported injection site reactions in eight percent of participants.59 Vaginal irritation and/or discharge was the next most common, occurring among up to 28 percent of women receiving vaginal progesterone and up to 24 percent of participants receiving a vaginal placebo. Two other studies mentioned injection or vaginal site discomfort, but did not report a specific number or proportion of participants.66, 79 Urticaria or pruritus, reported in two RCTs, were experienced by up to four percent of progestogen treated participants and two percent receiving placebo.35, 48 Nausea was assessed in three RCTs. Nausea was reported by two percent of participants receiving 17OHP injections, five percent of participants receiving progesterone via vaginal suppository, and up to 12 percent of participants receiving placebos via vaginal or injected route.35, 48, 67 Neither of the trials using oral progesterone had any participants with nausea in the placebo or treatment arms.

Three studies investigated occurrence of gestational diabetes in women receiving 17OHP injections with conflicting results. In a pooled analysis of two RCTs (n=1,094), seven percent of the treatment and placebo groups developed gestational diabetes during the study.38 In a second RCT, 16 percent of treated compared to 12 percent of control participants (RR=1.43; 95% CI: 0.31, 9.01) developed gestational diabetes in a cohort of women pregnant with triplets. While not statistically different, the authors caution that this could be significant in a larger study population.30 A retrospective cohort found a statistically significant association between 17OHP injections and gestational diabetes with 13 percent of progesterone treated participants (n=557) receiving the diagnosis compared to five percent of comparison participants (RR=3.09; 95% CI: 2.2, 4.4).50

Five RCTs30, 40, 48, 67, 72 assessed occurrence of pregnancy-induced hypertension (PIH) in their participants. In four trials30, 40, 48, 72 13 to 21 percent of participants receiving progesterone and up to 29 percent of participants receiving placebo met criteria. In one trial67 none of the women in either group had PIH. Five RCTs reported incidence of chorioamnionitis,60 with ranges from 1.4 up to 9 percent among participants receiving injectable or vaginal progestogens, compared to zero to 8 percent of participants receiving the related placebos. Cesarean birth varied widely among seven RCTs reporting this outcome.52, 60 Proportions of women having a cesarean spanned eight to 100 percent of treatment groups and 14 to 100 percent of placebo groups. These numbers are skewed higher than one might expect because of trials that included multiple gestations. Among studies with singleton pregnancies, cesareans were performed in eight to 29 percent of women in the treatment group and 14 to 28 percent of placebo group participants. Generally risk of cesarean was not reported in a way that allowed taking into account the proportion of cesareans attributable to prematurity and/or higher proportions of malpresentation among preterm fetuses.

Eight RCTs30, 34–35, 47–48, 55, 67, 79 and one other study84 tracked other maternal harms in pregnancy. These included milder effects like headache, fatigue, dizziness, and uterine contraction, as well as more severe effects such as sepsis, postpartum endometritis, cardiac rhythm abnormalities and jaundice. Events ranged in frequency from zero to 34 percent of participants in the progestogen arms to zero to 32 percent of participants receiving placebo or in the comparison group. Two RCTs67, 79 assessed postpartum bleeding disorders, including postpartum hemorrhage and prolonged bleeding. Fewer than one percent of participants treated with vaginal progesterone and up to four percent of placebo group members reported disorders. No bleeding disorders were reported in women treated with 17OHP injections or oral progesterone therapy.

Among adverse effects reported in the fetus or newborn, fetal and/or neonatal mortality was the most common. A total of 15 RCTs14, 30–31, 34–36, 40–41, 48, 52, 55, 60, 68, 72, 79 and ten other studies28, 37, 42, 53, 69, 73–76, 80 noted mortality in eleven percent of the progestogen treatment arms and up to 27 percent of the placebo or comparison groups. This discrepancy likely reflects differences in preterm births between treatment and comparison arms, suggesting that in some cases, mortality is due to side effects of prematurity and not a risk of progestogen treatment. Because of small numbers for any single study, analyses were not reported that assessed risk of mortality adjusting for gestational age at birth. Neonatal infection and/or sepsis were reported by eight RCTs30, 36–37, 47–48, 55, 60, 68 with similar broad ranges of incidence between participants receiving 17OHP (three to 20%), and placebo injections or suppositories (2 to 18%). Congenital anomalies among neonates were reported by eight RCTs35–36, 48, 52, 60, 68, 72, 79 and seven other studies.16, 58, 66, 69–70, 74, 76 In the RCTs of vaginal progesterone, up to 0.6 percent of those treated had a fetus or neonate with a congenital defect; compared to 0.7 percent in the placebo groups.35–36, 52 Among women receiving 17OHP or placebo, anomaly rates were zero to 11 percent in the treatment groups and zero to 12 percent in the placebo groups.48, 60, 68, 72, 79 The high percentage in this group is due to the inclusion of a study with only 43 participants and five affected by anomalies including accessory digits and functional cardiac murmurs.79 Among the other study types, zero to 12 percent of fetuses or neonates in the treatment group and zero to eight percent in the comparison groups were affected by an anomaly. The high percentage in this group is due to the inclusion of a study with only 50 participants and five affected by anomalies including accessory digits and a loper.70 One study not included in this analysis demonstrated a higher incidence of hypospadias in participants receiving oral progesterone, however this effect was not statistically significant at the gestational age when these develop and not viewed to be caused by the therapy, but by underlying infertility.85

None of the studies collected information about macrosomia as an adverse outcome of progestogen therapy. A more recent study found that 4 percent of infants born to women receiving 17OHP injections were > 90 percent for size, suggesting potential for reduced risk relative to population norms in which 10 percent would be expected to be above the 90^th^ percentile. However all women in the study received a progestogen so there is no internal comparison group.28

Long-term effects of progestogen therapy could not be discerned because few studies collected followup beyond hospital discharge. One poor quality study reports an increase in “femininity” in boyhood and erectile failure and low sex drive in adulthood in males whose mothers received progesterone during pregnancy at any point between 6 and 35 weeks of gestation. These findings were not quantified and required 30 year recall to report on exposure.13 One study83 reports followup of 278 children (mean age 48 months) whose mothers were in an RCT of intramuscular 17OHP versus placebo.60 Scores on the Ages and Stages Questionnaire were not different for the two groups of children, both for overall scores and the five domains this instrument includes: communication, gross motor, fine motor, problem solving, and personal-social. There were also no significant differences between groups in the nature and rate of diagnoses by health professionals, caregivers’ assessment of the children’s health, physical examinations, and genital or reproductive anomalies.83

In summary, most harms were rare, and studies that did track them were primarily conducting safety monitoring and ultimately underpowered to determine if the treatment or placebo group experienced a meaningfully disproportionate burden of adverse events. Most harms that are common, such as injection site pain with intramuscular preparations or vaginal discharge with vaginal preparations, appear to be a side effect of route and are experienced in similar high proportions across treatment and placebo groups. Others, like cesarean, are entangled with multiple pregnancies and would require additional modeling within study data to evaluate for any independent effect of the drug on risk. For most remaining harms that would be of interest, heterogeneity across aspects of study design, variation in progestogens and routes studied, and level of detail provided about harms measured prevents calculation of meaningful aggregate estimates.

## KQ3 Maternal Risk Factors as Modifiers of Outcomes

In the context of this report, we use the term modifier to mean a characteristic that may interact with progestogen treatment to change the expected outcomes within the group who have that characteristic compared to a group who do not. For instance as an unrelated example of modification: pregnant women with Type 1 diabetes have higher risk of intrauterine fetal demise than women with Type 2 diabetes even when their insulin treatment achieves similar levels of blood sugar control. In this example the type of diabetes is said to modify the outcome of insulin treatment for reducing risk of fetal demise. Modifiers can have either a negative or a positive effect; some groups may get more benefit from an intervention than others.

A crucial factor in study of modifiers is that it requires a sufficient number of study participants with and without the characteristic who did and did not receive the treatment. Even studies that are sufficiently large to address the effectiveness of treatment with excellent statistical confidence in the findings may have groups that are too small to provide reliable analysis of the effects of modifiers. To directly assess whether a characteristic acts as a modifier requires specific statistical approaches. For instance, researchers could use either a stratified analysis – comparing treatment effects among women with the trait and without; or multivariate analysis that captures and compares the joint effects for each of the four (or more) possible groups: with trait and treatment, with trait and placebo, without trait and with treatment, and without trait and with placebo. Other sorts of comparisons among groups of women with specific traits across the findings of separate studies are descriptive and may lead to new hypotheses but are generally not definitive for making care decisions.

### Gestational Age at Birth of Prior Spontaneous Preterm Birth

We sought evidence about whether gestational age of a prior preterm birth modifies outcomes, among women receiving progestogen for the indication of a current singleton pregnancy and a history of prior spontaneous preterm. Clinical discussion often gravitates toward whether women with a more severe prior preterm birth—meaning earlier in gestation—achieve more or less advantage from progestogens compared with women with a less severe, later prior preterm birth. Two publications aimed to address this question.36, 86

A secondary, subgroup analysis of an RCT of intramuscular 17OHP among women with a prior spontaneous preterm birth (n=459) reported greater effectiveness for prevention of preterm birth defined as birth before 37 weeks gestation if the prior preterm birth was less than 34 weeks.86 By gestational age of the most severe prior preterm birth, the odds ratios for preterm birth comparing 17OHP to placebo were:

- OR=0.43 (95% CI: 0.19, 0.98) if between 20+0 and 27+6 weeks
- OR=0.44 (95% CI: 0.23, 0.85) if between 28+0 and 33+6 weeks
- OR=0.62 (95% CI: 0.29, 1.32) if between 34+0 and 36+6 weeks

While the trend in point estimates suggests greater benefit among those with earlier prior preterm birth, it is important to note that all the OR estimates of risk reduction fall within the confidence bounds of the other groups, meaning there is insufficient statistical precision to be confident of a conclusion that prior preterm birth severity modifies response to treatment.

A secondary, subgroup analysis of a non-blinded controlled trial of intravaginal micronized progesterone in women with a prior spontaneous preterm birth also did not have sufficient power.36 Subdivision of the study population into three subgroups resulted in groups with, n=39, n=27, and n=9, insufficient for definitive conclusions.

A retrospective report29 of 2,338 women subdivided the subjects according to gestational age of prior spontaneous preterm birth. A small effect of progestogens, less than one week of prolonged pregnancy, was reported for each of the three groups.

The body of evidence is fair for consistent effectiveness of progestogens for prevention of preterm birth, based upon gestational age (GA) of the prior spontaneous preterm birth. There is no evidence for different adverse effects or safety, based upon GA of the prior spontaneous preterm birth.

### Number of Prior Spontaneous Preterm Births

Number of prior preterm births has also been a candidate of interest as a modifier of response to progestogens treatment. Two secondary analyses from the same trials described above also examined the potential influence of the number of prior preterm births on response to progestogens.36, 87 Both evaluated preterm birth risk among women with one prior preterm birth, compared to more than one by progesterone versus placebo groups.

To establish a common metric across the two studies we have summarized the observed absolute risks and risk reduction by number of prior preterm births:

#### One prior preterm birth

- 17OHP (National Institute of Child Health and Human Development [NICHD] Maternal Fetal Medicine Units Trial)87
  ○ Treated: 31.8 percent preterm (99/310); placebo 44.4 percent (68/153)
  ○ Absolute risk difference: 12.6 percent lower among women treated
- Oral Micronized Progesterone36
  ○ Treated: 11.1 percent preterm (5/45); no treatment 35.0 percent (14/40)
  ○ Absolute risk difference: 23.9 percent lower among women treated

#### More than one prior preterm birth

- 17OHP (NICHD Maternal Fetal Medicine Units Trial)87
  ○ Treated: 47.7 percent preterm (148/310); placebo 69.8 percent (107/153)
  ○ Absolute risk difference: 22.1 percent lower among women treated
- Oral Micronized Progesterone36
  ○ Treated: 20 percent preterm (1/5); no treatment 50 percent (5/10)
  ○ Absolute risk difference: 30.0 percent lower among women treated

Multivariate models using the NICHD trial data suggested that receiving 17OHP reduced the excess risk of a history of more than one prior spontaneous preterm birth and that the outcome of the immediate prior pregnancy exerted more influence. However for formal analysis of number of prior preterm births as an effect modifier, even this larger trial lacks sufficient precision of the estimates across strata to document a clear difference. As in the examples of risk estimates by strata for severity of prior preterm birth, the estimates of effect are nested within each others’ confidence intervals: for women with one prior spontaneous preterm birth, the absolute risk reduction was 13 percent (95% CI: −2.7, 28.8%) and for those with more than one prior, absolute risk reduction was 22.7 percent (95% CI: 9.5, 36.0%). The purpose of the logistic regression analysis was to detect differences in the association of a risk factor for preterm birth and the event of preterm birth between women treated with 17OHP and those treated with placebo. The logistic regression analysis yielded an odds ratio of 3.38 (95% CI: 1.36, 8.40) when comparing participants who had more than one prior spontaneous preterm to participants who had one prior within the placebo group. This indicates that in the absence of treatment number of prior spontaneous preterm births is a risk predictor. However, within the treatment group, the logistic regression analysis yielded an odds ratio of 1.54 (95% CI: 0.85, 2.79) when comparing participants who had more than one prior spontaneous preterm birth with participants who had one prior preterm birth, not a statistically significant difference.87

The post hoc subgroup analysis of data from a nonblinded controlled trial of intravaginal micronized progesterone did not have sufficient power to examine effect modification. The sample size of the original study was adequate for main effects, but subdivision of the study population into two subgroups resulted in inadequate power.36

A double-blind randomized controlled trial of weekly 17OHP injections in 168 women had only three percent of women with a history of prior spontaneous preterm birth. These five women were an inadequate sample size for comparative analysis of effectiveness.72 A retrospective analysis of 906 women treated with weekly 17OHP injections did not include an untreated comparison group. No conclusion could be drawn about differences in effectiveness. The preterm birth rate was higher in participants with a higher number of prior spontaneous preterm births; this risk factor has already been established.53

The body of evidence is poor for determining if the effectiveness of progestogen for prevention of preterm birth varies by the number of prior spontaneous preterm births. No data evaluated other maternal, neonatal, or childhood outcomes. No evidence addresses adverse effects or safety, in relation to the number of the prior spontaneous preterm births.

### Short Cervix as an Effect Modifier

Shortened cervical length has been studied and confirmed as an independent risk factor for preterm birth and is of interest as a modifier of treatment effectiveness when the primary goal is related to another indication. (The study of treatment for the specific indication of short cervix is reviewed with primary indications and outcomes in KQ1.) A consensus about cut-off for defining short cervix has not been established; data suggest that the shorter the cervical length, the greater the risk of subsequent preterm birth.

One RCT screened 24,620 women to identify 413 women and enroll 250 participants with cervical length of ≤ 1.5cm by ultrasound exam.55 The intervention in this placebo-controlled trial was 200 mg micronized progesterone via vaginal suppository each evening with the primary outcome birth before 34 weeks gestation. Within this study of women who all had short cervical length were women with other risk factors: 15 percent had a prior spontaneous preterm birth and 10 percent had a current twin pregnancy. All estimates of effect of progesterone by subgroup (cervical length, one or more prior preterm births, or twin gestation) have overlapping confidence intervals meaning there was no evidence of modification of progesterone treatment outcomes by these characteristics. While effect estimates favor benefit of progesterone they were not statistically significant for more than half of the subgroups suggesting overall study power was lower than anticipated in the design of the trial.

A secondary analysis of a study of 620 women with a history of prior preterm birth and a current singleton pregnancy analyzed a subgroup of 547 participants with a cervix length > 3.0 cm at randomization compared to a subgroup of 104 participants with a cervix length of ≤ 3.0 cm at randomization. The intervention comparison was progesterone or placebo gel nightly. Of the 620 participants, 104 had a cervix length < 3.0 cm at randomization and received a second ultrasound measurement of cervix length at 28 weeks; 54 were in the progesterone group and 50 were in the placebo group. Cervical length at randomization was different between the two groups; the placebo group average length was 0.2 cm shorter. For the surrogate outcomes of 28 week cervical length less than 2.5 cm, or 28 week cervical length less than 1.5 cm, or more than 50 percent change in cervical length, no difference was found between the progesterone and placebo groups. After performing an adjustment for clinically relevant covariates for the subgroup of 110 participants with initial length of less than 3.0 cm, they found a small difference, with a very wide confidence interval, in cervical length change over the time from randomization to 28 weeks. The adjustment was performed by assigning a cervical length measurement of zero to all participants who delivered before the 28 week ultrasound study could be performed. Birth and neonatal outcomes were not statistically significant if expressed as relative risk of the outcomes. This secondary analysis is downgraded for serious study limitations, risk of bias, imprecision, and selective outcome reporting.52, 84

Another study planned to report on women with a singleton pregnancy and without a history of prior spontaneous preterm birth, with a short cervix on ultrasound examination, but they had only nine women with short cervical length (1.3% of the study population), and reported that a separate analysis of these participants would not be meaningful.82 Thus in total there is no evidence in the literature for either effect modification or differential risk of harms based on cervical length.

### Order of Multiple Gestations

We sought evidence about whether the number of fetuses in a multiple gestation modifies outcomes, among women receiving progesterone for the indication of a current multiple pregnancy. No data were found for quadruplets or higher multiples.

All placebo-controlled randomized trials of progestogen for prevention of preterm birth before 35 weeks in twin pregnancies have found no significant difference between the progestogen and placebo groups.35, 41, 48 One subgroup analysis of 67 twin pregnancies from a larger RCT of 150 women reported a benefit for prevention of preterm birth before 37 weeks for progestogen compared to placebo.31 The effectiveness was not meaningfully different across twins versus singletons. These studies did not include triplets and as a result cannot contribute direct information about modification of effects of treatment by three compared to two fetuses. A single study enrolling exclusively triplet pregnancies found no benefit of 17OHP injections compared to placebo.40

Given lack of effectiveness for modifying critical outcomes in multiple gestations, it is probable but not proven that the effect estimates for twins and triplets both overlap the null and include the confidence intervals of the comparison subgroup indicating no expectation of effect modification. Of note as presented in KQ 1, expectations for singleton compared to twin gestation are substantively different with low strength of evidence suggesting benefit for singleton pregnancies while moderate strength of evidence suggests lack of benefit for multiple gestations. This is a tacit acknowledgement of potential effect modification by singleton versus twin/triplet status though studies have not been conducted with adequate numbers of both singleton and multiple gestations in the same study protocol to definitively reach this conclusion.

### Preterm Labor in the Index Pregnancy

While a number of studies have information about the occurrence and treatment of preterm labor among their participants, these data were most often presented as descriptive or surrogate outcome data. No studies were designed to assess effect modification by preterm labor status. A small non-blinded quasi-randomized trial of participants with a mixture of risk factors, including 44 with threatened preterm labor, utilizing oral micronized progesterone as the intervention, reported no significant difference in prolongation of the pregnancy across risk groups. The risk of bias in this study was profound, and sample size was very small: 10 women had preterm births (seven in the placebo group and three in the progesterone group, after excluding participants with a multiple pregnancy).65 There is insufficient evidence to determine whether the effect of progestogen treatment, either benefits or risks, is modified by occurrence of preterm labor.

### Socioeconomic Risk Factors

Socioeconomic status and race have been candidates of interest as modifiers of response to progestogen treatment. A multi-center double-blind placebo-controlled randomized trial of 463 singleton gestation pregnancies with a history of spontaneous preterm birth, using weekly 17OHP injections as the intervention, showed a benefit for preventing preterm birth before 37 weeks in both subgroups assessed: Black, non-Hispanic women and all other women. Relative risk and absolute risk reduction are very similar:60, 87

- Black, non-Hispanic: RR=0.68 (95% CI: 0.51, 0.90); ARR=9.8 percent (95% CI: 1.19, 18.42%); Number needed to treat (NNT)=11 (95% CI: 5.4, 84)
- White, Hispanic, Asian, and Other: RR=0.64 (95% CI: 0.47, 0.87); ARR=8.8 percent (95% CI: 0.93, 16.7%); NNT=12 (95% CI: 6, 108)

Confidence bounds for estimates of effect overlap suggesting similar response to progesterone treatment in this trial. Information about response to treatment by race/ethnicity and socioeconomic factors is scant. As these are often characteristics identified in reproductive epidemiology studies as correlates of risk for preterm birth the paucity of information is surprising. Evidence from a single trial suggests race/ethnicity does not modify response to treatment; no data of sufficient power are available to estimate whether risk of harm varies.

### Body Mass Index (BMI)

Speculation about the role of BMI in influencing treatment response includes concerns that the dose of progestogen may not be sufficient at the highest BMI, and that comorbidities cluster at the extremes of BMI; for instance eating disorders at below average levels and metabolic syndrome at the above average levels. A systematic review of the literature (39 studies: 1,788,633 women), including cohorts and case-control studies, published between 1968 and 2009, examined the association between BMI and preterm birth of all types.88 The comparator group was BMI between 20 and 24.9. The overweight group (BMI=25–29.9) had a reduced adjusted OR=0.85 (95% CI: 0.80, 0.92) for preterm birth. The obese group (BMI=30–34.9) had a reduced adjusted OR=0.83 (95% CI: 0.75, 0.92) for preterm birth. The severely obese group (BMI=35–39.9) had an increased adjusted OR=1.33 (95% CI: 1.12, 1.57) for preterm birth. The morbidly obese group (BMI > 40) had an increased adjusted OR=2.27 (95% CI: 1.76, 2.94) for preterm birth.88 The entanglement of BMI and its related morbidities with both risk of preterm birth and potentially with the biological activity or risk of treatment make it an important target for understanding modification of progestogen treatment outcomes.

Sub-analysis of a multi-center double-blind placebo-controlled randomized trial of 463 singleton gestation pregnancies with a history of spontaneous preterm birth, using weekly 17OHP injections as the intervention, showed a benefit for preventing preterm birth before 37 weeks in women with pre-pregnant BMI < 29, and no benefit for women with a pre-pregnant BMI > 29.^87^ The p-value for the interaction term in multivariate models was < 0.001; however the confidence intervals for the effect itself by strata are not provided. Interaction terms may be significant in models while precision for confirming distinctive differences in treatment response at the relative and absolute level is insufficient.

The average prepregnant BMI in this study was 26.0 ± 7.0 in the placebo group, and 26.9 ± 7.9 in the treatment group, indicating that the average participant was overweight. The difference between treatment groups was most pronounced in the subgroup with a low pregravid BMI < 20 having increased risk of preterm birth whether treated (29% higher point estimate; 95% CI: 0.58, 2.88) or not, with threefold higher odds in the placebo group compared to women of normal weight (95% CI: 0.78, 19.19); however the study was underpowered for this factor with especially sparse data for low BMI participants (n=20). The authors suggested that weekly 17OHP injections are more effective in women with lower pregravid BMI and less effective in women with elevated pregravid BMI. Another interpretation could be that the effectiveness of progestogen is greater in women with a lower pregravid BMI. Another, that higher doses of progestogen may be needed in participants with a high pregravid BMI or that higher pregravid is protective for reduction of future preterm birth after prior preterm birth, and that progestogen does not confer additional benefit for this subgroup of participants. Last, in keeping with the broader literature about the relationship between obesity and preterm birth, it is possible that the placebo group of this RCT is atypical, and the trend seen in the subanalysis is reflective of the atypical placebo group, rather than a differential effect of progestogen in women with differing pregravid BMI.87

The evidence is insufficient to understand the influence of BMI on response to progestogens. Given a typical expectation that effective dose and BMI may be related, high prevalence of obesity in the United States, and need to assess risk of interaction with co-morbidities, this is an important lack of data that makes the literature less applicable than is desirable.

### Cerclage

A planned secondary analysis32 of the Eunice Kennedy Shriver National Institute of Child Health and Human Development-sponsored randomized trial evaluating cervical cerclage for women with singleton gestations, prior spontaneous preterm birth (17–33 6/7 weeks), and cervix length < 25 mm reported the impact of 17P usage on the primary outcome of preterm birth before 35 weeks. The study subjects were stratified at randomization by intent to use or not to use 17P. Intramuscular 17P had no additional benefit for prevention of preterm birth in women who had prior spontaneous preterm birth and received the randomized intervention of ultrasound-indicated cerclage for CL < 25 mm. The clinical trial was not powered for this secondary analysis. According the post hoc analysis in the publication, 14 times the number of subjects would have been needed to show a 4 percent decrease in the preterm birth < 35 weeks.

### Other Candidate Modifiers

No analyses were identified that assessed modification of treatment effectiveness among women with these characteristics versus without:

- Fetal fibronectin testing results
- Prior PPROM
- Uterine malformation
- Conception using assisted reproductive technology (e.g., in vitro fertilization, intracytoplasmic sperm injection of eggs)
- Maternal age

Likewise, there were not related assessments of differences in adverse effects.

## KQ4 Type of Progestogen as a Modifier of Outcomes

Randomized controlled trials making direct comparisons of one form of progestogen to another have not been conducted with currently available progestogens. A single 1979 study comparing intramuscular 17OHP and oral chlormadinone acetate is the only head-to-head comparison.77 This means there are no high-quality data to determine superiority or equivalency of one formulation, dose, or route compared to another. As an extension of this lack of direct comparisons, it is not possible to determine with confidence whether acceptability, adherence, adverse effects, or safety of progestogens vary by formulation, dose, or interval of administration. Likewise no RCTs have investigated ideal timing for initiation or discontinuation of therapy.

Since the summary of the evidence for KQ1 is organized primarily by the risk group being treated with progestogens (prior preterm birth, preterm labor, multiple gestation), we reintroduce some of the related summary data in this section organized by type of progestogen.

First we present total yield of the literature search to convey the scope of the literature. Across all studies the most common progestogens and doses, by route, were: 250 mg of 17OHP injected intramuscularly weekly, 90 mg progesterone vaginal suppository or gel daily, and 200 to 1000 mg oral micronized progestogen daily. Next we present summary preterm birth outcomes in this order of prevalence in the literature, focusing on summaries of RCTS. Since data from separate RCTs cannot provide strong evidence for selecting one type of progestogen intervention over another, we have not provided detailed summaries of observational data which is even more prone to bias and less suitable to cross-study comparisons.

### Injection of 17OHP

We identified 27 studies that administered injected 17OHP for prevention of preterm birth, 12 were RCTs;30, 40–41, 46, 48, 56, 60, 68, 72, 77, 79, 83 three were clinical trials;66, 71, 73 two, prospective cohorts;74, 76 eight were retrospective cohorts;33, 39, 44, 53–54, 59, 70, 80 one, a retrospective case series;45 and one, a case-control study.58 Four of these publications are ancillary publications from a single study population60, 86–87, 89 and two share another population.52, 82 We considered them as only two study populations. The majority of studies (19) were conducted in the United States,30, 33, 39–41, 44–45, 48, 50, 53–54, 59–60, 70, 72, 76, 79–80, 83 seven in Europe,46, 56, 58, 71, 73–74, 77 and one in Asia.66 Exact combinations of dose, interval, and target window are provided in Table 3 under Results (above). The majority of 17OHP studies initiated treatment between 16–21 weeks gestation with a range of 15–36 weeks.

Table 18 summarizes the nine RCTs of 17OHP that reported prematurity outcomes at < 37 (singleton gestations) or < 35 (multiple gestations) weeks. Four different 17OHP doses were used and indications for treatment included prior preterm birth in one trial, preterm labor in two, multiple gestation in three, a variety of risk factors in one, and amniocentesis. Four of eight demonstrated effectiveness of 17OHP, four had nonsignificant findings, and none found significant advantage for the placebo group. Aggregate estimates indicated that 17OHP was not effective at reducing risk for neonatal mortality (OR=1.11, 95% BCI: 0.66, 1.73) but was effective at reducing risk of preterm birth (meta-estimate OR_17OHP_=0.75, 95% BCI: 0.60, 0.90).

Table 18 Injection of 17OHP in RCTs reporting prematurity outcomes at < 35 or < 37 weeks

Author Year | Dose | Outcome | Favors 17OHP | NS | Favors Placebo
Caritis et al.40 2009 | 250 mg q 7d | < 35 | | RR=1.0 (0.9, 1.1)
Combs et al.30 2010 | 250 mg q 7d | < 35 | | NR p=0.15
Briery et al.41 2009 | 250 mg q 7d | < 35 | | NR p=0.117
Facchinetti et al.46 2008 | 341 mg q 4d | < 37 | NR p=0.049
Rouse et al.48 2007 | 250 mg q 7d | < 35 | | RR=1.1 (0.09, 1.3)
Facchinetti et al.56 2007 | 341 mg q 4d | < 37 | NR p=0.004
Meis et al.60 2003 | 250 mg q 7d | < 37 | RR=0.66 (0.54, 0.81)
Corrado et al.62 2002 | 340 mg twice a week until 2^nd^ week after amniocentesis | < 37 | | NR p > 0.05
Yemini et al.68 1985 | 250–12,500 mg over 36 wks (NR) | < 36 | NR p < 0.05

17OHP = 17 alpha-hydroxyprogesterone caproate; d = day; mg = milligrams; NR = not reported; NS = not significant; q = every; RR = relative risk; wks = weeks.

### Vaginal Administration of Progestogens

We identified seven publications that report on either a vaginal gel, capsule, or suppository for administering progestogen treatment.31, 35–36, 47, 52, 55, 61 Two studies52, 82 are part of a single family of studies and are considered a single study population in this report. All studies31, 35–36, 47, 52, 55, 61 were RCTs with four conducted outside of the United States. These include the United Kingdom,35 Brazil,61 India,36 and Iran.47 The remaining studies were either in the United States31 or conducted at multiple sites. These include one study that included United States, South Africa, India, Czech Republic, Chile, and El Salvador52 and another study that included the United Kingdom, Chile, Brazil, and Greece.55 Exact combinations of dose, interval, and target window are provided in Table 3 under Results (above).

In the seven RCTs of vaginal administration, five different doses were used. The indication for treatment was history of preterm birth in two studies,36, 52 multiple gestation in one,35 varied risk factors in two,31, 61, and shortened cervical length in one.55 The gestational age at initiation of treatment was 24 weeks for three out of seven of these studies.35, 55, 61 The remaining studies initiated treatment at 18–22+6 weeks,52 20–24 weeks,36 24–34 weeks,31 and after tocolysis obtained.47 Table 19 summarizes findings for prevention of preterm birth. Overall, four of six demonstrated effectiveness of vaginal progesterone, two had nonsignificant findings, and none found significant advantage for the placebo group. Of note neither trial of gel found benefit (combined n=1,109).35, 52 Aggregate estimates indicated that vaginal progestogens were not effective at reducing risk for neonatal mortality (OR=0.77, 95% BCI: 0.39, 1.27) but were effective at reducing risk of preterm birth (meta-estimate OR_Vaginal_=0.76, 95% BCI: 0.57, 0.98).

Table 19 Vaginal progestogens in RCTs reporting prematurity outcomes at < 35 or < 37 weeks^*^

Study Country | Form | Dose | Outcome | Favors Progestogen | NS | Favors Placebo
Cetingoz et al.31 2010 Turkey | Vaginal Supp | 100 mg qd | < 37 | OR=0.5 (0.26, 0.96)
Norman et al.35 2009 UK | Vaginal Gel | 90 mg qd | < 34 | | OR=0.74 (0.48, 1.12)
Majhi et al.36 2009 India | Vaginal Cap | 100 mg qd | < 37 | RR=0.32 (0.14, 0.72)
O’Brien et al.52 2007 Multinational | Vaginal Gel | 90 mg qd | < 37 | | OR=0.93 (0.66, 1.32)
Fonseca et al.55 2007 Multinational | Vaginal Cap | 200 mg qd | < 34 | RR=0.60 (0.35, 0.94)
da Fonseca et al.61 2003 Brazil | Vaginal Supp | 100 mg qd | < 37 | NR p =0.03

* One study was not included because they report at 34 weeks gestation.

Cap = capsule; mg = milligrams; NR = not reported; NS = not significant; OR = odds ratio; qd = every day; RR = relative risk; Supp=suppository, UK = United Kingdom.

### Oral Administration of Progestogens

Five studies34, 63–65, 67 used oral progestogens alone or in combination with Ritodrine in the treatment group. Three recruited participants in Europe (France),63, 65, 67 one in the United States,64 and one in Asia (India).34 Four were RCTs 34, 64–65, 67 and one was a case-control study.63

Exact combinations of dose, interval, and target window are provided in Table 3 under Results (above). Two studies did not indicate gestational age at initiation63, 65 and three reported ranges between 18–36 weeks.35, 64, 67 One study required a previous history of preterm birth.34 None enrolled multiple gestations as an indication for progestogen treatment.

Three RCTs reported prematurity outcomes at < 37 weeks and are summarized in Table 20. Each of the three RCTs use different doses and had different indications for treatment, including history of preterm birth, preterm labor, and a variety of risk factors. One of three demonstrated effectiveness of oral progestogens, two had nonsignificant findings, and none found significant advantage for the placebo group. Aggregate estimates indicated that oral progestogens were not effective at reducing risk for neonatal mortality (OR=0.68, 95% BCI: 0.04, 2.17) but were the most effective at reducing risk of preterm birth relative to the other meta-estimates for 17OHP and vaginal progestogens which were approximately 0.75 (meta-estimate OR_Oral=_0.56, 95% BCI: 0.36, 0.79).

Table 20 Oral progestogens in RCTs reporting prematurity outcomes at < 37 weeks

Study Country | Progestogen | Dose | Outcome | Favors Progestogen | NS | Favors Placebo
Rai et al.34 2009 India | Progesterone^†^ | 100 mg b.i.d. | < 37 | NR p=0.002
Hobel et al.64 1994 U.S. | Provera | 20 mg b.i.d. | < 37 | | NR p=0.98
Noblot et al.65 1991 France | Progesterone^†^ | 4x 100 mg q6h for 24h; 4x 100 mg q8h for 24h; then 3 100 mg q8h | < 37 | | NR p=NS

† Micronized progesterone.

b.i.d. = twice a day; h = hours; mg = milligrams; NR = not reported; NS = not significant; q = every.

### Gestational Age at Initiation of Intervention

Gestational age at initiation has been a candidate of interest as a modifier of response to progestogens treatment. No direct comparator studies were found. Two clinical care cohorts in which timing of initiation varied, for reasons other than randomization, showed no significant difference in preterm birth rates based upon whether the progestogen was initiated before or after 21 weeks’ gestation (combined n=1,181).53–54 Two studies with intervention initiated before 20 weeks gestation in all participants have conflicting findings about prevention of preterm birth before 37 weeks:

- RR=0.66 (95% CI: 0.54, 0.81) with 17OHP and n=459^60^
- RR=1.03 (95% CI: 0.85, 1.24) with progesterone vaginal gel and n=611^52^

Initiation after 20 weeks gestation in all participants for birth before 37 weeks:

- RR=0.49 (95% CI: 0.25, 0.96) with progesterone vaginal suppository and n=142^61^

No RCTs directly address modification of effectiveness by timing of initiation. Given variation in pharmaceutical agents being studied, as outlined above, it is not possible to extrapolate from trends in study findings to determine an optimal time for initiation of treatment. There is no evidence available to determine if there are differences in adverse effects or safety, based upon gestational age at initiation of the intervention. Evidence is insufficient to define an ideal gestational age at which to start treatment.

### Adherence

17OHP. Eight studies reported on adherence to 17OHP treatment.33, 39–40, 45, 56, 59–60, 83 Two RCTs directly compared adherence among intervention and placebo groups. An RCT from Italy (n=38), reported 100 percent adherence in both the 17OHP intervention group and their control group,56 and a large RCT in the United States (n=459) reported 8.5 percent of the17OHP intervention group was nonadherent, but not statistically different from the placebo group.60 Another RCT in the United States (n=278), noted that 91.4 percent of the study participants were adherent with treatment but did not make statistical comparisons across groups. A prospective cohort from the United States (n=38), noted that 25 percent of the intervention group missed more than two doses.59 A retrospective cohort in the United States (n=684), compared early discontinuation of treatment for reasons other than birth between a 17OHP intervention group (250 mg every seven to ten days) (9.4%) and daily perinatal nursing surveillance (7.3%) and did not observe a significant difference.33 Only one study,45 a retrospective case series (n=208), directly assessed adherence in the context of frequency of injections; they observed that only 2.2 percent of participants missed a dose and all received less than five injections. None of the published studies directly compared adherence at varying gestational ages at initiation and discontinuation of treatment, or made comparisons across types of progestogens.

Vaginal progesterone. Adherence and/or compliance were only discussed in two studies of vaginal administration.52, 55 One study52 directly tested for differences in adherence between their treatment and intervention group and observed no significant difference between the two groups (96.2% compliance in treatment group versus 96.4% compliance in placebo group). The other55 was less clear about how they assessed adherence, noting 7.2 percent had adherence < 80 percent but that this was not significantly different from controls.

Oral Progestogens. None of the studies directly assessed participant adherence to treatment.

### Risk of Harms

Without direct comparisons of different formulations, doses and intervals it is not possible to know whether risk of harm varies for different formulations and routes of progestogens. Given lack of detailed reporting about harms and lack of consistent definitions, it is not meaningful to extrapolate among routes from available data. Overall, there is no evidence to help inform selection of the progestogen with the fewest side-effects and/or lowest risk of harms.

## KQ5 Cointerventions as Modifiers of Outcomes

Ten studies reported using tocolytic treatments as a cointervention to prevent spontaneous preterm birth31, 34, 50, 60–61, 64–65, 68, 74, 77 either alone or in combination with another cointervention. Eight studies used other forms of cointerventions for their intervention group including cortisol,73 daily nursing surveillance,43 nurses to administer drugs and availability to ask questions but not daily,33 bed rest,75 cervical cerclage,32 estrogen,78 omega-3 fatty acid supplements,28 and DES.13 None of these studies provide data that allow determination of the separate and joint effects of the progestogen and the cointervention. We sought stratified analyses (grouped either by the cointervention or the progestogen placebo or control status), models with an interaction term, or models of independent effect from which effect modification could be calculated. As a result, evidence is insufficient for understanding the role of cointerventions in either amplifying or undermining the potential benefits of progesterone treatment. It is not feasible to assess adherence or harms because of small group sizes by combinations of progestogen and cointervention and because of limited reporting of adverse events. No evidence is available to guide choice of cointerventions.

## KQ6 Effect of Health System and Provider Factors

### Approach

We sought research that explicitly studied the knowledge, attitudes, and prescribing behaviors of care providers with regard to their clinical use of progestogens for women at risk of preterm birth, broadly defined. We also sought publications that included data about use of progestogens in well-circumscribed populations in which the proportion of eligible women who received progestogens could be estimated or in which authors present analyses focused on the influence of health system factors like coverage for progestogens, formulary/availability, provider specialty, and institutional guidelines or policies.

### Results

Using this approach, we identified 11 publications, from nine distinct study populations.10, 33, 39, 49–50, 57, 59, 90–93 Three reports originate from a Matria Healthcare database, or databases, and present information from different but overlapping timeframes, likely resulting in some duplication of the clinical population studied.33, 49–50 The other study populations were women enrolled in the high-risk clinic,57 or a “prematurity prevention” clinic39 of academic tertiary care centers, and an analysis of use within the Missouri Medicaid managed care component.59

Five studies directly surveyed providers about their practice patterns, knowledge, attitudes, and concerns. Three of these surveys were conducted in the United States,10, 91, 93 with two directed to board-certified maternal-fetal medicine specialists (MFMS)10, 93 and one directed to members of the American Congress of Obstetricians and Gynecologists (ACOG) Collaborative Ambulatory Research Network.91 The remaining surveys were conducted in Canada (national registry of obstetricians)92 and Australia and New Zealand (members of the Royal College).90 In each of these surveys, information about progestogen use was collected from December 2003 and later; meaning all were conducted after the publication of the NICHD Maternal-Fetal Medicine Networks trial of 17OHP appeared in print.60

Among the six observational studies that provide data about use of progestogens in defined populations of participants, four publications had study objectives related to understanding prescribing practices or patterns of use;33, 49, 57, 59 and two provide data that are informative for this KQ but were incidental to the aims of the publications.39, 50 All reflect care for women in the United States from 1995 forward; the majority in 2003 and later.49–50, 57, 59

The provider survey studies reflect responses from 1,098 specialist practitioners (which includes an unknown but substantial amount of overlap given repeated survey of the same organization) and 345 generalist practitioners in the United States and 2,246 obstetricians in Australia, Canada and New Zealand, with survey response rates from 42 to 53 percent. The literature reflects increasing use in the United States from 38 percent of MFMS surveyed in 2003^93^ to 74 percent of ACOG network members by 2007.^91^ Ness and colleagues who surveyed MFMS twice, documented this was a statistically significant increase between 2003 with 38 percent prescribing for preterm birth prevention and 2005 with 67 percent prescribing (p < 0.001).10 If the NICHD trial indication for prevention of preterm birth in singleton gestations for mothers who have had a prior spontaneous preterm birth is used as a general rubric for eligibility for treatment, then the self-reported prescribing progestogens beyond that specific indication is also rising, with 20 percent of MFMS reporting use for short cervix or preterm labor symptoms in the 2003 publication; 39 percent of MFMS by 2005; and 52 percent of ACOG network obstetricians in 2007. More than three-quarters of use has been intramuscular administration of weekly injections, with vaginal the next most common, and oral rare.

The list of barriers to use reported by those who do prescribe progestogens was topped by lack of availability and lack of insurance coverage, with other factors including lack of FDA approval for the indication and need for greater information about long-term effects.10, 91 Nonprescribers identified similar ranking for barriers compared to prescribers in the MFMS survey but endorsed them as problems in higher proportions, with the exception of not being as likely to indicate that insurance coverage was an important barrier. Among generalists, the rank order of barriers differed from prescribers with nonprescribers concerns being greatest to least in order from need for data, long-term effects, availability, efficacy, liability, to FDA approval.91

The survey of obstetricians participating in the ACOG research network was the only one to ask about patient demand. Overall, 63 percent of respondents reported that patients “never request”; 35 percent, “infrequently request”; and 2 percent “frequently request.”91 This was also the only study to examine patterns in responses about use, finding in multivariate models that those who trained more recently, who were specialists, and practiced in group or academic settings were most likely to prescribe treatment, and that regionally practitioners in the Western United States were least likely to use progestogens for preterm birth prevention.

In sharp contrast with trends in the United States, studies outside the United States, which happen also to be from countries with national health systems, found little use of progesterone—2 percent among Australian/New Zealand obstetricians and seven percent among Canadian obstetricians. Seventy-one percent of Canadian obstetricians cited “evidence not convincing” as the primary reason they do not prescribe routinely for prevention of preterm birth. Both Canadian and Australian/New Zealand obstetricians expressed willingness to participate in large-scale trials (84% and 65% respectively), indicating alignment of the perceived weakness of evidence with willingness to pursue additional data. Given low reported use, neither report could provide data about use patterns or trends in indications.

Observational studies of progestogen use, suggest more than 40 percent of women who are eligible for treatment with progestogens, based on prior history of preterm birth and a current singleton gestation, do not receive treatment. Bailit and colleagues encompassed the earliest time period, investigating prescribing behavior from July 2003 through June 2004.^57^ They explicitly choose a site that was part of the Maternal-Fetal Medicine Research Network 17OHP trial in order to examine uptake and use patterns in an environment in which the care providers and clinical staff had a high level of familiarity with providing the intervention. Among 500 high-risk participants, 57 percent of eligible women were offered progestogens; another two percent were offered treatment who would not have met trial criteria, most of the latter had multiple gestations and most of the prescribing beyond the trial evidence was done by a single provider. The pattern of progestogens prescribed was surprising—25.5 percent received injections; 55.8 percent vaginal suppositories, and 18.6 percent had missing information about dose and route. Even if all missing are assumed to be injection, the majority of women were given vaginal suppositories. The authors anecdotally relate this to drug availability and coverage.

Durnwald and colleagues’ study at the other academic site encompassed 1999 to 2008 but did not relate the timing of care in secular time with the use of progestogens. Overall, 52.5 percent of eligible women received intramuscular 17OHP and analysis of predictors found older age, private insurance, earlier prior preterm birth, and earlier enrollment in prenatal care were associated with higher use.39

Missouri Medicaid managed care was an early adopter of coverage. This allowed comparison of 24 women who received 17OHP injections in 2004 to 14 who did not but would have been eligible. While the authors were focused on outcomes in their data analysis, they did offer the observation that later onset of care related to delays in establishing Medicaid eligibility could have contributed to lack of use when appropriate.59

Publications relying on Matria clinical care databases provide a different perspective. In order to be in the database a woman had to be referred for home health services that include a wide panel of options from home uterine activity monitoring, daily nurse calls, diabetes management, blood pressure monitoring, and home administration of 17OHP injections. Women referred include both Medicaid and private pay patients. The database includes prior pregnancy history and can be used to assess eligibility for progesterone use in the index pregnancy. Processes of care also ensure that the provider indication for desiring to initiate progestogen treatment is indicated. In a matched study of 342 women who received 17OHP injections (with or without other services) and 342 who did not but received uterine monitoring and nurse calls, early enrollment in care was a determinant with 80.4 percent of those receiving entering care before 21 weeks (the percentage of women enrolling before this time among those that did not receive 17OHP injections is not reported).33 Another analysis focused on gestational diabetes incidence among women receiving 17OHP injections, indirectly provides data that 557 women received progesterone treatment between April 2004 and January 2006, while another 1,524 women at similar risk of preterm birth based on prior preterm birth did not. Analysis of predictors of use whether provider or patient factors is not included.50 The largest and most direct analysis of use in the Matria patient population includes 1,979 women, from April 2004 to January 2006, who did receive 17OHP and focuses on patterns of use. Among those women receiving progesterone, 79.5 percent had a prior preterm birth and 63.6 percent met the MFMU trial criteria. Of those appropriately offered treatment, 56.5 initiated between the target gestational ages of 16 and 20.9 weeks. Multiple gestations made up eight percent of nonstandard use, with current preterm labor treatment comprising 44.8 percent and 23.2 percent with cerclage, being the largest groups.

Overall this research provides intriguing glimpses that suggest that, as for most preventive interventions, individuals, care providers, care systems, access, and coverage influence practice. This evidence confirms that targets for progestogen use are evolving with indications at risk of evolving beyond evidence; and that uptake, at least in the United States, is likely rising. The limited spectrum and preliminary level of detail about influences is an invitation to more substantive investigation. Certain gating factors like coverage of costs and the necessity of enrolling in care in time to start treatment in the appropriate time window can be taken as tacit areas for improvement of access to progestogen treatment. However, most influences will be more complex. For example, at least one reputable national mail-order pharmacy dispenses progestogens, making literal “availability” possible anywhere in the United States. Yet, without information about this resource and others, demands on patient and provider time can make such a logistic barrier—knowing how and where to order and what the payment options are—into an absolute barrier that prevents treatment. As evidence about effectiveness and eligible populations advances, health services research will be needed to translate the evidence into practice.