# References and Included Studies

1 Behrman RE, Butler AS. Institute of Medicine (US) Committee on Understanding Premature Birth and Assuring Healthy Outcomes. Preterm birth : causes, consequences, and prevention. Washington, D.C. National Academies Press. 2007.
2 Martin JA, Hamilton BE, Sutton PD, et al. Births: final data for 2005. Natl Vital Stat Rep. Dec. 5. 2007;56(6:):1-103. [pmid: 18277471].
3 Hamilton BE, Martin JA, Ventura SJ. Births: Preliminary data for 2007 National vital statistics reports. Web release Released March 18, 2009 Released March 18, 2009. 57(12).
4 Bailit JL, Votruba ME. Medical cost savings associated with 17 alpha-hydroxyprogesterone caproate. Am J Obstet Gynecol. Mar. 2007;196(3):219 e1-7. [pmid: 17346527].
5 FDA approves drug to reduce risk of preterm birth in at-risk pregnant women. United States Food and Drug Administration. 2011. http://www.fda.gov/NewsEvents/Newsroom/PressAnnouncements/ucm242234.htm. Accessed on February 4, 2011.
6 Simhan HN, Caritis SN. Prevention of preterm delivery. N Engl J Med. Aug. 2. 2007;357(5:):477-87. [pmid: 17671256].
7 Meis PJ, Aleman A. Progesterone treatment to prevent preterm birth. Drugs. 2004;64(21):2463-74. [pmid: 15482003].
8 ACOG Committee Opinion. Use of progesterone to reduce preterm birth. Obstet Gynecol. Nov. 2003;102(5 Pt 1):1115-6. [pmid: 14672496].
9 ACOG Committee Opinion number 419 October 2008 (replaces no. 291 November 2003). Use of progesterone to reduce preterm birth. Obstet Gynecol. Oct. 2008;112(4):963-5. [pmid: 18827143].
10 Ness A, Dias T, Damus K, et al. Impact of the recent randomized trials on the use of progesterone to prevent preterm birth: a 2005 follow-up survey. Am J Obstet Gynecol. Oct. 2006;195(4:):1174-9. [pmid: 17000251].
11 Loose DS, Stancel GM. Estrogens and progestins. Goodman & Gilman's the pharmacological basis of therapeutics. 11th edition. 2006.
12 Brucker MC, Likis FE. Steroid hormones. Pharmacology for Women's Health. 2011.
13 Kester P, Green R, Finch SJ, et al. Prenatal 'female hormone' administration and psychosexual development in human males. Psychoneuroendocrinology. Dec. 1980;5(4:):269-85. [pmid: 7208750].
14 Fuchs F, Stakemann G. Treatment of threatened premature labor with large doses of progesterone. Am J Obstet Gynecol. Jan. 1960;79:172-6. [pmid: 13825506].
15 Meyer Bahlburg HF, Grisanti GC, Ehrhardt AA. Prenatal effects of sex hormones on human male behavior: medroxyprogesterone acetate (MPA). Psychoneuroendocrinology. Oct. 1977;2(4:):383-90. [pmid: 564072].
16 Ovlisen B, Iversen J. Treatment of threatened premature labor with 6alpha-methyl-17alpha-acetoxyprogesterone. Am J Obstet Gynecol. Jun. 1. 1963;86:291-5. [pmid: 13940818].
17 Juni P, Holenstein F, Sterne J, et al. Direction and impact of language bias in meta-analyses of controlled trials: empirical study. Int J Epidemiol. Feb. 2002;31(1:):115-23. [pmid: 11914306].
18 Gelman A, Carlin J, Stern H, et al. Bayesian Data Analysis. 2004.
19 Sutton A, Abrams K. Bayesian methods in meta-analysis and evidence synthesis. 2001.
20 Lindley DV, Novick MR. The role of exchangeability in inference. Ann Stat. 1981;9(1):45-58.
21 Patil A, Huard D, Fonnesbeck C. Bayesian stochastic modelling in python. Journal of Statistical Software. 2010;35(4):1-80. [pmid: 21603108].
22 Matchar DB, Myers ER, Barber MW, et al. Management of uterine fibroids. Evid Rep Technol Assess (Summ). Jan. 2001;(34):1-6. [pmid: 11236283].
23 Schulz KF, Chalmers I, Grimes DA, et al. Assessing the quality of randomization from reports of controlled trials published in obstetrics and gynecology journals. JAMA. Jul. 13. 1994;272(2:):125-8. [pmid: 8015122].
24 Schulz KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. Feb. 1. 1995;273(5):408-12. [pmid: 7823387].
25 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. 2008. www.ncbi.nlm.nih.gov/entrez/query.fcgi?cmd=Retrieve&db=PubMed&dopt=Citation&list_uids=21433403.
26 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5:):513-23. [pmid: 19595577].
27 Mason MV, Poole-Yaeger A, Krueger CR, et al. Impact of 17P usage on NICU admissions in a managed medicaid population--a five-year review. Manag Care. Feb. 2010;19(2:):46-52. [pmid: 20550052].
28 Harper M, Thom E, Klebanoff MA, et al. Omega-3 fatty acid supplementation to prevent recurrent preterm birth: a randomized controlled trial. Obstet Gynecol. Feb. 2010;115(2 Pt 1):234-42. [pmid: 20093894].
29 Gonzalez-Quintero VH, de la Torre L, Rhea DJ, et al. Impact of prior gestational age at preterm delivery on effectiveness of 17-alpha-hydroxyprogesterone caproate in practice. Am J Obstet Gynecol. Sep. 2010;203(3):257 e1-5. [pmid: 20678745].
30 Combs CA, Garite T, Maurel K, et al. Failure of 17-hydroxyprogesterone to reduce neonatal morbidity or prolong triplet pregnancy: a double-blind, randomized clinical trial. Am J Obstet Gynecol. Sep. 2010;203(3):248 e1-9. [pmid: 20816146].
31 Cetingoz E, Cam C, Sakalli M, et al. Progesterone effects on preterm birth in high-risk pregnancies: a randomized placebo-controlled trial. Arch Gynecol Obstet. Mar. 2011;283(3:):423-9. [pmid: 20091317].
32 Berghella V, Figueroa D, Szychowski JM, et al. 17-alpha-hydroxyprogesterone caproate for the prevention of preterm birth in women with prior preterm birth and a short cervical length. Am J Obstet Gynecol. Apr. 2010;202(4):351 e1-6. [pmid: 20350641].
33 Rittenberg C, Newman RB, Istwan NB, et al. Preterm birth prevention by 17 alpha-hydroxyprogesterone caproate vs. daily nursing surveillance. J Reprod Med. Feb. 2009;54(2):47-52. [pmid: 19301566].
34 Rai P, Rajaram S, Goel N, et al. Oral micronized progesterone for prevention of preterm birth. Int J Gynaecol Obstet. Jan. 2009;104(1:):40-3. [pmid: 18929360].
35 Norman JE, Mackenzie F, Owen P, et al. Progesterone for the prevention of preterm birth in twin pregnancy (STOPPIT): a randomised, double-blind, placebo-controlled study and meta-analysis. Lancet. Jun. 13. 2009;373(9680:):2034-40. [pmid: 19523680].
36 Majhi P, Bagga R, Kalra J, et al. Intravaginal use of natural micronised progesterone to prevent pre-term birth: a randomised trial in India. J Obstet Gynaecol. Aug. 2009;29(6:):493-8. [pmid: 19697195].
37 Keeler SM, Kiefer D, Rochon M, et al. A randomized trial of cerclage vs. 17 alpha-hydroxyprogesterone caproate for treatment of short cervix. J Perinat Med. 2009;37(5):473-9. [pmid: 19492920].
38 Gyamfi C, Horton AL, Momirova V, et al. The effect of 17-alpha hydroxyprogesterone caproate on the risk of gestational diabetes in singleton or twin pregnancies. Am J Obstet Gynecol. Oct. 2009;201(4):392 e1-5. [pmid: 19716543].
39 Durnwald CP, Lynch CD, Walker H, et al. The effect of treatment with 17 alpha-hydroxyprogesterone caproate on changes in cervical length over time. Am J Obstet Gynecol. Oct. 2009;201(4):410 e1-5. [pmid: 19716117].
40 Caritis SN, Rouse DJ, Peaceman AM, et al. Prevention of preterm birth in triplets using 17 alpha-hydroxyprogesterone caproate: a randomized controlled trial. Obstet Gynecol. Feb. 2009;113(2 Pt 1):285-92. [pmid: 19155896].
41 Briery CM, Veillon EW, Klauser CK, et al. Progesterone does not prevent preterm births in women with twins. South Med J. Sep. 2009;102(9:):900-4. [pmid: 19668021].
42 Ventolini G, Duke J, Po W, et al. The impact of maternal body mass on the effectiveness of 17 alpha-hydroxyprogesterone caproate. J Reprod Med. Sep. 2008;53(9:):667-71. [pmid: 18839818].
43 Rittenberg C, Sullivan S, Istwan N, et al. Women receiving 17-alpha-hydroxyprogesterone caproate hospitalized for preterm labor at less than 34 weeks benefit from daily perinatal nursing surveillance. Am J Obstet Gynecol. Oct. 2008;199(4):389 e1-4. [pmid: 18928983].
44 Rebarber A, Cleary-Goldman J, Istwan NB, et al. The use of 17 alpha-hydroxyprogesterone caproate (17p) in women with cervical cerclage. Am J Perinatol. May. 2008;25(5:):271-5. [pmid: 18401840].
45 Mason MV, House KM, Linehan J, et al. Optimizing the use of 17P in pregnant managed Medicaid members. Manag Care. Jan. 2008;17(1:):47-52. [pmid: 18274315].
46 Facchinetti F, Dante G, Venturini P, et al. 17alpha-hydroxy-progesterone effects on cervical proinflammatory agents in women at risk for preterm delivery. Am J Perinatol. Sep. 2008;25(8):503-6. [pmid: 18756431].
47 Borna S, Sahabi N. Progesterone for maintenance tocolytic therapy after threatened preterm labour: a randomised controlled trial. Aust N Z J Obstet Gynaecol. Feb. 2008;48(1:):58-63. [pmid: 18275573].
48 Rouse DJ, Caritis SN, Peaceman AM, et al. A trial of 17 alpha-hydroxyprogesterone caproate to prevent prematurity in twins. N Engl J Med. Aug. 2. 2007;357(5:):454-61. [pmid: 17671253].
49 Rittenberg C, Sullivan S, Istwan N, et al. Clinical characteristics of women prescribed 17 alpha-hydroxyprogesterone caproate in the community setting. Am J Obstet Gynecol. Sep. 2007;197(3):262 e1-4. [pmid: 17826412].
50 Rebarber A, Istwan NB, Russo-Stieglitz K, et al. Increased incidence of gestational diabetes in women receiving prophylactic 17alpha-hydroxyprogesterone caproate for prevention of recurrent preterm delivery. Diabetes Care. Sep. 2007;30(9:):2277-80. [pmid: 17563346].
51 Rebarber A, Ferrara LA, Hanley ML, et al. Increased recurrence of preterm delivery with early cessation of 17-alpha-hydroxyprogesterone caproate. Am J Obstet Gynecol. Mar. 2007;196(3):224 e1-4. [pmid: 17346529].
52 O'Brien JM, Adair CD, Lewis DF, et al. Progesterone vaginal gel for the reduction of recurrent preterm birth: primary results from a randomized, double-blind, placebo-controlled trial. Ultrasound Obstet Gynecol. Oct. 2007;30(5:):687-96. [pmid: 17899572].
53 How HY, Barton JR, Istwan NB, et al. Prophylaxis with 17 alpha-hydroxyprogesterone caproate for prevention of recurrent preterm delivery: does gestational age at initiation of treatment matter?. Am J Obstet Gynecol. Sep. 2007;197(3):260 e1-4. [pmid: 17826411].
54 Gonzalez-Quintero VH, Istwan NB, Rhea DJ, et al. Gestational age at initiation of 17-hydroxyprogesterone caproate (17P) and recurrent preterm delivery. J Matern Fetal Neonatal Med. Mar. 2007;20(3:):249-52. [pmid: 17437227].
55 Fonseca EB, Celik E, Parra M, et al. Progesterone and the risk of preterm birth among women with a short cervix. N Engl J Med. Aug. 2. 2007;357(5:):462-9. [pmid: 17671254].
56 Facchinetti F, Paganelli S, Comitini G, et al. Cervical length changes during preterm cervical ripening: effects of 17-alpha-hydroxyprogesterone caproate. Am J Obstet Gynecol. May. 2007;196(5):453 e1-4. discussion 21. [pmid: 17466698].
57 Bailit JL, Berkowitz R, Thorp JM, et al. Use of progesterone to prevent preterm birth at a tertiary care center. J Reprod Med. Apr. 2007;52(4:):280-4. [pmid: 17506366].
58 Dudas I, Gidai J, Czeizel AE. Population-based case-control teratogenic study of hydroxyprogesterone treatment during pregnancy. Congenit Anom (Kyoto). Dec. 2006;46(4):194-8. [pmid: 17096820].
59 Mason MV, House KM, Fuest CM, et al. 17 alpha-hydroxyprogesterone caproate (17P) usage in a Medicaid managed care plan and reduction in neonatal intensive care unit days. Manag Care. Oct. 2005;14(10):58-63. [pmid: 16277194].
60 Meis PJ, Klebanoff M, Thom E, et al. Prevention of recurrent preterm delivery by 17 alpha-hydroxyprogesterone caproate. N Engl J Med. Jun. 12. 2003;348(24:):2379-85. [pmid: 12802023].
61 da Fonseca EB, Bittar RE, Carvalho MH, et al. Prophylactic administration of progesterone by vaginal suppository to reduce the incidence of spontaneous preterm birth in women at increased risk: a randomized placebo-controlled double-blind study. Am J Obstet Gynecol. Feb. 2003;188(2:):419-24. [pmid: 12592250].
62 Corrado F, Dugo C, Cannata ML, et al. A randomised trial of progesterone prophylaxis after midtrimester amniocentesis. Eur J Obstet Gynecol Reprod Biol. Jan. 10. 2002;100(2:):196-8. [pmid: 11750964].
63 Bacq Y, Sapey T, Brechot MC, et al. Intrahepatic cholestasis of pregnancy: a French prospective study. Hepatology. Aug. 1997;26(2:):358-64. [pmid: 9252146].
64 Hobel CJ, Ross MG, Bemis RL, et al. The West Los Angeles Preterm Birth Prevention Project. I. Program impact on high-risk women. Am J Obstet Gynecol. Jan. 1994;170(1 Pt 1):54-62. [pmid: 8296845].
65 Noblot G, Audra P, Dargent D, et al. The use of micronized progesterone in the treatment of menace of preterm delivery. Eur J Obstet Gynecol Reprod Biol. Jul. 25. 1991;40(3:):203-9. [pmid: 1879595].
66 Suvonnakote T. Prevention of pre-term labour with progesterone. J Med Assoc Thai. Oct. 1986;69(10:):538-42. [pmid: 3819611].
67 Erny R, Pigne A, Prouvost C, et al. The effects of oral administration of progesterone for premature labor. Am J Obstet Gynecol. Mar. 1986;154(3:):525-9. [pmid: 3513581].
68 Yemini M, Borenstein R, Dreazen E, et al. Prevention of premature labor by 17 alpha-hydroxyprogesterone caproate. Am J Obstet Gynecol. Mar. 1. 1985;151(5:):574-7. [pmid: 3976757].
69 Resseguie LJ, Hick JF, Bruen JA, et al. Congenital malformations among offspring exposed in utero to progestins, Olmsted County, Minnesota, 1936–1974. Fertil Steril. Apr. 1985;43(4):514-9. [pmid: 3987922].
70 Kester PA. Effects of prenatally administered 17 alpha-hydroxyprogesterone caproate on adolescent males. Arch Sex Behav. Oct. 1984;13(5:):441-55. [pmid: 6517685].
71 Szekeres-Bartho J, Csernus V, Hadnagy J, et al. Influence of treatment with prostaglandin synthesis inhibitor or progesterone on cytotoxic activity and progesterone binding capacity of lymphocytes during pregnancy. Prostaglandins. Aug. 1983;26(2:):187-95. [pmid: 6647870].
72 Hauth JC, Gilstrap LC 3rd, Brekken AL, et al. The effect of 17 alpha-hydroxyprogesterone caproate on pregnancy outcome in an active-duty military population. Am J Obstet Gynecol. May. 15. 1983;146(2:):187-90. [pmid: 6682631].
73 Kauppila A, Hartikainen-Sorri AL, Janne O, et al. Suppression of threatened premature labor by administration of cortisol and 17 alpha-hydroxyprogesterone caproate: a comparison with ritodrine. Am J Obstet Gynecol. Oct. 15. 1980;138(4:):404-8. [pmid: 7424996].
74 Hartikainen-Sorri AL, Kauppila A, Tuimala R. Inefficacy of 17 alpha-hydroxyprogesterone caproate in the prevention of prematurity in twin pregnancy. Obstet Gynecol. Dec. 1980;56(6:):692-5. [pmid: 7443111].
75 Cortes-Prieto J, Bosch AO, Rocha JA. Allylestrenol: three years of experience with Gestanon in threatened abortion and premature labor. Clin Ther. 1980;3(3):200-8. [pmid: 7459930].
76 Johnson JW, Lee PA, Zachary AS, et al. High-risk prematurity--progestin treatment and steroid studies. Obstet Gynecol. Oct. 1979;54(4:):412-8. [pmid: 492618].
77 Breart G, Lanfranchi M, Chavigny C, et al. A comparative study of the efficiency of hydroxyprogesterone caproate and of chlormadinone acetate in the prevention of premature labor. Int J Gynaecol Obstet. Mar–Apr. 1979;16(5):381-4. [pmid: 86468].
78 Reinisch JM, Karow WG. Prenatal exposure to synthetic progestins and estrogens: effects on human development. Arch Sex Behav. Jul. 1977;6(4:):257-88. [pmid: 889431].
79 Johnson JW, Austin KL, Jones GS, et al. Efficacy of 17alpha-hydroxyprogesterone caproate in the prevention of premature labor. N Engl J Med. Oct. 2. 1975;293(14:):675-80. [pmid: 1099445].
80 Hill LM, Johnson CE, Lee RA. Prophylactic use of hydroxyprogesterone caproate in abdominal surgery during pregnancy. A retrospective evaluation. Obstet Gynecol. Sep. 1975;46(3):287-90. [pmid: 1161231].
81 Combs CA, Garite T, Maurel K, et al. 17-hydroxyprogesterone caproate for twin pregnancy: a double-blind, randomized clinical trial. Am J Obstet Gynecol. Mar. 2011;204(3):221 e1-8. [pmid: 21376161].
82 DeFranco EA, O'Brien JM, Adair CD, et al. Vaginal progesterone is associated with a decrease in risk for early preterm birth and improved neonatal outcome in women with a short cervix: a secondary analysis from a randomized, double-blind, placebo-controlled trial. Ultrasound Obstet Gynecol. Oct. 2007;30(5:):697-705. [pmid: 17899571].
83 Northen AT, Norman GS, Anderson K, et al. Follow-up of children exposed in utero to 17 alpha-hydroxyprogesterone caproate compared with placebo. Obstet Gynecol. Oct. 2007;110(4:):865-72. [pmid: 17906021].
84 O'Brien JM, Defranco EA, Adair CD, et al. Effect of progesterone on cervical shortening in women at risk for preterm birth: secondary analysis from a multinational, randomized, double-blind, placebo-controlled trial. Ultrasound Obstet Gynecol. Dec. 2009;34(6:):653-9. [pmid: 19918965].
85 Czeizel A, Huiskes N. A case-control study to evaluate the risk of congenital anomalies as a result of allylestrenol therapy during pregnancy. Clin Ther. 1988;10(6):725-39. [pmid: 3219686].
86 Spong CY, Meis PJ, Thom EA, et al. Progesterone for prevention of recurrent preterm birth: impact of gestational age at previous delivery. Am J Obstet Gynecol. Sep. 2005;193(3 Pt 2):1127-31. [pmid: 16157124].
87 Meis PJ, Klebanoff M, Dombrowski MP, et al. Does progesterone treatment influence risk factors for recurrent preterm delivery?. Obstet Gynecol. Sep. 2005;106(3:):557-61. [pmid: 16135587].
88 Torloni MR, Betran AP, Daher S, et al. Maternal BMI and preterm birth: a systematic review of the literature with meta-analysis. J Matern Fetal Neonatal Med. Nov. 2009;22(11:):957-70. [pmid: 19900068].
89 Klebanoff MA, Meis PJ, Dombrowski MP, et al. Salivary progesterone and estriol among pregnant women treated with 17-alpha-hydroxyprogesterone caproate or placebo. Am J Obstet Gynecol. Nov. 2008;199(5):506 e1-7. [pmid: 18456237].
90 Dodd JM, Ashwood P, Flenady V, et al. A survey of clinician and patient attitudes towards the use of progesterone for women at risk of preterm birth. Aust N Z J Obstet Gynaecol. Apr. 2007;47(2:):106-9. [pmid: 17355298].
91 Henderson ZT, Power ML, Berghella V, et al. Attitudes and practices regarding use of progesterone to prevent preterm births. Am J Perinatol. Aug. 2009;26(7:):529-36. [pmid: 19301227].
92 Hui D, Liu G, Kavuma E, et al. Preterm labour and birth: a survey of clinical practice regarding use of tocolytics, antenatal corticosteroids, and progesterone. J Obstet Gynaecol Can. Feb. 2007;29(2:):117-30. [pmid: 17346482].
93 Ness A, Baxter J, Hyslop T, et al. Progesterone for preventing premature birth: practice patterns of board-certified maternal-fetal medicine specialists in the United States. J Reprod Med. May. 2006;51(5:):411-5. [pmid: 16779989].
94 Hassan SS, Romero R, Vidyadhari D, et al. Vaginal progesterone reduces the rate of preterm birth in women with a sonographic short cervix: a multicenter, randomized, double-blind, placebo-controlled trial. Ultrasound Obstet Gynecol. Jul. 2011;38(1:):18-31. [pmid: 21472815].
95 Glover MM, McKenna DS, Downing CM, et al. A randomized trial of micronized progesterone for the prevention of recurrent preterm birth. Am J Perinatol. May. 2011;28(5:):377-81. [pmid: 21380990].
96 Ibrahim M, Mohamed Ramy AR, Younis MAF. Progesterone supplementation for prevention of preterm labor: A randomized controlled trial. Middle East Fertility Society Journal. January. 2010;15(1:):39-41.
97 Sharami SH, Zahiri Z, Shakiba M, et al. Maintenance therapy by vaginal progesterone after threatened idiopathic preterm labor: A randomized placebo-controlled double-blind trial. International Journal of Fertility and Sterility. July–September. 2010;4(2):45-50.
98 Chawanpaiboon S, Pimol K, Sirisomboon R. Comparison of success rate of nifedipine, progesterone, and bed rest for inhibiting uterine contraction in threatened preterm labor. J Obstet Gynaecol Res. 2011;37(7):787-91. [pmid: 21395905].
99 Lim AC, Schuit E, Bloemenkamp K, et al. 17alpha-hydroxyprogesterone caproate for the prevention of adverse neonatal outcome in multiple pregnancies: A randomized controlled trial. Obstetrics and Gynecology. 2011;118(3):513-20. [pmid: 21860279].
100 Briery CM, Veillon EW, Klauser CK, et al. Women with preterm premature rupture of the membranes do not benefit from weekly progesterone. Am J Obstet Gynecol. Jan. 2011;204(1):54 e1-5. [pmid: 20869038].
101 Brancazio LR, Murtha AP, Heine RP. Prevention of recurrent preterm delivery by 17 alpha-hydroxyprogesterone caproate. N Engl J Med. Sep. 11. 2003;349(11):1087-8. author reply -8. [pmid: 12968095].
102 Iams JD. Was the preterm birth rate in the placebo group too high in the Meis MFMU Network trial of 17-OHPC?. Am J Obstet Gynecol. May. 2010;202(5:):409-10. [pmid: 20452480].
103 Saade G, Spong C. Surgeon General's Conference on the Prevention of Preterm Birth. Biomedical Research Workgroup--Purpse and Goals. 2008. www.nichd.nih.gov/about/meetings/2008/SG_pretermbirth/agenda/upload/WG1-Biomedical-Presentation-2.pdf. Accessed on April 5 2010.
104 GovTrack.us. Prematurity Research Expansion and Education for Mothers who deliver Infants Early Act of 2006. 2007. www.govtrack.us/congress/bill.xpd?bill=s109-707.