# Methods

In this section we document the procedures that the Vanderbilt Evidence-based Practice Center used to produce a complete evidence report on the use of progestogens to prevent preterm birth. We first describe the assistance provided by the technical expert panel throughout the topic refinement and review process. We then present the Key Questions (KQs) and analytic framework. We also discuss our strategy for identifying articles relevant to our six KQs, our inclusion and exclusion criteria, and the process we used to abstract pertinent information from the eligible articles and generate our evidence tables. In addition, we discuss our method for grading the quality of individual articles and for rating the strength of the evidence. Finally, we describe the peer review process.

## Technical Expert Panel (TEP)

We identified technical experts on the topic of the use of progestogens to prevent preterm birth in the fields of obstetrics and gynecology, midwifery, nursing, epidemiology, pharmacology, primary care, and patient advocacy to provide assistance during the project. The TEP was expected to contribute to AHRQ’s broader goals of (1) creating and maintaining science partnerships as well as public-private partnerships and (2) meeting the needs of an array of potential customers and users of its products. Thus, the TEP was both an additional resource and a sounding board during the project. The TEP included eight members serving as technical or clinical experts. To ensure robust scientifically relevant work, we called on the TEP to provide reactions to work in progress and advice on substantive issues or possibly overlooked areas of research. TEP members participated in conference calls and discussion through email to:

- Refine the analytic framework and KQs during topic refinement;
- Discuss the preliminary assessment of the literature, including inclusion/exclusion criteria;
- Provide input on the information and domains included in evidence tables;
- Develop a hierarchy of participant characteristics and outcomes to systematically assess;
- Advise about the clinical availability, use, and doses of progestational agents.

Because of their extensive knowledge of the literature, including numerous articles authored by TEP members themselves, and their active involvement in professional societies and trial networks, and as practitioners in the field, we also asked TEP members to participate in the external peer review of the draft report.

## Analytic Framework for Progestogens for the Prevention of Preterm Birth

The analytic framework in Figure 1 summarizes the conceptual model used to guide this systematic review by focusing the KQs on the critical health care-related pathways and decision points. Our analytic framework emphasizes that care takes place at the interface of the health care system and the individual. The pathway through care is indicated in the boxes along the center line where the person and care meet. Each KQ is indicated within the framework at the relevant point of influence in care. Each of the domains listed among individual and system factors, such as patient factors, use of cointerventions, provider factors, and health system factors, has been shown to influence care trajectories and outcomes. Making these domains explicit as they influence the care pathway provides the framework in which the review team and technical expert panel conducted this review. To the degree that individuals or care settings vary in context-specific points of influence, this framework may or may not be applicable.

Figure 1 Analytic framework for progestogens for the prevention of preterm birth

The analytic framework in Figure 1 summarizes the conceptual model used to guide this systematic review by focusing the key questions on the critical healthcare related pathways and decision points. Our analytic framework emphasizes that care takes place at the interface of the healthcare system and the individual. The pathway through care is indicated in the boxes along the center line where the person and care meet. Each key question is indicated within the framework at the relevant point of influence in care. Each of the domains listed among individual and system factors, such as patient factors, use of cointerventions, provider factors and health system factors, has been shown to influence care trajectories and outcomes. Making these domains explicit as they surround and influence the care pathway provides the framework in which the review team and technical expert panel conducted this review. To the degree that individuals or care settings vary in context-specific points of influence, this framework may or may not be applicable. Overall, the figure represents the population of interest, women at risk for preterm birth, and how the intervention of progestogens, at various timings, doses, routes, and intervals, (KQ 1–3) affects adherence, as well as intermediate and health outcomes (KQ 2–4). Adverse effects of treatment are examined in Key Question 6. Finally, we sought to examine factors within the central care pathway as well as selected contextual domains like health system factors (KQ 5–6), and influence of individual characteristic on outcomes as a step towards enhancing applicability of the results (KQ3). Portions of the framework that are unexplored in the scientific literature are highlighted in the considerations of future research needs.

Overall, the figure represents the population of interest, women at risk for preterm birth, and how the intervention of progestogens, at various timings, doses, routes, and intervals, (KQs 1–3) affects adherence, as well as intermediate and health outcomes (KQs 2–4). Adverse effects of treatment are examined in KQ 6. Finally, we sought to examine factors within the central care pathway as well as selected contextual domains like health system factors (KQs 5 and 6), and influence of individual characteristic on outcomes as a step towards enhancing applicability of the results (KQ 3). Portions of the framework that are unexplored in the scientific literature are highlighted in the discussion of future research needs.

## Literature Review Methods

### Literature Search and Retrieval Process

Databases. Our search included examination of results in MEDLINE^®^ and Embase. We also hand-searched the reference lists of included articles to identify additional studies for review.

Search terms. Controlled vocabulary terms served as the foundation of our search in each database, complemented by additional keyword phrases to represent the myriad ways in which progestogens and preterm labor are referred to in the clinical literature. We also employed indexing terms within each of the databases to exclude undesired publication types (e.g., reviews, case reports, Continuing Medical Education handouts) and items published in languages other than English.

Appendix A outlines our search terms and results. Our searches were executed between August 2009 and October 2010, prior to FDA approval of a dedicated progestogen product for preterm birth prevention among women with prior preterm birth,5 and were not limited by date.

### Inclusion and Exclusion Criteria

Our inclusion and exclusion criteria were developed in consultation with the TEP to capture the literature most tightly related to the KQs. Criteria are summarized in Table 1.

Table 1 Criteria for inclusion and exclusion of studies in the review

Category | Criteria
Study population | Adult females
Publication languages | English only
Admissible evidence | [underlined: Study design]; - Controlled trials; - Prospective trials with historical controls; - Prospective or retrospective cohort studies; - Case control studies; - Case series with n ≥ 20; [underlined: Other criteria]; - Original research studies that provide sufficient detail regarding methods and results to enable use and adjustment of data and results; - Abstraction of relevant outcomes from data presented in papers must be possible; - Sample sizes must be appropriate for study aims; single case reports or small case series (< 20 participants) are excluded

The study population is adult females. We did not have translation services available to us to review non-English papers, and our TEP agreed that the vast majority if not all of the relevant literature would be published in English. Furthermore, this review is intended to inform United States health care and most research in this population is published in English language journals. Empirical evidence on the potential for bias created by excluding non-English studies also suggests little effect.17 Appendix B contains the list of excluded articles along with the reason for exclusion.

Article selection process. Once we identified articles through the electronic database searches, review articles, and bibliographies, we examined abstracts of articles to determine whether studies met our criteria. Two reviewers separately evaluated the abstracts for inclusion or exclusion, using an Abstract Review Form (Appendix C). If one reviewer concluded that the article could be eligible for the review based on the abstract, we retained it. The group included two physicians (KH, JA), a certified nurse-midwife and nurse practitioner (FL), two health services researchers (AW, JM) and two library scientists (RJ, TS).

## Literature Synthesis

### Development of Evidence Tables and Data Abstraction Process

The staff members and clinical experts who conducted this review jointly developed the evidence tables. We designed the tables to provide sufficient information to enable readers to understand the studies and to determine their quality; we gave particular emphasis to essential information related to our KQs. We based the format of our evidence tables on successful designs used for prior systematic reviews.

The team was trained to abstract by abstracting several articles into evidence tables and then reconvening as a group to discuss the utility of the table design. We repeated this process through several iterations until we decided that the tables included the appropriate categories for gathering the information contained in the articles. All team members shared the task of initially entering information into the evidence tables. Another member of the team also reviewed the articles and edited all initial table entries for accuracy, completeness, and consistency. The two abstractors reconciled disagreements concerning the information reported in the evidence tables. The full research team met regularly during the article abstraction period and discussed global issues related to the data abstraction process. In addition to outcomes related to treatment effectiveness, we abstracted all data available on adverse effects (harms). Harms encompass the full range of specific negative effects, including the narrower definition of adverse events.

The final evidence tables are presented in their entirety in Appendix D. Studies are presented in the evidence tables alphabetically by the last name of the first author. When possible, studies resulting from the same study population were grouped into a single evidence table.

### Synthesis of the Evidence

Conduct of meta-analysis. We conducted a Bayesian meta-analysis18–19 in order to provide aggregate estimates of the effectiveness of progestogen treatment for preventing preterm birth and reducing neonatal mortality. We constructed models to address two aspects of clinical utility: (1) grouping RCTs by the indications for which the progestogens were administered in the study (prior preterm birth, multiple gestations, current preterm labor, and study populations with various risk factors) and by (2) the progestogen formulation used in the trial (intramuscular, oral, or vaginal). Data were too sparse to create models addressing the interaction of indications and formulation for the two primary outcomes.

A total of 16 studies were included in the meta-analyses: seven related to effectiveness for preventing preterm birth before 37 weeks and four for reducing mortality in singletons; four for preventing preterm birth before 35 weeks and five for reducing mortality in multiple gestations; and 15 for estimation of effectiveness by formulation.

In order for inferences from meta-analyses to be valid, it must be reasonable to assume the studies are in some way comparable. In the context of Bayesian analysis, we assume an exchangeable model, whereby the units of analysis (here, individual studies), are neither considered to be identical replicates nor entirely unrelated to one another.20 The meta-analysis attempts to parametrically estimate both the aspects of the studies that are similar and those which cause them to differ. For understanding the influence of formulation, we estimated an overall effect of varying the formulation of progestogen in relation to both outcomes.

The sampling model for the data expressed both the number of preterm births (y_i_^(p)^) and the number of neonatal mortalities (y_i_^(m)^) for each of p^(preterm)^=30 and m^(mortality)^=22 groups (either treatment or control) by study combinations as binomial random variables, where the θ values represent the group- and study-specific probabilities of each event. In this model, we posit that the specific values of these parameters vary according to (1) random (unmeasured) processes causing heterogeneity among studies, (2) a treatment effect of administering progestogen during pregnancy, and (3) the specific formulation of the progestogen treatment.

y_i_^( p )^ ~ Bin ( n_i_^( p )^ , θ_i_^( p )^ ) y_i_^( m )^ ~ Bin ( n_i_^( m )^ , θ_i_^( m )^ )

To implement this structure, we used a logit-linear mixed model to describe the variation in θ among the studies. The first component of this model, irrespective of whether formulation or indications was used as covariates, is a study-specific random effect β_0,s[i]_, where s[i] denotes the study corresponding to observation i. This allows the model intercept for each study to be drawn from a “population” of studies, the distribution of which describes the variability due to any number of factors that are not measured or otherwise cannot be modeled. We chose a normal distribution as the sampling distribution for these parameters.

β_0 , s [ i ]_^( p )^ ~ N ( μ^( p )^ , τ^( p )^ ) β_0 , s [ i ]_^( m )^ ~ N ( μ^( m )^ , τ^( m )^ )

To account for potential covariance between the probabilities of preterm birth and neonatal death, these were initially modeled as bivariate normal random variates, with non-zero covariance. However, results from this model gave no indication of substantial covariance, and hence the model was simplified to assume independence. Note that τ_p_ and τ_m_, inverse-variance parameters for the study random effects, are a measure of the heterogeneity among studies for each metric. Hence, large values of τ_p_ suggest relative homogeneity, while values close to zero indicate a high level of heterogeneity. For ease of interpretation, these were converted to standard deviations, via an inverse square-root transformation.

For estimating the study-specific means of preterm birth probability, we accounted for varying threshold values for determining incidences of preterm birth, which ranged from less than 34 weeks to less than 37 weeks across studies. The mean of the random effect was estimated as a linear function of the threshold value for each study.

The threshold values w_s[í]_ were expressed as additional weeks relative to the lowest threshold value, making the lowest value a baseline, simply equal to γ_0_.

μ_s [ i ]_^( p )^ = γ_0_ + γ_1_ w_s [ i ]_

The second component of the logit-linear model for formulation effects is an array of fixed

logit ( θ_i_^( p )^ ) = β_0 , s [ i ]_^( p )^ + β_1 , j [ i ]_^( p )^ I ( x_i_ = j ) logit ( θ_i_^( m )^ ) = β_0 , s [ i ]_^( m )^ + β_1 , j [ i ]_^( m )^ I ( x_i_ = j )

effects {β_1, im_, β_1,oral_, β_1, vaginal_} that account for the effect of progestogen treatment by formulation. Here, I is the indicator function, which indexes the appropriate formulation effect parameter for each study. The sum of these components are logit-transformed, to ensure they fall in the [0, 1] interval. Clearly, the β_1;j[i]_ are the parameters of interest, and since they are parameters in a logistic regression model they can be interpreted as the log-odds ratio for the effect of treatment via formulation j.

δ_j_^( p )^ = exp [ β_i , j [ i ]_^( p )^ ] δ_j_^( m )^ = exp [ β_i , j [ i ]_^( m )^ ]

Similarly, the second component of the logit-linear model for maternal factors consists of a fixed effect for the progestogens treatment for each of three indications.

The models for the indication of multiple gestation included an additional level of hierarchical structure, which accounted for whether the multiple gestation comprised twins or triplets. Specifically, the β_2_ parameters were modeled as:

β_1_^( p )^ = α_0_^( p )^ I ( m g e s t_i_ ) + α_1_^( p )^ I ( t r i p l e t s_i_ ) β_1_^( m )^ = α_0_^( m )^ I ( m g e s t_i_ ) + α_1_^( m )^ I ( t r i p l e t s_i_ )

where I is the indicator function. In other words, the effect of twins would be α_0_ and the effect of triplets α_0_ + α_1_. Thus, the parameter α_1_ can be interpreted as the marginal increase in effect of triplets on either response variable relative to twins.

Prior distributions. In each model, we sought to minimize the influence of prior information by specifying vague prior distributions for all unknown parameters. For logit-linear model coefficients, this was implemented via normal priors with mean zero and variance 100 (precision 0.01); on the probability scale, this resulted in suitably diffuse priors. To model heterogeneity, the standard deviation (sigma) parameters were given uniform priors over the interval [0, 100], implying equal prior probability for all values in this interval, which exceeds the expected range of variation for the random effects. To examine sensitivity to prior specification for the logit-linear model covariates, models were also run with Cauchy prior distributions with scale parameters set to 2.5. This distribution, with broader tails, is more robust to extreme values. The parameter estimates did not change as a result of using this alternative prior specification.

Estimation. Each model was implemented in PyMC version 2.1,^21^ which fits Bayesian hierarchical models using Markov chain Monte Carlo (MCMC) algorithms. One million samples were generated for each model, with the first 900,000 iterations conservatively discarded as burn-in. The remaining samples were thinned by a factor of 10, leaving 10,000 samples for posterior inference. Model outputs showed no evidence of lack of convergence, based on inspection of the posterior samples and on R-hat values (Gelman-Rubin statistics). To check the fit of the model, we conducted posterior predictive checks, which generate simulated datasets based on the fitted model. The distribution of simulated datasets was then compared to the observed data from the studies in the meta-analysis. The observed data fell within the 95 percent intervals of the simulated datasets for each study, suggesting an acceptable fit of the model to the data.

### Rating Quality of Individual Studies

#### Internal Validity

Randomized allocation to treatment. This assessment combines randomization and method of randomization into a single criterion with a three-point scale.

Rationale: By randomly assigning groups to the intervention of interest, other factors that may confound the results are equally distributed between groups (assuming a large enough sample size). This equal distribution minimizes the chances of over-or under-estimation of treatment effect based on unequal distribution of confounding factors.

If randomized, we also evaluated the study for randomization methods, using the rationale described in Matchar and colleagues, 2001.^22^

Rationale: “Pseudo-randomization” methods may be susceptible to bias, as demonstrated by evidence of unequal distribution of participant characteristics23 and larger effect sizes compared to studies using more rigorous methods.24 In addition, methods of allocation concealment are also important in preventing bias (e.g., use of prepared sealed envelopes).

We combined these elements into a single operational definition, as described below:

Operational definition: Criterion met if randomization methods were not susceptible to bias, such as computer-generated numbers in sealed sequentially numbered envelopes (+). Criterion not met by studies that either used methods more prone to bias, such as alternate medical record numbers, or did not describe randomization methods or methods of allocation concealment (−). Criterion not applicable if treatment was not randomly allocated (NA).

Masking. Rationale: Masking, also known as blinding, refers to the concealment of treatment allocation from the care provider, the assessor, and the patient. In certain trials, particularly surgical trials, masking the patient or the surgeon from the treatment allocation can be challenging or impossible. Similarly, masking the assessor assigned to record immediate post-procedural outcomes such as wound healing can also be difficult. Nevertheless, when possible, masking prevents expectations from influencing findings.

Operational definition: Criterion was met if assessors and participants were masked to treatment or group (+). Criterion was not met if either care provider, assessor, or patient were not masked (−). Criterion not applicable if treatment was not randomly allocated.

Adequate description of participants and control selection criteria. Rationale: Patient characteristics that might affect outcomes (such as history of prior preterm birth, gestational age at initiation of treatment, multiple gestation) are likely to differ between two interventions. If these differences are not characterized, then erroneous conclusions may be drawn.

Operational definition: Criterion met if inclusion and exclusion criteria for participation in the study were well described.

We expected that the study population should be adequately described to make clear the potential for confounding in the analysis. We expected the study authors to adequately describe the study population such that it could theoretically be reproducible by another investigator. We expected comparable methods to be used to identify and screen participants across exposure or treatment groups. In addition, where applicable, we expected the study authors to provide a participant flow diagram; reporting numbers of participants randomly assigned, number of those who received the intended treatment, completed the study protocol, and were included in the analysis of the primary outcome.

Description of loss to followup. Rationale: Failing to account for participants lost to followup may lead to erroneous conclusions, especially if the loss to followup is related to either the underlying disease or the intervention (e.g., participants seeking care elsewhere because of continuing symptoms or unacceptable side effects of treatment).

Operational definition: Criterion met for adequate followup (+) if (a) loss to followup was explicitly reported and (b) no more than 20 percent of any study arm was lost to followup. Those studies with less than 10 percent lost to followup were given an extra (+). Studies with greater than 20 percent loss to followup were considered inadequate for this measure (−).

Description of dropout rates. Rationale: Dropout rates may reflect differences in clinically important variables, such as side effects or treatment response. Failure to account for dropouts may result in erroneous conclusions similar to those seen with failure to account for loss to followup.

Operational definition: Criterion met if (a) participants dropping out of the study prior to completion were reported and (b) no more than 10 percent in any study arm left the study for reasons related to the study intervention or withdrawal of consent. Those studies with less than 5 percent in any study arm who left the study for reasons related to the study intervention or withdrawal of consent were given an extra (+).

Power calculation provided. Rationale: Many studies, especially case series, lack sufficient power to detect clinically important differences in outcomes or patient characteristics.

Operational Definition: Criterion met if a power calculation (pre or post) was provided.

Recognition and description of statistical issues. Rationale: Use of inappropriate tests may lead to misleading conclusions. For example, variables such as birth weight are often not normally distributed; use of means instead of medians when data may be affected by outlying observations can be misleading.

Operational definition: Criterion met if (a) appropriate statistical tests were used (e.g., nonparametric methods for variables with nonnormal distributions, or survival analysis techniques to account for loss to followup and dropouts) and (b) potential study limitations regarding design and analysis were discussed. Criterion not met if (a) inappropriate statistical tests were used or (b) study limitations were not discussed. An intention-to-treat (ITT) analysis was required of clinical trials.

#### External Validity

Baseline characteristics. We created a composite score for adequacy of the description of baseline characteristics. At minimum, we expected prior preterm birth and multiple gestation information to be presented. If either of these were omitted, criteria were not met. In order to receive a (+) study authors had to provided information on prior preterm birth and multiple gestation as well as at least three of the following: gestational age at initiation, race/ethnicity, body mass index (BMI), parity, smoking status, and outcome of the immediately preceding pregnancy.

Prior Preterm Birth. Rationale: Prior preterm birth is the strongest known predictor of a preterm birth and differences in prevalence in treatment groups would be likely confounders of observed relationships.

Operational definition: Criterion met if summary statistics of a history of preterm birth were given by comparison group or if study inclusion and exclusion criteria state that participants were included or excluded due to a history of preterm birth. Criterion not met if summary statistics were not provided.

Multiple gestation. Rationale: Similarly to prior preterm birth, multiple gestation is a strong risk factor for prior preterm birth and could confound an observed relationship between the treatment and the outcome. Therefore it is important that the distribution of this covariate be equivalent in the treatment groups.

Operational definition: Criterion met if summary statistics or inclusion and exclusion criteria related to multiple gestations were presented by group.

Adequate description of the intervention provided to participants. Rationale: The ability to replicate study results is dependent on adequate description of methods. Additionally, readers should be aware of aspects of clinical care that might influence outcomes.

Operational definition: Criterion met if (a) a detailed description of the therapy (dose, dosing schedule, protocols for behavioral interventions, and route of administration for medications and/or techniques for invasive therapies) was provided; (b) a reference to another publication describing the procedure was provided; or (c) statistical adjustment was made for likely sources of variation in clinical care (e.g., site where care was given, type of specialist providing care, individual provider, dose and timing).

Criterion not met if (a), (b), or (c) was not provided.

Adequate description of the outcomes. Rationale: Studies should designate a “called shot” or intended a priori primary outcome, and should provide group level data on that outcome at a minimum. Therefore, those that purport to attempt to change rates of preterm birth and birthweight should provide data by group on gestational age and birthweight.

Adequate length of followup for infant. Rationale: In an effort to capture longer term maternal and neonatal outcomes, we required that studies include followup information for the infant. In order to get a (+), studies needed to include outcome measures up to and including discharge from the hospital. Studies that included outcomes after hospitalization received (++). In addition, studies that only included measures up to the birth of the infant received (−).

Adequate description of methods used for outcome measurement. Rationale: Comparison between studies requires common methods of measurement, which in turn requires adequate description of the methods used to assess comparability.

Operational definition: Criterion met if (a) methods used to measure outcomes were adequately described or referenced, (b) definitions were given (e.g., definition of criteria for gestational age dating), or (c) outcomes were unambiguous (e.g., birth weight). Criterion not met if (a), (b), or (c) was not present.

Adequate description of reliability of outcome measurement. Rationale: Measurements of outcomes are only useful if changes in the outcome being measured are reflected in changes in the measurement (validity) and if these changes are reasonably consistent between the same observer measuring at different times or between different observers (reliability). For example, changes in a scale to assess menstrual blood flow should correlate with some other physiological measure of menstrual blood loss, and this correlation should be consistent when different women apply the same scale.

Operational definition: Criterion met if (a) a description of the methods used to assess validity and reliability of at least one outcome measure was provided, (b) a reference to another article documenting validity and reliability was provided, or (c) only unambiguous outcomes were included as primary outcomes. Criterion not met if none (a), (b), or (c) was not present.

#### Composite Quality Scores

A composite quality score of good, fair, or poor was calculated for both internal and external validity. The internal validity score was based on ten measures (see list above). In order to receive a rating of good, studies could not have any negative (−) scores. Studies were considered fair if they received three or fewer negative scores, or had intermediate levels of loss-to-followup or drop out. Studies were rated poor quality if they (1) had the highest level of loss-to-followup or dropout, (2) received four or more negative scores, or (3) had both three negative scores and intermediate loss-to-followup. The external validity score was based on eight measures, including the composite score for baseline scores (see list above). In order to receive a rating of good, studies could not have any negative (−) scores. The designation of fair quality was given to those studies that received one to three negative (−) scores. Poor quality scores were given to studies with four or more negative (−) scores.

Scores for internal and external validity were combined in order to determine overall quality. Studies with both good internal and external validity were characterized as good. Studies with any combination of good and fair, good and poor, or fair and fair for each measure were considered fair quality overall. Studies receiving any combination of poor and fair or those receiving poor for both internal and external validity were considered poor quality. The scoring algorithm for rating the quality of individual studies is included in Table 2. Quality scores for individual studies are presented in Appendix E.

Table 2 Scoring algorithm for quality rating

Definition and Scoring Algorithm | Rating
Score Algorithm for Internal Validity Quality Rating
• No negative scores, lowest loss-to-followup score, and lowest dropout rate | Good internal validity
• One to three negative scores or intermediate loss-to-followup score or dropout rate | Fair internal validity
• High loss-to-followup score or high dropout rate OR | Poor internal validity
• Four negative scores OR
• Three negative scores and intermediate loss-to-followup score
Score Algorithm for External Validity Quality Rating
• No negative scores | Good external validity
• One to three negative scores | Fair external validity
• Four or more negative scores | Poor external validity
Score Algorithm for Overall Quality Rating
• Good internal validity and good external validity | Good overall
• Fair internal validity and fair external validity OR | Fair overall
• Good internal validity and fair external validity OR | Fair overall
• Good internal validity and poor external validity OR | Fair overall
• Fair internal validity and good external validity OR | Fair overall
• Poor internal validity and good external validity | Fair overall
• Poor internal validity and poor external validity OR | Poor overall
• Fair internal validity and poor external validity OR | Poor overall
• Poor internal validity and fair external validity | Poor overall

### Grading Strength of Evidence

Strength of evidence is typically assigned to reviews of medical treatments after assessing four domains: risk of bias, consistency, directness and precision.25–26 Although these categories were developed for assessing the strength of treatment studies, the domains apply also to studies of prevalence and screening. Available evidence for each KQ was assessed for each of these four domains; the domains were combined qualitatively to develop the strength of evidence for each KQ.

We graded the body of literature for each KQ and present those ratings as part of the Discussion section (below). The possible grades were:

I. High: High confidence that the evidence reflects the true effect. Further research is unlikely to change estimates.
II. Moderate: Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
III. Low: Low confidence that the evidence reflects the true effect. Further research is likely to change confidence in the estimate of effect and is also likely to change the estimate.
IV. Insufficient: Evidence is either unavailable or does not permit a conclusion.

### Applicability

For decision makers to use this report to inform clinical care, it is important to consider the degree to which findings of the included research might be expected to apply in the types of populations and settings in which prenatal care is provided in the United States. Our assessment of applicability took place in two steps: (1) summary of similarity or lack of comparability of populations, interventions, comparison groups, outcomes, and settings represented in the available literature for each KQ (see Appendix E) and (2) eight questions on external validity on each study during quality assessment:

1. Were baseline characteristics related to the risk of preterm birth reported in sufficient detail to allow the reader to assess similarities or differences from a clinical population of interest?
2. Was the intervention adequately described to the degree that it could be replicated?
3. Was the primary outcome indicated and relevant to the use of progestogens in clinical care to prevent preterm birth?
4. Was a summary measure of gestational age at birth provided by group?
5. Was a summary measure of birth weight provided by group?
6. What was the timing of outcome measurement from initiation of treatment?
7. Do the authors define timing, approach, and tools for collection of outcome information?
8. Has the measurement approach/tool used for the primary outcome(s) been characterized in this or prior publications with respect to reliability and repeatability?

## Peer Review and Public Commentary

Experts were invited to provide external peer review. The draft report was posted for four weeks to elicit public comment. We addressed all reviewer comments by revising the text as appropriate. We responded to each comment submitted from peer and public review in a disposition of comments report. This report will be available on the AHRQ Web site 3 months after the posting of this final CER.