# Introduction

## Background

### Burden of Preterm Birth

Births before the 37th week of pregnancy are considered preterm. Risks of complications from preterm birth are related to how early the birth is with the earliest births at greatest risk. Preterm births contribute to more than 85 percent of all perinatal morbidity and mortality and are the leading cause of infant mortality and long-term disability.1–2 Each year more than 475,000 infants are born preterm in the United States, representing 12.5 percent of live births.3 Efforts to reduce occurrence of preterm births have been unsuccessful, with a 20 percent relative increase in the proportion of preterm births in the United States since 1990.^2^

The morbidity and mortality associated with preterm birth represent untold distress for families, as well as significant costs to patients, health care systems, and payers. Mean neonatal costs are estimated to be $17,300 (in 2004 dollars) greater for preterm infants relative to term infants, amounting to more than $8.6 billion of annual medical spending in the United States.4 Preterm birth occurs disproportionately in populations of low socioeconomic status. Because many public programs serve these populations the costs of preterm birth in the public arena are substantial. It is estimated that 40 percent of the medical costs associated with preterm births are paid by Medicaid.1

Approaches to prevent preterm births by intervening at the time a woman has symptoms of preterm labor have proven elusive and only minimally effective. Attention has increasingly focused on methods to prevent preterm birth using earlier interventions to reach women based on risks rather than symptoms. Some paths such as treating bacterial vaginosis or periodontal disease as a route to decrease immune system activation and reduce systemic inflammation, both linked with preterm birth risk, have proven ineffective. Others, such as maternal administration of corticosteroids to enhance fetal lung development when there is a risk of preterm birth have proven fruitful for mitigating neonatal effects but not for delaying births. Progestogen administration has been investigated as a preventive intervention that may be useful for more women, earlier in pregnancy, offering options for prevention across several groups of women with increased risk of preterm birth—those with prior preterm birth, multiple gestation, a short cervix, symptoms of preterm labor, or a variety of risk factors.

### Use of Progestogens

Within the last decade, accumulating evidence from randomized clinical trials (RCTs) led professional organizations and an Institute of Medicine working group to endorse the use of 17 alpha-hydroxyprogesterone caproate (17OHP) for women with prior spontaneous preterm births. Indeed during the course of completing this review, the U.S. Food and Drug Administration (FDA) approved a 17OHP formulation for the indication of prevention of preterm birth among women with a prior preterm birth.5

Other progestogens may also be effective. Progesterone is a hormone that inhibits the uterus from contracting and is involved in maintaining pregnancy, especially early in gestation. The exact mechanism for pharmaceutical effects is not well understood.

In the United States, approximately 133,000 expectant mothers annually have a history of preterm birth and are potential candidates for progestogens. If the results of the largest U.S. trial for that indication are used, an estimated 10,000 preterm births might be prevented annually by use of progestogens in this group.4

Rates of preterm birth are higher among low-income and other vulnerable populations, and thus a larger ratio of this population relative to the general population may benefit from progestogen treatment. A recent study to assess the impact of a specific progestogen treatment, 17OHP, on future medical costs for expectant mothers with a prior preterm birth found that potential cost savings substantially exceed the cost of treatment.4 The cost of a typical 17OHP treatment regimen is relatively modest; one study estimates it to be about $400 per treated patient.4 This estimate factors in the cost of each dose of drug, the number of injections needed, and the hourly wage of a registered nurse needed to administer the injections. If all at-risk pregnant women were treated with 17OHP, the aggregate medical cost savings could be sizeable. The cost of treating eligible women would be approximately $53 million annually, and is projected to reduce initial neonatal medical costs by more than $505 million each year. In this scenario annual net savings would be $452 million, and over the lifetime of affected infants the discounted annual medical savings could be more than $2 billion.4

The ultimate goal in preventing preterm birth is to eliminate the risks of neonatal death or complications in order to prevent longstanding health consequences and to promote normal childhood development.6 Progestogen treatment with 17OHP has been shown to prolong pregnancy for women who have had a prior preterm birth. However, the long-term safety of this intervention is not well understood, and the legacy of diethylstilbestrol (DES) suggests the need for caution and extended followup of mothers and infants.

This topic includes important components of variation in care and clinical controversy. Progesterone treatment for preventing preterm birth was first studied in several small trials during the 1960s.7 In the context of decades of research on progestogens with mixed results, clinical use outside specialized settings has recently begun to increase for prevention of preterm birth in women at risk.7 In 2003, the American Congress of Obstetricians and Gynecologists stated it is important to restrict use of 17OHP to women with a documented history of a previous spontaneous birth at less than 37 weeks of gestation, because unresolved issues such as optimal route of drug delivery and long-term drug safety remain.8–9 In a 2005 survey, both prescribers and non-prescribers of 17OHP for the prevention of preterm birth noted concerns about the need for more data on safety and efficacy and also on long-term neonatal effects, as well as about the lack of FDA approval.10 We undertook this review to systematically update what is known about use of progestogens for prevention of preterm birth.

## Treatment Options

Progestogens are substances with biologic activity similar to the endogenous sex steroid progesterone.11 Progestogens include natural progesterone, synthetic progesterone, and synthetic progestins that are similar but not identical in chemical structure.12 Natural progesterone and synthetic progestins can be administered orally, vaginally, or via injection. Oral and vaginal preparations may be micronized to improve absorption.

Any progestogen used to treat pregnant women at risk for preterm birth was eligible for inclusion in this review, regardless of formulation or route. The most common progestogen in the studies in this review is the synthetic progestin 17OHP. Other injectable forms of progesterone used include crystalline progesterone and natural progesterone. Vaginal progestogens used in these studies were administered via suppositories, gel, and capsules. Oral progestogens included medroxyprogesterone acetate (trade names Provera® and Perlutex®), allylestrenol, and oral chlormadinone acetate. Of these three oral formulations, only medroxyprogesterone acetate is currently available in the United States. Five studies used other progestogens.13–16 These include exogenous progestin and estrogen with and without thyroid hormone, DES with natural and synthetic progesterone, 6-alpha-methyl-17-alpha-acetoxy-progesterone, and crystalline progesterone dissolved in vegetable oil.

## Scope of This Report

### Key Questions

We have synthesized evidence in the published literature to address these Key Questions (KQs):

1. In pregnant women who are at risk for preterm birth (which is birth before 37 weeks gestational age), does progestogen treatment, compared to placebo, usual care or other interventions improve maternal or fetal/neonatal health outcomes, including, but not limited to:
  - Complications during pregnancy (e.g., chorioamnionitis, antenatal hospitalizations and intrauterine growth restriction)?
  - Mode of birth and complications during birth (e.g., cesarean birth and surgical complications)?
  - Prematurity?
  - Postpartum and neonatal complications (e.g., maternal postpartum hemorrhage and intraventricular hemorrhage)?
  - Longer term outcomes (e.g., neurodevelopmental delay and future reproductive outcomes)?
2. What is the nature and frequency of maternal and child adverse effects of progestogen treatment, including but not limited to:
  - Complications during pregnancy (e.g., allergic reactions or development of gestational diabetes)?
  - Mode of birth and complications during birth (e.g., unanticipated maternal harms)?
  - Postpartum and neonatal complications (e.g., infections and sepsis)?
  - Longer term outcomes?
3. How do the effectiveness, adverse effects and safety of progestogen treatment differ based on the maternal risk factors for preterm birth, such as severity of prior preterm birth, degree of cervical shortening, order of multiple gestations, fetal fibronectin status, preterm premature rupture of membranes, threatened preterm birth, and socioeconomic predictors of prematurity, including race/ethnicity?
4. How do the effectiveness, acceptability, adherence, adverse effects, and safety of progestogen treatment differ based on the formulation, dose, frequency of administration and gestational age at initiation or discontinuation of progestogen therapy?
5. How do the effectiveness, adverse effects, and safety of progestogen treatment differ based on cointerventions used to prevent preterm birth and its consequences, including antibiotics, corticosteroids, tocolysis, and surgical interventions such as cervical cerclage?
6. What are the effects of health system and provider factors, including provider knowledge and attitudes, provider specialty, cost of drug, availability of drug in formularies, and Medicaid and private payer coverage, on the utilization of progestogens for eligible at risk women?

### Organization of This Report

The Methods chapter describes our methods, including our search strategy, inclusion and exclusion criteria, approach to review of abstracts and full publications, and methods for extracting data into evidence tables and compiling evidence. We also describe our approach to grading the quality of the literature and to describing the strength of the literature.

The Results chapter presents the results of the literature search and the review of the evidence by KQ, synthesizing the findings across treatment types. We report the number and type of studies identified and we differentiate between total numbers of publications and unique studies to bring into focus the number of duplicate publications in this literature in which multiple publications are derived from the same study population. The Discussion chapter discusses the results and enlarges on the methodologic considerations relevant to each KQ. We also outline the current state of the literature and challenges for future research on the use of progestogens to prevent preterm birth.

### Uses of This Report

We anticipate this report will be of value to all health care practitioners who take care of women of childbearing age, including members of the American Congress of Obstetricians and Gynecologists, the Association of Women’s Health, Obstetric and Neonatal Nurses, the American College of Nurse-Midwives, the American Academy of Family Physicians, the American Academy of Nurse Practitioners, and other clinical professional organizations. In addition, this review will be of use to the National Institutes of Health, Centers for Disease Control and Prevention, Centers for Medicare and Medicaid Services, and the Health Resources and Services Administration—all of which have offices or bureaus devoted to women’s health issues. This report can bring practitioners up to date about the current state of evidence, and it provides an assessment of the quality of studies that aim to determine the outcomes of progestogens use for the prevention of preterm birth. It will be of interest to individual women and the general public because of the burden that preterm birth places on families and society as a whole, and the recurring need for women and their health care providers to make the best possible decisions among numerous options. We also anticipate it will be of use to private sector organizations concerned with women’s health, such as Childbirth Connection, March of Dimes, the National Women’s Health Network, and Our Bodies Ourselves.

Researchers can obtain a concise analysis of the current state of knowledge in this field. They will be poised to pursue further investigations that are needed to advance research methods, understand risk factors, develop prevention strategies, develop new treatment options, and optimize the effectiveness and safety of clinical care for those women who are at risk for preterm birth.